# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Lynn F. Bufka, Ph.D.
  American Psychological Association
  Washington, DC
- Lauren G. Caldwell, J.D., Ph.D.
  American Psychological Association
  Washington, DC
- Elizabeth Edgerton, M.D.
  Health Resources and Services Administration
  Rockville, MD
- Stephanie C. Eken, M.D., FAAP
  Rogers Behavioral Health
  Tampa, FL
- Raquel Halfond, Ph.D.^*^
  American Psychological Association
  Washington, DC
- Adrienne Kennedy, M.A.
  National Alliance on Mental Illness
  Austin, TX
- Anna E. Ordóñez, M.D., M.A.S.
  National Institute of Mental Health
  Bethesda, MD
- Judith L. Rapoport, M.D.
  National Institute of Mental Health
  Bethesda, MD
- Moira A. Rynn, M.D.^*^
  Chair of Department of Psychiatry & Behavioral Sciences
  Duke University Medical Center
  Durham, NC
- Joel Sherrill, Ph.D.
  National Institute of Mental Health
  Bethesda, MD
- Elizabeth Sweet, M.Ed.
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Jing Zhang, M.D., Ph.D.
  Food and Drug Administration
  Silver Spring, MD

* Provided input on Draft Report.