# Appendix I References for Appendixes

1 Abikoff H, McGough J, Vitiello B, . Sequential pharmacotherapy for children with comorbid attention-deficit/hyperactivity and anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2005 May;44(5):418–27. doi: 10.1097/01.chi.0000155320.52322.37. PMID: 15843763.15843763
2 Alfano CA, Ginsburg GS, Kingery JN. Sleep-related problems among children and adolescents with anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2007 Feb;46(2):224–32. doi: 10.1097/01.chi.0000242233.06011.8e. PMID: 17242626.17242626
3 Beidel DC, Turner SM, Sallee FR, . SET-C versus fluoxetine in the treatment of childhood social phobia. J Am Acad Child Adolesc Psychiatry. 2007 Dec;46(12):1622–32. doi: 10.1097/chi.0b013e318154bb57. PMID: 18030084.18030084
4 Black B, Uhde TW. Treatment of elective mutism with fluoxetine: a double-blind, placebo-controlled study. J Am Acad Child Adolesc Psychiatry. 1994 Sep;33(7):1000–6. doi: 10.1097/00004583-199409000-00010. PMID: 7961338.7961338
5 Birmaher B, Axelson DA, Monk K, . Fluoxetine for the treatment of childhood anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2003 Apr;42(4):415–23. doi: 10.1097/01.CHI.0000037049.04952.9F. PMID: 12649628.12649628
6 da Costa CZ, de Morais RM, Zanetta DM, . Comparison among clomipramine, fluoxetine, and placebo for the treatment of anxiety disorders in children and adolescents. J Child Adolesc Psychopharmacol. 2013 Dec;23(10):687–92. doi: 10.1089/cap.2012.0110. PMID: 24350814.24350814
7 Geller D, Donnelly C, Lopez F, . Atomoxetine treatment for pediatric patients with attention-deficit/hyperactivity disorder with comorbid anxiety disorder. J Am Acad Child Adolesc Psychiatry. 2007 Sep;46(9):1119–27. doi: 10.1097/chi.0b013e3180ca8385. PMID: 17712235.17712235
8 Gittelman K, Rachel, Klein, . School phobia: Diagnostic considerations in the light of imipramine effects. Journal of Nervous and Mental Disease. 1973 Mar;156(3):199–215. PMID: 1974-01582-001.4698665
9 Graae F, Milner J, Rizzotto L, . Clonazepam in childhood anxiety disorders. J Am Acad Child Adolesc Psychiatry. 1994 Mar–Apr;33(3):372–6. doi:10.1097/00004583-199403000-00011. PMID: 8169182.8169182
10 March JS, Entusah AR, Rynn M, . A Randomized controlled trial of venlafaxine ER versus placebo in pediatric social anxiety disorder. Biol Psychiatry. 2007 Nov 15;62(10):1149–54. doi: 10.1016/j.biopsych.2007.02.025. PMID: 17553467.17553467
11 Pine, D S, Walkup, . Fluvoxamine for the treatment of anxiety disorders in children and adolescents. New England Journal of Medicine. 2001 26 Apr;344(17):1279–85. doi:10.1056/NEJM200104263441703. PMID: 2001155341.11323729
12 Reinblatt SP, Riddle MA. Selective serotonin reuptake inhibitor-induced apathy: a pediatric case series. J Child Adolesc Psychopharmacol. 2006 Feb–Apr;16(1–2):227–33. doi:10.1089/cap.2006.16.227. PMID: 16553543.16553543
13 Reinblatt SP, DosReis S, Walkup JT, . Activation adverse events induced by the selective serotonin reuptake inhibitor fluvoxamine in children and adolescents. J Child Adolesc Psychopharmacol. 2009 Apr;19(2):119–26. doi: 10.1089/cap.2008.040. PMID: 19364290.19364290
14 Rynn MA, Siqueland L, Rickels K. Placebo-controlled trial of sertraline in the treatment of children with generalized anxiety disorder. Am J Psychiatry. 2001 Dec;158(12):2008–14. doi: 10.1176/appi.ajp.158.12.2008. PMID: 11729017.11729017
15 Rynn MA, Riddle MA, Yeung PP, . Efficacy and safety of extended-release venlafaxine in the treatment of generalized anxiety disorder in children and adolescents: two placebo-controlled trials. Am J Psychiatry. 2007 Feb;164(2):290–300. doi: 10.1176/ajp.2007.164.2.290. PMID: 17267793.17267793
16 Scharfstein LA, Beidel DC, Finnell LR, . Do pharmacological and behavioral interventions differentially affect treatment outcome for children with social phobia? Behav Modif. 2011 Sep;35(5):451–67. doi: 10.1177/0145445511408590. PMID: 21586501.21586501
17 Strawn JR, Prakash A, Zhang Q, . A randomized, placebo-controlled study of duloxetine for the treatment of children and adolescents with generalized anxiety disorder. J Am Acad Child Adolesc Psychiatry. 2015 Apr;54(4):283–93. doi: 10.1016/j.jaac.2015.01.008. PMID: 25791145.25791145
18 Wagner, K, Berard, . A multicenter, randomized, double-blind, placebo-controlled trial ofparoxetine in children and adolescents with social anxiety disorder. Archives of General Psychiatry. 2004;61(11):1153–62. doi: 10.1001/archpsyc.61.11.1153.15520363
19 Walkup J, Labellarte M, Riddle MA, . Treatment of pediatric anxiety disorders: an open-label extension of the research units on pediatric psychopharmacology anxiety study. J Child Adolesc Psychopharmacol. 2002 Fall;12(3):175–88. doi: 10.1089/104454602760386879. PMID: 12427292.12427292
20 Walkup JT, Albano AM, Piacentini J, . Cognitive behavioral therapy, sertraline, or a combination in childhood anxiety. N Engl J Med. 2008 Dec 25;359(26):2753–66. doi: 10.1056/NEJMoa0804633. PMID: 18974308.18974308
21 Ginsburg GS, Kendall PC, Sakolsky D, . Remission after acute treatment in children and adolescents with anxiety disorders: findings from the CAMS. J Consult Clin Psychol. 2011 Dec;79(6):806–13. doi: 10.1037/a0025933. PMID: 22122292.22122292
22 Gonzalez A, Peris TS, Vreeland A, . Parental anxiety as a predictor of medication and CBT response for anxious youth. Child Psychiatry Hum Dev. 2015 Feb;46(1):84–93. doi: 10.1007/s10578-014-0454-6. PMID: 24610431.24610431
23 Keeton CP, Ginsburg GS, Drake KL, . Benefits of child-focused anxiety treatments for parents and family functioning. Depress Anxiety. 2013 Sep;30(9):865–72. doi: 10.1002/da.22055. PMID: 23390005.23390005
24 Nail, Jennifer E, Christofferson, . Academic impairment and impact of treatments among youth with anxiety disorders. Child & Youth Care Forum. 2015 Jun;44(3):327–42. doi: 10.1007/s10566-014-9290-x. PMID: 2014-51382-001.
25 Piacentini J, Bennett S, Compton SN, . 24- and 36-week outcomes for the Child/Adolescent Anxiety Multimodal Study (CAMS). J Am Acad Child Adolesc Psychiatry. 2014 Mar;53(3):297–310. doi: 10.1016/j.jaac.2013.11.010. PMID: 24565357.24565357
26 Rynn MA, Walkup JT, Compton SN, . Child/Adolescent anxiety multimodal study: evaluating safety. J Am Acad Child Adolesc Psychiatry. 2015 Mar;54(3):180–90. doi: 10.1016/j.jaac.2014.12.015. PMID: 25721183.25721183
27 Abbasi, Z, Amiri, . The effective comparison between modular cognitive behavioral therapy (MCBT) and child-parent relationship training (CPRT) in children with separation anxiety symptoms. Social Sciences (Pakistan). 2016;11(6):890–902. doi: 10.3923/sscience.2016.890.902.
28 Adler Nevo GW, Avery D, Fiksenbaum L, . Eight years later: outcomes of CBT-treated versus untreated anxious children. Brain Behav. 2014 Sep;4(5):765–74. doi: 10.1002/brb3.274. PMID: 25328851.25328851
29 Afshari A, Neshat-Doost HT, Maracy MR, . The effective comparison between emotion-focused cognitive behavioral group therapy and cognitive behavioral group therapy in children with separation anxiety disorder. J Res Med Sci. 2014 Mar;19(3):221–7. PMID: 24949029.24949029
30 Arendt K, Thastum M, Hougaard E. Efficacy of a Danish version of the Cool Kids program: a randomized wait-list controlled trial. Acta Psychiatr Scand. 2015 May 27;133(2):109–21. doi: 10.1111/acps.12448. PMID: 26016532.26016532
31 Baer S, Garland EJ. Pilot study of community-based cognitive behavioral group therapy for adolescents with social phobia. J Am Acad Child Adolesc Psychiatry. 2005 Mar;44(3):258–64. doi: 10.1097/00004583-200503000-00010. PMID: 15725970.15725970
32 Barrett PM, Dadds MR, Rapee RM. Family treatment of childhood anxiety: a controlled trial. J Consult Clin Psychol. 1996 Apr;64(2):333–42. doi: 10.1037//0022-006X.64.2.333. PMID: 8871418.8871418
33 Barrett PM. Evaluation of cognitive-behavioral group treatments for childhood anxiety disorders. J Clin Child Psychol. 1998 Dec;27(4):459–68. doi: 10.1207/s15374424jccp2704_10. PMID: 9866083.9866083
34 Chalfant AM, Rapee R, Carroll L. Treating anxiety disorders in children with high functioning autism spectrum disorders: a controlled trial. J Autism Dev Disord. 2007 Nov;37(10):1842–57. doi: 10.1007/s10803-006-0318-4. PMID: 17171539.17171539
35 Chiu AW, Langer DA, McLeod BD, . Effectiveness of modular CBT for child anxiety in elementary schools. Sch Psychol Q. 2013 Jun;28(2):141–53. doi: 10.1037/spq0000017. PMID: 23750860.23750860
36 Cobham VE. Do anxiety-disordered children need to come into the clinic for efficacious treatment? J Consult Clin Psychol. 2012 Jun;80(3):465–76. doi: 10.1037/a0028205. PMID: 22545740.22545740
37 Dewis LM, Kirkby KC, Martin F, . Computer-aided vicarious exposure versus live graded exposure for spider phobia in children. J Behav Ther Exp Psychiatry. 2001 Mar;32(1):17–27. doi: 10.1016/S0005-7916(01)00019-2. PMID: 11729943.11729943
38 Donovan CL, Cobham V, Waters AM, . Intensive group-based CBT for child social phobia: a pilot study. Behav Ther. 2015 May;46(3):350–64. doi: 10.1016/j.beth.2014.12.005. PMID: 25892171.25892171
39 Flannery S, E C, Kendall, . Group and individual cognitive-behavioral treatments for youth with anxiety disorders: A randomized clinical trial. Cognitive Therapy and Research. 2000 June;24(3):251–78. doi: 10.1023/A:1005500219286. PMID: 2000223577.
40 Flannery S, E, Choudhury, . Group and individual cognitive-behavioral treatments for youth with anxiety disorders: 1-Year follow-up. Cognitive Therapy and Research. 2005 April;29(2):253–9. doi:10.1007/s10608-005-3168-z. PMID: 2005221485.
41 Gallagher HM, Rabian BA, McCloskey MS. A brief group cognitive-behavioral intervention for social phobia in childhood. J Anxiety Disord. 2004;18(4):459–79. doi: 10.1016/S0887-6185(03)00027-6. PMID: 15149708.15149708
42 Gallo KP, Chan PT, Buzzella BA, . The impact of an 8-day intensive treatment for adolescent panic disorder and agoraphobia on comorbid diagnoses. Behav Ther. 2012 Mar;43(1):153–9. doi: 10.1016/j.beth.2011.05.002. PMID: 22304887.22304887
43 Gil B, F, Hernandez G, . [Cognitive-behavioural treatment in Mexican children with social phobia]. Anuario de Psicologia. 2009;40(1):89–104. PMID: CN-00753537 UPDATE.
44 Hancock KM, Swain J, Hainsworth CJ, . Acceptance and Commitment Therapy versus Cognitive Behavior Therapy for Children With Anxiety: Outcomes of a Randomized Controlled Trial. J Clin Child Adolesc Psychol. 2016 Mar 21:1–16. doi: 10.1080/15374416.2015.1110822. PMID: 26998803.26998803
45 Hayward C, Varady S, Albano AM, . Cognitive-behavioral group therapy for social phobia in female adolescents: results of a pilot study. J Am Acad Child Adolesc Psychiatry. 2000 Jun;39(6):721–6. doi: 10.1097/00004583-200006000-00010. PMID: 10846306.10846306
46 Holmes MC, Donovan CL, Farrell LJ, . The efficacy of a group-based, disorder-specific treatment program for childhood GAD--a randomized controlled trial. Behav Res Ther. 2014 Oct;61:122–35. doi: 10.1016/j.brat.2014.08.002. PMID: 25193003.25193003
47 Hirshfeld-Becker DR, Masek B, Henin A, . Cognitive behavioral therapy for 4- to 7-year-old children with anxiety disorders: a randomized clinical trial. J Consult Clin Psychol. 2010 Aug;78(4):498–510. doi: 10.1037/a0019055. PMID: 20658807.20658807
48 Kendall, P C. Treating anxiety disorders in children: results of a randomized clinical trial. Annual Progress in Child Psychiatry and Child Development. 1995doi:10.1037/0022-006X.62.1.100 ·. PMID: CN-00216211 UPDATE.
49 Kendall PC, Flannery-Schroeder E, Panichelli-Mindel SM, . Therapy for youths with anxiety disorders: a second randomized clinical trial. J Consult Clin Psychol. 1997 Jun;65(3):366–80. doi: 10.1037/0022-006X.65.3.366. PMID: 9170760.9170760
50 Leutgeb V, Schienle A. Changes in facial electromyographic activity in spider-phobic girls after psychotherapy. J Psychiatr Res. 2012 Jun;46(6):805–10. doi: 10.1016/j.jpsychires.2012.02.017. PMID: 22424962.22424962
51 Masia-Warner C, Klein RG, Dent HC, . School-based intervention for adolescents with social anxiety disorder: results of a controlled study. J Abnorm Child Psychol. 2005 Dec;33(6):707–22. doi: 10.1007/s10802-005-7649-z. PMID: 16328746.16328746
52 McConachie H, McLaughlin E, Grahame V, . Group therapy for anxiety in children with autism spectrum disorder. Autism. 2014 Aug;18(6):723–32. doi: 10.1177/1362361313488839. PMID: 24101715.24101715
53 McNally Keehn RH, Lincoln AJ, Brown MZ, . The Coping Cat program for children with anxiety and autism spectrum disorder: a pilot randomized controlled trial. J Autism Dev Disord. 2013 Jan;43(1):57–67. doi: 10.1007/s10803-012-1541-9. PMID: 22588377.22588377
54 Melfsen S, Kuhnemund M, Schwieger J, . Cognitive behavioral therapy of socially phobic children focusing on cognition: a randomised wait-list control study. Child Adolesc Psychiatry Ment Health. 2011 Feb 28;5(1):5. doi: 10.1186/1753-2000-5-5. PMID: 21356037.21356037
55 Mendez, Xavier, Orgiles, . Psychological treatment of the phobia of the dark in a game situation: A controlled essay. Revista de Psicopatologia y Psicologia Clinica. 2003 Dec;8(3):199–210. PMID: 2004-12003-002.
56 Mendlowitz SL, Manassis K, Bradley S, . Cognitive-behavioral group treatments in childhood anxiety disorders: the role of parental involvement. J Am Acad Child Adolesc Psychiatry. 1999 Oct;38(10):1223–9. doi: 10.1097/00004583-199910000-00010. PMID: 10517054.10517054
57 Menzies RG, Clarke JC. A comparison of in vivo and vicarious exposure in the treatment of childhood water phobia. Behav Res Ther. 1993 Jan;31(1):9–15. doi: 10.1016/0005-7967(93)90037-U. PMID: 8093340.8093340
58 Miller LC, Barrett CL, Hampe E, . Comparison of reciprocal inhibition, psychotherapy, and waiting list control for phobic children. J Abnorm Psychol. 1972 Jun;79(3):269–79. PMID: 5033367.5033367
59 Hampe E, Noble H, Miller LC, . Phobic children one and two years posttreatment. J Abnorm Psychol. 1973 Dec;82(3):446–53. PMID: 4770914.4770914
60 Obler M, Terwilliger RF. Pilot study on the effectiveness of systematic desensitization with neurologically impaired children with phobic disorders. J Consult Clin Psychol. 1970 Jun;34(3):314–8. doi: 10.1037/h0029367. PMID: 5523436.5523436
61 Olivares, J, Garcia L, . Results at long-term among three psychological treatments for adolescents with generalized social phobia (I): Statistical significance. Psicologia Conductual. 2002;10(1):147–64. PMID: 2002236025.
62 Olivares J, Olivares-Olivares PJ, Rosa-Alcazar AI, . The contribution of the therapist’s competence in the treatment of adolescents with generalized social phobia. Psicothema. 2014;26(4):483–9. doi: 10.7334/psicothema2014.69. PMID: 25340895.25340895
63 Ollendick TH, Ost LG, Reuterskiold L, . One-session treatment of specific phobias in youth: a randomized clinical trial in the United States and Sweden. J Consult Clin Psychol. 2009 Jun;77(3):504–16. doi: 10.1037/a0015158. PMID: 19485591.19485591
64 Ortbandt, C, Petermann, . Effects of a cognitive behavioral training program for children with social anxiety. Kindheit und Entwicklung. 2009;18(1):21–9.
65 Moller, C, Petermann, . Short- and long-term effects of a cognitive-behavioural training programme for children with social anxiety. [German]. Verhaltenstherapie. 2011 March;21(1):15–22. PMID: 2011134836.
66 Ost LG, Svensson L, Hellstrom K, . One-Session treatment of specific phobias in youths: a randomized clinical trial. J Consult Clin Psychol. 2001 Oct;69(5):814–24. doi: 10.1037/0022-006X.69.5.814. PMID: 11680558.11680558
67 Ost, L G, Cederlund, . Behavioral treatment of social phobia in youth: Does parent education training improve the outcome? Behaviour Research and Therapy. 2015 April 01;67:19–29. doi:10.1016/j.brat.2015.02.001. PMID: 2015788786.25727679
68 Rapee, Ronald M. Group treatment of children with anxiety disorders: Outcome and predictors of treatment response. Australian Journal of Psychology. 2000;52(3):125–9. doi: 10.1080/00049530008255379.
69 Rapee RM, Abbott MJ, Lyneham HJ. Bibliotherapy for children with anxiety disorders using written materials for parents: A randomized controlled trial. J Consult Clin Psychol. 2006 Jun;74(3):436–44. doi: 10.1037/0022-006X.74.3.436. PMID: 16822101.16822101
70 Reaven, J A, Blakeley S, . Cognitive-behavioral group treatment for anxiety symptoms in children with high-functioning autism spectrum disorders: A pilot study. Focus on Autism and Other Developmental Disabilities. 2009 March;24(1):27–37. doi:10.1177/1088357608327666. PMID: 2009069887.
71 Ritter B. The group desensitization of children’s snake phobias using vicarious and contact desensitization procedures. Behav Res Ther. 1968 Feb;6(1):1–6. doi: 10.1016/0005-7967(68)90033-8. PMID: 5689466.5689466
72 Rosa A, Ana I, Olivares O, . The role of non-specific effects in the psychological treatment of adolescents with social phobia. Anuario de Psicologia. 2009 Apr;40(1):43–61. PMID: 2009-08210-003.
73 Rodriguez, J O, Alcazar, . Early detection and treatment of adolescents with generalized social phobia. Psicothema. 2005;17(1):1–8. PMID: CN-00596495 UPDATE.
74 Sanchez-Garcia R, Olivares J. Effectiveness of a program for early detection/intervention in children/adolescents with generalized social phobia. Anales De Psicologia. 2009 Dec;25(2):241–9. PMID: WOS:000272061800006.
75 Sánchez G, Raquel, Rodríguez, . Intervención temprana en niños y adolescentes con fobia social. Anuario de psicología/The UB Journal of psychology. 2009;40(1):75–88.
76 Santucci LC, Ehrenreich-May J. A randomized controlled trial of the child anxiety multi-day program (CAMP) for separation anxiety disorder. Child Psychiatry Hum Dev. 2013 Jun;44(3):439–51. doi: 10.1007/s10578-012-0338-6. PMID: 23053618.23053618
77 Schneider S, Blatter-Meunier J, Herren C, . Disorder-specific cognitive-behavioral therapy for separation anxiety disorder in young children: a randomized waiting-list-controlled trial. Psychother Psychosom. 2011;80(4):206–15. doi: 10.1159/000323444. PMID: 21494062.21494062
78 Shortt AL, Barrett PM, Fox TL. Evaluating the FRIENDS program: a cognitive-behavioral group treatment for anxious children and their parents. J Clin Child Psychol. 2001 Dec;30(4):525–35. doi: 10.1207/S15374424JCCP3004_09. PMID: 11708240.11708240
79 Silverman WK, Kurtines WM, Ginsburg GS, . Treating anxiety disorders in children with group cognitive-behaviorial therapy: a randomized clinical trial. J Consult Clin Psychol. 1999 Dec;67(6):995–1003. doi: 10.1037/0022-006X.67.6.995 PMID: 10596522.10596522
80 Spence SH, Donovan C, Brechman-Toussaint M. The treatment of childhood social phobia: the effectiveness of a social skills training-based, cognitive-behavioural intervention, with and without parental involvement. J Child Psychol Psychiatry. 2000 Sep;41(6):713–26. doi: 10.1111/1469-7610.00659. PMID: 11039684.11039684
81 Spence SH, Holmes JM, March S, . The feasibility and outcome of clinic plus internet delivery of cognitive-behavior therapy for childhood anxiety. J Consult Clin Psychol. 2006 Jun;74(3):614–21. doi: 10.1037/0022-006X.74.3.614. PMID: 16822117.16822117
82 Spence SH, Donovan CL, March S, . A randomized controlled trial of online versus clinic-based CBT for adolescent anxiety. J Consult Clin Psychol. 2011 Oct;79(5):629–42. doi: 10.1037/a0024512. PMID: 21744945.21744945
83 Treadwell KR, Kendall PC. Self-talk in youth with anxiety disorders: states of mind, content specificity, and treatment outcome. J Consult Clin Psychol. 1996 Oct;64(5):941–50. doi: 10.1037//0022-006X.64.5.941 PMID: 8916623.8916623
84 Arándiga, Antonio V, Rodríguez, . Competencia social y autoestima en adolescentes con fobia social. Investigar el cambio curricular en el espacio europeo de educación superior. 2014:459–79.
85 Van S, F. J A, Bogels, . CBT for anxiety disorders in children with and without autism spectrum disorders. Journal of Consulting and Clinical Psychology. 2015 01 Jun;83(3):512–23. doi:10.1037/a0039108. PMID: 2015938821.25894668
86 Waters AM, Ford LA, Wharton TA, . Cognitive-behavioural therapy for young children with anxiety disorders: Comparison of a Child + Parent condition versus a Parent Only condition. Behav Res Ther. 2009 Aug;47(8):654–62. doi: 10.1016/j.brat.2009.04.008. PMID: 19457471.19457471
87 Warner CM, Colognori D, Kim RE, . Cognitive-behavioral treatment of persistent functional somatic complaints and pediatric anxiety: an initial controlled trial. Depress Anxiety. 2011 Jul;28(7):551–9. doi: 10.1002/da.20821. PMID: 21681863.21681863
88 Wergeland GJ, Fjermestad KW, Marin CE, . An effectiveness study of individual vs. group cognitive behavioral therapy for anxiety disorders in youth. Behav Res Ther. 2014 Jun;57:1–12. doi: 10.1016/j.brat.2014.03.007. PMID: 24727078.24727078
89 Wergeland GJ, Fjermestad KW, Marin CE, . Predictors of treatment outcome in an effectiveness trial of cognitive behavioral therapy for children with anxiety disorders. Behav Res Ther. 2016 Jan;76:1–12. doi: 10.1016/j.brat.2015.11.001. PMID: 26583954.26583954
90 White SW, Ollendick T, Albano AM, . Randomized controlled trial: Multimodal Anxiety and Social Skill Intervention for adolescents with autism spectrum disorder. J Autism Dev Disord. 2013 Feb;43(2):382–94. doi: 10.1007/s10803-012-1577-x. PMID: 22735897.22735897
91 Wood JJ, Drahota A, Sze K, . Cognitive behavioral therapy for anxiety in children with autism spectrum disorders: a randomized, controlled trial. J Child Psychol Psychiatry. 2009 Mar;50(3):224–34. doi: 10.1111/j.1469-7610.2008.01948.x. PMID: 19309326.19309326
92 Beidel DC, Turner SM, Morris TL. Behavioral treatment of childhood social phobia. J Consult Clin Psychol. 2000 Dec;68(6):1072–80. doi: 10.1037//0022-006X.68.6.1072. PMID: 11142541.11142541
93 Fujii, Cori, Renno, . Intensive cognitive behavioral therapy for anxiety disorders in school-aged children with autism: A preliminary comparison with treatment-as-usual. School Mental Health. 2013;5(1):25–37. doi: 10.1007/s12310-012-9090-0. PMID: CN-01000510 UPDATE.
94 Ginsburg GS, Drake KL. School-based treatment for anxious african-american adolescents: a controlled pilot study. J Am Acad Child Adolesc Psychiatry. 2002 Jul;41(7):768–75. doi: 10.1097/00004583-200207000-00007. PMID: 12108800.12108800
95 Ginsburg GS, Becker KD, Drazdowski TK, . Treating Anxiety Disorders in Inner City Schools: Results from a Pilot Randomized Controlled Trial Comparing CBT and Usual Care. Child Youth Care Forum. 2012 Feb;41(1):1–19. doi: 10.1007/s10566-011-9156-4. PMID: 22701295.22701295
96 Halldorsdottir T, Ollendick TH. Long-term outcomes of brief, intensive CBT for specific phobias: The negative impact of ADHD symptoms. J Consult Clin Psychol. 2016 May;84(5):465–71. doi: 10.1037/ccp0000088. PMID: 26900895.26900895
97 Herbert JD, Gaudiano BA, Rheingold AA, . Cognitive behavior therapy for generalized social anxiety disorder in adolescents: a randomized controlled trial. J Anxiety Disord. 2009 Mar;23(2):167–77. doi: 10.1016/j.janxdis.2008.06.004. PMID: 18653310.18653310
98 Hudson JL, Rapee RM, Deveney C, . Cognitive-behavioral treatment versus an active control for children and adolescents with anxiety disorders: a randomized trial. J Am Acad Child Adolesc Psychiatry. 2009 May;48(5):533–44. doi: 10.1097/CHI.0b013e31819c2401. PMID: 19318990.19318990
99 Ingul JM, Aune T, Nordahl HM. A randomized controlled trial of individual cognitive therapy, group cognitive behaviour therapy and attentional placebo for adolescent social phobia. Psychother Psychosom. 2014;83(1):54–61. doi: 10.1159/000354672. PMID: 24281563.24281563
100 Kendall PC, Hudson JL, Gosch E, . Cognitive-behavioral therapy for anxiety disordered youth: a randomized clinical trial evaluating child and family modalities. J Consult Clin Psychol. 2008 Apr;76(2):282–97. doi: 10.1037/0022-006X.76.2.282. PMID: 18377124.18377124
101 Khanna MS, Kendall PC. Exploring the role of parent training in the treatment of childhood anxiety. J Consult Clin Psychol. 2009 Oct;77(5):981–6. doi: 10.1037/a0016920. PMID: 19803577.19803577
102 Khanna MS, Kendall PC. Computer-assisted cognitive behavioral therapy for child anxiety: results of a randomized clinical trial. J Consult Clin Psychol. 2010 Oct;78(5):737–45. doi: 10.1037/a0019739. PMID: 20873909.20873909
103 Last CG, Hansen C, Franco N. Cognitive-behavioral treatment of school phobia. J Am Acad Child Adolesc Psychiatry. 1998 Apr;37(4):404–11. doi: 10.1097/00004583-199804000-00018. PMID: 9549961.9549961
104 Masia Warner C, Fisher PH, Shrout PE, . Treating adolescents with social anxiety disorder in school: an attention control trial. J Child Psychol Psychiatry. 2007 Jul;48(7):676–86. doi: 10.1111/j.1469-7610.2007.01737.x. PMID: 17593148.17593148
105 Muris, P, Meesters, . Cognitive coping vs emotional disclosure in the treatment of anxious children: A pilot-study. Cognitive Behaviour Therapy. 2002;31(2):59–67. doi: 10.1080/16506070252959490. PMID: 2003069119.
106 O’Brien, F, Olden, . Group cognitive behavioural therapy for children with anxiety disorder - An evaluation of the ‘Friends for Youth’ programme. Irish Journal of Psychological Medicine. 2007 March;24(1):5–12. doi: doi.org/10.1017/S0790966700010065.PMID: 2007447394.
107 Pincus DB, May JE, Whitton SW, . Cognitive-behavioral treatment of panic disorder in adolescence. J Clin Child Adolesc Psychol. 2010;39(5):638–49. doi: 10.1080/15374416.2010.501288. PMID: 20706917.20706917
108 Reigada, Laura C, Polokowski, . Treatment for comorbid pediatric gastrointestinal and anxiety disorders: A pilot study of a flexible health sensitive cognitive-behavioral therapy program. Clinical Practice in Pediatric Psychology. 2015 Dec;3(4):314–26. doi: 10.1037/cpp0000116 PMID: 2015-55574-002.
109 Rosa A, Ana I, Olivares R, . The role of planned interaction in the treatment of generalized social phobia. Terapia Psicologica. 2007;25(2):205–12. PMID: 2008-02112-012.
110 Southam-Gerow MA, Weisz JR, Chu BC, . Does cognitive behavioral therapy for youth anxiety outperform usual care in community clinics? An initial effectiveness test. J Am Acad Child Adolesc Psychiatry. 2010 Oct;49(10):1043–52. doi: 10.1016/j.jaac.2010.06.009. PMID: 20855049.20855049
111 Silk JS, Tan PZ, Ladouceur CD, . A Randomized Clinical Trial Comparing Individual Cognitive Behavioral Therapy and Child-Centered Therapy for Child Anxiety Disorders. J Clin Child Adolesc Psychol. 2016 Mar 16:1–13. doi: 10.1080/15374416.2016.1138408. PMID: 26983904.26983904
112 Storch EA, Salloum A, King MA, . A Randomized Controlled Trial in Community Mental Health Centers of Computer-Assisted Cognitive Behavioral Therapy Versus Treatment as Usual for Children with Anxiety. Depress Anxiety. 2015 Nov;32(11):843–52. doi: 10.1002/da.22399. PMID: 26366886.26366886
113 Storch EA, Arnold EB, Lewin AB, . The effect of cognitive-behavioral therapy versus treatment as usual for anxiety in children with autism spectrum disorders: a randomized, controlled trial. J Am Acad Child Adolesc Psychiatry. 2013 Feb;52(2):132–42 e2. doi: 10.1016/j.jaac.2012.11.007. PMID: 23357440.23357440
114 Suveg C, Hudson JL, Brewer G, . Cognitive-behavioral therapy for anxiety-disordered youth: secondary outcomes from a randomized clinical trial evaluating child and family modalities. J Anxiety Disord. 2009 Apr;23(3):341–9. doi: 10.1016/j.janxdis.2009.01.003. PMID: 19216048.19216048
115 Van S, F. J A, Dirksen, . Cost-effectiveness of cognitive-behavioral therapy versus treatment as usual for anxiety disorders in children with autism spectrum disorder. Research in Autism Spectrum Disorders. 2014 February;8(2):127–37. doi:10.1016/j.rasd.2013.11.001. PMID: 2013783128.
116 Masia W, Carrie, Colognori, . Can school counselors deliver cognitive-behavioral treatment for social anxiety effectively? A randomized controlled trial. Journal of Child Psychology and Psychiatry. 2016 Mar: No Pagination Specified. doi:10.1111/jcpp.12550. PMID: 2016-14653-001.
117 Yen CF, Chen YM, Cheng JW, . Effects of cognitive-behavioral therapy on improving anxiety symptoms, behavioral problems and parenting stress in Taiwanese children with anxiety disorders and their mothers. Child Psychiatry Hum Dev. 2014 Jun;45(3):338–47. doi: 10.1007/s10578-013-0403-9. PMID: 24002227.24002227
118 Bernstein GA, Borchardt CM, Perwien AR, . Imipramine plus cognitive-behavioral therapy in the treatment of school refusal. J Am Acad Child Adolesc Psychiatry. 2000 Mar;39(3):276–83. doi: 10.1097/00004583-200003000-00008. PMID: 10714046.10714046
119 Eichstedt JA, Tobon JI, Phoenix E, . Worried no more: The effects of medication status on treatment response to a CBT group for children with anxiety in a community setting. Clin Child Psychol Psychiatry. 2011 Apr;16(2):265–77. doi: 10.1177/1359104510366282. PMID: 21059669.21059669
120 Klein RG, Koplewicz HS, Kanner A. Imipramine treatment of children with separation anxiety disorder. J Am Acad Child Adolesc Psychiatry. 1992 Jan;31(1):21–8. doi: 10.1097/00004583-199201000-00005. PMID: 1347039.1347039
121 Melvin GA, Dudley AL, Gordon MS, . Augmenting Cognitive Behavior Therapy for School Refusal with Fluoxetine: A Randomized Controlled Trial. Child Psychiatry Hum Dev. 2016 Aug 02doi:10.1007/s10578-016-0675-y. PMID: 27485100.27485100
122 Cartwright-Hatton S, McNally D, Field AP, . A new parenting-based group intervention for young anxious children: results of a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2011 Mar;50(3):242–51 e6. doi: 10.1016/j.jaac.2010.12.015. PMID: 21334564.21334564
123 Ozyurt, Gonca, Gencer, . Is triple p positive parenting program effective on anxious children and their parents? 4th month follow up results. Journal of Child and Family Studies. 2015 Dec:No Pagination Specified. doi: 10.1007/s10826-015-0343-z. PMID: 2015-57339-001.
124 Santacruz, I, Mendez, . Play therapy applied by parents for children with darkness phobia: comparison of two programmes. Child & family behavior therapy. 2006;28(1):19–35. doi: 10.1300/J019v28n01_02. PMID: CN-00709646 UPDATE.
125 Smith AM, Flannery-Schroeder EC, Gorman KS, . Parent cognitive-behavioral intervention for the treatment of childhood anxiety disorders: a pilot study. Behav Res Ther. 2014 Oct;61:156–61. doi: 10.1016/j.brat.2014.08.010. PMID: 25217169.25217169
126 Thirlwall K, Cooper PJ, Karalus J, . Treatment of child anxiety disorders via guided parent-delivered cognitive-behavioural therapy: randomised controlled trial. Br J Psychiatry. 2013 Dec;203(6):436–44. doi: 10.1192/bjp.bp.113.126698. PMID: 23969483.23969483
127 Brown A, Creswell C, Barker C, . Guided parent-delivered cognitive behaviour therapy for children with anxiety disorders: Outcomes at 3- to 5-year follow-up. Br J Clin Psychol. 2017 Jan 09doi:10.1111/bjc.12127. PMID: 28070889.28070889
128 Hiller, R M, Apetroaia, . The effect of targeting tolerance of children’s negative emotions among anxious parents of children with anxiety disorders: A pilot randomised controlled trial. Journal of Anxiety Disorders. 2016 01 Aug;42:52–9. doi:10.1016/j.janxdis.2016.05.009. PMID: 20160447547.27314763
129 Donovan CL, March S. Online CBT for preschool anxiety disorders: a randomised control trial. Behav Res Ther. 2014 Jul;58:24–35. doi: 10.1016/j.brat.2014.05.001. PMID: 24927471.24927471
130 Infantino A, Donovan CL, March S. A randomized controlled trial of an audio-based treatment program for child anxiety disorders. Behav Res Ther. 2016 Apr;79:35–45. doi: 10.1016/j.brat.2016.02.007. PMID: 26950257.26950257
131 Lyneham HJ, Rapee RM. Evaluation of therapist-supported parent-implemented CBT for anxiety disorders in rural children. Behav Res Ther. 2006 Sep;44(9):1287–300. doi: 10.1016/j.brat.2005.09.009. PMID: 16313883.16313883
132 March S, Spence SH, Donovan CL. The efficacy of an internet-based cognitive-behavioral therapy intervention for child anxiety disorders. J Pediatr Psychol. 2009 Jun;34(5):474–87. doi: 10.1093/jpepsy/jsn099. PMID: 18794187.18794187
133 Spence SH, Donovan CL, March S, . Generic versus disorder specific cognitive behavior therapy for social anxiety disorder in youth: A randomized controlled trial using internet delivery. Behav Res Ther. 2017 Mar;90:41–57. doi: 10.1016/j.brat.2016.12.003. PMID: 27988427.27988427
134 Tillfors M, Andersson G, Ekselius L, . A randomized trial of Internet-delivered treatment for social anxiety disorder in high school students. Cogn Behav Ther. 2011;40(2):147–57. doi: 10.1080/16506073.2011.555486. PMID: 25155815.25155815
135 Vigerland S, Ljotsson B, Thulin U, . Internet-delivered cognitive behavioural therapy for children with anxiety disorders: A randomised controlled trial. Behav Res Ther. 2016 Jan;76:47–56. doi: 10.1016/j.brat.2015.11.006. PMID: 26649465.26649465
136 Vigerland S, Serlachius E, Thulin U, . Long-term outcomes and predictors of internet-delivered cognitive behavioral therapy for childhood anxiety disorders. Behav Res Ther. 2017 Mar;90:67–75. doi: 10.1016/j.brat.2016.12.008. PMID: 28012300.28012300
137 Wuthrich VM, Rapee RM, Cunningham MJ, . A randomized controlled trial of the Cool Teens CD-ROM computerized program for adolescent anxiety. J Am Acad Child Adolesc Psychiatry. 2012 Mar;51(3):261–70. doi: 10.1016/j.jaac.2011.12.002. PMID: 22365462.22365462
138 Eldar S, Apter A, Lotan D, . Attention bias modification treatment for pediatric anxiety disorders: a randomized controlled trial. Am J Psychiatry. 2012 Feb;169(2):213–20. doi: 10.1176/appi.ajp.2011.11060886. PMID: 22423353.22423353
139 Waters AM, Zimmer-Gembeck MJ, Craske MG, . Look for good and never give up: A novel attention training treatment for childhood anxiety disorders. Behav Res Ther. 2015 Oct;73:111–23. doi: 10.1016/j.brat.2015.08.005. PMID: 26310362.26310362
140 Britton JC, Bar-Haim Y, Clementi MA, . Training-associated changes and stability of attention bias in youth: Implications for Attention Bias Modification Treatment for pediatric anxiety. Dev Cogn Neurosci. 2013 Apr;4:52–64. doi: 10.1016/j.dcn.2012.11.001. PMID: 23200784.23200784
141 Pergamin-Hight L, Pine DS, Fox NA, . Attention bias modification for youth with social anxiety disorder. J Child Psychol Psychiatry. 2016 Nov;57(11):1317–25. doi: 10.1111/jcpp.12599. PMID: 27435286.27435286
142 Waters AM, Farrell LJ, Zimmer-Gembeck MJ, . Augmenting one-session treatment of children’s specific phobias with attention training to positive stimuli. Behav Res Ther. 2014 Nov;62:107–19. doi: 10.1016/j.brat.2014.07.020. PMID: 25156398.25156398
143 Ebrahiminejad S, Poursharifi H, Bakhshiour Roodsari A, . The Effectiveness of Mindfulness-Based Cognitive Therapy on Iranian Female Adolescents Suffering From Social Anxiety. Iran Red Crescent Med J. 2016 Nov;18(11):e25116. doi: 10.5812/ircmj.25116. PMID: 28191335.28191335
144 Azadeh SM, Kazemi-Zahrani H, Besharat MA. Effectiveness of Acceptance and Commitment Therapy on Interpersonal Problems and Psychological Flexibility in Female High School Students With Social Anxiety Disorder. Glob J Health Sci. 2015 Jul 12;8(3):131–8. doi: 10.5539/gjhs.v8n3p131. PMID: 26493425.26493425
145 Gottken T, White LO, Klein AM, . Short-term psychoanalytic child therapy for anxious children: a pilot study. Psychotherapy (Chic). 2014 Mar;51(1):148–58. doi: 10.1037/a0036026. PMID: 24635002.24635002
146 Cornwall, E, Spence, . The effectiveness of emotive imagery in the treatment of darkness phobia in children. Behaviour Change. 1996;13(4):223–9. doi: 10.1017/S0813483900004824. PMID: 1997031833.
147 Elkins, R M, Gallo, . Moderators of intensive cognitive behavioral therapy for adolescent panic disorder: The roles of fear and avoidance. Child and Adolescent Mental Health. 2016;21(1):30–6. doi: 10.1111/camh.12122.26929742
148 Goldbeck L, Ellerkamp T. A randomized controlled trial of multimodal music therapy for children with anxiety disorders. J Music Ther. 2012 Winter;49(4):395–413. doi: 10.1093/jmt/49.4.395. PMID: 23705344.23705344
149 Joormann, J, Unnewehr, . The efficacy of a cognitive-behavioral group treatment for children and adolescents with social phobia: A controlled trial. [German]. Zeitschrift fur Klinische Psychologie und Psychotherapie. 2002;31(4):284–90. PMID: 2002363778.
150 Klein AM, Rapee RM, Hudson JL, . Interpretation modification training reduces social anxiety in clinically anxious children. Behav Res Ther. 2015 Dec;75:78–84. doi: 10.1016/j.brat.2015.10.006. PMID: 26580081.26580081
151 Lee SS, Victor AM, James MG, . School-Based Interventions for Anxious Children: Long-Term Follow-Up. Child Psychiatry Hum Dev. 2016 Apr;47(2):183–93. doi: 10.1007/s10578-015-0555-x. PMID: 26003419.26003419
152 Yoosefi L, M, Kamali, . Treating social phobia in children through group narrative therapy. Arts in Psychotherapy. 2014 February;41(1):16–20. doi:10.1016/j.aip.2013.11.005. PMID: 2013786357.
153 Muris P, Merckelbach H, Holdrinet I, . Treating phobic children: effects of EMDR versus exposure. J Consult Clin Psychol. 1998 Feb;66(1):193–8. doi: 10.1037//0022-006X.66.1.193. PMID: 9489274.9489274
154 Muris P, Meesters C, van Melick M. Treatment of childhood anxiety disorders: a preliminary comparison between cognitive-behavioral group therapy and a psychological placebo intervention. J Behav Ther Exp Psychiatry. 2002 Sep–Dec;33(3–4):143–58. doi:10.1016/S0005-7916(02)00025-3. PMID: 12628633.12628633
155 Parr CJ, Cartwright-Hatton S. Social anxiety in adolescents: the effect of video feedback on anxiety and the self-evaluation of performance. Clin Psychol Psychother. 2009 Jan–Feb;16(1):46–54. doi:10.1002/cpp.599. PMID: 19123484.19123484
156 Chavira DA, Drahota A, Garland AF, . Feasibility of two modes of treatment delivery for child anxiety in primary care. Behav Res Ther. 2014 Sep;60:60–6. doi: 10.1016/j.brat.2014.06.010. PMID: 25075802.25075802
157 Karbasi A, Arman S, Maracy MR. The efficacy of attendance and semi-attendance group cognitive-behavioral therapy (CBT) on the anxiety disorders of adolescent girls. J Res Med Sci. 2010 Sep;15(5):256–63. PMID: 21526093.21526093
158 Leong J, Cobham VE, de Groot J, . Comparing different modes of delivery: a pilot evaluation of a family-focused, cognitive-behavioral intervention for anxiety-disordered children. Eur Child Adolesc Psychiatry. 2009 Apr;18(4):231–9. doi: 10.1007/s00787-008-0723-7. PMID: 19165538.19165538
159 Monga S, Rosenbloom BN, Tanha A, . Comparison of child-parent and parent-only cognitive-behavioral therapy programs for anxious children aged 5 to 7 years: short- and long-term outcomes. J Am Acad Child Adolesc Psychiatry. 2015 Feb;54(2):138–46. doi: 10.1016/j.jaac.2014.10.008. PMID: 25617254.25617254
160 Waters AM, Pittaway M, Mogg K, . Attention training towards positive stimuli in clinically anxious children. Dev Cogn Neurosci. 2013 Apr;4:77–84. doi: 10.1016/j.dcn.2012.09.004. PMID: 23063461.23063461
161 Amoros-Boix M, Rosa-Alcazar AI, Olivares-Olivares PJ. Role of the focus of attention in the treatment of generalized social phobia in adolescents. Anales De Psicologia. 2011 Oct;27(3):718–28. PMID: WOS:000293716800017.
162 Bodden DH, Dirksen CD, Bogels SM, . Costs and cost-effectiveness of family CBT versus individual CBT in clinically anxious children. Clin Child Psychol Psychiatry. 2008 Oct;13(4):543–64. doi: 10.1177/1359104508090602. PMID: 18927140.18927140
163 Bodden DH, Bogels SM, Nauta MH, . Child versus family cognitive-behavioral therapy in clinically anxious youth: an efficacy and partial effectiveness study. J Am Acad Child Adolesc Psychiatry. 2008 Dec;47(12):1384–94. doi: 10.1097/CHI.0b013e318189148e. PMID: 18981932.18981932
164 Chase, Rhea M, Whitton, . Treatment of adolescent panic disorder: A nonrandomized comparison of intensive versus weekly CBT. Child & Family Behavior Therapy. 2012 Oct;34(4):305–23. doi: 10.1080/07317107.2012.732873. PMID: 2012-30128-004.
165 Cobham VE, Dadds MR, Spence SH. The role of parental anxiety in the treatment of childhood anxiety. J Consult Clin Psychol. 1998 Dec;66(6):893–905. doi: 10.1037//0022-006X.66.6.893. PMID: 9874902.9874902
166 Creswell C, Cruddace S, Gerry S, . Treatment of childhood anxiety disorder in the context of maternal anxiety disorder: a randomised controlled trial and economic analysis. Health Technol Assess. 2015 May;19(38):1–184, vii–viii. doi: 10.3310/hta19380. PMID: 26004142.26004142
167 de Groot J, Cobham V, Leong J, . Individual versus group family-focused cognitive-behaviour therapy for childhood anxiety: pilot randomized controlled trial. Aust N Z J Psychiatry. 2007 Dec;41(12):990–7. doi: 10.1080/00048670701689436. PMID: 17999271.17999271
168 Esbjorn BH, Somhovd MJ, Nielsen SK, . Parental changes after involvement in their anxious child’s cognitive behavior therapy. J Anxiety Disord. 2014 Oct;28(7):664–70. doi: 10.1016/j.janxdis.2014.07.008. PMID: 25124503.25124503
169 Garcia L, L J, Diaz C, . Can parent training for parents with high levels of expressed emotion have a positive effect on their child’s social anxiety improvement? Journal of Anxiety Disorders. 2014 December 01;28(8):812–22. doi:10.1016/j.janxdis.2014.09.001. PMID: 2014880948.25265549
170 Hudson JL, Newall C, Rapee RM, . The impact of brief parental anxiety management on child anxiety treatment outcomes: a controlled trial. J Clin Child Adolesc Psychol. 2014;43(3):370–80. doi: 10.1080/15374416.2013.807734. PMID: 23845064.23845064
171 Ishikawa S, Motomura N, Kawabata Y, . Cognitive behavioural therapy for Japanese children and adolescents with anxiety disorders: a pilot study. Behav Cogn Psychother. 2012 May;40(3):271–85. doi: 10.1017/S1352465811000713. PMID: 22217534.22217534
172 Liber JM, Van Widenfelt BM, Utens EM, . No differences between group versus individual treatment of childhood anxiety disorders in a randomised clinical trial. J Child Psychol Psychiatry. 2008 Aug;49(8):886–93. doi: 10.1111/j.1469-7610.2008.01877.x. PMID: 18341545.18341545
173 Liber JM, McLeod BD, Van Widenfelt BM, . Examining the relation between the therapeutic alliance, treatment adherence, and outcome of cognitive behavioral therapy for children with anxiety disorders. Behav Ther. 2010 Jun;41(2):172–86. doi: 10.1016/j.beth.2009.02.003. PMID: 20412883.20412883
174 Manassis K, Mendlowitz SL, Scapillato D, . Group and individual cognitive-behavioral therapy for childhood anxiety disorders: a randomized trial. J Am Acad Child Adolesc Psychiatry. 2002 Dec;41(12):1423–30. doi: 10.1097/00004583-200212000-00013. PMID: 12447028.12447028
175 Muris P, Mayer B, Bartelds E, . The revised version of the Screen for Child Anxiety Related Emotional Disorders (SCARED-R): treatment sensitivity in an early intervention trial for childhood anxiety disorders. Br J Clin Psychol. 2001 Sep;40(Pt 3):323–36. doi: 10.1348/014466501163724. PMID: 11593959.11593959
176 Nauta, Maaike H, Scholing, . Cognitive-behavioural therapy for anxiety disordered children in a clinical setting: Does additional cognitive parent training enhance treatment effectiveness? Clinical Psychology & Psychotherapy. 2001 Sep–Oct;8(5):330–40. doi:10.1002/cpp.314. PMID: 2011-15198-004.
177 Nauta MH, Scholing A, Emmelkamp PM, . Cognitive-behavioral therapy for children with anxiety disorders in a clinical setting: no additional effect of a cognitive parent training. J Am Acad Child Adolesc Psychiatry. 2003 Nov;42(11):1270–8. doi: 10.1097/01.chi.0000085752.71002.93. PMID: 14566163.14566163
178 Olivares R, Jose, Rosa-Alcazar A, . The relevance of the individualized attention in the treatment with adolescents under generalized social phobia. International journal of clinical and health psychology. 2006;6(3):565–80. PMID: CN-00634079 UPDATE.
179 Olivares O, P J, Rosa A, . Does individual attention improve the effect of group treatment of adolescents with social phobia? International journal of clinical and health psychology. 2008;8(2):465–81. PMID: CN-00744423 UPDATE.
180 Ollendick TH, Halldorsdottir T, Fraire MG, . Specific phobias in youth: a randomized controlled trial comparing one-session treatment to a parent-augmented one-session treatment. Behav Ther. 2015 Mar;46(2):141–55. doi: 10.1016/j.beth.2014.09.004. PMID: 25645164.25645164
181 Rosa-Alcazar A, I, Boix M, . Contributions of cognitive restructuring in the treatment of social phobia in adolescents. Behavioral Psychology / Psicologia Conductual: Revista Internacional Clinica y de la Salud Psicologia Conductual Revista Internacional de Psicologia Clinica de la Salud. 2013;21(1):6–23. PMID: CN-01038693 NEW.
182 Schneider S, Blatter-Meunier J, Herren C, . The efficacy of a family-based cognitive-behavioral treatment for separation anxiety disorder in children aged 8–13: a randomized comparison with a general anxiety program. J Consult Clin Psychol. 2013 Oct;81(5):932–40. doi: 10.1037/a0032678. PMID: 23607501.23607501
183 Siqueland L, Rynn M, Diamond GS. Cognitive behavioral and attachment based family therapy for anxious adolescents: Phase I and II studies. J Anxiety Disord. 2005;19(4):361–81. doi: 10.1016/j.janxdis.2004.04.006. PMID: 15721570.15721570
184 Silverman WK, Kurtines WM, Jaccard J, . Directionality of change in youth anxiety treatment involving parents: an initial examination. J Consult Clin Psychol. 2009 Jun;77(3):474–85. doi: 10.1037/a0015761. PMID: 19485589.19485589
185 St-Jacques J, Bouchard S, Belanger C. Is virtual reality effective to motivate and raise interest in phobic children toward therapy? A clinical trial study of in vivo with in virtuo versus in vivo only treatment exposure. J Clin Psychiatry. 2010 Jul;71(7):924–31. doi: 10.4088/JCP.08m04822blu. PMID: 20441721.20441721
186 Whiteside SP, Ale CM, Young B, . The feasibility of improving CBT for childhood anxiety disorders through a dismantling study. Behav Res Ther. 2015 Oct;73:83–9. doi: 10.1016/j.brat.2015.07.011. PMID: 26275761.26275761
187 Wood JJ, Piacentini JC, Southam-Gerow M, . Family cognitive behavioral therapy for child anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2006 Mar;45(3):314–21. doi: 10.1097/01.chi.0000196425.88341.b0. PMID: 16540816.16540816
188 Walczak M, Esbjorn BH, Breinholst S, . Parental Involvement in Cognitive Behavior Therapy for Children with Anxiety Disorders: 3-Year Follow-Up. Child Psychiatry Hum Dev. 2016 Jul 12doi:10.1007/s10578-016-0671-2. PMID: 27405872.27405872
189 Biederman J. Clonazepam in the treatment of prepubertal children with panic-like symptoms. J Clin Psychiatry. 1987 Oct;48 Suppl:38–42. doi: 10.1097/00004583-199403000-00011. PMID: 3667548.3667548
190 Birmaher B, Waterman GS, Ryan N, . Fluoxetine for childhood anxiety disorders. J Am Acad Child Adolesc Psychiatry. 1994 Sep;33(7):993–9. doi: 10.1097/00004583-199409000-00009. PMID: 7961355.7961355
191 Chavira DA, Stein MB. Combined psychoeducation and treatment with selective serotonin reuptake inhibitors for youth with generalized social anxiety disorder. J Child Adolesc Psychopharmacol. 2002 Spring;12(1):47–54. doi: 10.1089/10445460252943560. PMID: 12014595.12014595
192 Chutko, L S, Surushkina, . Treatment of anxiety disorders in school maladaptation with adaptol. Neuroscience and Behavioral Physiology. 2011 June;41(5):520–4. doi: 10.1007/s11055-011-9448-z. PMID: 2011364339.
193 Compton SN, Grant PJ, Chrisman AK, . Sertraline in children and adolescents with social anxiety disorder: an open trial. J Am Acad Child Adolesc Psychiatry. 2001 May;40(5):564–71. doi: 10.1097/00004583-200105000-00016. PMID: 11349701.11349701
194 D’Amato G. Chlordiazepoxide in management of school phobia. Dis Nerv Syst. 1962 May;23:292–5. PMID: 13882945.13882945
195 Dummit ES, 3rd, Klein RG, Tancer NK, . Fluoxetine treatment of children with selective mutism: an open trial. J Am Acad Child Adolesc Psychiatry. 1996 May;35(5):615–21. doi: 10.1097/00004583-199605000-00016. PMID: 8935208.8935208
196 Fairbanks JM, Pine DS, Tancer NK, . Open fluoxetine treatment of mixed anxiety disorders in children and adolescents. J Child Adolesc Psychopharmacol. 1997 Spring;7(1):17–29. doi: 10.1089/cap.1997.7.17. PMID: 9192539.9192539
197 Isolan L, Pheula G, Salum GA, Jr., . An open-label trial of escitalopram in children and adolescents with social anxiety disorder. J Child Adolesc Psychopharmacol. 2007 Dec;17(6):751–60. doi: 10.1089/cap.2007.0007. PMID: 18315447.18315447
198 Karabekiroglu K, Karakurt MN, Yuce M, . Fluoxetine for the Treatment of Childhood and Adolescence Social Phobia: Factors playing a role in Efficacy. Klinik Psikofarmakoloji Bulteni-Bulletin of Clinical Psychopharmacology. 2011 Dec;21(4):317–24. doi: 10.5455/Bcp.20110810012912. PMID: WOS:000297959300004.
199 Lepola U, Leinonen E, Koponen H. Citalopram in the treatment of early-onset panic disorder and school phobia. Pharmacopsychiatry. 1996 Jan;29(1):30–2. doi: 10.1055/s-2007-979539. PMID: 8852532.8852532
200 Mancini C, Van Ameringen M, Oakman JM, . Serotonergic agents in the treatment of social phobia in children and adolescents: a case series. Depress Anxiety. 1999;10(1):33–9. doi: 10.1002/(SICI)1520-6394(1999)10:1<33::AID-DA6>3.0.CO;2-H. PMID: 10499188.10499188
201 Masi G, Toni C, Mucci M, . Paroxetine in child and adolescent outpatients with panic disorder. J Child Adolesc Psychopharmacol. 2001 Summer;11(2):151–7. doi: 10.1089/104454601750284054. PMID: 11436954.11436954
202 Mrakotsky C, Masek B, Biederman J, . Prospective open-label pilot trial of mirtazapine in children and adolescents with social phobia. J Anxiety Disord. 2008;22(1):88–97. doi: 10.1016/j.janxdis.2007.01.005. PMID: 17419001.17419001
203 Renaud J, Birmaher B, Wassick SC, . Use of selective serotonin reuptake inhibitors for the treatment of childhood panic disorder: a pilot study. J Child Adolesc Psychopharmacol. 1999;9(2):73–83. doi: 10.1089/cap.1999.9.73. PMID: 10461817.10461817
204 Simeon JG, Ferguson HB. Alprazolam effects in children with anxiety disorders. Can J Psychiatry. 1987 Oct;32(7):570–4. doi: 10.1177/070674378703200712. PMID: 3315169.3315169
205 Simeon JG, Knott VJ, Dubois C, . Buspirone Therapy of Mixed Anxiety Disorders in Childhood and Adolescence - a Pilot-Study. Journal of Child and Adolescent Psychopharmacology. 1994 Fal;4(3):159–70. doi: DOI 10.1089/cap.1994.4.159. PMID: WOS:A1994PK77100003.
206 Zwier KJ, Rao U. Buspirone use in an adolescent with social phobia and mixed personality disorder (cluster A type). J Am Acad Child Adolesc Psychiatry. 1994 Sep;33(7):1007–11. doi: 10.1097/00004583-199409000-00011. PMID: 7961339.7961339
207 Higgins JPT, Green S, eds. Cochrane handbook for systematic reviews of interventions Version 5.1.0 [updated March 2011]: The Cochrane Collaboration; 2011.
208 Wells G, Shea B, O’connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 2000.
209 Spence, Susan H, Donovan, . The treatment of childhood social phobia: The effectiveness of a social skills training-based, cognitive-behavioural intervention, with and without parental involvement. Journal of Child Psychology and Psychiatry. 2000;41(6):713–26. doi: 10.1111/1469-7610.00659.11039684
210 White IR, Barrett JK, Jackson D, . Consistency and inconsistency in network meta-analysis: model estimation using multivariate meta-regression. Res Synth Methods. 2012 Jun;3(2):111–25. doi: 10.1002/jrsm.1045. PMID: 26062085.26062085
211 Arándiga, Antonio V, Rodríguez, . Competencia social y autoestima en adolescentes con fobia social. Investigar el cambio curricular en el espacio europeo de educación superior. 2007:459–79.