# Appendix H Figures

Figure H.1 Funnel plot CBT versus waitlisting or no treatment for primary anxiety symptoms, clinician report

This figure is a funnel plot for the comparison between CBT and waitlisting on primary anxiety symptoms, clinician version. The figure shows asymmetry of the funnel plot and indicates potential publication bias.

Figure H.2 Funnel plot CBT versus waitlisting or no treatment for primary anxiety symptoms, child report

This figure is a funnel plot for the comparison between CBT and waitlisting on primary anxiety symptoms, child version. The figure shows asymmetry of the funnel plot and indicates potential publication bias.

Figure H.3 Funnel plot for CBT versus waitlisting or no treatment for primary anxiety symptoms, parent report

This figure is a funnel plot for the comparison between CBT and waitlisting on primary anxiety symptoms, parent version. The figure shows asymmetry of the funnel plot and indicates potential publication bias.