# Appendix G Subgroup Analysis

Table G.1 Subgroup analysis – age

Subgroup | Comparison | Outcome | Subgroup Variable | Conclusion
Age | CBT vs. attention control or treatment as usual | Primary anxiety, child report | 7–12 years | SMD: −1.05; 95% CI: −1.99 to −0.11; I^2^= N/A^105^
Age | CBT vs. attention control or treatment as usual | Primary anxiety, child report | 13–18 years | SMD: −1.04; 95% CI: −1.65 to −0.42; I^2^= 60.7%^94, 104^
Age | CBT vs. waitlisting or no treatment | Primary anxiety, clinician report | 7–12 years | SMD: −0.82; 95% CI: −1.34 to −0.30; I^2^= 58.9%^38, 41^
Age | CBT vs. waitlisting or no treatment | Primary anxiety, clinician report | 13–18 years | SMD: −1.19; 95% CI: −1.87 to −0.52; I^2^= 0.0%^31, 61^
Age | CBT vs. waitlisting or no treatment | Primary anxiety, child report | 7–12 years | SMD: −0.37; 95% CI: −1.17 to 0.43; I^2^= 0.0%^38, 41, 56^
Age | CBT vs. waitlisting or no treatment | Primary anxiety, child report | 13–18 years | SMD: −1.22; 95% CI: −1.89 to −0.55; I^2^= 0.0%^31, 61^
Age | CBT vs. waitlisting or no treatment | Function | 7–12 years | SMD: −0.48; 95% CI: −1.00 to 0.04; I^2^= 88.7%^38, 41^
Age | CBT vs. waitlisting or no treatment | Function | 13–18 years | SMD: −1.65; 95% CI: −2.50 to −0.80; I^2^= N/A^61^

CBT: cognitive behavioral therapy, CI: confidence interval, N/A: not applicable, SMD: standardized mean difference

Table G.2 Subgroup analysis – comorbidity

Subgroup | Comparison | Outcome | Subgroup Variable | Conclusion
Comorbidity | CBT vs. attention control or treatment as usual | Primary anxiety, child report | Comorbidity | SMD: −0.31; 95% CI: −0.84 to 0.23; I^2^= N/A^103^
Comorbidity | CBT vs. attention control or treatment as usual | Primary anxiety, child report | No comorbidity | SMD: −0.53; 95% CI: −1.49 to 0.44; I^2^= 74.7%^99, 102, 104, 116^
Comorbidity | CBT vs. Pill Placebo | Function | Comorbidity | SMD: 0.02; 95% CI: −0.59 to 0.63; I^2^= N/A^121^
Comorbidity | CBT vs. Pill Placebo | Function | No comorbidity | SMD: −0.60; 95% CI: −0.84 to −0.36; I^2^= 90.5%^3, 20–26^
Comorbidity | CBT vs. Pill Placebo | Secondary measure | Comorbidity | SMD: 0.30; 95% CI: −0.32 to 0.91; I^2^= N/A^121^
Comorbidity | CBT vs. Pill Placebo | Secondary measure | No comorbidity | SMD: −1.02; 95% CI: −1.45 to −0.58; I^2^= N/A^3^
Comorbidity | CBT vs. waitlisting or no treatment | Primary anxiety, clinician report | Comorbidity | SMD: −1.25; 95% CI: −1.79 to −0.70; I^2^= 93.2%^90, 91^
Comorbidity | CBT vs. waitlisting or no treatment | Primary anxiety, clinician report | No comorbidity | SMD: −0.83; 95% CI: −1.85 to 0.20; I^2^= 88.8%^30, 31, 36, 38, 41, 44, 46, 81, 82, 88, 89, 209^
Comorbidity | CBT vs. waitlisting or no treatment | Primary anxiety, child report | Comorbidity | SMD: −0.85; 95% CI: −2.82 to 1.12; I^2^= 90.0%^34, 53, 70, 91^
Comorbidity | CBT vs. waitlisting or no treatment | Primary anxiety, child report | No comorbidity | SMD: −0.42; 95% CI: −0.78 to −0.07; I^2^= 74.4%^30, 31, 36, 38–41, 44, 46, 48, 49, 81, 82, 88, 89, 209^
Comorbidity | CBT vs. waitlisting or no treatment | Primary anxiety, parent report | Comorbidity | SMD: −1.82; 95% CI: −4.44 to 0.80; I^2^= 0.90.5%^34, 53, 70, 91^
Comorbidity | CBT vs. waitlisting or no treatment | Primary anxiety, parent report | No comorbidity | SMD: −0.63; 95% CI: −1.15 to −0.12; I^2^= 76.7%^30, 38–40, 46, 48, 49, 81, 82, 88, 89^
Comorbidity | CBT vs. waitlisting or no treatment | Function | Comorbidity | SMD: −0.62; 95% CI: −1.19 to −0.05; I^2^= 75.8%^53, 210^
Comorbidity | CBT vs. waitlisting or no treatment | Function | No comorbidity | SMD: −0.20; 95% CI: −1.07 to 0.67; I^2^= 91.9%^30, 38, 41, 44, 46, 82^
Comorbidity | CBT vs. waitlisting or no treatment | Secondary measure | Comorbidity | SMD: −0.33; 95% CI: −0.92 to 0.25; I^2^= N/A^34^
Comorbidity | CBT vs. waitlisting or no treatment | Secondary measure | No comorbidity | SMD: 0.24; 95% CI: −0.54 to 1.02; I^2^= 94.5%^39, 40, 44, 46, 48, 49, 209^
Comorbidity | CBT vs. waitlisting or no treatment | Response | Comorbidity | RR: 12.69; 95% CI: 0.81 to 198.10; I^2^= N/A^53^
Comorbidity | CBT vs. waitlisting or no treatment | Response | No comorbidity | RR: 10.16; 95% CI: 2.98 to 34.66; I^2^=0.0%^39, 40, 46, 49, 209^
Comorbidity | Fluvoxamine vs. pill placebo | Primary anxiety, clinician report | Comorbidity | SMD: −0.30; 95% CI: −1.11 to 0.51; I^2^= N/A^1^
Comorbidity | Fluvoxamine vs. pill placebo | Primary anxiety, clinician report | No comorbidity | SMD: −1.11; 95% CI: −1.49 to −0.74; I^2^= N/A^11^

CBT: cognitive behavioral therapy, CI: confidence interval, N/A: not applicable, RR: risk ratio, SMD: standardized mean difference

Table G.3 Subgroup analysis – ADHD

Subgroup | Comparison | Outcome | Subgroup Variable | Conclusion
ADHD | Fluvoxamine vs. pill placebo | Primary anxiety, clinician report | ADHD | SMD: −0.30; 95% CI: −1.11 to 0.51; I^2^= N/A^1^
ADHD | Fluvoxamine vs. pill placebo | Primary anxiety, clinician report | No ADHD | SMD: −1.11; 95% CI: −1.49 to −0.74; I^2^= N/A ^11^

ADHD: attention deficit hyperactivity disorder, CI: confidence interval, N/A: not applicable, SMD: standardized mean difference

Table G.4 Subgroup analysis – autism

Subgroup | Comparison | Outcome | Subgroup Variable | Conclusion
Autism | CBT vs. waitlisting or‎ no treatment | Primary anxiety, clinician report | Autism | SMD: −1.25; 95% CI: −1.79 to −0.70; I^2^= 93.2%^91, 210^
Autism | CBT vs. waitlisting or‎ no treatment | Primary anxiety, clinician report | No Autism | SMD: −0.83; 95% CI: −1.85 to 0.20; I^2^= 88.8%^30, 31, 36, 38, 41, 46, 81, 82, 88^
Autism | CBT vs. waitlisting or‎ no treatment | Primary anxiety, child report | Autism | SMD: −0.85; 95% CI: −2.82 to 1.12; I^2^= 90.0%^34, 53, 70, 91^
Autism | CBT vs. waitlisting or‎ no treatment | Primary anxiety, child report | No Autism | SMD: −0.42; 95% CI: −0.78 to −0.07; I^2^= 74.4%^30, 31, 34, 36, 38–41, 44, 46, 48, 49, 81, 82, 88, 89, 209^
Autism | CBT vs. waitlisting or‎ no treatment | Primary anxiety, parent report | Autism | SMD: −1.82; 95% CI: −4.44 to 0.80; I^2^= 90.5%^34, 53, 70, 91^
Autism | CBT vs. waitlisting or‎ no treatment | Primary anxiety, parent report | No Autism | SMD: −0.62; 95% CI: −1.14 to −0.10; I^2^=74.4%^30, 34, 38–40, 46, 48, 49, 81, 82, 88, 89^
Autism | CBT vs. waitlisting or‎ no treatment | Function | Autism | SMD: −0.62; 95% CI: −1.19 to −0.05; I^2^= 75.8%^53, 210^
Autism | CBT vs. waitlisting or‎ no treatment | Function | No Autism | SMD: −0.20; 95% CI: −1.07 to 0.67; I^2^= 91.9%^30, 38, 41, 44, 46, 82^
Autism | CBT vs. waitlisting or‎ no treatment | Response | Autism | RR: 12.69; 95% CI: 0.81 to 198.10; I^2^= N/A^53^
Autism | CBT vs. waitlisting or‎ no treatment | Response | No Autism | RR: 9.91; 95% CI: 2.25 to 43.65; I^2^= 0.0%^39, 40, 46, 49, 209^

CBT: cognitive behavioral therapy, CI: confidence interval, N/A: not applicable, RR: risk ratio, SMD: standardized mean difference

Table G.5 Subgroup analysis – school refusal

Subgroup | Comparison | Outcome | Subgroup Variable | Conclusion
School Refusal | CBT vs. attention control or treatment as usual | Primary anxiety, child report | School refusal | SMD: −0.31; 95% CI: −0.84 to 0.23; I^2^= N/A^103^
School Refusal | CBT vs. attention control or treatment as usual | Primary anxiety, child report | No School refusal | SMD: −0.53; 95% CI: −1.49 to 0.44; I^2^= 74.7%^99, 102, 104, 116^
School Refusal | CBT vs. pill placebo | Secondary measure | School refusal | SMD: 0.30; 95% CI: −0.32 to 0.91; I^2^= N/A^121^
School Refusal | CBT vs. pill placebo | Secondary measure | No School refusal | SMD: −1.02; 95% CI: −1.45 to −0.58; I^2^= N/A^3^

CBT: cognitive behavioral therapy, CI: confidence interval, N/A: not applicable, SMD: standardized mean difference

Table G.6 Subgroup analysis – diagnosis

Subgroup | Comparison | Outcome | Subgroup Variable | Conclusion
Diagnosis | CBT vs. attention control or yreatment as usual | Primary anxiety, clinician report | Panic Disorder | SMD: −0.97; 95% CI: −1.79 to −0.15; I^2^= N/A^107^
Diagnosis | CBT vs. attention control or yreatment as usual | Primary anxiety, clinician report | Social Anxiety Disorder | SMD: −0.44; 95% CI: −1.95 to 1.08; I^2^= 73.9%^72, 97, 116^
Diagnosis | CBT vs. attention control or yreatment as usual | Primary anxiety, clinician report | Specific Phobias | SMD: −0.00; 95% CI: −0.36 to 0.35; I^2^= 87.8% ^96, 110^
Diagnosis | CBT vs. attention control or yreatment as usual | Primary anxiety, child report | Panic Disorder | SMD: −0.24; 95% CI: −1.02 to 0.53; I^2^= N/A ^107^
Diagnosis | CBT vs. attention control or yreatment as usual | Primary anxiety, child report | Social Anxiety Disorder | SMD: −0.70; 95% CI: −1.34 to −0.05 ; I^2^= 66.4%^72, 99, 104, 109, 116^
Diagnosis | CBT vs. attention control or yreatment as usual | Primary anxiety, parent report | Social Anxiety Disorder | SMD: −0.65; 95% CI: −2.67 to 1.38; I^2^= 90.3%^72, 97, 104, 116^
Diagnosis | CBT vs. attention control or yreatment as usual | Primary anxiety, parent report | Specific Phobias | SMD: 0.11; 95% CI: −0.45 to 0.68; I^2^= N/A^110^
Diagnosis | CBT vs. attention control or yreatment as usual | Secondary measure | Panic Disorder | SMD: −0.50; 95% CI: −1.28 to 0.29; I^2^= N/A^107^
Diagnosis | CBT vs. attention control or yreatment as usual | Secondary measure | Social Anxiety Disorder | SMD: −1.71; 95% CI: −2.46 to −0.96; I^2^= N/A^72^
Diagnosis | CBT vs. waitlisting or no treatment | Primary anxiety, clinician report | Generalized Anxiety | SMD: −2.42; 95% CI: −3.23 to −1.62; I^2^= N/A^46^
Diagnosis | CBT vs. waitlisting or no treatment | Primary anxiety, clinician report | Panic Disorder | SMD: −1.09; 95% CI: −1.71 to −0.47; I^2^= N/A^42^
Diagnosis | CBT vs. waitlisting or no treatment | Primary anxiety, clinician report | Social Anxiety Disorder | SMD: −1.59; 95% CI: −2.38 to −0.80; I^2^= 81.0%^31, 38, 41, 45, 51, 54, 61, 67, 74, 80, 178^
Diagnosis | CBT vs. waitlisting or no treatment | Primary anxiety, clinician report | Specific Phobias | SMD: −1.01; 95% CI: −1.35 to −0.68; I^2^= 83.2%^58, 63^
Diagnosis | CBT vs. waitlisting or no treatment | Primary anxiety, Child report | Generalized Anxiety | SMD: −0.30; 95% CI: −0.91 to 0.31; I^2^= N/A^46^
Diagnosis | CBT vs. waitlisting or no treatment | Primary anxiety, Child report | Separation Anxiety | SMD: −0.29; 95% CI: −0.89 to 0.32; I^2^= N/A^77^
Diagnosis | CBT vs. waitlisting or no treatment | Primary anxiety, Child report | Social Anxiety Disorder | SMD: −1.21; 95% CI: −1.91 to −0.52; I^2^= 87.4%^31, 38, 41, 45, 51, 54, 61, 62, 67, 74, 80, 178^
Diagnosis | CBT vs. waitlisting or no treatment | Primary anxiety, Child report | Specific Phobias | SMD: −0.08; 95% CI: −0.93 to 0.77; I^2^= 9.4%^50, 63, 66, 124^
Diagnosis | CBT vs. waitlisting or no treatment | Primary anxiety, parent report | Generalized Anxiety | SMD: −0.14; 95% CI: −0.75 to 0.47; I^2^= N/A^46^
Diagnosis | CBT vs. waitlisting or no treatment | Primary anxiety, parent report | Separation Anxiety | SMD: −1.27; 95% CI: −1.90 to −0.65; I^2^= 50.0%^27, 77^
Diagnosis | CBT vs. waitlisting or no treatment | Primary anxiety, parent report | Social Anxiety Disorder | SMD: −0.89; 95% CI: −1.66 to −0.13; I^2^= 72.9%^38, 51, 62, 65, 67^
Diagnosis | CBT vs. waitlisting or no treatment | Primary anxiety, parent report | Specific Phobias | SMD: −0.83; 95% CI: −1.45 to −0.21; I^2^= N/A^58^
Diagnosis | CBT vs. waitlisting or no treatment | Function | Generalized Anxiety | SMD: −0.30; 95% CI: −0.91 to 0.31; I^2^= N/A^46^
Diagnosis | CBT vs. waitlisting or no treatment | Function | Separation Anxiety | SMD: 1.41; 95% CI: 0.74 to 2.08; I2= N/A^77^
Diagnosis | CBT vs. waitlisting or no treatment | Function | Social Anxiety Disorder | SMD: −1.00; 95% CI: −1.74 to −0.26; I^2^= 83.7%^38, 41, 51, 54, 61, 62, 67, 178^
Diagnosis | CBT vs. waitlisting or no treatment | Secondary measure | Generalized Anxiety | SMD: −0.38; 95% CI: −0.99 to 0.23; I^2^=N/A^46^
Diagnosis | CBT vs. waitlisting or no treatment | Secondary measure | Social Anxiety Disorder | SMD: −0.57; 95% CI: −1.53 to 0.38; I^2^= 94.2%^61, 62, 74, 178, 209^
Diagnosis | CBT vs. waitlisting or no treatment | Secondary measure | Specific Phobias | SMD: 1.18; 95% CI: −3.99 to 6.34; I^2^= 93.8%^50, 63, 66^
Diagnosis | CBT vs. waitlisting or no treatment | Social function | Generalized Anxiety | SMD: −0.61; 95% CI: −1.24 to 0.01; I^2^= N/A^46^
Diagnosis | CBT vs. waitlisting or no treatment | Social function | Social Anxiety Disorder | SMD: 0.15; 95% CI: −1.27 to 1.56; I^2^= 90.6%^38, 41, 61, 80, 178^
Diagnosis | CBT vs. waitlisting or no treatment | Remission | Generalized Anxiety | RR: 7.67; 95% CI: 0.42 to 139.83; I^2^= N/A^46^
Diagnosis | CBT vs. waitlisting or no treatment | Remission | Social Anxiety Disorder | RR: 11.38; 95% CI: 1.56 to 83.22; I^2^= 0.0%^43, 62^
Diagnosis | CBT vs. waitlisting or no treatment | Response | Generalized Anxiety | RR: 20.81; 95% CI: 1.29 to 335.97; I^2^= N/A^46^
Diagnosis | CBT vs. waitlisting or no treatment | Response | Social Anxiety Disorder | RR: 8.42; 95% CI: 3.88 to 18.25; I^2^= 0.0%^45, 51, 67, 80, 178^
Diagnosis | CBT vs. waitlisting or no treatment | Response | Specific Phobias | RR: 22.67; 95% CI: 3.24 to 158.60; I^2^= N/A^63^
Diagnosis | Venlafaxine vs. pill placebo | Primary anxiety, child report | Generalized Anxiety | SMD: −0.52; 95% CI: −0.84 to −0.19; I^2^= N/A^15^
Diagnosis | Venlafaxine vs. pill placebo | Primary anxiety, child report | Social Anxiety Disorder | SMD: −0.47; 95% CI: −0.70 to −0.24; I^2^= N/A^10^

CBT: cognitive behavioral therapy, CI: confidence interval, N/A: not applicable, RR: risk ratio, SMD: standardized mean difference

Table G.7 Subgroup analysis – treatment settings

Subgroup | Comparison | outcome | Subgroup Variable | Conclusion
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Primary anxiety, clinician report | Mental health clinic | SMD: −0.11; 95% CI: −0.55 to 0.33; I^2^= 55.2%^96–98, 101, 106, 110^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Primary anxiety, clinician report | School | SMD: −0.24; 95% CI: −2.46 to 1.98; I^2^= 84.7%^72, 95, 116^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Primary anxiety, child report | Mental health clinic | SMD: −0.32; 95% CI: −0.66 to 0.01; I^2^= 54.2%^98–101, 103, 107, 108, 117, 154^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Primary anxiety, child report | School | SMD: −0.49; 95% CI: −1.16 to 0.17; I^2^= 66.2%^34, 72, 95, 109, 116^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Primary anxiety, parent report | Mental health clinic | SMD: 0.08; 95% CI: −0.20 to 0.37; I^2^= 0.0% ^97, 98, 100, 101, 110, 117^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Primary anxiety, parent report | School | SMD: −0.68; 95% CI: −2.66 to 1.30; I^2^= 89.6^72, 95, 104, 116^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Function | Mental health clinic | SMD: −0.30; 95% CI: −1.26 to 0.66; I^2^= 61.9%^99, 101, 114^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Function | School | SMD: −1.18; 95% CI: −3.42 to 1.05; I^2^= 79.2%^72, 104, 109^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Secondary measure | Mental health clinic | SMD: −0.50; 95% CI: −1.28 to 0.29; I^2^= N/A^100, 101, 107^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Secondary measure | School | SMD: −1.71; 95% CI: −2.46 to −0.96; I^2^= N/A^72, 109^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Social function | Mental health clinic | SMD: −0.36; 95% CI: −1.02 to 0.30; I^2^= 15.7%^97, 114, 117^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Social function | School | SMD: −0.34; 95% CI: −0.72 to 0.03; I^2^= 82.6%^109, 116, 211^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Remission | Mental health clinic | RR: 1.53; 95% CI: 1.11 to 2.11; I^2^= 0.0%^98, 111^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Remission | School | RR: 2.68; 95% CI: 0.11 to 64.50; I^2^= 64.3%^72, 95, 116^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Response | Mental health clinic | RR: 1.50; 95% CI: 1.07 to 2.11; I^2^= 0.0%^98, 100, 101^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. attention control or treatment as usual | Response | School | RR: 1.95; 95% CI: 0.28 to 13.39; I^2^= 79.1%^95, 104, 116^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Primary anxiety, clinician report | Mental health clinic | SMD: −1.07; 95% CI: −1.66 to −0.47; I^2^= 84.8%^30–32, 36, 38, 41, 42, 44–47, 52, 54, 58, 59, 63, 67, 69, 79–82, 86–88, 90, 91^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Primary anxiety, clinician report | School | SMD: −1.97; 95% CI: −3.26 to −0.68; I^2^= 89.5%^35, 51, 61, 74, 151, 178^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Primary anxiety, child report | Mental health clinic | SMD: −0.58; 95% CI: −0.88 to −0.28; I^2^= 83.7%^29–34, 36, 38, 39, 41, 44–46, 48–50, 52–54, 56, 62, 63, 66–70, 77–82, 88, 91^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Primary anxiety, child report | School | SMD: −1.32; 95% CI: −2.43 to −0.21; I^2^= 91.4%^35, 61, 74, 151, 178^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Primary anxiety, parent report | Mental health clinic | SMD: −0.86; 95% CI: −1.23 to −0.48; I^2^= 81.1%^27, 29, 30, 34, 38, 39, 46–49, 52, 53, 58, 59, 62, 65, 67, 69, 70, 77, 79, 81, 82, 88, 91^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Primary anxiety, parent report | School | SMD: −0.50; 95% CI: −1.24 to 0.24; I^2^= 0.0%^35, 51, 151^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Function | Mental health clinic | SMD: −0.64; 95% CI: −1.41 to 0.14; I^2^= 92.6%^30, 32, 38, 41, 44, 46, 53, 54, 59, 62, 67, 77, 82, 87, 90^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Function | School | SMD: −1.27; 95% CI: −3.09 to 0.55; I^2^= 74.2%^51, 61, 178^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Secondary measure | Mental health clinic | SMD: 0.05; 95% CI: −0.44 to 0.55; I^2^= 93.5%^32, 34, 39, 44, 46–50, 56, 62, 63, 66, 69, 80^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Secondary measure | School | SMD: −0.14; 95% CI: −1.87 to 1.59; I^2^=94.7% ^61, 74, 178^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Social function | Mental Health Clinic | SMD: −0.07; 95% CI: −0.69 to 0.55; I2= 74.8%^38, 39, 41, 44, 46, 48, 80^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Social function | School | SMD: 0.10; 95% CI: −4.66 to 4.86; I^2^= 95.1%^61, 178^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Remission | Mental health clinic | RR: 2.78; 95% CI: 0.24 to 31.98; I^2^= 76.1%^32, 46, 62, 86^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Remission | School | RR: 5.74; 95% CI: 2.17 to 15.20; I^2^= 0.0%^35, 46^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Response | Mental health clinic | RR: 3.60; 95% CI: 1.77 to 7.32; I^2^= 83.0%^45–49, 52, 53, 63, 67, 79, 80, 86, 87^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | CBT vs. Waitlisting or‎ No Treatment | Response | School | RR: 14.45; 95% CI: 2.94 to 71.01; I^2^= 0.0%^51, 178^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | Fluvoxamine vs. pill placebo | Primary anxiety, clinician report | Mental health clinic | SMD: −0.30; 95% CI: −1.11 to 0.51; I^2^= N/A^1^
Treatment Settings (School, Mental Health Clinic, Outpatient primary care) | Fluvoxamine vs. pill placebo | Primary anxiety, clinician report | Outpatient primary care | SMD: −1.11; 95% CI: −1.49 to −0.74; I^2^= N/A^11^

CBT: cognitive behavioral therapy, CI: confidence interval, N/A: not applicable, RR: risk ratio, SMD: standardized mean difference

Table G.8 Subgroup analysis – follow up less than 6 months

Subgroup | Comparison | Outcome | Subgroup Variable | Conclusion
Follow up (less than 6 months) | Benzodiazepine vs. pill placebo | Primary anxiety, clinician report | Less than 6 months | SMD: −0.40; 95% CI: −1.43 to 0.63; I^2^=N/A^9^
Follow up (less than 6 months) | CBT vs. attention control or treatment as usual | Primary anxiety, clinician report | Less than 6 months | SMD: −0.11; 95% CI: −0.52 to 0.30; I^2^=49.9%^95–98, 101, 106, 116^
Follow up (less than 6 months) | CBT vs. attention control or treatment as usual | Primary anxiety, child report | Less than 6 months | SMD: −0.41; 95% CI: −0.88 to 0.07; I^2^= 54.2%^95, 98, 101, 104, 108, 109, 116^
Follow up (less than 6 months) | CBT vs. attention control or treatment as usual | Primary anxiety, parent report | Less than 6 months | SMD: 0.16; 95% CI: −0.53 to 0.85; I^2^=76.7%^95, 97, 98, 106, 116^
Follow up (less than 6 months) | CBT vs. attention control or treatment as usual | Function | Less than 6 months | SMD: −0.87; 95% CI: −2.98 to 1.23; I^2^=79.5%^101, 109, 116^
Follow up (less than 6 months) | CBT vs. attention control or treatment as usual | Social Function | Less than 6 months | SMD: 0.62; 95% CI: −1.03 to 2.26; I^2^=82.0%^97, 109, 116^
Follow up (less than 6 months) | CBT vs. attention control or treatment as usual | Remission | Less than 6 months | RR: 1.52; 95% CI: 0.22 to 10.48; I^2^=74.9%^95, 98, 116^
Follow up (less than 6 months) | CBT vs. attention control or treatment as usual | Response | Less than 6 months | RR:1.70; 95% CI: 0.34 to 8.53; I^2^=77.9%^95, 98, 116^
Follow up (less than 6 months) | CBT vs. waitlisting or no treatment | Primary anxiety, clinician report | Less than 6 months | SMD: −1.02; 95% CI: −1.65 to −0.38; I^2^=86.1%^32, 41, 46, 58, 59, 63, 72, 74, 76, 151, 178^
Follow up (less than 6 months) | CBT vs. waitlisting or no treatment | Primary anxiety, child report | Less than 6 months | SMD: −1.43; 95% CI: −2.72 to −0.14; I^2^=94.4%^29, 32, 41, 46, 63, 72, 74, 76, 151, 178^
Follow up (less than 6 months) | CBT vs. waitlisting or no treatment | Primary anxiety, parent report | Less than 6 months | SMD: −0.93; 95% CI: −2.98 to 1.13; I^2^=85.1%^29, 46, 58, 59, 72, 76, 151^
Follow up (less than 6 months) | CBT vs. waitlisting or no treatment | Function | Less than 6 months | SMD: −0.52, 95% CI: −1.28 to 0.23; I^2^=73.0%^32, 41, 59, 72, 76, 178^
Follow up (less than 6 months) | CBT vs. waitlisting or no treatment | Social function | Less than 6 months | SMD: −1.60; 95% CI: −11.13 to 7.92; I^2^=96.1%^41, 46, 84, 178^
Follow up (less than 6 months) | CBT vs. waitlisting or no treatment | Remission | Less than 6 months | RR: 4.38; 95% CI: 0.03 to 598.20; I^2^=78.2%^32, 46, 72^
Follow up (less than 6 months) | CBT vs. waitlisting or no treatment | Response | Less than 6 months | RR: 1.50; 95% CI: 0.71 to 3.17; I^2^=N/A^178^
Follow up (less than 6 months) | Clonazepam vs. pill placebo | Primary anxiety, clinician report | Less than 6 months | SMD: −0.40; 95% CI: −1.43 to 0.63; I^2^=N/A^9^
Follow up (less than 6 months) | Fluoxetine plus CBT vs. CBT | Function | Less than 6 months | SMD: −0.53; 95% CI: −0.10 to 1.15; I^2^=N/A^121^
Follow up (less than 6 months) | Fluoxetine plus CBT vs. CBT | Secondary aeasure | Less than 6 months | SMD: 0.39; 95% CI: −0.23 to 1.01; I^2^=N/A^121^

CBT: cognitive behavioral therapy, CI: confidence interval, N/A: not applicable, RR: risk ratio, SMD: standardized mean difference

Table G.9 Subgroup analysis – follow up longer than 6 months

Subgroup | Comparison | Outcome | Subgroup Variable | Conclusion
Follow up (longer than 6 months) | CBT vs. attention control or treatment as usual | Primary anxiety, clinician report | Longer than 6 months | SMD: −0.06; 95% CI: −0.50 to 0.38; I^2^=N/A^96^
Follow up (longer than 6 months) | CBT vs. attention control or treatment as usual | Primary anxiety, child report | Longer than 6 months | SMD: −0.20; 95% CI: −0.48 to −0.09; I^2^=83.5%^99–101^
Follow up (longer than 6 months) | CBT vs. attention control or treatment as usual | Function | Longer than 6 months | SMD: −0.31; 95% CI: −0.59 to −0.02; I^2^=89.7%^99, 114^
Follow up (longer than 6 months) | CBT vs. attention control or treatment as usual | Social function | Longer than 6 months | SMD: −0.09; 95% CI: −0.47 to 0.29; I^2^=N/A^114^
Follow up (longer than 6 months) | CBT vs. attention control or treatment as usual | Remission | Longer than 6 months | RR: 1.26; 95% CI: 0.99 to 1.60; I^2^=N/A^111^
Follow up (longer than 6 months) | CBT vs. attention control or treatment as usual | Response | Longer than 6 months | RR: 1.40; 95% CI: 0.97 to 2.04; I^2^=N/A^100, 101^
Follow up (longer than 6 months) | CBT vs. waitlisting or no treatment | Primary anxiety, clinician report | Longer than 6 months | SMD: −0.59; 95% CI: −1.31 to −0.13; I^2^=0.0%^32, 72, 151^
Follow up (longer than 6 months) | CBT vs. waitlisting or no treatment | Primary anxiety, child report | Longer than 6 months | SMD: −0.08; 95% CI: −0.56 to 0.39; I^2^=0.0%^32, 45, 72, 151^
Follow up (longer than 6 months) | CBT vs. waitlisting or no treatment | Primary anxiety, parent report | Longer than 6 months | SMD: −1.55; 95% CI: −8.38 to 5.28; I^2^=96.1%^59, 72, 151^
Follow up (longer than 6 months) | CBT vs. waitlisting or no treatment | Function | Longer than 6 months | SMD: −0.36, 95% CI; −2.39 to 1.67; I^2^=85.1%^32, 59, 72^
Follow up (longer than 6 months) | CBT vs. waitlisting or no treatment | Remission | Longer than 6 months | RR: 0.71; 95% CI: 0.57 to 1.03; I^2^=N/A^32^
Follow up (longer than 6 months) | Fluoxetine plus CBT vs. CBT | Function | Longer than 6 months | SMD: −0.64; 95% CI: −1.26 to −0.01; I^2^=N/A^121^
Follow up (longer than 6 months) | Fluoxetine plus CBT vs. CBT | Secondary measure | Longer than 6 months | SMD: 0.65; 95% CI: 0.02 to 1.27; I^2^=N/A^121^

CBT: cognitive behavioral therapy, CI: confidence interval, N/A: not applicable, RR: risk ratio, SMD: standardized mean difference

Table G.10 Subgroup analysis – therapy components

Subgroup | Comparison | Outcome | Subgroup Variable | Conclusion
CBT with cognitive strategies | CBT without cognitive strategies vs. CBT with cognitive strategies | Primary anxiety, clinician report | No cognitive vs. cognitive | SMD: −0.30; 95% CI: −1.44 to 0.83; I^2^=41.3%^74, 181, 186^
CBT with cognitive strategies | CBT without cognitive strategies vs. CBT with cognitive strategies | Primary anxiety, child report | No cognitive vs. cognitive | SMD: 0.09; 95% CI: −2.25 to 2.44; I^2^= 87.0%^74, 181, 186^
CBT with cognitive strategies | CBT without cognitive strategies vs. CBT with cognitive strategies | Primary anxiety, parent report | No cognitive vs. cognitive | SMD: −1.29; 95% CI: −2.46 to −0.13; I^2^= N/A^186^
CBT with cognitive strategies | CBT without cognitive strategies vs. CBT with cognitive strategies | Function | No cognitive vs. cognitive | SMD: 0.09; 95% CI: −0.42 to 0.59; I^2^= 82.4%^181, 186^
CBT with cognitive strategies | CBT without cognitive strategies vs. CBT with cognitive strategies | Secondary measure | No cognitive vs. cognitive | SMD: −0.27; 95% CI: −0.83 to 0.29; I^2^= N/A^186^
CBT with cognitive strategies | CBT without cognitive strategies vs. CBT with cognitive strategies | Social function | No cognitive vs. cognitive | SMD: −0.36; 95% CI: −0.92 to 0.20; I^2^= N/A^181^
CBT with cognitive strategies | CBT without cognitive strategies vs. CBT with cognitive strategies | Response | No cognitive vs. cognitive | RR: 0.62; 95% CI: 0.31 to 1.22; I^2^= N/A^181^
CBT with exposure sessions | CBT without exposure sessions vs. CBT with exposure sessions | Primary anxiety, clinician report | No exposure vs. exposure | SMD: 0.13; 95% CI: −0.74 to 1.37; I^2^= N/A^186^
CBT with exposure sessions | CBT without exposure sessions vs. CBT with exposure sessions | Primary anxiety, child report | No exposure vs. exposure | SMD: 0.62; 95% CI: −0.46 to 1.70; I^2^= N/A^186^
CBT with exposure sessions | CBT without exposure sessions vs. CBT with exposure sessions | Primary anxiety, parent report | No exposure vs. exposure | SMD: 1.29; 95% CI: 0.13 to 2.46; I^2^= N/A^186^
CBT with relaxation strategies | CBT without relaxation strategies vs. CBT with relaxation strategies | Primary anxiety, clinician report | No relaxation vs. relaxation | SMD: −0.15; 95% CI: −0.64 to 0.33; I^2^= 0.0%^164, 186^
CBT with relaxation strategies | CBT without relaxation strategies vs. CBT with relaxation strategies | Primary anxiety, child report | No relaxation vs. relaxation | SMD: −0.16; 95% CI: −1.08 to 0.75; I^2^= 48.4%^46, 164, 182, 186^
CBT with relaxation strategies | CBT without relaxation strategies vs. CBT with relaxation strategies | Primary anxiety, parent report | No relaxation vs. Relaxation | SMD: −0.16; 95% CI: −2.37 to 2.05; I^2^= 65.3%^46, 186^
CBT with relaxation strategies | CBT without relaxation strategies vs. CBT with relaxation strategies | Function | No relaxation vs. relaxation | SMD: −0.01; 95% CI: −0.46 to 0.44; I^2^= 78.3%^182, 186^
CBT with relaxation strategies | CBT without relaxation strategies vs. CBT with relaxation strategies | Secondary measure | No relaxation vs. relaxation | SMD: 0.41; 95% CI: −0.14 to 0.97; I^2^= N/A^164, 186^
CBT with relaxation strategies | CBT without relaxation strategies vs. CBT with relaxation strategies | Social function | No relaxation vs. relaxation | SMD: 0.88; 95% CI: −0.38 to 2.13; I^2^= N/A^46^
CBT with relaxation strategies | CBT without relaxation strategies vs. CBT with relaxation strategies | Remission | No relaxation vs. relaxation | RR: 1.25; 95% CI: 0.33 to 4.77; I^2^= N/A^46^

CBT: cognitive behavioral therapy, CI: confidence interval, N/A: not applicable, RR: risk ratio, SMD: standardized mean difference

Table G.11 Subgroup analysis – CBT delivery mode

Subgroup | Comparison | Outcome | Subgroup Variable | Conclusion
Individual-based CBT vs Group-based CBT | Individual-based CBT vs group-based CBT | Primary anxiety, clinician report | Individual vs group | SMD: −0.07; 95% CI: −0.35 to 0.22; I^2^= 0.0%^88, 89, 97, 164, 167, 174^
Individual-based CBT vs Group-based CBT | Individual-based CBT vs group-based CBT | Primary anxiety, child report | Individual vs group | SMD: −0.1; 95% CI: −0.35 to 0.16; I^2^= 0.0%^88, 89, 164, 167, 172, 174^
Individual-based CBT vs Group-based CBT | Individual-based CBT vs group-based CBT | Primary anxiety, parent report | Individual vs group | SMD: −0.03; 95% CI: −0.81 to 0.75; I^2^= 49.9% ^88, 89, 97, 174^
Individual-based CBT vs Group-based CBT | Individual-based CBT vs group-based CBT | Function | Individual vs group | SMD: −0.64; 95% CI: −1.10 to −0.19; I^2^= N/A^174^
Individual-based CBT vs Group-based CBT | Individual-based CBT vs group-based CBT | Secondary measure | Individual vs group | SMD: −0.41; 95% CI: −0.97 to 0.14; I^2^= N/A^164^
Individual-based CBT vs Group-based CBT | Individual-based CBT vs group-based CBT | Social function | Individual vs group | SMD: 0.28; 95% CI: −0.30 to 0.85; I^2^= N/A^97^
Individual-based CBT vs Group-based CBT | Individual-based CBT vs group-based CBT | Remission | Individual vs group | RR: 0.81; 95% CI: 0.47 to 1.39; I^2^= N/A ^88, 89^
Individual-based CBT vs Group-based CBT | Individual-based CBT vs group-based CBT | Response | Individual vs group | RR: 0.93; 95% CI: 0.70 to 1.23; I^2^= 0.0%^88, 89, 172, 173^

CBT: cognitive behavioral therapy, CI: confidence interval, N/A: not applicable, RR: risk ratio, SMD: standardized mean difference

Table G.12 Subgroup analysis – CBT intensity

Subgroup | Comparison | Outcome | Subgroup Variable | Conclusion
Treatment Intensity (low, medium, and high) | CBT with low intensity vs. CBT with medium intensity CBT vs. CBT with high intensity | Primary anxiety, child report | Low intensity vs. medium | SMD: 0.22; 95% CI: −0.11 to 0.56; I^2^= N/A^164, 166^
Treatment Intensity (low, medium, and high) | CBT with low intensity vs. CBT with medium intensity CBT vs. CBT with high intensity | Primary anxiety, parent report | Low intensity vs. medium | SMD: 0.18; 95% CI: −0.15 to 0.51; I^2^= N/A^164, 166^
Treatment Intensity (low, medium, and high) | CBT with low intensity vs. CBT with medium intensity CBT vs. CBT with high intensity | Function | Low intensity vs. medium | SMD: −0.02; 95% CI: −0.35 to 0.31; I^2^= N/A^166^
Treatment Intensity (low, medium, and high) | CBT with low intensity vs. CBT with medium intensity CBT vs. CBT with high intensity | Primary anxiety, clinician report | Medium intensity vs. high | SMD: 0.16; 95% CI: −0.24 to 0.56; I^2^= 0.0%^166^
Treatment Intensity (low, medium, and high) | CBT with low intensity vs. CBT with medium intensity CBT vs. CBT with high intensity | Primary anxiety, child report | Medium intensity vs. high | SMD: 0.25; 95% CI: −0.03 to 0.54; I^2^= 84.2%^166^
Treatment Intensity (low, medium, and high) | CBT with low intensity vs. CBT with medium intensity CBT vs. CBT with high intensity | Primary anxiety, parent report | Medium intensity vs. high | SMD: 0.04; 95% CI: −0.24 to 0.33; I^2^= 35.2%^166^
Treatment Intensity (low, medium, and high) | CBT with low intensity vs. CBT with medium intensity CBT vs. CBT with high intensity | Function | Medium intensity vs. high | SMD: −0.12; 95% CI: −0.46 to 0.21; I2= N/A166
Treatment Intensity (low, medium, and high) | CBT with low intensity vs. CBT with medium intensity CBT vs. CBT with high intensity | Secondary measure | Medium intensity vs. high | SMD: −0.41; 95% CI: −0.97 to 0.14; I^2^= N/A^166^

Intensity: low: less than 480 minutes in total sessions; medium: 480 minutes to 960 minutes in total sessions; high: greater than 960 minutes in total sessions. CBT: cognitive behavioral therapy, CI: confidence interval, N/A: not applicable, SMD: standardized mean difference