# Appendix F Risk of Bias

Table F.1 Risk of bias for randomized controlled trials (Cochrane Risk of Bias tool)^207^

Author, Year | Random Sequence Generation | Allocation Concealment | Blinding of Participants and Personnel | Blinding of Outcome Assessment | Incomplete Outcome Data | Selective Reporting | Overall Risk of Bias
Abbasi, 2016 ^27^ | Low | Unclear | High | High | Unclear | Unclear | High
Abikoff, 2005 ^1^ | Unclear | Unclear | Unclear | Unclear | High | Unclear | Unclear
Adler Nevo, 2014^28^ | Low | Low | Unclear | Low | Low | Unclear | Moderate
Afshari, 2014 ^29^ | Low | Unclear | High | High | High | Low | High
Alfano, 2007 ^2^ | Unclear | Unclear | Low | Low | Unclear | Low | Unclear
Amoros-Boix, 2011^161^ | Unclear | Unclear | Unclear | Unclear | Low | Low | Unclear
Arendt, 2015 ^30^ | Low | Low | High | Low | Low | Low | High
Azadeh, 2015^144^ | Unclear | Unclear | High | High | Unclear | High | High
Baer, 2005 ^31^ | Low | High | High | High | Low | Low | High
Barrett, 1996 ^32^ | Low | Unclear | High | Low | Low | Low | High
Barrett, 1998 ^33^ | Low | Unclear | High | High | Low | Low | High
Beidel, 2000 ^92^ | Unclear | Unclear | Unclear | Unclear | High | Low | Unclear
Beidel, 2007 ^3^ | Low | Unclear | High | High | High | Low | High
Bernstein, 2000 ^118^ | High | Unclear | Low | Low | Low | Low | High
Birmaher, 2003 ^5^ | Unclear | Unclear | Unclear | Unclear | High | Unclear | Unclear
Black, 1994 ^4^ | Unclear | Unclear | Low | Unclear | Low | Low | Unclear
Bodden, 2008 ^162, 163^ | Unclear | Low | Low | Unclear | Low | Low | Unclear
Britton, 2013 ^140^ | Unclear | Unclear | High | Low | High | Low | High
Cartwright-Hatton, 2011 ^122^ | Low | Unclear | High | High | Low | Unclear | High
Chalfant, 2007 ^34^ | Low | Unclear | Unclear | Unclear | Low | Low | Unclear
Chavira, 2014 ^156^ | Low | Unclear | High | High | High | Low | High
Chiu, 2013 ^35^ | Low | Unclear | High | Low | Low | Low | High
Cobham, 1998 ^165^ | Unclear | High | High | High | Unclear | Low | High
Cobham, 2012 ^36^ | Low | Unclear | High | Unclear | Low | Low | High
Cornwall, 1996 ^146^ | Unclear | Unclear | High | High | Unclear | Unclear | High
Creswell, 2015^166^ | Low | Low | High | High | High | Low | High
da Costa, 2013^6^ | Low | Unclear | Low | Unclear | Low | High | Unclear
De Groot, 2007^167^ | Low | Unclear | Low | Unclear | Low | Low | Unclear
Dewis, 2001^37^ | Low | Unclear | Unclear | Unclear | Low | Low | Unclear
Donovan, 2014^129^ | Low | High | High | High | Low | Low | High
Donovan, 2015^38^ | High | Unclear | High | High | High | Low | High
Ebrahiminejad, 2016^143^ | Unclear | Unclear | High | High | Low | Unclear | High
Eldar, 2012^138^ | Low | Unclear | Low | Unclear | Low | Low | Unclear
Elkins, 2016^147^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear
Esbjorn, 2014^168^ | Unclear | Unclear | High | High | Unclear | Low | High
Flannery-Schroeder, 2000^39, 40^ | Low | Unclear | High | High | Low | Low | High
Fujii, 2013^93^ | Low | Unclear | Unclear | Unclear | Unclear | Low | Unclear
Gallagher, 2004^41^ | Low | Unclear | High | High | Unclear | Low | High
Gallo, 2012^42^ | Low | Unclear | High | High | Unclear | Low | High
Garcia-Lopez, 2014^169^ | Unclear | Unclear | Unclear | Unclear | Low | Low | Unclear
Geller, 2007^7^ | Low | Low | Low | Low | High | Unclear | Unclear
Gil-Bernal, 2009^43^ | Unclear | Unclear | Unclear | Unclear | Low | Low | Unclear
Ginsburg, 2002^94^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear
Ginsburg, 2012^95^ | Low | High | High | Low | Low | Low | High
Gittelman-Klein, 1973^8^ | Unclear | Unclear | Low | Low | Low | Low | Unclear
Goldbeck, 2012^148^ | High | Unclear | High | High | Low | Low | High
Gottken, 2014^145^ | High | High | High | High | High | Low | High
Graae, 1994^9^ | Unclear | Unclear | Low | Low | Low | Low | Unclear
Halldorsdottir, 2016^96^ | Unclear | Unclear | High | High | High | Low | High
Hancock, 2016 ^44^ | Low | Unclear | High | High | High | Low | High
Hayward, 2000^45^ | Low | Unclear | High | Low | Low | Low | High
Herbert, 2009^97^ | Low | Unclear | High | High | High | Low | High
Hiller, 2016^128^ | Low | Unclear | Low | High | High | Low | High
Hirshfeld-Becker, 2010^47^ | Low | Unclear | High | High | Low | High | High
Holmes, 2014^46^ | Low | Unclear | Unclear | Unclear | Low | Low | Unclear
Hudson, 2009^98^ | Low | Unclear | High | High | Low | Low | High
Hudson, 2014^170^ | Low | Unclear | Unclear | Unclear | Low | Unclear | Unclear
Infantino, 2016^130^ | Low | Unclear | High | High | Low | Low | High
Ingul, 2014^99^ | Low | Unclear | Unclear | Unclear | Unclear | Low | Unclear
Joormann, 2002^149^ | Unclear | Unclear | High | High | Low | Low | High
Karbasi, 2010^157^ | Low | Unclear | High | High | Low | Low | High
Kendall, 1995^48^ | Low | Unclear | High | High | Unclear | Low | High
Kendall, 1997 ^49^ | Unclear | Unclear | High | High | High | Low | High
Kendall, 2008^100, 101^ | Unclear | Unclear | High | High | High | Low | High
Khanna, 2010^102^ | Low | High | High | High | Low | Low | High
Klein, 1992^120^ | Unclear | Unclear | Low | Unclear | Low | Unclear | Unclear
Klein, 2015^150^ | Unclear | Unclear | Low | Low | Unclear | Unclear | Unclear
Last, 1998^103^ | Unclear | Unclear | High | High | High | Low | High
Lee, 2016^151^ | Unclear | Unclear | Unclear | Unclear | Low | Low | Unclear
Leong,2009^158^ | Low | Unclear | High | High | Low | Low | High
Leutgeb, 2011^50^ | Unclear | Unclear | High | High | Low | Low | High
Liber, 2008^172, 173^ | Unclear | Unclear | High | High | Low | Low | High
Lyneham, 2006^131^ | Unclear | Unclear | Unclear | Unclear | Low | Low | Unclear
Manassis, 2002^174^ | Unclear | Unclear | High | High | Low | Low | High
March, 2007^10^ | Low | Low | Low | Unclear | High | Low | Unclear
March, 2009^132^ | Low | Unclear | High | High | Low | Low | High
Masia-Warner, 2005^51^ | Low | Unclear | High | High | Low | Low | High
Masia-Warner, 2007 ^104^ | Low | Unclear | High | Low | High | Low | High
McConachie, 2014^52^ | Low | Low | High | Low | Low | Low | High
McNally Keehn, 2013^53^ | Low | Unclear | High | High | Low | Low | High
Melfsen, 2011^54^ | Low | Unclear | High | High | High | Low | High
Melvin, 2016^121^ | Unclear | Unclear | High | High | Unclear | Unclear | High
Mendez, 2003^55^ | Unclear | Unclear | High | Unclear | Unclear | Unclear | High
Mendlowitz, 1999 ^56^ | Unclear | Unclear | High | High | Low | Low | High
Menzies, 1993^57^ | Low | Unclear | High | High | Low | Unclear | High
Miller, 1972^58, 59^ | Low | Low | High | High | Low | Low | High
Monga, 2015^159^ | Low | Low | High | Low | Low | Low | High
Muris, 1998 ^153^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear
Muris, 2001 ^175^ | Unclear | Unclear | Unclear | Unclear | High | High | Unclear
Muris, 2002 ^154^ | Low | Unclear | High | High | Low | Low | High
Muris, 2002 ^105^ | Unclear | Unclear | High | High | Low | Low | High
Nauta, 2001^176^ | Unclear | High | High | High | Low | Low | High
Nauta, 2003 ^177^ | Unclear | Unclear | Unclear | Unclear | Low | Low | Unclear
O’Brien, 2007^106^ | Unclear | Unclear | Low | Unclear | High | Low | Unclear
Obler, 1970^60^ | Unclear | Unclear | High | High | Low | Low | High
Olivares, 2014^62^ | High | Unclear | Unclear | Unclear | Unclear | Unclear | High
Olivares-Olivares, 2008^179^ | Low | Unclear | High | Unclear | Low | Low | High
Olivares-Rodriguez, 2006^178^ | Unclear | Unclear | Unclear | Unclear | Low | Low | Unclear
Ollendick, 2009^63^ | Low | Low | High | High | Low | Low | High
Ollendick Thomas, 2015^180^ | Unclear | Unclear | High | High | High | Unclear | High
Ortbandt, 2009^64, 65^ | Unclear | Unclear | High | High | Low | Low | High
Ost, 2001^66^ | Low | Unclear | High | High | High | Unclear | High
Ost, 2015^67^ | Low | Low | High | Low | Low | Low | High
Ozyurt, 2015^123^ | Low | Low | High | Low | High | Low | High
Parr, 2009^155^ | High | Unclear | High | High | Low | Low | High
Pergamin-Hight, 2016^141^ | Low | Low | Low | Unclear | Low | Unclear | Low
Pincus, 2010^107^ | High | Unclear | Unclear | Unclear | Low | Unclear | High
Pine, 2001 ^11, 12^ | Unclear | Unclear | Low | Low | High | Low | Unclear
Rapee, 2006^69^ | Low | Unclear | High | High | High | Low | High
Reaven, 2009^70^ | High | High | High | High | Low | Low | High
Reigada, 2015^108^ | Low | High | High | High | Low | Low | High
Reinblatt, 2009^13^ | Low | Unclear | Low | Low | Low | Unclear | Unclear
Ritter, 1968^71^ | Low | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear
Rodriguez, 2005^73^ | Unclear | Unclear | Unclear | Unclear | Low | Low | Unclear
Rosa-Alcazar, 2007^109^ | Unclear | Unclear | Unclear | Unclear | Low | Low | Unclear
Rosa-Alcazar, 2009^72^ | High | Low | Unclear | Unclear | Unclear | High | High
Rosa-Alcazar Ana, 2013^181^ | Unclear | Unclear | Unclear | Unclear | Unclear | Low | Unclear
Rynn, 2001^14^ | Unclear | Unclear | Low | Low | Low | Low | Unclear
Rynn, 2007^15^ | Unclear | Unclear | Low | Low | High | Low | Unclear
Sanchez-Garcia, 2009 ^74^ | Unclear | Unclear | Unclear | Unclear | High | Low | Unclear
Sánchez-García, 2009 ^75^ | Unclear | Unclear | Unclear | Unclear | Low | Low | Unclear
Santacruz, 2006^124^ | Unclear | Unclear | Unclear | Unclear | Low | Low | Unclear
Santucci, 2013^76^ | Low | Unclear | High | High | Low | Low | High
Scharfstein, 2011^16^ | Unclear | Low | Low | Low | Low | Low | Unclear
Schneider, 2011^77^ | Low | Low | High | High | Low | Unclear | High
Schneider, 2013^182^ | Low | Unclear | Unclear | Unclear | Low | Low | Unclear
Shortt, 2001^78^ | Unclear | Unclear | Low | Low | High | Low | Unclear
Silk, 2016 ^111^ | Low | Unclear | Unclear | Unclear | High | High | High
Silverman, 1999 ^79^ | Unclear | Unclear | High | Low | High | Low | Unclear
Silverman, 2009^184^ | Low | Unclear | Unclear | Unclear | High | Low | Unclear
Siqueland, 2005^183^ | High | High | Unclear | Unclear | Low | Low | High
Smith, 2014^125^ | Low | Unclear | High | Unclear | Low | Low | High
Southam-Gerow, 2010^110^ | Unclear | Unclear | Low | Unclear | High | Low | Unclear
Spence, 2000^80^ | Low | Unclear | High | High | Low | Low | High
Spence, 2006^81^ | Low | Unclear | High | High | Low | Low | High
Spence, 2011^82^ | Unclear | Unclear | High | High | High | Low | High
Spence, 2017^133^ | Low | Unclear | High | High | Unclear | Unclear | High
St-Jacques, 2010^185^ | Low | Unclear | Unclear | Unclear | Unclear | Low | Unclear
Storch, 2013^113^ | Low | Low | High | Low | Low | Low | High
Storch, 2015^112^ | Low | Unclear | Unclear | Unclear | Low | Low | Unclear
Strawn, 2015^17^ | Unclear | Unclear | Low | Low | High | Low | Unclear
Suveg, 2009^114^ | Unclear | High | High | High | Unclear | Low | High
Thirlwall, 2013^126, 127^ | Low | Low | Unclear | Unclear | High | Low | Unclear
Tillfors, 2011^134^ | Unclear | Unclear | High | High | Low | Low | High
Treadwell, 1996^83^ | Unclear | Unclear | Unclear | Unclear | Low | Low | Unclear
Valles-Arandiga, 2014 ^84^ | High | Unclear | Unclear | Unclear | Low | Unclear | High
Van Steensel, 2014^115^ | Low | Unclear | High | High | Low | Low | High
Vigerland, 2016^135, 136^ | Unclear | Unclear | High | High | Low | Low | High
Wagner, 2004^18^ | Low | Low | Low | Unclear | Low | Low | Unclear
Walczak, 2016^188^ | Unclear | Unclear | High | High | Low | Unclear | High
Walkup, 2002^19^ | Low | Unclear | High | High | High | Low | High
Walkup, 2008^20–26^ | Low | Low | High | Low | Low | Low | Moderate
Warner, 2011^87^ | Low | Unclear | High | High | Low | Low | High
Warner, 2016^116^ | Low | Unclear | Low | Low | Low | Low | Low
Waters, 2009^86^ | Low | Unclear | High | High | High | Low | High
Waters, 2013^160^ | Low | Unclear | Low | Low | High | Low | Unclear
Waters, 2014^142^ | Low | Unclear | High | Low | Low | Low | High
Waters, 2015^139^ | Unclear | Unclear | High | High | Low | Low | High
Wergeland, 2014^88, 89^ | Low | Unclear | High | Unclear | Low | Low | High
White, 2013^90^ | Low | Unclear | High | Unclear | Unclear | Low | High
Whiteside, 2015^186^ | Low | Unclear | Unclear | Unclear | High | Low | Unclear
Wood, 2006^187^ | Low | Low | High | High | Low | Low | High
Wood, 2009 ^91^ | Low | Low | Low | Unclear | Low | Unclear | Unclear
Wuthrich, 2012^137^ | Low | Unclear | High | High | Low | Low | High
Yoosefi Looyeh, 2014^152^ | Low | Unclear | High | High | Low | Low | High

Low: low risk of bias; Moderate: moderate risk of bias; High: high risk of bias; Unclear: unclear risk of bias

Table F.2 Risk of bias for non-randomized comparative studies (Newcastle-Ottawa Quality Assessment Scale)^208^

Author, Year | Representativeness of the Population | Selection of the Cohort | Ascertainment of Exposure | Ascertainment of Outcome | Adequacy of Follow Up | Possible Conflicts of Interest | Overall Risk of Bias
Chase, 2012^164^ | Moderate | High | Low | High | Low | Unclear | High
Eichstedt, 2011^119^ | Low | Low | Low | High | High | Low | High
Ishikawa, 2012^171^ | Moderate | Unclear | Low | High | Low | Low | High
Olivares, 2002^61^ | Moderate | Low | Low | High | Low | Unclear | High
Rapee, 2000^68^ | Moderate | Low | Low | High | Low | Low | High
van Steensel, 2015^85^ | High | High | Low | Low | Moderate | Unclear | Moderate
Yen, 2014^117^ | Moderate | Low | Low | Low | Unclear | Unclear | Moderate

Low: low risk of bias; Moderate: moderate risk of bias; High: high risk of bias; Unclear: unclear risk of bias