# Appendix E Description of Included Studies

Table E.1 Characteristics of the included studies comparing drugs versus pill placebo

Table E.2 Characteristics of the included studies comparing drugs versus drugs

Table E.3 Characteristics of the included studies comparing CBT versus drugs

Table E.4 Characteristics of the included studies comparing CBT versus waitlisting or no treatment

Table E.5 Characteristics of the included studies comparing CBT versus pill placebo

Table E.6 Characteristics of the included studies comparing CBT versus attention control or treatment as usual

Table E.7 Characteristics of studies evaluating combination of CBT with drugs versus CBT

Table E.8 Characteristics of studies comparing parent only intervention versus waitlisting

Table E.9 Characteristics of studies comparing different components of parent only interventions

Table E.10 Characteristics of studies comparing distance therapy versus waitlisting

Table E.11 Characteristics of studies comparing different components of distance therapy

Table E.12 Characteristics of studies comparing attention bias modification versus wait listing or pill placebo

Table E.13 Characteristics of studies comparing combined attention bias modification intervention and other therapy versus other therapy

Table E.14 Characteristics of studies comparing mindfulness based CBT to waitlisting

Table E.15 Characteristics of studies comparing acceptance and commitment therapy versus waitlist or no treatment

Table E.16 Characteristics of studies comparing non-CBT psychoanalysis versus wait listing

Table E.17 Characteristics of studies comparing other therapy versus waitlisting or attention control or treatment as usual

Table E.18 Characteristics of studies comparing different non-CBT psychotherapies

Table E.19 Characteristics of studies comparing CBT versus other psychotherapy

Table E.20 Characteristics of studies comparing different CBTs

Table E.21 Characteristics of single-cohort observational studies with adverse events