# Appendix D Excluded Studies

1 Al-Namankany A, Petrie A, Ashley P. Video modelling and reducing anxiety related to dental injections - a randomised clinical trial. Br Dent J. 2014 Jun;216(12):675–9. doi: 10.1038/sj.bdj.2014.497 PMID: 24970519. The study does not have children with anxiety (3–18 yrs).24970519
2 Alfano CA, Pina AA, Villalta IK, . Mediators and moderators of outcome in the behavioral treatment of childhood social phobia. J Am Acad Child Adolesc Psychiatry. 2009 Sep;48(9):945–53. doi: 10.1097/CHI.0b013e3181af8216 PMID: 19625981. The study is not a comparative study (case reports only included for side effects/ harms).19625981
3 Anbar RD, Hummell KE. Teamwork approach to clinical hypnosis at a pediatric pulmonary center. American Journal of Clinical Hypnosis. 2005;48(1):45–9 doi:10.1080/00029157.2005.10401489 PMID: 2005408928. The study does not have children with anxiety (3–18 yrs).16238171
4 Anderson RE, Spence SH, Donovan CL, . Working alliance in online cognitive behavior therapy for anxiety disorders in youth: comparison with clinic delivery and its role in predicting outcome. J Med Internet Res. 2012 Jun 28;14(3):e88. doi:10.1080/00029157.2005.10401489 PMID: 2012-32354-008. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).22789657
5 Andrzejewska E, Bogucka A, Losiowski Z. [Effectiveness of psychotherapy in the treatment of adolescents]. Psychiatr Pol. 1979 Jul–Aug;13(4):373–6 PMID: 515252. Other reason for exclusion.515252
6 Araya R, Fritsch R, Spears M, . School intervention to improve mental health of students in Santiago, Chile: a randomized clinical trial. JAMA Pediatr. 2013 Nov;167(11):1004–10. doi: 10.1001/jamapediatrics.2013.2361 PMID: 2013761184. The study does not have children with anxiety (3–18 yrs).23999656
7 Attwood M, Meadows S, Stallard P, . Universal and targeted computerised cognitive behavioural therapy (Think, Feel, Do) for emotional health in schools: Results from two exploratory studies. Child and Adolescent Mental Health. 2012;17(3):173–8 doi:10.1111/j.1475-3588.2011.00627.x. PMID: WOS:000306402400008. The study does not have children with anxiety (3–18 yrs).
8 Aydin A, Tekinsav-Sütçü S, Sorias O. Evaluation of the effectiveness of a cognitive-behavioral therapy program for alleviating the symptoms of social anxiety in adolescents. Turk Psikiyatri Dergisi. 2010;21(1):1. PMID: 20204902. Turkish study.20204899
9 Bar-Haim Y, Morag I, Glickman S. Training anxious children to disengage attention from threat: a randomized controlled trial. J Child Psychol Psychiatry. 2011 Aug;52(8):861–9. doi: 10.1111/j.1469-7610.2011.02368.x PMID: 21250993. The study does not have children with anxiety (3–18 yrs).21250993
10 Barnes VA, Johnson MH, Williams RB, . Impact of Williams Lifeskills(R) Training on Anger, Anxiety and Ambulatory Blood Pressure in Adolescents. Transl Behav Med. 2012 Dec 01;2(4):401–10. doi: 10.1007/s13142-012-0162-3 PMID: 23482659. The study does not have children with anxiety (3–18 yrs).23482659
11 Barrett PM, Duffy AL, Dadds MR, . Cognitive-behavioral treatment of anxiety disorders in children: long-term (6-year) follow-up. J Consult Clin Psychol. 2001 Feb;69(1):135–41. PMID: 11302272. Other reason.11302272
12 Barrett, P M, Lock, . Developmental differences in universal preventive intervention for child anxiety. Clinical Child Psychology and Psychiatry. 2005 October;10(4):539–55. doi:10.1177/1359104505056317. The study does not have children with anxiety (3–18 yrs).
13 Barrett, P M, Sonderegger, . Using FRIENDS to combat anxiety and adjustment problems among young migrants to Australia: A national trial. Clinical Child Psychology and Psychiatry. 2003 April;8(2):241–60. doi:10.1177/1359104503008002008. The study does not have children with anxiety (3–18 yrs).
14 Barrington, J, Prior, . Effectiveness of CBT versus standard treatment for childhood anxiety disorders in a community clinic setting. Behaviour Change. 2005;22(1):29–43. doi:10.1375/bech.22.1.29.66786. Other reason.
15 Baumgartner JL, Emslie GJ, Crismon ML. Citalopram in children and adolescents with depression or anxiety. Ann Pharmacother. 2002 Nov;36(11):1692–7. doi:10.1345/aph.1C078 PMID: 12398561. The study does not have children with anxiety (3–18 yrs).12398561
16 Becker, Emily M, Becker, . Modular cognitive behavioral therapy for youth with anxiety disorders: A closer look at the use of specific modules and their relation to treatment process and response. School Mental Health. 2012 Dec;4(4):243–53. doi:10.1007/s12310-012-9080-2. The study is not a comparative study (case reports only included for side effects/ harms).
17 Beidel DC, Turner SM, Young BJ. Social effectiveness therapy for children: five years later. Behav Ther. 2006 Dec;37(4):416–25. doi: 10.1016/j.beth.2006.06.002 PMID: 17071218. Other reason.17071218
18 Beidel DC, Turner SM, Young B, . Social effectiveness therapy for children: three-year follow-up. J Consult Clin Psychol. 2005 Aug;73(4):721–5. doi:10.1037/0022-006X.73.4.721 PMID: 16173859. The study is not a comparative study (case reports only included for side effects/ harms).16173859
19 Benjamin CL, Harrison JP, Settipani CA, . Anxiety and related outcomes in young adults 7 to 19 years after receiving treatment for child anxiety. J Consult Clin Psychol. 2013 Oct;81(5):865–76. doi: 10.1037/a0033048 PMID: 23688146. The study is not a comparative study (case reports only included for side effects/ harms).23688146
20 Benjamin CL, O’Neil KA, Crawley SA, . Patterns and predictors of subjective units of distress in anxious youth. Behav Cogn Psychother. 2010 Jul;38(4):497–504. doi:10.1017/S1352465810000287 PMID: 20509987. The study is not a comparative study (case reports only included for side effects/ harms).20509987
21 Berg I, Fielding D. An evaluation of hospital in-patient treatment in adolescent school phobia. Br J Psychiatry. 1978 May;132:500–5. doi: 10.1192/bjp.132.5.500 PMID:656715. The study does not include any of the interventions listed above (pharmacotherapy or psychotherapy)656715
22 Berman, S L, Weems, . Predictors of outcome in exposure-based cognitive and behavioral treatments for phobic and anxiety disorders in children. Behavior Therapy. 2000;31(4):713–31. doi:10.1016/S0005-7894(00)80040-4. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).
23 Berney T, Kolvin I, Bhate SR, . School phobia: a therapeutic trial with clomipramine and short-term outcome. Br J Psychiatry. 1981 Feb;138:110–8. doi:10.1192/bjp.138.2.110 PMID: 7020816. The study does not have children with anxiety (3–18 yrs).7020816
24 Bernstein GA, Anderson LK, Hektner JM, . Imipramine compliance in adolescents. J Am Acad Child Adolesc Psychiatry. 2000 Mar;39(3):284–91. doi:10.1097/00004583-200003000-00009 PMID: 10714047. The study is not a comparative study (case reports only included for side effects/ harms).10714047
25 Bernstein GA, Hektner JM, Borchardt CM, . Treatment of school refusal: one-year follow-up. J Am Acad Child Adolesc Psychiatry. 2001 Feb;40(2):206–13. doi:10.1097/00004583-200102000-00015 PMID: 11211369. The study does not have children with anxiety (3–18 yrs).11211369
26 Bernstein GA, Bernat DH, Victor AM, . School-based interventions for anxious children: 3-, 6-, and 12-month follow-ups. J Am Acad Child Adolesc Psychiatry. 2008 Sep;47(9):1039–47. doi:10.1097/CHI.ob013e31817eecco PMID: 18665000. The study does not have children with anxiety (3–18 yrs).18665000
27 Bernstein GA, Layne AE, Egan EA, . School-based interventions for anxious children. J Am Acad Child Adolesc Psychiatry. 2005 Nov;44(11):1118–27. doi:10.1097/01.chi.0000177323.40005.a1 PMID: 16239860. The study does not have children with anxiety (3–18 yrs).16239860
28 Berry K, Hunt CJ. Evaluation of an Intervention Program for Anxious Adolescent Boys Who Are Bullied at School. Journal of Adolescent Health. 2009 Oct;45(4):376–82. doi:10.1016/j.jadohealth.2009.04.023 PMID: 19766942. The study does not have children with anxiety (3–18 yrs).19766942
29 Bilek EL, Ehrenreich-May J. An open trial investigation of a transdiagnostic group treatment for children with anxiety and depressive symptoms. Behav Ther. 2012 Dec;43(4):887–97. doi:10.1016/j.beth.2012.04.007 PMID: 23046789. The study is not a comparative study (case reports only included for side effects/ harms).23046789
30 Bjaastad JF, Haugland BS, Fjermestad KW, . Competence and Adherence Scale for Cognitive Behavioral Therapy (CAS-CBT) for anxiety disorders in youth: Psychometric properties. Psychol Assess. 2016 Aug;28(8):908–16. doi:10.1037/pas0000230 PMID:26460894. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).26460894
31 Blagg NR, Yule W. The behavioural treatment of school refusal--a comparative study. Behav Res Ther. 1984;22(2):119–27. doi:10.1016/0005-7967(84)90100-1 PMID:6712554. The study does not have children with anxiety (3–18 yrs).6712554
32 Blatter M, Judith, Schneider, . Cognitive behavioral therapy for children suffering from separation anxiety. Journal de Therapie Comportementale et Cognitive. 2011 Sep;21(3):84–9. doi:10.1016/j.jtcc.2011.07.011. The study is not original (commentaries, letters, etc.)
33 Bodden DH, Bögels SM, Nauta MH, . Child versus family cognitive-behavioral therapy in clinically anxious youth: an efficacy and partial effectiveness study. Journal of the American Academy of Child & Adolescent Psychiatry. 2008;47(12):1384–94. doi:10.1097/CHI.0b013e318189148e PMID: 18981932. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).18981932
34 Bogels SM, Siqueland L. Family cognitive behavioral therapy for children and adolescents with clinical anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2006 Feb;45(2):134–41. doi:10.1097/01.chi.0000190467.01072.ee PMID: 16429083. The study is not a comparative study (case reports only included for side effects/ harms).16429083
35 Byrne SP, Rapee RM, Richardson R, . D-cycloserine enhances generalization of fear extinction in children. Depress Anxiety. 2015 Jun;32(6):408–14. doi:10.1002/da.22356 PMID: 25775435. The study does not include any of the interventions listed above (pharmacotherapy or psychotherapy)25775435
36 Calear AL, Batterham PJ, Poyser CT, . Cluster randomised controlled trial of the e-couch Anxiety and Worry program in schools. J Affect Disord. 2016 May 15;196:210–7. doi:10.1016/j.jad.2016.02.049 PMID: 26926660. The study does not have children with anxiety (3–18 yrs).26926660
37 Caporino, N E, Herres, . Dysregulation in Youth with Anxiety Disorders: Relationship to Acute and 7- to 19- Year Follow-Up Outcomes of Cognitive-Behavioral Therapy. Child Psychiatry and Human Development. 2015. doi:10.1007/s10578-015-0587-2 PMID: 26384978. Child Psychiatry and Human Development. 2015. The study is not a comparative study (case reports only included for side effects/ harms)26384978
38 Caporino NE, Brodman DM, Kendall PC, . Defining treatment response and remission in child anxiety: signal detection analysis using the pediatric anxiety rating scale. J Am Acad Child Adolesc Psychiatry. 2013 Jan;52(1):57–67. doi:10.1016/j.jaac.2012.10.006 PMID: 23265634. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).23265634
39 Cederblad, M, Bodén, . Barnpsykiatrisk slutenvård i två iän reduktion av platsantalet i östergötland, effekt på klientelsammansättdng och vårdkonsumtion. Nordic Journal of Psychiatry. 1988;42(5):361–7. The study does not have children with anxiety (3–18 yrs).
40 Chambers, J A, Power, . Parental styles and long-term outcome following treatment for anxiety disorders. Clinical Psychology and Psychotherapy. 2004 May/June;11(3):187–98. doi:10.1002/cpp.406. Clinical Psychology and Psychotherapy. 2004 May/June;11(3):187–98. PMID:2004453864. The study does not have children with anxiety (3–18 yrs).
41 Chutko LS, Surushkina S, Nikishena IS, . [Adaptol in the treatment of anxiety disorders in children with school maladaptation]. Zh Nevrol Psikhiatr Im S S Korsakova. 2010;110(2):45–9. doi:10.1007/s11055-011-9448-z PMID: 20436449 The study does not have children with anxiety (3–18 yrs).20436449
42 Clark DB, Birmaher B, Axelson D, . Fluoxetine for the treatment of childhood anxiety disorders: open-label, long-term extension to a controlled trial. J Am Acad Child Adolesc Psychiatry. 2005 Dec;44(12):1263–70. doi:10.1097/01.chi.0000183464.41777.c1 PMID: 16292118. Other reason.16292118
43 Comer JS, Puliafico AC, Aschenbrand SG, . A pilot feasibility evaluation of the CALM Program for anxiety disorders in early childhood. J Anxiety Disord. 2012 Jan;26(1):40–9.doi:10.1016/j.janxdis.2011.08.011 PMID: 21917417. The study is not a comparative study (case reports only included for side effects/ harms).21917417
44 Compton SN, Peris TS, Almirall D, . Predictors and moderators of treatment response in childhood anxiety disorders: results from the CAMS trial. J Consult Clin Psychol. 2014 Apr;82(2):212–24. doi:10.1037/a0035458 PMID: 24417601. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).24417601
45 Compton SN, Walkup JT, Albano AM, . Child/Adolescent Anxiety Multimodal Study (CAMS): rationale, design, and methods. Child Adolesc Psychiatry Ment Health. 2010 Jan 05;4:1.2010;4:1. doi: 10.1186/1753-2000-4-1 PMID: 20051130. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).20051130
46 Cooper, P J, Gallop, . Treatment response in child anxiety is differentially related to the form of maternal anxiety disorder. Behavioural and Cognitive Psychotherapy. 2008 January;36(1):41–8. doi:10.1017/S1352465807003943. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc)
47 Cotton, S, Luberto, . Mindfulness-based cognitive therapy for youth with anxiety disorders at risk for bipolar disorder: a pilot trial. doi:10.1111/eip.12216 PMID:25582800 Early Intervention in Psychiatry. 2015. The study is not a comparative study (case reports only included for side effects/ harms)25582800
48 Crawford AM, Manassis K. Familial predictors of treatment outcome in childhood anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2001 Oct;40(10):1182–9. doi:10.1097/00004583-200110000-00012 PMID: 11589531. The study is not a comparative study (case reports only included for side effects/ harms).11589531
49 Crawley, S A, Beidas, . Treating socially phobic youth with CBT: Differential outcomes and treatment considerations. Behavioural and Cognitive Psychotherapy. 2008 July;36(4):379–89. doi:10.1017/S1352465808004542. The study is not a comparative study (case reports only included for side effects/ harms).
50 Crawley SA, Kendall PC, Benjamin CL, . Brief Cognitive-Behavioral Therapy for Anxious Youth: Feasibility and Initial Outcomes. Cogn Behav Pract. 2013 May 01;20(2):123–33. doi:10.1016/j.cbpra.2012.07.003 PMID: 24244089. The study is not a comparative study (case reports only included for side effects/ harms).24244089
51 Creswell C, Willetts L, Murray L, . Treatment of child anxiety: an exploratory study of the role of maternal anxiety and behaviours in treatment outcome. Clin Psychol Psychother. 2008 doi:10.1002/cpp.559 PMID:19115426. The study is not a comparative study (case reports only included for side effects/ harms)19115426
52 Cummings CM, Caporino NE, Settipani CA, . The therapeutic relationship in cognitive-behavioral therapy and pharmacotherapy for anxious youth. J Consult Clin Psychol. 2013 Oct;81(5):859–64. doi:10.1037/a0033294 PMID: 23750468. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).23750468
53 Cummings CM, Fristad MA. Anxiety in children with mood disorders: a treatment help or hindrance? J Abnorm Child Psychol. 2012 Apr;40(3):339–51. doi:10.1007/s10802-011-9568-5 PMID: 21912843. The study does not have children with anxiety (3–18 yrs).21912843
54 Cunningham MJ, Wuthrich V. Examination of barriers to treatment and user preferences with computer-based therapy using the Cool Teens CD for adolescent anxiety. Sensoria: A Journal of Mind, Brain & Culture. 2008;4(2):12–7 doi:10.7790/ejap.v4i2.115. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).
55 Cunningham NR, Jagpal A, Tran ST, . Anxiety Adversely Impacts Response to Cognitive Behavioral Therapy in Children with Chronic Pain. J Pediatr. 2016 Apr;171:227–33. doi:10.1016/j.jpeds.2016.01.018 PMID: 26879812. The study does not have children with anxiety (3–18 yrs).26879812
56 Dadds MR, Holland DE, Laurens KR, . Early intervention and prevention of anxiety disorders in children: results at 2-year follow-up. J Consult Clin Psychol. 1999 Feb;67(1):145–50. PMID:10028219. The study does not have children with anxiety (3–18 yrs).10028219
57 Dadds MR, Spence SH, Holland DE, . Prevention and early intervention for anxiety disorders: a controlled trial. J Consult Clin Psychol. 1997 Aug;65(4):627–35. doi: 10.1037/0022-006X.65.4.627 PMID: 9256564. The study does not have children with anxiety (3–18 yrs).9256564
58 Dadsetan, Parirokh, Anari, . Social anxiety disorders and drama-therapy. Journal of Iranian Psychologists. 2008;4(14):115–23. Persian study.
59 Dahlstrom H, Fedor-Freybergh P, Kareland H, . Benzoctamine and medazepam in treatment of anxiety of children and adolescents: a comparative study. Acta Psychiatr Scand. 1973 Jul;49(6):735–43. doi:10.1111/j.1600-0447.1973.tb04462.x PMID: 4592708. The study does not have children with anxiety (3–18 yrs).4592708
60 De J, P J, Andrea, . Spider phobia in children: Disgust and fear before and after treatment. Behaviour Research and Therapy. 1997 June;35(6):559–62. doi:10.1016/S0005-7967(97)00002-8 PMID: 9159980. The study is not a comparative study (case reports only included for side effects/ harms).9159980
61 De Los R, Andres, Alfano, . Are the clinical characteristics of anxious youths participating in non-treatment-related research comparable to those of youths receiving treatment? Child & Youth Care Forum. 2016 Apr: No Pagination Specified. doi:10.1007/s10566-016-9355-0. The study does not include any of the interventions listed above (pharmacotherapy or psychotherapy)
62 Díaz, Cristina. Evaluación y tratamiento cognitivo-conductual de un caso de fobia social. Psicologia.com. 1997;1(1). The study is not a comparative study (case reports only included for side effects/ harms)
63 Diomsina B, Vyciniene D. [Anxiety disorders in children and adolescents. Psychotherapeutic interventions]. Medicina (Kaunas). 2002;38(4):466–70. PMID:12474798. The study does not have children with anxiety (3–18 yrs).12474798
64 Diukova G, Vorob’eva O, Petrova E, . The efficacy of alprazolam in the therapy of panic disorders. Zhurnal nevrologii i psikhiatrii imeni SS Korsakova. 1995;95(4):9–13. PMID:8533521. Other reason for exclusion8533521
65 Dour, H J, Chorpita, . Sudden gains as a long-term predictor of treatment improvement among children in community mental health organizations. Behaviour Research and Therapy. 2013 September;51(9):564–72. doi:10.1016/j.brat.2013.05.012 PMID:23856657. The study does not have children with anxiety (3–18 yrs).23856657
66 Drahota A, Wood JJ, Sze KM, . Effects of cognitive behavioral therapy on daily living skills in children with high-functioning autism and concurrent anxiety disorders. J Autism Dev Disord. 2011 Mar;41(3):257–65. doi:10.1007/s10803-010-1037-4 PMID: 20508979. The study does not have children with anxiety (3–18 yrs).20508979
67 Drtílková, I, Blažek, . Retrospective evaluation of the effect of sertraline in different indications in children and adolescents. Ceska a Slovenska Psychiatrie. 2001;97(4):157–61. The study does not have children with anxiety (3–18 yrs).
68 Duan YE. [Treatment of child extensive anxiety disorder with catgut implantation of point plus western medicine]. Zhongguo Zhen Jiu. 2007 May;27(5):341–3. PMID:17645255. The study does not have children with anxiety (3–18 yrs).17645255
69 Eckmann, F, Hoeppner, . Sulpiride treatment of children with behavior disturbances. Fortschritte der Medizin. 1975;93(9):464–5. The study does not have children with anxiety (3–18 yrs).
70 Eisen AR, Raleigh H, Neuhoff CC. The unique impact of parent training for separation anxiety disorder in children. Behav Ther. 2008 Jun;39(2):195–206. doi:10.1016/j.beth.2007.07.004 PMID: 18502252. The study is not a comparative study (case reports only included for side effects/ harms).18502252
71 Eisenberg L, Gilbert A, Cytryn L, . The effectiveness of psychotherapy alone and in confunction with perphenazine or placebo in the treatment of neurotic and hyperkinetic children. Am J Psychiatry. 1961 Jun;117:1088–93. doi:10.1176/ajp.117.12.1088 PMID: 13726172. The study does not have children with anxiety (3–18 yrs).13726172
72 Emslie, G J. Combination of cognitive behavioral therapy and sertraline is more effective than monotherapy for pediatric anxiety disorders. Journal of Pediatrics. 2009 May;154(5):775–6. doi:10.1016/j.jpeds.2009.02.045 PMID: 19364568. Conference procceeding without full text.19364568
73 Farrell, L J, Barrett, . Community trial of an evidence-based anxiety intervention for children and adolescents (the FRIENDS program): A pilot study. Behaviour Change. 2005;22(4):236–48. doi:10.1375/bech.22.4.236 The study does not have children with anxiety (3–18 yrs).
74 Fathi A, A, Salimi, . Test-anxiety in Iranian students: Cognitive therapy vs. systematic desensitisation. Archives of Medical Science. 2006 September;2(3):199–204. The study does not have children with anxiety (3–18 yrs).
75 Festen H, Hartman CA, Hogendoorn S, . Temperament and parenting predicting anxiety change in cognitive behavioral therapy: the role of mothers, fathers, and children. J Anxiety Disord. 2013 Apr;27(3):289–97. doi:10.1016/j.janxdis.2013.03.001 PMID: 23602942. The study is not a comparative study (case reports only included for side effects/ harms).23602942
76 Fitzgerald A, Rawdon C, Dooley B. A randomized controlled trial of attention bias modification training for socially anxious adolescents. Behav Res Ther. 2016 Sep;84:1–8. doi:10.1016/j.brat.2016.06.003 PMID: 27379745. Behaviour Research and Therapy. 2016;84:1–8. The study does not have children with anxiety (3–18 yrs).27379745
77 Fjermestad KW, Lerner MD, McLeod BD, . Therapist-youth agreement on alliance change predicts long-term outcome in CBT for anxiety disorders. J Child Psychol Psychiatry. 2016 May;57(5):625–32. doi:10.1111/jcpp.12485 PMID: 26647901. The study is not a comparative study (case reports only included for side effects/ harms).26647901
78 Forbes EE, Stepp SD, Dahl RE, . Real-world affect and social context as predictors of treatment response in child and adolescent depression and anxiety: an ecological momentary assessment study. J Child Adolesc Psychopharmacol. 2012 Feb;22(1):37–47. doi:10.1089/cap.2011.0085 PMID: 22339611. The study does not have children with anxiety (3–18 yrs).22339611
79 Fox E, Zougkou K, Ashwin C, . Investigating the efficacy of attention bias modification in reducing high spider fear: The role of individual differences in initial bias. Journal of behavior therapy and experimental psychiatry. 2015;49:84–93 doi:10.1016/j.jbtep.2015.05.001 PMID:26060177. The study does not have children with anxiety (3–18 yrs).26060177
80 Fu X, Du Y, Au S, . Reducing negative interpretations in adolescents with anxiety disorders: a preliminary study investigating the effects of a single session of cognitive bias modification training. Dev Cogn Neurosci. 2013 Apr;4:29–37. doi:10.1016/j.dcn.2012.11.003 PMID: 23219491. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).23219491
81 Galla BM, Wood JJ, Chiu AW, . One year follow-up to modular cognitive behavioral therapy for the treatment of pediatric anxiety disorders in an elementary school setting. Child Psychiatry Hum Dev. 2012 Apr;43(2):219–26. doi:10.1007/s10578-011-0258-x PMID: 21987227. The study is not a comparative study (case reports only included for side effects/ harms).21987227
82 Garcia L, L J, Olivares, . A pilot study on sensitivity of outcome measures for treatments of generalized social phobia in Spanish adolescents. International journal of clinical and health psychology. 2005;5(2):385–92. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).
83 Garcia L, L J, Olivares, . Results at long-term among three psychological treatments for adolescents with generalized social phobia (II): Clinical significance and effect size. Psicologia Conductual. 2002;10(2):371–85. Other reason.
84 García L, L J, Ruiz, . Transporting a school-based multicomponent treatment for adolescents to young adults with social anxiety: A pilot study. Psicologia Conductual. 2006;14(1):63–73. The study is not a comparative study (case reports only included for side effects/ harms).
85 Gil-Bernal F, Hernández-Guzmán L. Tratamiento cognitivo-conductual para niños mexicanos con fobia social. Anuario de Psicología. 2009;40(1). The study does not have children with anxiety (3–18 yrs).
86 Girling B, R D, Ronan, . Brief cognitive-behavioural therapy for children with anxiety disorders: Initial evaluation of a program designed for clinic settings. Behaviour Change. 2009 April;26(1):27–53. doi:10.1375/bech.26.1.27. The study is not a comparative study (case reports only included for side effects/ harms)
87 Gittelman K, R, Klein, . Controlled Imipramine Treatment of School Phobia. Archives of General Psychiatry. 1971;25(3):204–7. PMID:18730587. The study does not have children with anxiety (3–18 yrs).18730587
88 GlaxoSmithKline. A 16 Week Double-Blind, Placebo Controlled Study to Investigate the Efficacy and Tolerability of Paroxetine in the Treatment of Children and Adolescents with Social Anxiety Disorder/Social Phobia (29060/676). GSK Clinical Study Register [www.gskclinicalstudyregister.com]. 2001 Other reason.
89 Gonzalez A, Peris TS, Vreeland A, . Parental anxiety as a predictor of medication and CBT response for anxious youth. Child psychiatry and human development. 2015;46(1):84 doi:10.1007/s10578-014-0454-6 PMID:24610431. The study does not have children with anxiety (3–18 yrs).24610431
90 Graca, M. Clinical trial with RO 5-3350 (Lexotan) in child psychiatry. Folha Medica. 1976;72(4):399–402. The study does not have children with anxiety (3–18 yrs).
91 Gutierrez M, J, Magallon N, . Virtual reality exposure therapy for school phobia. Anuario de Psicologia. 2009;40(2):223–36. The study does not have children with anxiety (3–18 yrs).
92 Hagopian, L P, Slifer, . Treatment of separation anxiety disorder with graduated exposure and reinforcement targeting school attendance: A controlled case study. Journal of Anxiety Disorders. 1993;7(3):271–80. doi:10.1016/0887-6185(93)90007-8. The study is not a comparative study (case reports only included for side effects/ harms).
93 Hedman E, Andersson E, Ljótsson B, . Cost-effectiveness of Internet-based cognitive behavior therapy vs. cognitive behavioral group therapy for social anxiety disorder: results from a randomized controlled trial. Behaviour research and therapy. 2011;49(11):729–36. doi:10.1016/j.brat.2011.07.009 PMID: 21851929. The study does not have children with anxiety (3–18 yrs).21851929
94 Hepburn SL, Blakeley-Smith A, Wolff B, . Telehealth delivery of cognitive-behavioral intervention to youth with autism spectrum disorder and anxiety: A pilot study. Autism. 2016 Feb;20(2):207–18. doi:10.1177/1362361315575164 PMID: 25896267. The study does not have children with anxiety (3–18 yrs).25896267
95 Heyne D, King NJ, Tonge BJ, . Evaluation of child therapy and caregiver training in the treatment of school refusal. J Am Acad Child Adolesc Psychiatry. 2002 Jun;41(6):687–95. doi:10.1097/00004583-200206000-00008 PMID: 12049443. The study does not have children with anxiety (3–18 yrs).12049443
96 Hilton RC, Rengasamy M, Mansoor B, . Impact of treatments for depression on comorbid anxiety, attentional, and behavioral symptoms in adolescents with selective serotonin reuptake inhibitor-resistant depression. J Am Acad Child Adolesc Psychiatry. 2013 May;52(5):482–92. doi:10.1016/j.jaac.2013.02.013 PMID: 23622849. The study does not have children with anxiety (3–18 yrs).23622849
97 Hoek W, Schuurmans J, Koot HM, . Effects of Internet-based guided self-help problem-solving therapy for adolescents with depression and anxiety: a randomized controlled trial. PLoS One. 2012 Aug;7(8):e43485. doi:10.1371/journal.pone.0043485 PMID: 22952691. The study does not have children with anxiety (3–18 yrs).22952691
98 Hogendoorn SM, Prins PJ, Boer F, . Mediators of cognitive behavioral therapy for anxiety-disordered children and adolescents: Cognition, perceived control, and coping. Journal of Clinical Child & Adolescent Psychology. 2014;43(3):486–500 doi:10.1080/15374416.2013.807736 PMID:23795885. The study is not a comparative study (case reports only included for side effects/ harms).23795885
99 Howard, B L, Kendall, . Cognitive-behavioral family therapy for anxiety-disordered children: a multiple-baseline evaluation. Cognitive therapy and research. 1996;20(5):423–43. doi:10.1007/BF02227906. The study is not a comparative study (case reports only included for side effects/ harms).
100 Hrdlicka, M, Goetz, . Panic Disorder in Paedopsychiatry. [Czech]. Ceska a Slovenska Psychiatrie. 2004;100(1):4–8. The study does not include any of the interventions listed above (pharmacotherapy or psychotherapy)
101 Hrdlička, M, Goetz, . Panic Disorder in Paedopsychiatry. Ceska a Slovenska Psychiatrie. 2004;100(1):4–8. The study is not a comparative study (case reports only included for side effects/ harms).
102 Huang X, Li C, Li WH, . Clinical evaluation of the efficacy and safety of tandospirone versus sertraline monotherapy for social anxiety disorder: a randomized open-label trial. Hum Psychopharmacol. 2013 Nov;28(6):594–9. doi:10.1002/hup.2361 PMID: 24519693. The study does not have children with anxiety (3–18 yrs).24519693
103 Ishikawa Si, Okajima I, Matsuoka H, . Cognitive behavioural therapy for anxiety disorders in children and adolescents: A meta-analysis. Child and Adolescent Mental Health. 2007;12(4):164–72 doi:10.1111/j.1475-3588.2006.00433.x. A systematic review/meta-analysis/guideline.
104 Jansen M, van Doorn MM, Lichtwarck-Aschoff A, . Effectiveness of a cognitive-behavioral therapy (CBT) manualized program for clinically anxious children: study protocol of a randomized controlled trial. BMC Psychiatry. 2012 Mar 12;12:16. doi:10.1186/1471-244X-12-16 PMID: 22404798. Other reason.22404798
105 Johnco CJ, Salloum A, Lewin AB, . Refining Clinical Judgment of Treatment Response and Symptom Remission Identification in Childhood Anxiety Using a Signal Detection Analysis on the Pediatric Anxiety Rating Scale. J Child Adolesc Psychopharmacol. 2015 Nov;25(9):674–83. doi:10.1089/cap.2015.0102 PMID: 26579629. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).26579629
106 Johnstone KA, Page AC. Attention to phobic stimuli during exposure: The effect of distraction on anxiety reduction, self-efficacy and perceived control. Behaviour research and therapy. 2004;42(3):249–75 doi:10.1016/S0005-7967(03)00137-2 PMID:14975769. The study does not have children with anxiety (3–18 yrs).14975769
107 Jones JE, Blocher JB, Jackson DC, . Social anxiety and self-concept in children with epilepsy: a pilot intervention study. Seizure. 2014;23(9):780–5 doi:10.1016/j.seizure.2014.06.011 PMID:25053153. The study is not a comparative study (case reports only included for side effects/ harms).25053153
108 Jongerden, Loes, Bogels, . Parenting, family functioning and anxiety-disordered children: Comparisons to controls, changes after family versus child CBT. Journal of Child and Family Studies. 2015 Jul;24(7):2046–59. doi:10.1007/s10826-014-0005-6 The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).
109 Kammerer, Emil, Mattejat, . Inpatient treatment of severe school phobia: A follow-up study. Zeitschrift fur Kinder- und Jugendpsychiatrie und Psychotherapie. 1981;9(3):273–87. The study is not a comparative study (case reports only included for side effects/ harms).
110 Kearney, Christopher A, Silverman, . Functionally Based Prescriptive and Nonprescriptive Treatment for Children and Adolescents With School Refusal Behavior. Behavior Therapy. 1999 Aut;30(4):673–95. doi:10.1016/S0005-7894(99)80032-X. The study does not have children with anxiety (3–18 yrs).
111 Kelly D, Guirguis W, Frommer E, . Tratamiento de los estados fóbicos con antidepresivos. Un estudio retrospectivo de 246 pacientes. Psiquiatría Biológica. 2005;12(4):166–76. The study is not a comparative study (case reports only included for side effects/ harms).
112 Kelly D, Guirguis W, Frommer E, . Treatment of phobic states with antidepressants. A retrospective study of 246 patients. Br J Psychiatry. 1970 Apr;116(533):387–98. doi:10.1192/bjp.116.533.387 PMID: 4909796. The study does not have children with anxiety (3–18 yrs).4909796
113 Kendall PC, Brady EU, Verduin TL. Comorbidity in childhood anxiety disorders and treatment outcome. J Am Acad Child Adolesc Psychiatry. 2001 Jul;40(7):787–94. doi:10.1097/00004583-200107000-00013 PMID: 11437017. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).11437017
114 Kendall PC, Sugarman A. Attrition in the treatment of childhood anxiety disorders. J Consult Clin Psychol. 1997 Oct;65(5):883–8. PMID:9337507. The study does not have children with anxiety (3–18 yrs).9337507
115 Kendall, P C, Treadwell, . The Role of Self-Statements as a Mediator in Treatment for Youth With Anxiety Disorders. Journal of Consulting and Clinical Psychology. 2007 June;75(3):380–9. doi:10.1037/0022-006X.75.3.380 PMID: 17563155. Other reason.17563155
116 Kendall PC, Comer JS, Marker CD, . In-session exposure tasks and therapeutic alliance across the treatment of childhood anxiety disorders. J Consult Clin Psychol. 2009 Jun;77(3):517–25. doi:10.1037/a0013686 PMID: 19485592. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).19485592
117 Kendall PC, Cummings CM, Villabo MA, . Mediators of change in the Child/Adolescent Anxiety Multimodal Treatment Study. J Consult Clin Psychol. 2016 Jan;84(1):1–14. doi:10.1037/a0039773 PMID: 26460572. The study is not a comparative study (case reports only included for side effects/ harms).26460572
118 Kendall PC, Safford S, Flannery-Schroeder E, . Child anxiety treatment: outcomes in adolescence and impact on substance use and depression at 7.4-year follow-up. J Consult Clin Psychol. 2004 Apr;72(2):276–87. doi:10.1037/0022-006X.72.2.276 PMID: 15065961. The study is not a comparative study (case reports only included for side effects/ harms).15065961
119 Kerns CM, Read KL, Klugman J, . Cognitive behavioral therapy for youth with social anxiety: differential short and long-term treatment outcomes. J Anxiety Disord. 2013 Mar;27(2):210–5. doi:10.1016/j.janxdis.2013.01.009 PMID: 23474911. The study is not a comparative study (case reports only included for side effects/ harms).23474911
120 Klein AM, Rapee RM, Hudson JL, . Interpretation modification training reduces social anxiety in clinically anxious children. Behav Res Ther. 2015 Dec;75:78–84. doi:10.1016/j.brat.2015.10.006 PMID: 26580081. Other reason.26580081
121 Kley H, Heinrichs N, Bender C, . Predictors of outcome in a cognitive-behavioral group program for children and adolescents with social anxiety disorder. J Anxiety Disord. 2012 Jan;26(1):79–87. doi:10.1016/j.janxdis.2011.09.002 PMID: 21975266. The study is not a comparative study (case reports only included for side effects/ harms).21975266
122 Klingman A. Biblioguidance with kindergartners: Evaluation of a primary prevention program to reduce fear of the dark. Journal of Clinical Child Psychology. 1988;17(3):237–41. doi:10.1207/s15374424jccp1703_7 The study does not have children with anxiety (3–18 yrs).
123 Knox M, Lentini J, Cummings T, . Game-based biofeedback for paediatric anxiety and depression. Ment Health Fam Med. 2011 Sep;8(3):195–203. PMID:22942901. The study does not have children with anxiety (3–18 yrs).22942901
124 Kronenberg, S, Apter, . Serotonin transporter polymorphism (5-HTTLPR) and citalopram effectiveness and side effects in children with depression and/or anxiety disorders. Journal of Child and Adolescent Psychopharmacology. 2007 01 Dec;17(6):741–50. doi:10.1089/cap.2006.0144 PMID:18315446. The study does not have children with anxiety (3–18 yrs).18315446
125 Kronmuller KT, Postelnicu I, Hartmann M, . [Efficacy of psychodynamic short-term psychotherapy for children and adolescents with anxiety disorders]. Prax Kinderpsychol Kinderpsychiatr. 2005 Sep;54(7):559–77. PMID:16180526. The study does not have children with anxiety (3–18 yrs).16180526
126 Lau WY, Chan CK, Li JC, . Effectiveness of group cognitive-behavioral treatment for childhood anxiety in community clinics. Behav Res Ther. 2010 Nov;48(11):1067–77. doi:10.1016/j.brat.2010.07.007 PMID: 20696421. The study does not have children with anxiety (3–18 yrs).20696421
127 Layne AE, Bernstein GA, Egan EA, . Predictors of treatment response in anxious-depressed adolescents with school refusal. J Am Acad Child Adolesc Psychiatry. 2003 Mar;42(3):319–26. doi:10.1097/00004583-200303000-00012 PMID: 12595785. The study does not have children with anxiety (3–18 yrs).12595785
128 Lee SW, Kwon JH. The efficacy of imagery rescripting (IR) for social phobia: a randomized controlled trial. J Behav Ther Exp Psychiatry. 2013 Dec;44(4):351–60. doi:10.1016/j.jbtep.2013.03.001 PMID: 23563218. The study does not have children with anxiety (3–18 yrs).23563218
129 Lee SS, Victor AM, James MG, . School-based interventions for anxious children: long-term follow-up. Child psychiatry and human development. 2016;47(2):183. doi:10.1007/s10578-015-0555-x PMID:26003419 The study does not have children with anxiety (3–18 yrs)26003419
130 Leger E, Ladouceur R, Dugas MJ, . Cognitive-behavioral treatment of generalized anxiety disorder among adolescents: A case series. Journal of the American Academy of Child and Adolescent Psychiatry. 2003 Mar;42(3):327–30. doi:10.1097/00004583-200303000-00013 PMID: 12595786. The study is not a comparative study (case reports only included for side effects/ harms).12595786
131 Legerstee JS, Garnefski N, Jellesma FC, . Cognitive coping and childhood anxiety disorders. Eur Child Adolesc Psychiatry. 2010 Feb;19(2):143–50. doi:10.1007/s00787-009-0051-6 PMID: 19727903. The study is not a comparative study (case reports only included for side effects/ harms).19727903
132 Legerstee JS, Huizink AC, van Gastel W, . Maternal anxiety predicts favourable treatment outcomes in anxiety-disordered adolescents. Acta Psychiatr Scand. 2008 Apr;117(4):289–98. doi:10.1111/j.1600-0447.2008.01161.x PMID: 18321354. The study is not a comparative study (case reports only included for side effects/ harms).18321354
133 Legerstee JS, Tulen JH, Kallen VL, . Threat-related selective attention predicts treatment success in childhood anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2009 Feb;48(2):196–205. doi:10.1097/CHI.0b013e31819176e4 PMID: 19127173. The study is not a comparative study (case reports only included for side effects/ harms).19127173
134 Lessard, Lyse, Coutu, . Efficacy of a social skills program for children presenting with heterogeneous psychiatric diagnoses. Canadian Journal of Behavioural Science/Revue canadienne des sciences du comportement. 2011 Jan;43(1):30–9. doi:10.1037/a0020227. The study does not have children with anxiety (3–18 yrs).
135 Levy K, Hunt C, Heriot S. Treating comorbid anxiety and aggression in children. J Am Acad Child Adolesc Psychiatry. 2007 Sep;46(9):1111–8. doi:10.1097/chi.0b013e318074eb32PMID:17712234. The study is not a comparative study (case reports only included for side effects/ harms).17712234
136 Lewis PJ, James NM. Haloperidol and chlorpromazine: a double-blind cross-over trial and clinical study in children and adolescents. Aust N Z J Psychiatry. 1973 Mar;7(1):59–65. doi:10.3109/00048677309161478 PMID: 4579394. The study does not have children with anxiety (3–18 yrs).4579394
137 Liber, J M, van W, . Parenting and Parental Anxiety and Depression as Predictors of Treatment Outcome for Childhood Anxiety Disorders: Has the Role of Fathers Been Underestimated? Journal of clinical child and adolescent psychology. 2008;37(4):747–58. doi:10.1080/15374410802359692 PMID: 18991126. The study is not a comparative study (case reports only included for side effects/ harms).18991126
138 Liber JM, van Widenfelt BM, van der Leeden AJ, . The relation of severity and comorbidity to treatment outcome with Cognitive Behavioral Therapy for childhood anxiety disorders. J Abnorm Child Psychol. 2010 Jul;38(5):683–94. doi:10.1007/s10802-010-9394-1 PMID: 20180011. The study is not a comparative study (case reports only included for side effects/ harms).20180011
139 Liehr P, Diaz N. A pilot study examining the effect of mindfulness on depression and anxiety for minority children. Archives of Psychiatric Nursing. 2010;24(1):69–71. doi:10.1016/j.apnu.2009.10.001 PMID: 20117691. The study does not have children with anxiety (3–18 yrs).20117691
140 Livheim F, Hayes L, Ghaderi A, . The effectiveness of acceptance and commitment therapy for adolescent mental health: Swedish and Australian pilot outcomes. Journal of Child and Family Studies. 2015;24(4):1016. doi:10.1007/s10826-014-9912-9. The study does not have children with anxiety (3–18 yrs).
141 Love, Steven R, Matson, . Mothers as effective therapists for autistic children’s phobias. Journal of Applied Behavior Analysis. 1990 Fal;23(3):379–85. doi:10.1901/jaba.1990.23-379 PMID: 2249973. The study is not a comparative study (case reports only included for side effects/ harms)2249973
142 Lu DP, Lu GP, Lu WI. Anxiety control of dental patients by clinical combination of acupuncture, bi-digital O-ring test, and eye movement desensitization with sedation via submucosal route. Acupuncture & electro-therapeutics research. 2007;32(1–2):15–30. PMID:18077936. The study does not have children with anxiety (3–18 yrs).18077936
143 Lundkvist H, Irene, Thastum, . Anxious children and adolescents non-responding to cbt: Clinical predictors and families’ experiences of therapy. Clinical Psychology & Psychotherapy. 2015 Oct: No Pagination Specified. doi:10.1002/cpp.1982. The study is not a comparative study (case reports only included for side effects/ harms)
144 Manassis K, Avery D, Butalia S, . Cognitive-behavioral therapy with childhood anxiety disorders: functioning in adolescence. Depress Anxiety. 2004;19(4):209–16. doi:10.1002/da.10133 PMID: 15274169. The study is not a comparative study (case reports only included for side effects/ harms).15274169
145 Maskey M, Lowry J, Rodgers J, . Reducing specific phobia/fear in young people with autism spectrum disorders (ASDs) through a virtual reality environment intervention. PLoS One. 2014;9(7):e100374. doi:10.1371/journal.pone.0100374 PMID: 24987957. The study does not have children with anxiety (3–18 yrs).24987957
146 Masia W, Carrie, Colognori, . Can school counselors deliver cognitive-behavioral treatment for social anxiety effectively? A randomized controlled trial. Journal of Child Psychology and Psychiatry. 2016 Mar:No Pagination Specified. doi:10.1111/jcpp.12550 PMID:27002215. Other reason.27002215
147 McMENAMY C, Katz RC. Brief parent-assisted treatment for children’s nighttime fears. Journal of Developmental & Behavioral Pediatrics. 1989;10(3):145–8. doi:10.1017/bec.2014.19 PMID: 2663926. The study does not have children with anxiety (3–18 yrs).2663926
148 Mcshane G, Walter G, Rey JM. Functional outcome of adolescents with ‘school refusal’. Clinical Child Psychology and Psychiatry. 2004;9(1):53–60. doi:10.1177/1359104504039172. The study does not have children with anxiety (3–18 yrs).
149 Medvedev VE, Tereshchenko ON, Kost NV, . [Optimization of the treatment of anxiety disorders with selank]. Zh Nevrol Psikhiatr Im S S Korsakova. 2015;115(6):33–40. doi:10.17116/jnevro20151156133-40 PMID: 26356395. The study does not have children with anxiety (3–18 yrs).26356395
150 Menatti AR, Weeks JW, Carleton RN, . The Social Interaction Phobia Scale: Continued support for the psychometric validity of the SIPS using clinical and non-clinical samples. Journal of anxiety disorders. 2015;32:46–55. doi:10.1016/j.janxdis.2015.03.003 PMID: 25855057. The study does not have children with anxiety (3–18 yrs).25855057
151 Micco, J A, Choate S, . Identifying efficacious treatment components of panic control treatment for adolescents: A preliminary examination. Child and Family Behavior Therapy. 2007;29(4):1–23. doi:10.1300/J019v29n04_01. The study is not a comparative study (case reports only included for side effects/ harms).
152 Mifsud C, Rapee RM. Early intervention for childhood anxiety in a school setting: outcomes for an economically disadvantaged population. J Am Acad Child Adolesc Psychiatry. 2005 Oct;44(10):996–1004. doi:10.1097/01.chi.0000173294.13441.87 PMID: 16175104. Other reason.16175104
153 Milos ME, Reiss S. Effects of three play conditions on separation anxiety in young children. J Consult Clin Psychol. 1982 Jun;50(3):389–95. doi:10.1037//0022-006X.50.3.389 PMID: 7096740. The study does not have children with anxiety (3–18 yrs).7096740
154 Mitchell JH, Newall C, Broeren S, . The role of perfectionism in cognitive behaviour therapy outcomes for clinically anxious children. Behav Res Ther. 2013 Sep;51(9):547–54. doi:10.1016/j.brat.2013.05.015 PMID: 23850630. The study is not a comparative study (case reports only included for side effects/ harms).23850630
155 Moniot M, Mises R. [Comparative double blind study of doxepine and medazepam in adolescents]. Ann Med Psychol (Paris). 1971 Mar;1(3):431–4. PMID: 4934283. The study does not have children with anxiety (3–18 yrs).4934283
156 Morgan AJ, Rapee RM, Bayer JK. Prevention and early intervention of anxiety problems in young children: a pilot evaluation of Cool Little Kids Online. Internet Interventions. 2016;4:105–12. doi:10.1186/s13063-015-1022-5 PMID: 26541812. The study does not have children with anxiety (3–18 yrs).26541812
157 Muratori, F, Picchi, . Efficacy of brief dynamic psychotherapy for children with emotional disorders. Psychotherapy and Psychosomatics. 2001;71(1):28–38. doi:10.1159/000049341 PMID: 11740166. The study does not have children with anxiety (3–18 yrs).11740166
158 Muris P, Merckelbach H, Van Haaften H, . Eye movement desensitisation and reprocessing versus exposure in vivo. A single-session crossover study of spider-phobic children. Br J Psychiatry. 1997 Jul;171(JULY):82–6. doi:10.1002/jclp.10100 PMID: 9328502. The study is not a comparative study (case reports only included for side effects/ harms).9328502
159 Muris P, Mayer B, Bartelds E, . The revised version of the screen for child anxiety related emotional disorders (SCARED-R): Treatment sensitivity in an early intervention trial for childhood anxiety disorders. British Journal of Clinical Psychology. 2001;40(3):323–36. doi:10.1348/014466501163724 PMID: 11593959 Other reason.11593959
160 Murphy, Cynthia M, Bootzin, . Active and passive participation in the contact desensitization of snake fear in children. Behavior Therapy. 1973 Mar;4(2):203–11. doi:10.1016/S0005-7894(73)80029-2. The study does not have children with anxiety (3–18 yrs).
161 Nakamura, B J, Pestle, . Differential sequencing of cognitive-behavioral techniques for reducing child and adolescent anxiety. Journal of Cognitive Psychotherapy. 2009;23(2):114–35. doi:10.1891/0889-8391.23.2.114. The study is not a comparative study (case reports only included for side effects/ harms).
162 Nauta, M H, Scholing, . Cognitive-behavioural therapy for anxiety disordered children in a clinical setting: does additional cognitive parent training enhance treatment effectiveness? Clinical psychology & psychotherapy. 2001;8(5):330–40. doi:10.1097/01.chi.0000085752.71002.93 PMID:14566163 Other reason.14566163
163 Nishitsuji K, To H, Murakami Y, . Tandospirone in the treatment of generalised anxiety disorder and mixed anxiety-depression: results of a comparatively high dosage trial. Clinical drug investigation. 2004;24(2):121–7. doi:10.2165/00044011-200424020-00007 PMID: 17516698. The study does not have children with anxiety (3–18 yrs).17516698
164 Oar EL, Farrell LJ, Waters AM, . One session treatment for pediatric blood-injection-injury phobia: A controlled multiple baseline trial. Behav Res Ther. 2015 Oct;73:131–42. doi:10.1016/j.brat.2015.08.002 PMID: 26313620. The study is not a comparative study (case reports only included for side effects/ harms).26313620
165 Ohmann S, Schuch B, Sackl P, . Cognitive behavioral group therapy for adolescents with school refusal. An observational study. Verhaltenstherapie. 2007;17(3):175–81. doi: 10.1159/000104353 The study does not have children with anxiety (3–18 yrs).
166 Olivares O, P J, Rosa A, . Social validity of adolescent intervention in social phobia: Parents vs. teachers. Terapia Psicologica. 2007;25(1):63–71. doi:10.4067/S0718-48082007000100005 Terapia Psicologica. 2007;25(1):63–71. Other reason.
167 Olivares, J, García L, . Application of the Spanish version of Social Effectiveness Therapy for adolescents (SET-Asv) to the treatment of an adolescent with generalized social phobia. Psicologia Conductual. 2002;10(2):409–19. The study does not have children with anxiety (3–18 yrs).
168 Olivares, J, Rosa A, . Transmisión de información cualificada frente a tratamiento psicológico estructurado de adolescentes con fobia social generalizada. International Journal of Clinical and Health Psychology. 2009;9(2):241–58. Other reason.
169 Pantazatos SP, Talati A, Schneier FR, . Reduced anterior temporal and hippocampal functional connectivity during face processing discriminates individuals with social anxiety disorder from healthy controls and panic disorder, and increases following treatment. Neuropsychopharmacology. 2014;39(2):425–34. doi:10.1038/npp.2013.211 PMID: 24084831. The study does not have children with anxiety (3–18 yrs).24084831
170 Payne, S, Bolton, . A pilot investigation of cognitive therapy for generalized anxiety disorder in children aged 7–17 years. Cognitive Therapy and Research. 2011 April;35(2):171–8. doi:10.1007/s10608-010-9341-z. The study is not a comparative study (case reports only included for side effects/ harms)
171 Pennant ME, Loucas CE, Whittington C, . Computerised therapies for anxiety and depression in children and young people: a systematic review and meta-analysis. Behav Res Ther. 2015 Apr;67:1–18. doi:10.1016/j.brat.2015.01.009 PMID: 25727678. A systematic review/meta-analysis/guideline.25727678
172 Peris TS, Compton SN, Kendall PC, . Trajectories of change in youth anxiety during cognitive-behavior therapy. J Consult Clin Psychol. 2015 Apr;83(2):239–52. doi:10.1037/a0038402 PMID: 25486372. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).25486372
173 Peterman JS, Carper MM, Elkins RM, . The effects of cognitive-behavioral therapy for youth anxiety on sleep problems. Journal of anxiety disorders. 2016;37:78–88. doi:10.1016/j.janxdis.2015.11.006 PMID: 26735330. The study is not a comparative study (case reports only included for side effects/ harms).26735330
174 Pettit JW, Silverman WK, Rey Y, . Moving to Second-Stage Treatments Faster: Identifying Midtreatment Tailoring Variables for Youth with Anxiety Disorders. J Clin Child Adolesc Psychol. 2016 Jul–Aug;45(4):457–68. doi:10.1080/15374416.2015.1038824 PMID:25984794. The study is not a comparative study (case reports only included for side effects/ harms)25984794
175 Phelan JR. Parent, teacher, or analyst: the adolescent-group therapist’s trilemma. Int J Group Psychother. 1974 Apr;24(2):238–44. doi:10.1080/00207284.1974.11491822 PMID: 4821467. The study is not original (commentaries, letters, etc.)4821467
176 Pina AA, Zerr AA, Villalta IK, . Indicated prevention and early intervention for childhood anxiety: a randomized trial with Caucasian and Hispanic/Latino youth. J Consult Clin Psychol. 2012 Oct;80(5):940–6. doi:10.1037/a0029460 PMID: 22823856. The study does not have children with anxiety (3–18 yrs).22823856
177 Pliszka S, Borcherding S. The stop signal task in children with attention deficit hyperactivity disorder and anxiety. Unpublished manuscript. 1995. Other reason for exclusion.
178 Prince J, Bostic J, Monuteaux M, . Citalopram for the treatment of adolescent anxiety disorders: a pilot study. Psychopharmacology bulletin. 2001;36(3):100–7. PMID:12473968. Other reason.12473968
179 Propper, L, Hrdlicka, . Mianserin in the treatment of depression and anxiety in childhood and adolescence. [Czech]. Ceska a Slovenska Psychiatrie. 2000;96(7):376–80. The study does not have children with anxiety (3–18 yrs).
180 Puleo, C M, Conner, . CBT for childhood anxiety and substance use at 7.4-year follow-up: A reassessment controlling for known predictors. Journal of Anxiety Disorders. 2011 June;25(5):690–6. doi:10.1016/j.janxdis.2011.03.005 PMID: 21497052. The study is not a comparative study (case reports only included for side effects/ harms).21497052
181 Puleo CM, Kendall PC. Anxiety disorders in typically developing youth: autism spectrum symptoms as a predictor of cognitive-behavioral treatment. J Autism Dev Disord. 2011 Mar;41(3):275–86. doi:10.1007/s10803-010-1047-2 PMID: 20694508. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).20694508
182 Rapee RM, Jones MP, Hudson JL, . d-Cycloserine does not enhance the effects of in vivo exposure among young people with broad-based anxiety disorders. Behaviour research and therapy. 2016;87:225–31. doi:10.1016/j.brat.2016.10.004 PMID: 27771572. The study does not include any of the interventions listed above (pharmacotherapy or psychotherapy)27771572
183 Reaven J, Blakeley-Smith A, Culhane-Shelburne K, . Group cognitive behavior therapy for children with high-functioning autism spectrum disorders and anxiety: a randomized trial. J Child Psychol Psychiatry. 2012 Apr;53(4):410–9. doi:10.1111/j.1469-7610.2011.02486.x PMID: 22435114. The study does not have children with anxiety (3–18 yrs).22435114
184 Reigada LC, Benkov KJ, Bruzzese JM, . Integrating illness concerns into cognitive behavioral therapy for children and adolescents with inflammatory bowel disease and co-occurring anxiety. Journal for Specialists in Pediatric Nursing. 2013;18(2):133–43. doi:10.1111/jspn.12019 PMID: 23560585. The study is not a comparative study (case reports only included for side effects/ harms).23560585
185 Reinholdt D, M L, Mogg, . Attention Control and Attention to Emotional Stimuli in Anxious Children Before and After Cognitive Behavioral Therapy. Cognitive Therapy and Research. 2015 19 Jul;39(6):785–96. doi:10.1007/s10608-015-9708-2. The study is not a comparative study (case reports only included for side effects/ harms)
186 Riahi F, Tashakori A, Izadi-Mazidi S. Effectiveness of reboxetine in treatment of outpatient children and adolescents with attention deficit-hyperactivity disorder with comorbid anxiety disorders. Iranian journal of psychiatry. 2013;8(4):195. PMID:25628714. The study does not include any of the interventions listed above (pharmacotherapy or psychotherapy)25628714
187 Riemann BC, Kuckertz JM, Rozenman M, . Augmentation of youth cognitive behavioral and pharmacological interventions with attention modification: a preliminary investigation. Depress Anxiety. 2013 Sep;30(9):822–8. doi:10.1002/da.22127 PMID: 23658147. The study does not have children with anxiety (3–18 yrs).23658147
188 Roberts CL, Farrell LJ, Waters AM, . Parents’ Perceptions of Novel Treatments for Child and Adolescent Specific Phobia and Anxiety Disorders. Child Psychiatry Hum Dev. 2016 Jun;47(3):459–71. doi:10.1007/s10578-015-0579-2 PMID:26349600 The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).26349600
189 Rodgers A, Dunsmuir S. A controlled evaluation of the ‘FRIENDS for Life’ emotional resiliency programme on overall anxiety levels, anxiety subtype levels and school adjustment. Child and Adolescent Mental Health. 2015 Feb;20(1):13–9. doi:10.1111/camh.12030. The study does not have children with anxiety (3–18 yrs).
190 Ruggiero, L. Clinical trial of medazepam in children. Clinica Pediatrica. 1975;57(7):318–31. The study does not have children with anxiety (3–18 yrs).
191 Ruini C, Belaise C, Brombin C, . Well-being therapy in school settings: a pilot study. Psychother Psychosom. 2006 October;75(6):331–6. doi:10.1159/000095438 PMID:17053333. The study does not have children with anxiety (3–18 yrs).17053333
192 Saavedra LM, Silverman WK, Morgan-Lopez AA, . Cognitive behavioral treatment for childhood anxiety disorders: long-term effects on anxiety and secondary disorders in young adulthood. J Child Psychol Psychiatry. 2010 Aug;51(8):924–34. doi:10.1111/j.1469-7610.2010.02242.x PMID: 20345838. Other reason.20345838
193 Sadjadi, S A, Hashemian, . Sadjadi, S A, Hashemian, . Effectiveness of neurofeedback therapy in children with separation anxiety disorder. African Journal of Psychiatry (South Africa). 2014;17 (6) (no pagination)(1000149) doi:10.4172/Psychiatry.1000149. The study does not include any of the interventions listed above (pharmacotherapy or psychotherapy)
194 Sallee FR, Sethuraman G, Sine L, . Yohimbine challenge in children with anxiety disorders. American Journal of Psychiatry. 2000;157(8):1236–42. doi:10.1176/appi.ajp.157.8.1236 PMID: 10910785. Other reason.10910785
195 Sanchez, B, Pedreira, . Separation anxiety disorders in children: Comorbidity and follow-up. Revista de Psiquiatria Infanto-Juvenil. 1998;2:87–93. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).
196 Saraf KR, Klein DF, Gittelman-Klein R, . Imipramine side effects in children. Psychopharmacologia. 1974 Jul 11;37(3):265–74. doi:10.1007/BF00421540. The study does not have children with anxiety (3–18 yrs).4852352
197 Wong Sarver N, Beidel DC, Spitalnick JS. The feasibility and acceptability of virtual environments in the treatment of childhood social anxiety disorder. Journal of Clinical Child & Adolescent Psychology. 2014;43(1):63–73. doi:10.1080/15374416.2013.843461 PMID: 24144182. The study is not a comparative study (case reports only included for side effects/ harms).24144182
198 Schirman S, Kronenberg S, Apter A, . Effectiveness and tolerability of citalopram for the treatment of depression and anxiety disorders in children and adolescents: an open-label study. J Neural Transm (Vienna). 2010 Jan;117(1):139–45. doi:10.1007/s00702-009-0330-x PMID: 19851705. The study does not have children with anxiety (3–18 yrs).19851705
199 Schleider JL, Ginsburg GS, Keeton CP, . Parental psychopathology and treatment outcome for anxious youth: roles of family functioning and caregiver strain. J Consult Clin Psychol. 2015 Feb;83(1):213–24. doi:10.1037/a0037935 PMID: 25222799. The study is not a comparative study (case reports only included for side effects/ harms).25222799
200 Schmidtchen S, Hobrucker B. [Efficiency testing of client-centered play therapy in children from educational guidance centers]. Prax Kinderpsychol Kinderpsychiatr. 1978 Jun;27(4):117–25. PMID: 683949. The study does not have children with anxiety (3–18 yrs).683949
201 Semple RJ, Reid EF, Miller L. Treating anxiety with mindfulness: An open trial of mindfulness training for anxious children. Journal of Cognitive Psychotherapy. 2005;19(4):379–92. doi:10.1891/088983905780907702. The study is not a comparative study (case reports only included for side effects/ harms).
202 Settipani CA, Kendall PC. Social functioning in youth with anxiety disorders: association with anxiety severity and outcomes from cognitive-behavioral therapy. Child Psychiatry Hum Dev. 2013 Feb;44(1):1–18. doi:10.1007/s10578-012-0307-0 PMID: 22581270. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).22581270
203 Sheykhan, R, Mohammadkhani, . Sheykhan R, Mohamadkhani S, Hasanabadi H. Self-Focused Attention in Treatment of Social Anxiety: A Controlled Clinical Trial. Journal of Mazandaran University of Medical Sciences. 2013;23(106):120–8. Persian article.
204 Simeon JG, Ferguson HB, Knott V, . Clinical, cognitive, and neurophysiological effects of alprazolam in children and adolescents with overanxious and avoidant disorders. J Am Acad Child Adolesc Psychiatry. 1992 Jan;31(1):29–33. doi:10.1097/00004583-199201000-00006 PMID: 1537778. The study does not have children with anxiety (3–18 yrs).1537778
205 Simon E, Bogels SM, Voncken JM. Efficacy of child-focused and parent-focused interventions in a child anxiety prevention study. J Clin Child Adolesc Psychol. 2011;40(2):204–19. doi:10.1080/15374416.2011.546039 PMID: 21391018. The study does not have children with anxiety (3–18 yrs).21391018
206 Silverman WK, Kurtines WM, Ginsburg GS, . Treating anxiety disorders in children with group cognitive-behavioral therapy: A randomized clinical trial. Journal of consulting and clinical psychology. 1999;67(6):995. doi:10.1037/0022-006X.67.6.995 PMID:10596522 The study does not have children with anxiety (3–18 yrs).10596522
207 Sofronoff K, Attwood T, Hinton S. A randomised controlled trial of a CBT intervention for anxiety in children with Asperger syndrome. J Child Psychol Psychiatry. 2005 Nov;46(11):1152–60. doi:10.1111/j.1469-7610.2005.00411.x PMID: 16238662. The study does not have children with anxiety (3–18 yrs).16238662
208 Spence SH, Donovan C, Brechman-Toussaint M. The treatment of childhood social phobia: The effectiveness of a social skills training-based, cognitive-behavioural intervention, with and without parental involvement. The Journal of Child Psychology and Psychiatry and Allied Disciplines. 2000;41(6):713–26. doi:10.1111/1469-7610.00659 PMID:11039684 Other reason.11039684
209 Spence, S H, Donovan, . Online CBT in the treatment of child and adolescent anxiety disorders: Issues in the development of BRAVE-ONLINE and two case illustrations. Behavioural and Cognitive Psychotherapy. 2008 July;36(4):411–30. doi:10.1017/S135246580800444X. The study is not a comparative study (case reports only included for side effects/ harms).
210 Spiegelberg U, Petrilowitsch N, Betz B. Medazepam. A new tranquilizer: simple test, intraindividual comparisons and combination therapy. Arzneimittel-Forschung. 1968;18(12):1559. PMID:5756249. The study does not have children with anxiety (3–18 yrs).5756249
211 Sportel BE, de Hullu E, de Jong PJ, . Cognitive bias modification versus CBT in reducing adolescent social anxiety: a randomized controlled trial. PLoS One. 2013 14 May;8(5):e64355. doi:10.1371/journal.pone.0064355 PMID:23691203. The study does not have children with anxiety (3–18 yrs).23691203
212 Stallard P, Richardson T, Velleman S, . Computerized CBT (Think, Feel, Do) for depression and anxiety in children and adolescents: outcomes and feedback from a pilot randomized controlled trial. Behav Cogn Psychother. 2011 May;39(3):273–84. doi:10.1017/S135246581000086X PMID: 21272393. The study does not have children with anxiety (3–18 yrs).21272393
213 Starkova, L, Nemeckova, . Fluvoxamine in child and adolescent psychiatry (Retrospective study). [Czech]. Ceska a Slovenska Psychiatrie. 2002;98(5):278–82. The study does not have children with anxiety (3–18 yrs).
214 St-Jacques J, Bouchard S, Bélanger C. Is virtual reality effective to motivate and raise interest in phobic children toward therapy? A clinical trial study of in vivo with in virtuo versus in vivo only treatment exposure. The Journal of clinical psychiatry. 2010;71(7):924–31. doi:10.4088/JCP.08m04822blu PMID:20441721 Other reason.20441721
215 Storch, E A. Computer-Assisted Cognitive-Behavioral Treatment for Anxiety Disorders in Children With Autism Spectrum Disorders. Http://clinicaltrials.gov/show/NCT01565629. 2012. Other reason.
216 Storch EA, Lewin AB, Collier AB, . A randomized controlled trial of cognitive-behavioral therapy versus treatment as usual for adolescents with autism spectrum disorders and comorbid anxiety. Depress Anxiety. 2015 Mar;32(3):174–81. doi:10.1002/da.22332 PMID: 25424398. The study does not have children with anxiety (3–18 yrs).25424398
217 Stulmaker, Hayley L, Ray, . Child-centered play therapy with young children who are anxious: A controlled trial. Children and Youth Services Review. 2015 Oct;57:127–33. doi:10.1016/j.childyouth.2015.08.005. The study does not have children with anxiety (3–18 yrs).
218 Sung M, Ooi YP, Goh TJ, . Effects of cognitive-behavioral therapy on anxiety in children with autism spectrum disorders: A randomized controlled trial. Child Psychiatry & Human Development. 2011;42(6):634–49. doi:10.1007/s10578-011-0238-1. PMID: 21660428. Other reason.21660428
219 Suveg, C, Kendall, . Emotion-focused cognitive-behavioral therapy for anxious youth: A multiple-baseline evaluation. Journal of Contemporary Psychotherapy. 2006 June;36(2):77–85. doi:10.1007/s10879-006-9010-4. The study is not a comparative study (case reports only included for side effects/ harms).
220 Suveg C, Sood E, Comer JS, . Changes in emotion regulation following cognitive-behavioral therapy for anxious youth. J Clin Child Adolesc Psychol. 2009 May;38(3):390–401. doi:10.1080/15374410902851721 PMID: 19437299. The study is not a comparative study (case reports only included for side effects/ harms).19437299
221 Svedin, Carl G, Arvidsson, . Symptom changes after family therapy: A follow-up study of 56 cases treated with family therapy in an outpatient child psychiatric clinic. Nordisk Psykiatrisk Tidsskrift. 1990;44(1):31–40. doi:10.3109/08039489009096542. The study is not a comparative study (case reports only included for side effects/ harms).
222 Svensson L, Larsson A, Ost L-G. How children experience brief-exposure treatment of specific phobias. Journal of Clinical Child and Adolescent Psychology. 2002;31(1):80–9. doi:10.1207/S15374424JCCP3101_10 PMID: 11845654. The study is not a comparative study (case reports only included for side effects/ harms).11845654
223 Taboas, W, Ojserkis, . Change in disgust reactions following cognitive-behavioral therapy for childhood anxiety disorders. International Journal of Clinical and Health Psychology. 2015;15(1):1–7. doi:10.1016/j.ijchp.2014.06.002 The study does not have children with anxiety (3–18 yrs).
224 Katschnig H. The International Multicenter Clinical Trial Group on Moclobemide in Social Phobia. Moclobemide in social anxiety disorder. A double-blind, placebo-controlled clinical study. Eur Arch Psychiatry Clin Neurosci. 1997;247:71–80. PMID: 9177952. Other reason for exclusion.9177952
225 Thienemann M, Moore P, Tompkins K. A parent-only group intervention for children with anxiety disorders: pilot study. Journal of the American Academy of Child & Adolescent Psychiatry. 2006;45(1):37–46. doi:10.1097/01.chi.0000186404.90217.02 PMID: 16327579. The study is not a comparative study (case reports only included for side effects/ harms).16327579
226 Tishby, O, Raitchick, . Changes in interpersonal conflicts among adolescents during psychodynamic therapy. Psychotherapy Research. 2007 May;17(3):301–9. doi:10.1080/10503300600607944. The study does not have children with anxiety (3–18 yrs).
227 Torma S, Halsti A. Outcome in truancy and school phobias. Psychiatria Fennica. 1976. The study is not a comparative study (case reports only included for side effects/ harms)
228 Ultee, C A, Griffioen, . The reduction of anxiety in children: a comparison of the effects of ‘systematic desensitization in vitro’ and ‘systematic desensitization in vivo’. Behaviour research and therapy. 1982;20(1):61–7. PMID:6121554. The study does not have children with anxiety (3–18 yrs).6121554
229 van der Leeden AJ, van Widenfelt BM, van der Leeden R, . Stepped care cognitive behavioural therapy for children with anxiety disorders: a new treatment approach. Behav Cogn Psychother. 2011 Jan;39(1):55–75. doi:10.1017/S1352465810000500 PMID: 20932360. The study is not a comparative study (case reports only included for side effects/ harms).20932360
230 Vassilopoulos SP, Banerjee R, Prantzalou C. Experimental modification of interpretation bias in socially anxious children: Changes in interpretation, anticipated interpersonal anxiety, and social anxiety symptoms. Behav Res Ther. 2009 Dec;47(12):1085–9. doi:10.1016/j.brat.2009.07.018 PMID: 19679299. The study does not have children with anxiety (3–18 yrs).19679299
231 Victor AM, Bernat DH, Bernstein GA, . Effects of parent and family characteristics on treatment outcome of anxious children. J Anxiety Disord. 2007;21(6):835–48. doi:10.1016/j.janxdis.2006.11.005 PMID: 17161582. The study does not have children with anxiety (3–18 yrs).17161582
232 Vitiello B, Davis M, Greenhill LL, . Blindness of clinical evaluators, parents, and children in a placebo-controlled trial of fluvoxamine. J Child Adolesc Psychopharmacol. 2006 Feb–Apr;16(1–2):219–25. doi:10.1089/cap.2006.16.219 PMID: 16553542. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc)16553542
233 Walkup JT, Albano AM, Piacentini J, . Cognitive behavioral therapy, sertraline, or a combination in childhood anxiety. N Engl J Med. 2008 Dec 25;359(26):2753–66. doi:10.1056/NEJMoa0804633 PMID: 18974308. The study is not original (commentaries, letters, etc.)18974308
234 Vitiello B, Group RUoPPAS. Searching for moderators and mediators of pharmacological treatment effects in children and adolescents with anxiety disorders. Journal of the American Academy of Child & Adolescent Psychiatry. 2003;42(1):13–21. doi:10.1097/00004583-200301000-00006 PMID: 12500072. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).12500072
235 Waters, A M, Potter, . Predictors of treatment outcomes in anxious children receiving group cognitive-behavioural therapy: Pretreatment attention bias to threat and emotional variability during exposure tasks. Behaviour Change. 2015 27 Jul;32(3):143–58. doi:10.1017/bec.2015.6. The study is not a comparative study (case reports only included for side effects/ harms)
236 Weisz JR, Chorpita BF, Palinkas LA, . Testing standard and modular designs for psychotherapy treating depression, anxiety, and conduct problems in youth: a randomized effectiveness trial. Arch Gen Psychiatry. 2012 Mar;69(3):274–82. doi:10.1001/archgenpsychiatry.2011.147 PMID: 22065252. The study does not have children with anxiety (3–18 yrs).22065252
237 Wergeland GJ, Fjermestad KW, Marin CE, . Predictors of treatment outcome in an effectiveness trial of cognitive behavioral therapy for children with anxiety disorders. Behav Res Ther. 2016 Jan;76:1–12. doi:10.1016/j.brat.2015.11.001 PMID: 26583954. The study is not a comparative study (case reports only included for side effects/ harms).26583954
238 Wettig, H. H G, Coleman, . Evaluating the effectiveness of theraplay in treating shy, socially withdrawn children. International Journal of Play Therapy. 2011;20(1):26–37. The study is not a comparative study (case reports only included for side effects/ harms).
239 Wijnhoven LA, Creemers DH, Engels RC, . The effect of the video game Mindlight on anxiety symptoms in children with an Autism Spectrum Disorder. BMC Psychiatry. 2015 Jul 01;15:138. doi:10.1186/s12888-015-0522-x PMID: 26129831. The study does not have children with anxiety (3–18 yrs).26129831
240 Wolk CB, Kendall PC, Beidas RS. Cognitive-behavioral therapy for child anxiety confers long-term protection from suicidality. J Am Acad Child Adolesc Psychiatry. 2015 Mar;54(3):175–9. doi:10.1016/j.jaac.2014.12.004 PMID: 25721182. The study does not report anxiety outcomes (symptom severity and scales, behavioral outcomes, adverse effects, etc).25721182
241 Wood JJ, Ehrenreich-May J, Alessandri M, . Cognitive behavioral therapy for early adolescents with autism spectrum disorders and clinical anxiety: a randomized, controlled trial. Behav Ther. 2015 Jan;46(1):7–19. doi:10.1016/j.beth.2014.01.002 PMID: 25526831. The study does not have children with anxiety (3–18 yrs).25526831
242 Wood JJ, McLeod BD, Piacentini JC, . One-year follow-up of family versus child CBT for anxiety disorders: Exploring the roles of child age and parental intrusiveness. Child Psychiatry Hum Dev. 2009 Jun;40(2):301–16. doi:10.1007/s10578-009-0127-z PMID: 19165592. Other reason.19165592
243 Wood JJ, Drahota A, Sze K, . Brief report: Effects of cognitive behavioral therapy on parent-reported autism symptoms in school-age children with high-functioning autism. Journal of autism and developmental disorders. 2009;39(11):1608–12. doi:10.1007/s10803-009-0791-7 PMID:19562475 Other reason.19562475
244 Wright H, Hall S, Hames A, . Pet Dogs Improve Family Functioning and Reduce Anxiety in Children with Autism Spectrum Disorder. Anthrozoos. 2015;28(4):611–24. doi:10.1080/08927936.2015.1070003 The study does not have children with anxiety (3–18 yrs).
245 Wu X, Liu F, Cai H, . Cognitive Behaviour Therapy Combined Fluoxetine Treatment Superior to Cognitive Behaviour Therapy Alone for School Refusal. International Journal of Pharmacology. 2013 Apr 1;9(3):197–203. doi:10.3923/ijp.2013.197.203. The study does not have children with anxiety (3–18 yrs).
246 Yan, Yu L, Wang, . Effects of group cognitive-behavioral therapy on adolescent anxiety symptoms. Chinese Mental Health Journal. 2015 Jan;29(1):10–5. The study does not have children with anxiety (3–18 yrs).
247 Zarghami, Firouzeh, Heydarinasab, . The effectiveness of cognitive behavior treatment based on Kendall’s Coping Program on anxiety disorders: A transdiagnostic approach. Journal of Iranian Psychologists. 2015 Fal;12(45):37–50. Persian article.
248 Zozulia AA, Neznamov GG, Siuniakov TS, . [Efficacy and possible mechanisms of action of a new peptide anxiolytic selank in the therapy of generalized anxiety disorders and neurasthenia]. Zh Nevrol Psikhiatr Im S S Korsakova. 2008;108(4):38–48. PMID:18454096. The study does not have children with anxiety (3–18 yrs).18454096
249 Zwaanswijk, M, Kösters, . Children’s and parents’ evaluations of ‘FRIENDS for life’, an indicated school-based prevention program for children with symptoms of anxiety and depression. Behaviour Change. 2015;32(4):243–54. doi:10.1017/bec.2015.13. The study does not have children with anxiety (3–18 yrs).