# Appendix B Search Strategy

## Ovid

Database(s): Embase 1988 to 2017 Week 05, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations and Ovid MEDLINE(R) 1946 to Present, PsycINFO 1806 to January Week 4 2017, EBM Reviews - Cochrane Central Register of Controlled Trials November 2016, EBM Reviews - Cochrane Database of Systematic Reviews 2005 to January 25, 2017

## Search Strategy

# | Searches | Results
1 | Anxiety Disorders/dh, dt, su, th | 9492
2 | anxiety disorder/dm, dt, rt, su, th [Disease Management, Drug Therapy, Radiotherapy, Surgery, Therapy] | 13722
3 | exp Panic Disorder/dt, su, th [Drug Therapy, Surgery, Therapy] | 7765
4 | exp panic/dm, dt, su, th [Disease Management, Drug Therapy, Surgery, Therapy] | 5422
5 | exp Phobic Disorders/dh, dt, su, th [Diet Therapy, Drug Therapy, Surgery, Therapy] | 3954
6 | exp phobia/dm, dt, su, th [Disease Management, Drug Therapy, Surgery, Therapy] | 5441
7 | exp Anxiety, Separation/dt, th [Drug Therapy, Therapy] | 724
8 | exp separation anxiety/dm, dt, th [Disease Management, Drug Therapy, Therapy] | 425
9 | exp generalized anxiety disorder/dm, dt, su, th [Disease Management, Drug Therapy, Surgery, Therapy] | 2415
10 | (((“social anxiet*” or “generalized anxiet*” or overanxious) adj3 (disorder* or neuroses or neurosis or neurotic or phobia* or phobic)) or ((anxiety or anxieties) adj3 (disorder* or neuroses or neurosis or neurotic)) or (panic adj3 (disorder* or attack*)) or Acrophobia* or agoraphobia* or claustrophobia* or homophobia* or neophobia* or Ophidiophobia* or phobia* or phobic or “separation anxiet*” or xenophobia*).mp. | 244817
11 | exp Psychotherapy/ | 569654
12 | exp Electroconvulsive Shock Therapy/ | 20518
13 | exp Electroconvulsive Therapy/ | 27336
14 | exp brain depth stimulation/ | 30937
15 | exp Deep Brain Stimulation/ | 39654
16 | exp transcranial magnetic stimulation/ | 34619
17 | exp Vagus Nerve/ | 40508
18 | exp Vagus Nerve Stimulation/ | 9498
19 | exp electrostimulation therapy/ | 181773
20 | exp Electric Stimulation Therapy/ | 254786
21 | exp electrical brain stimulation/ | 38192
22 | exp alternative medicine/ | 268544
23 | exp phototherapy/ | 102362
24 | exp kinesiotherapy/ | 58263
25 | exp Exercise Therapy/ | 105637
26 | exp Exercise/ | 459889
27 | exp yoga/ | 9351
28 | exp complementary therapies/ | 261302
29 | exp alternative medicine/ | 268544
30 | exp Combined Modality Therapy/ | 300497
31 | ((brain adj2 excitation) or (brain adj2 stimulat*) or “12 step program*” or abreaction or acupressure* or acupuncture or “age regression” or agent* or “alternative medicine” or aromatherap* or Aromatherapy or auriculotherap* or “Balint group*” or “behavior contracting” or “behavior modification” or bibliotherapy or biofeedback or “breathing exercise*” or catharsis or chemotherap* or Chronotherapy or “cognitive rehabilitation” or “cognitive restructuring” or “combined modalit*” or “complementary medicine*” or “consciousness raising” or “contingency management” or cotherap* or counseling or countercondition* or Countertransference or “crisis intervention*” or Desensitization or drug* or “electric stimulat*” or “electrical stimulat*” or Electroacupuncture or electrosleep or electrostimulat* or electrotherap* or “empty chair” or exercise or fading or “fatty acid*” or “flower remed*” or “free association*” or gestalt or “group development” or “group dynamics” or “group intervention*” or heliotherap* or holistic or homeopathy or “human potential*” or humanis* or hypnosis or Hypnotherapy or imagery or intervention* or kinesiotherap* or kinesitherap* or Logotherapy or manag* or massage or medication* or “mental healing” or microbicid* or “mind-body” or neurofeedback or neurosurger* or operat* or overcorrection or “paradoxical technique*” or pharmacotherap* or phototherap* or phytotherap* or prevent* or Psychoanaly* or psychodrama or psychodrama* or psychotherap* or Psychotherapeutic* or radiotherap* or reflexotherap* or relaxation or resect* or “response cost” or “role play*” or “role playing” or “sensory feedback” or sociotherapy or spiritual* or “stress management” or suggestion* or “support group*” or surg* or “tai ji” or therap* or “therapeutic communit*” or “therapeutic touch*” or therapies or therapy or timeout* or training or “Transactional Analysis” or “transcranial magnetic stimulat*” or transference or treat* or treatment* or “twelve step program*” or “vagal nerve” or “vagal stimulat*” or “vagus nerve” or “vagus stimulat*” or yoga).mp. | 29404851
32 | or/11–31 | 29519244
33 | 10 and 32 | 168615
34 | or/1–9 | 37562
35 | 33 or 34 | 170412
36 | limit 35 to “all child (0 to 18 years)” [Limit not valid in Embase,PsycINFO,CCTR,CDSR; records were retained] | 140150
37 | limit 36 to (childhood or adolescence <13 to 17 years>) [Limit not valid in Embase,Ovid MEDLINE(R),Ovid MEDLINE(R) In-Process,CCTR,CDSR; records were retained] | 104599
38 | limit 37 to (preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years>) [Limit not valid in Ovid MEDLINE(R),Ovid MEDLINE(R) In-Process,PsycINFO,CCTR,CDSR; records were retained] | 34306
39 | (toddler* or child* or adolescent* or paediatric* or pediatric* or girl or girls or boy or boys or teen or teens or teenager* or preschooler* or “pre-schooler*” or preteen or preteens or “pre-teen” or “pre-teens” or youth or youths).mp. | 6640078
40 | 35 and 39 | 41617
41 | from 38 keep 1–26193 | 26193
42 | 40 or 41 | 42800
43 | exp meta analysis/ | 234764
44 | exp Meta-Analysis as Topic/ | 53463
45 | exp “systematic review”/ | 153050
46 | ((meta adj analys*) or (systematic* adj3 review*)).mp,pt. | 550689
47 | 43 or 44 or 45 or 46 | 550689
48 | exp controlled study/ | 5658493
49 | exp Randomized Controlled Trial/ | 905465
50 | exp triple blind procedure/ | 204
51 | exp Double-Blind Method/ | 390501
52 | exp Single-Blind Method/ | 68129
53 | exp latin square design/ | 570
54 | ((control* adj3 study) or (control* adj3 trial) or (randomized adj3 study) or (randomized adj3 trial) or (randomised adj3 study) or (randomised adj3 trial) or “pragmatic clinical trial” or (doubl* adj blind*) or (doubl* adj mask*) or (singl* adj blind*) or (singl* adj mask*) or (tripl* adj blind*) or (tripl* adj mask*) or (trebl* adj blind*) or (trebl* adj mask*) or “latin square”).mp,pt. | 7148487
55 | or/48–54 | 7148556
56 | controlled study/ | 5390344
57 | exp comparative study/ | 2718783
58 | exp Cross-Sectional Studies/ | 447921
59 | exp Cohort Studies/ | 2043883
60 | exp longitudinal study/ | 327400
61 | exp retrospective study/ | 1141189
62 | exp prospective study/ | 905077
63 | exp population research/ | 90005
64 | exp observational study/ | 158991
65 | clinical study/ | 223234
66 | exp Evaluation Studies/ | 259715
67 | exp quantitative study/ | 59289
68 | exp validation studies/ | 146273
69 | exp quasi experimental study/ | 4492
70 | exp field study/ | 10921
71 | in vivo study/ | 265314
72 | exp panel study/ | 1232
73 | exp prevention study/ | 6709
74 | exp replication study/ | 2630
75 | exp Feasibility Studies/ | 137033
76 | exp trend study/ | 19095
77 | exp correlational study/ | 24732
78 | exp case-control studies/ | 978796
79 | exp confidence interval/ | 320632
80 | exp regression analysis/ | 902411
81 | exp proportional hazards model/ | 170815
82 | ((control* adj3 study) or “comparative study” or “comparative survey” or “comparative analysis” or “cross-sectional study” or “cross-sectional analysis” or “cross-sectional survey” or “cross-sectional design” or “prevalence study” or “prevalence analysis” or “prevalence survey” or “disease frequency study” or “disease frequency analysis” or “disease frequency survey” or cohort* or longitudinal* or retrospectiv* or prospectiv* or (population adj3 (stud* or survey* or analys* or research)) or ((“follow-up” or followup) adj (stud* or survey or analysis)) or ((observation or observational) adj (study or survey or analysis)) or “clinical study” or “evaluation study” or “evaluation survey” or “evaluation analysis” or “quantitative study” or “quantitative analys*” or “numerical study” or “validation study” or “validation survey” or “validation analysis” or “quasi experimental study” or “quasi experimental analysis” or “quasiexperimental study” or “quasiexperimental analysis” or “field study” or “field survey” or “field analysis” or “in vivo study” or “in vivo analysis” or “panel study” or “panel survey” or “panel analysis” or ((prevention or preventive) adj3 (trial or study or analysis or survey)) or “replication study” or “replication analysis “ or “replication trial” or “feasibility study” or “feasibility analysis” or “trend study” or “trend survey” or “trend analysis” or ((correlation* adj2 study) or (correlation* adj2 analys*)) or “case control study” or “case base study” or “case referrent study” or “case referent study” or “case referent study” or “case compeer study” or “case comparison study” or “matched case control” or “confidence interval” or “regression analysis” or “least square” or “least squares” or (hazard* adj (model or analys* or regression or ratio or ratios)) or “Cox model” or “Cox multivariate analyses” or “Cox multivariate analysis” or “Cox regression” or “Cox survival analyses” or “Cox survival analysis” or “Cox survival model” or ((study or trial or random* or control*) and compar*)).mp,pt. | 17278574
83 | or/56–82 | 17643418
84 | 47 or 55 or 83 | 18237284
85 | 42 and 84 | 22522
86 | from 42 keep 16973–28898 | 11926
87 | limit 86 to (clinical study or clinical trial, all or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or clinical trial or controlled clinical trial or multicenter study or observational study or randomized controlled trial or pragmatic clinical trial or comparative study or controlled clinical trial or evaluation studies or meta analysis or multicenter study or observational study or randomized controlled trial or pragmatic clinical trial or systematic reviews or validation studies) [Limit not valid in Embase,PsycINFO,CCTR,CDSR; records were retained] | 3206
88 | 85 or 87 | 22732
89 | limit 88 to (editorial or erratum or letter or note or addresses or autobiography or bibliography or biography or blogs or comment or dictionary or directory or interactive tutorial or interview or lectures or legal cases or legislation or news or newspaper article or overall or patient education handout or periodical index or portraits or published erratum or video-audio media or webcasts) [Limit not valid in Embase,Ovid MEDLINE(R),Ovid MEDLINE(R) In-Process,PsycINFO,CCTR,CDSR; records were retained] | 548
90 | from 89 keep 1–234 | 234
91 | 88 not 90 | 22498
92 | limit 91 to yr=“2015 – Current” | 4188
93 | remove duplicates from 92 | 2858
94 | limit 91 to yr=“2012–2014” | 5471
95 | remove duplicates from 94 | 3662
96 | limit 91 to yr=“2008–2011” | 4733
97 | remove duplicates from 96 | 3267
98 | limit 91 to yr=“2001 – 2007” | 4836
99 | remove duplicates from 98 | 3351
100 | limit 91 to yr=“1806 – 2000” | 3250
101 | remove duplicates from 100 | 2276
102 | 93 or 95 or 97 or 99 or 101 | 15414

## Scopus

1 | TITLE-ABS-KEY(((“social anxiet*” or “generalized anxiet*” or overanxious) W/3 (disorder* or neuroses or neurosis or neurotic or phobia* or phobic)) OR ((anxiety or anxieties) W/3 (disorder* or neuroses or neurosis or neurotic)) OR (panic W/3 (disorder* or attack*)) OR Acrophobia* OR agoraphobia* OR claustrophobia* OR homophobia* OR neophobia* OR Ophidiophobia* OR phobia* OR phobic OR “separation anxiet*” OR xenophobia*)
2 | TITLE-ABS-KEY((brain W/2 excitation) or (brain W/2 stimulat*) or “12 step program*” or abreaction or acupressure* or acupuncture or “age regression” or agent* or “alternative medicine” or aromatherap* or Aromatherapy or auriculotherap* or “Balint group*” or “behavior contracting” or “behavior modification” or bibliotherapy or biofeedback or “breathing exercise*” or catharsis or chemotherap* or Chronotherapy or “cognitive rehabilitation” or “cognitive restructuring” or “combined modalit*” or “complementary medicine*” or “consciousness raising” or “contingency management” or cotherap* or counseling or countercondition* or Countertransference or “crisis intervention*” or Desensitization or drug* or “electric stimulat*” or “electrical stimulat*” or Electroacupuncture or electrosleep or electrostimulat* or electrotherap* or “empty chair” or exercise or fading or “fatty acid*” or “flower remed*” or “free association*” or gestalt or “group development” or “group dynamics” or “group intervention*” or heliotherap* or holistic or homeopathy or “human potential*” or humanis* or hypnosis or Hypnotherapy or imagery or intervention* or kinesiotherap* or kinesitherap* or Logotherapy or manag* or massage or medication* or “mental healing” or microbicid* or “mind-body” or neurofeedback or neurosurger* or operat* or overcorrection or “paradoxical technique*” or pharmacotherap* or phototherap* or phytotherap* or prevent* or Psychoanaly* or psychodrama or psychodrama* or psychotherap* or Psychotherapeutic* or radiotherap* or reflexotherap* or relaxation or resect* or “response cost” or “role play*” or “role playing” or “sensory feedback” or sociotherapy or spiritual* or “stress management” or suggestion* or “support group*” or surg* or “tai ji” or therap* or “therapeutic communit*” or “therapeutic touch*” or therapies or therapy or timeout* or training or “Transactional Analysis” or “transcranial magnetic stimulat*” or transference or treat* or treatment* or “twelve step program*” or “vagal nerve” or “vagal stimulat*” or “vagus nerve” or “vagus stimulat*” or yoga)
3 | TITLE-ABS-KEY(newborn* or neonat* or infant* or toddler* or child* or adolescent* or paediatric* or pediatric* or girl or girls or boy or boys or teen or teens or teenager* or preschooler* or “pre-schooler*” or preteen or preteens or “pre-teen” or “pre-teens” or youth or youths)
4 | TITLE-ABS-KEY((meta W/1 analys*) OR (systematic* W/3 review*) OR guideline* OR (control* W/3 study) OR (control* W/3 trial) OR (randomized W/3 study) OR (randomized W/3 trial) OR (randomised W/3 study) OR (randomised W/3 trial) OR “pragmatic clinical trial” OR (doubl* W/1 blind*) OR (doubl* W/1 mask*) OR (singl* W/1 blind*) OR (singl* W/1 mask*) OR (tripl* W/1 blind*) OR (tripl* W/1 mask*) OR (trebl* W/1 blind*) OR (trebl* W/1 mask*) OR “latin square” OR placebo* OR nocebo*)
5 | TITLE-ABS-KEY((control* W/3 study) OR “comparative study” OR “comparative survey” OR “comparative analysis” OR “cross-sectional study” OR “cross-sectional analysis” OR “cross-sectional survey” OR “cross-sectional design” OR “prevalence study” OR “prevalence analysis” OR “prevalence survey” OR “disease frequency study” OR “disease frequency analysis” OR “disease frequency survey” OR cohort* OR longitudinal* OR retrospectiv* OR prospectiv* OR (population W/3 (stud* or survey* or analys* or research)) OR ((“follow-up” or followup) W/1 (stud* or survey or analysis)) OR ((observation or observational) W/1 (study or survey or analysis)) OR “clinical study” OR “evaluation study” OR “evaluation survey” OR “evaluation analysis” OR “quantitative study” OR “quantitative analys*” OR “numerical study” OR “validation study” OR “validation survey” OR “validation analysis” OR “quasi experimental study” OR “quasi experimental analysis” OR “quasiexperimental study” OR “quasiexperimental analysis” OR “field study” OR “field survey” OR “field analysis” OR “in vivo study” OR “in vivo analysis” OR “panel study” OR “panel survey” OR “panel analysis” OR ((prevention or preventive) W/3 (trial or study or analysis or survey)) OR “replication study” OR “replication analysis “ OR “replication trial” OR “feasibility study” OR “feasibility analysis” OR “trend study” OR “trend survey” OR “trend analysis” OR ((correlation* W/2 study) OR (correlation* W/2 analys*)) OR “case control study” OR “case base study” OR “case referrent study” OR “case referent study” OR “case referent study” OR “case compeer study” OR “case comparison study” OR “matched case control” OR “confidence interval” OR “regression analysis” OR “least square” OR “least squares” OR (hazard* W/1 (model OR analys* OR regression or ratio or ratios)) OR “Cox model” OR “Cox multivariate analyses” OR “Cox multivariate analysis” OR “Cox regression” OR “Cox survival analyses” OR “Cox survival analysis” OR “Cox survival model” OR ((study OR trial OR random* OR control*) AND compar*))
6 | 1 and 2 and 3 and (4 or 5)
7 | DOCTYPE(le) OR DOCTYPE(ed) OR DOCTYPE(bk) OR DOCTYPE(er) OR DOCTYPE(no) OR DOCTYPE(sh)
8 | 6 and not 7
9 | PMID(0*) OR PMID(1*) OR PMID(2*) OR PMID(3*) OR PMID(4*) OR PMID(5*) OR PMID(6*) OR PMID(7*) OR PMID(8*) OR PMID(9*)
10 | 8 and not 9

## ClinicalTrials.Gov

Open Studies | anxiety OR overanxious OR phobia OR acrophobia OR agoraphobia OR claustrophobia OR homophobia OR neophobia OR ophidiophobia OR xenophobia | Child

Active, not recruiting | anxiety OR overanxious OR phobia OR acrophobia OR agoraphobia OR claustrophobia OR homophobia OR neophobia OR ophidiophobia OR xenophobia | Child

Enrolling by invitation | anxiety OR overanxious OR phobia OR acrophobia OR agoraphobia OR claustrophobia OR homophobia OR neophobia OR ophidiophobia OR xenophobia | Child

## Health Canada

Any of these words: anxiety overanxious phobia acrophobia agoraphobia claustrophobia homophobia neophobia ophidiophobia xenophobia

All of these words: child

Any of these words: anxiety overanxious phobia acrophobia agoraphobia claustrophobia homophobia neophobia ophidiophobia xenophobia

All of these words: children

Any of these words: anxiety overanxious phobia acrophobia agoraphobia claustrophobia homophobia neophobia ophidiophobia xenophobia

All of these words: adolescent

Any of these words: anxiety overanxious phobia acrophobia agoraphobia claustrophobia homophobia neophobia ophidiophobia xenophobia

All of these words: teen

## Medicines and Healthcare Products Regulatory Agency

Any of these words: anxiety overanxious phobia acrophobia agoraphobia claustrophobia homophobia neophobia ophidiophobia xenophobia

## AHRQ’s Horizon Scanning System

Anxiety OR overanxious OR phobia OR acrophobia OR agoraphobia OR claustrophobia OR homophobia OR neophobia OR ophidiophobia OR xenophobia