# Appendix A Flow Chart

Figure A.1 Flow chart

The figure shows the flow of the literature search and screening process. We identified 31,828 potential citations from database search and 328 from grey literature. After removing duplications, we found 27,250 citations. We removed 24,141 citations after title and abstract screening. In addition, 2,903 citations were removed after full-text screening. At the end, 206 studies met eligibility criteria and were included in the analyses.