# Abbreviations

AACAP: American Academy of Child and Adolescent Psychiatry
ADHD: Attention Deficit Hyperactivity Disorder
ADIS: Anxiety Disorder Interview Schedule
AE: Adverse Event
CBT: Cognitive Behavioral Therapy
CGAS: Children’s Global Assessment Scale
CGI-I: Clinical Global Impression - Improvement Scale
CGI-S: Clinical Global Impressions Scale - Severity Scale
CI: Confidence Interval
CMAS: Children’s Manifest Anxiety Scale
DSM-5: Diagnostic and Statistical Manual of Mental Disorders
EAS Temperament Survey: Emotionality-Activity-Sociability Temperament Survey
FSSCR: Fear Survey Schedule for Children - Revised
ITT: Intention-to-treat
MASC: Multidimensional Anxiety Scale for Children
N/A: Not Applicable
NICE: National Institute for Health and Care Excellence
NIMH: The National Institute of Mental Health
OCD: Obsessive Compulsive Disorder
ODD: Oppositional Defiant Disorder
PARS: Pediatric Anxiety Rating Scale
PICOTS: Population, Interventions, Comparisons, Outcomes, Timing, and Setting
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
PST: Problem Solving Therapy
RCMAS: Revised Children’s Manifest Anxiety Scale
RCT: Randomized Controlled Trial
SCARED: Screen for Child Anxiety Related Emotional Disorders
SCAS: Spence Children’s Anxiety Scale
SES: Socioeconomic Status
SMD: Standardized Mean Difference
SNRI: Serotonin-Norepinephrine Reuptake Inhibitor
SOE: Strength of Evidence
SPAI: Social Phobia and Anxiety Inventory
SRI: Serotonin Reuptake Inhibitor
SSRI: Selective Serotonin Reuptake Inhibitor
STAI: State-Trait Anxiety Inventory
TCA: Tricyclic Antidepressant