# Results

The Results chapter is organized first by Key Question, then by surgery—in the following order: total hip replacement (THR), total knee replacement (TKR), and hip fracture (HFx) surgery. Subsequently, results are ordered by comparison in alphabetical order. Comparisons with no evidence (no studies) are omitted. Outcomes are reported in three categories, as follows: 1) venous thromboembolism (VTE) related outcomes—including VTE, pulmonary embolism (PE), deep vein thrombosis (DVT), and other VTE-related outcomes (postthrombotic syndrome [PTS] and pulmonary hypertension [HTN]); 2) adverse events, including major bleeding, other bleeding, serious adverse events (study-defined combinations of adverse events), and other adverse events; and 3) adherence. Specific outcomes not reported within each intervention comparison section had no data.

Appendix A presents the literature search strategies (for each searched database). Appendix B lists the articles that were reviewed in full text that were excluded, with their rejection reasons. Appendix C presents the study-level risk of bias assessments of all studies (divided by surgery type for randomized controlled trials [RCT] and then for all nonrandomized comparative studies [NRCS]). Appendix D presents study-level study design and baseline data (divided as in Appendix C). Appendix E presents study-level intervention arm details (also divided as in Appendix C). Appendix F presents study-level results details.

## Summary of Studies

The literature searches yielded 1738 citations (Figure 2). We rescreened 118 studies included in the 2012 VTE report and 107 references found in relevant existing systematic reviews. Of these, 455 articles were screened in full text, of which 313 were excluded for the reasons listed in Figure 2 and Appendix B. The 142 studies included 127 RCTs and 15 NRCSs; they provided 85 studies of THR, 60 of TKR, and 12 of HFx surgery. The publication status and sources of the studies are listed in Figure 2. The grey literature searches added two studies, both unpublished reports with results in ClinicalTrials.gov.

Figure 2 Literature flow

Abbreviations: MA = meta-analysis, N=sample size, NRCS = nonrandomized comparative study, RCT = randomized controlled trial, SR = systematic review, VTE = venous thromboembolism.

* Sums to more than 142 since some studies reported different surgeries separately.

This figure demonstrates the process by which 127 randomized control trials and 15 nonrandomized comparative studies were eligible for this review. From electronic database searches, there were 1738 citations. An additional 118 studies were rescreened from the 2012 VTE report and another 107 studies from existing systematic reviews. From all of these combined, 1508 were excluded based on abstract screening. 455 full text studies were screened and an additional 313 were excluded for the following reasons: Study published prior to 2010 (95), duplicate publication (52), combined surgeries (39), no intervention of interest (27), no comparison of interest (24), nonrandomized comparative study with N<750 (18), no primary data (14), systematic review or meta-analysis without references (12), not surgery of interest (8), not population of interest (6), no or insufficient results data reported (75), comparator mixed interventions (3), no abstract or full text available (3), no analysis by intervention (2), nonrandomized comparative study without comparison of interest (2), no outcome of interest (1). Among the 142 included studies, 85 reported on total hip replacement, 60 on total knee replacement, and 12 on hip fracture surgery (this sums to more than 142 since some studies reported different surgeries separately). 138 were peer reviewed, 2 were reported only in conference abstracts, and 2 in ClinicalTrials.gov results reporting. 81 studies came from the 2012 VTE report, 56 from the new literature search, 3 from existing systematic reviews, and 2 from grey literature searches.

Studies evaluated the following thromboprophylaxis classes (and combinations thereof): antiplatelet drugs, direct thrombin inhibitors (DTI), factor VIII inhibitors (FEI), factor Xa inhibitors (FXaI), factor XI inhibitors (FXIi), low molecular weight heparin (LMWH), mechanical devices, unfractionated heparin (UFH), and vitamin K antagonists (VKA). The studies evaluated the following specific interventions (and combinations thereof): aspirin (antiplatelet drug); dabigatran and desirudin (DTIs); TB402 (FEI); apixaban, darexaban, edoxaban, eribaxaban, fondaparinux, rivaroxaban, and TAK422 (FXaIs); factor XI antisense oligonucleotide (FXIASO; FXIi); dalteparin, enoxaparin, semuloparin, and tinzaparin (LMWHs); flexion devices, graduated compression stockings (GCS), intermittent pneumatic compression (IPC), and venous foot pumps (VFP) (mechanical devices); UFH; and warfarin (VKA).

We chose the principal outcomes for this review (the various VTE outcomes, major bleeding, and serious adverse events) based on an a priori determination of their importance in regards to thromboprophylaxis choice decisionmaking and the high likelihood that these outcomes would be available to researches of almost all RCTs. However, only total DVT was reported by more than 80 percent of the studies (82%), an arbitrary threshold we chose to suggest high risk of reporting bias. In descending order, the remaining principal outcomes were proximal DVT (66% of studies reported), total PE (52%), major bleeding (52%), fatal PE (48%), symptomatic DVT (40%), symptomatic VTE (18%), symptomatic PE (17%), total VTE (15%), and study-defined serious adverse events (11%).

Of note, almost all studies that reported serious adverse events did not define the outcome. Presumably, it included major bleeding, but this is not clear. Two studies described them as treatment-related events that lead to death, are life-threatening, require or prolong hospitalization, cause disability or incapacity, jeopardize the subject, or require an intervention. ^24, 25^ One study referred to “standard regulatory definitions”, but did not further define.^26^

### Randomized Controlled Trials

Among the RCTs, 61 (50%) reported industry funding, 4 (3%) used materials supplied by industry, 18 (15%) explicitly reported no industry support, and 40 (33%) did not provide funding information (Appendix D).

In general, for the RCTs the risk of bias was low regarding randomization, allocation concealment, group similarity at baseline, and methods used for outcome assessment. Reporting, compliance with interventions, timing of outcome assessment, and definition of adverse effects were explicitly reported in fewer than half of the RCTs. Fifty-two RCTs had a high risk of bias regarding blinding of patients (in addition, 16 had unclear risk of bias, 1 not reported from the original report^a^), 51 for blinding of health care providers (25 unclear, 1 not reported from the original report), and 20 for blinding of outcome assessors (29 unclear). Twenty-eight RCTs had a high risk of bias in compliance of intention-to-treat principle in data analysis (8 unclear). Attrition bias was rated high in 22 RCTs (10 unclear). A full list of risk of bias evaluation is available in Appendix C.

### Nonrandomized Comparative Studies

Overall, we included 15 NRCSs. Five NRCSs evaluated only THR,^27–31^ six only TKR,^32–37^ three had separate analyses of THR and TKR,^38–40^ and one evaluated HFx surgery.^41^ Two reported industry funding,^36, 40^ 12 explicitly reported no industry support,^27–35, 37, 39, 41^ and in one it was not reported (Appendix D).^38^ In general, the risk of bias was low for incomplete results reporting (2 unclear) and timing of outcome assessments (3 unclear). One NRCS had high risk of bias for adverse event reporting and one was unclear. Similarly, one NRCS had high risk of bias for compliance with interventions and a second was unclear. One NRCS had high risk of bias for patient selection, and a second was unclear. Seven NRCSs had high risk of bias for group similarity at baseline (4 unclear); five for assessment of outcomes (4 unclear). Seven NRCSs had high risk of bias for blinding of outcome assessors, and another five were unclear. Eight had high risk of bias for selective outcome reporting. Full risk of bias evaluations are in Appendix C.

### Correlation of DVT and PE Across Trials

To help put the VTE outcomes into context, we performed simple correlation analyses of rates of DVT (proximal, symptomatic, and total) and of PE (fatal, symptomatic, and total) across studies and interventions, including placebo. Analyses were run excluding studies arms with no DVT or PE events; more than half the studies that reported PE outcomes had no PE events. We also excluded studies with atypically high rates of PE (i.e., outlier studies that typically represented single events in small studies). Across studies, rates of total PE (the most commonly reported PE outcome) were correlated with symptomatic DVT (r=0.57), but not distal or total DVT (|r|≤0.10). Rates of symptomatic PE were correlated with rates of proximal DVT (r=0.33) but not symptomatic DVT (r=0.19). Fewer than five studies reported (non-zero) fatal PE events or both symptomatic PE and total DVT, so correlations were not assessed for associated pairs of outcomes. In summary, the rates of the most commonly reported PE and DVT outcomes (total PE and total DVT) are not correlated within these studies; however, rates of symptomatic DVT are correlated with rates of total PE across studies.

### Subgroup Analyses

Only two of the RCTs reported subgroup analyses. These are reported in the appropriate sections, based on the Key Question, surgery, and intervention comparison. We collected data to conduct metaregressions across studies based on different population characteristics as listed in the Methods section (under Subgroup Analyses and Metaregression). However, overall, studies were generally homogeneous in regard to study eligibility criteria (within surgical types). Almost all studies included all-comers and did not restrict eligibility based on patient or surgery characteristics. Some studies excluded patients with a bleeding history or chronic VKA or antiplatelet drug use, but the counterfactuals (studies that included only patients with a bleeding history or on chronic antithrombotic drugs) were rare or nonexistent. Therefore, analyses across studies of different subgroups were not productive.

For comparisons with at least six studies that could be meta-analyzed (that evaluated the same surgery and the same class or intervention comparison), we conducted metaregressions if at least one of the studies differed in a study-level covariate. Based on the available data, we thus conducted metaregressions for differences in funding source (industry vs. other funding source) and geography (Asian vs. non-Asian study). This latter comparison was conducted due to a perception that risks of VTE and adverse effects may differ in Asian populations.^42^

## Key Question 1 Comparison of Thromboprophylaxis Intervention Classes

Note that network meta-analyses comparing classes in regard to total DVT and major bleeds are presented under Key Question 5. The results of comparisons with sufficient evidence are summarized here; other comparisons are noted, but were deemed to have insufficient evidence.

### Key Question 1: Total Hip Replacement

The results summary table (Table 1) includes results for all reported comparisons and outcomes from THR RCTs. The reader should refer to this table for each results section summary even though the table is not repeatedly cited in each section. Where data are summarized only in appendix tables or are summarized in figures, these are cited.

Table 1 Results summary: Total hip replacement, intervention class versus class comparisons

Comparison | Outcome | Studies, N | OR (95% CI), 1^*^ or Summary OR (95% CI) ^†^ | OR (95% CI), 2^*^ | OR (95% CI), 3^*^ | No Events^‡^
Antiplatelet vs. VKA | DVT, Total | 1 | 0.71 (0.34, 1.47)
| DVT, Proximal | 1 | 0.31 (0.08, 1.18)
Antiplatelet vs. VKA (+mechanical device both arms) | PE, Total | 1 | 3.00 (0.12, 74.9)
| DVT, Proximal | 1 | 1.13 (0.36, 3.55)
DTI vs. FXaI (+LMWH both arms) | DVT, Total | 1 | 0.54 (0.12, 2.42)
DTI vs. UFH | PE, Total | 2 | 0.11 (0.01, 2.03) | 3.42 (0.14, 84.4)
| PE, Fatal | 2 | No estimate | | | 2 RCTs
| DVT, Total | 2 | 0.26 (0.13, 0.50) | 0.44 (0.28, 0.69)
| DVT, Proximal | 2 | 0.13 (0.05, 0.31) | 0.18 (0.05, 0.62)
| Bleeding, Fatal | 2 | | | | 2 RCTs
| Bleeding, Leading to reoperation | 2 | 2.01 (0.37, 11.1) | | | 1 RCT
| Bleeding, Surgical site/joint | 1 | 1.15 (0.41, 3.21)
| Mortality, 30 day or in-hospital | 2 | 0.20 (0.01, 4.15) | 0.38 (0.02, 9.28)
FEI vs. FXaI | VTE, Total | 1 | 1.11 (0.44, 2.78)
| VTE, Symptomatic | 1 | No estimate | | | 1 RCT
| PE, Fatal | 1 | No estimate | | | 1 RCT
| PE, Symptomatic | 1 | No estimate | | | 1 RCT
| DVT, Total | 1 | 1.11 (0.44, 2.78)
| DVT, Symptomatic | 1 | No estimate | | | 1 RCT
| DVT, Proximal | 1 | 4.02 (0.45, 36.3)
| Bleeding, Major | 1 | 11.22 (0.62, 204)
| Bleeding, Surgical site/joint | 1 | 2.87 (1.30, 6.34)
| Mortality, 30 day or in-hospital | 1 | 0.33 (0.01, 8.15)
LMWH vs. antiplatelet | PE, total | 2 | 0.94 (0.75, 1.17) | 0.2% vs. 1.7%
| DVT, symptomatic | 1 | 0.84 (0.70, 1.03)
| Bleeding, major | 1 | 0.95 (0.77, 1.17)
LMWH vs. DTI | VTE, Symptomatic | 1 | 6.09 (0.73, 50.6)
| PE, Total | 2 | 0.60 (0.14, 2.50) | 2.40 (0.62, 9.30)
| PE, Fatal | 2 | 0.34 (0.01, 8.36) | | | 1 RCT
| DVT, Total | 3 | 1.14 (0.79, 1.64) | 1.18 (0.67, 2.07) | 1.52 (1.19, 1.94)
| DVT, Symptomatic | 2 | 0.17 (0.02, 1.37) | 9.12 (0.49, 170)
| DVT, Proximal | 3 | 1.35 (0.53, 3.42) | 1.73 (1.13, 2.65) | 1.89 (1.04, 3.44)
| Bleeding, Major | 4 (MA) | 0.79 (0.55, 1.14)
| Bleeding, Fatal | 2 | 0.33 (0.01, 8.13) | | | 1 RCT
| Bleeding, Leading to reoperation | 1 | 1.49 (0.25, 8.94)
| Bleeding, Surgical site/joint | 1 | 1.03 (0.86, 1.24)
| Mortality, 30 day or in-hospital | 3 | 0.14 (0.01, 2.75) | 0.25 (0.03, 2.28) | 3.03 (0.12, 74.5)
LMWH vs. FXaI | VTE, Total | 6 (MA) | 2.18 ( 1.52, 3.13 )
| VTE, Symptomatic | 7 (MA) | 0.72 ( 0.40, 1.30 ) | | | 2 RCTs
| PE, Total | 4 | 0.33 (0.11, 1.03) | 1.01 (0.14, 7.15) | 1.67 (0.40, 7.01) | 1 RCT
| PE, Fatal | 9 | 0.33 (0.01, 8.21) | 2.00 (0.18, 22.1) | | 7 RCTs
| PE, Symptomatic | 6 | 0.33 (0.01, 8.19) | 0.56 (0.02, 13.8) | 0.99 (0.06, 16.0) | 3 RCTs
| DVT, Total | 10 (MA) | 1.71 ( 1.22, 2.39 )
| DVT, Symptomatic | 9 (MA) | 0.76 (0.37, 1.57) | | | 3 RCTs
| DVT, Proximal | 10 (MA) | 2.40 ( 1.23, 4.69 ) | | | 2 RCTs
| Bleeding, Major | 10 (MA) | 0.74 ( 0.54, 0.99 ) | | | 2 RCTs
| Bleeding, Fatal | 3 | No estimate | | | 3 RCTs
| Bleeding, Leading to reoperation | 3 | 0.60 (0.14, 2.53) | 1.00 (0.14, 7.11) | 1.01 (0.06, 16.1)
| Bleeding, Surgical site/joint | 3 | 0.50 (0.05, 5.56) | 0.72 (0.44, 1.17) | 0.89 (0.45, 1.75)
| Mortality, 30 day or in-hospital | 5 | 0.50 (0.12, 2.00) | 0.50 (0.12, 2.00) | 2.02 (0.37, 11.0) | 2 RCT
| Infection, Joint | 1 | No estimate | | | 1 RCT
| Infection, Wound | 1 | No estimate | | | 1 RCT
| Adverse event, Serious | 5 (MA) | 0.95 (0.78, 1.17)
| Adherent/Compliant | 2 | 0.11 (0.01, 2.05) | 2.64 (1.35, 5.14)
LMWH vs. Mechanical Devices | VTE, Total | 1 | 1.03 (0.42, 2.54)
| PE, Total | 1 | 0.33 (0.01, 8.08)
| PE, Fatal | 2 | No estimate | | | 2 RCTs
| PE, Symptomatic | 1 | 1.03 (0.14, 7.40)
| DVT, Total | 3 | 0.70 (0.36, 1.36) | 1.00 (0.06, 17.0) | 1.03 (0.38, 2.81)
| DVT, Symptomatic | 2 | 2.98 (0.12, 73.8) | | | 1 RCT
| DVT, Proximal | 3 | 0.67 (0.31, 1.45) | 0.68 (0.11, 4.14) | 1.00 (0.06, 16.9)
| Bleeding, Major | 1 | 24.9 (1.46, 425)
| Bleeding, Fatal | 1 | No estimate | | | 1 RCT
| Mortality, 30 day or in-hospital | 1 | No estimate | | | 1 RCT
| Adverse event, Serious | 1 | 3.53 (0.96, 13.0)
LMWH vs. UFH | VTE, Symptomatic | 1 | 1.00 (0.14, 7.39)
| PE, Total | 8 (MA) | 0.29 ( 0.13, 0.63 ) | | | 3 RCTs
| PE, Fatal | 7 | No estimate | | | 7 RCTs
| DVT, Total | 10 (MA) | 0.84 (0.60, 1.18)
| DVT, Symptomatic | 4 (MA) | 0.83 (0.30, 2.35)
| DVT, Proximal | 6 (MA) | 0.59 ( 0.38, 0.93 )
| Bleeding, Major | 6 (MA) | 0.46 ( 0.23, 0.92 ) | | | 1 RCT
| Bleeding, Fatal | 6 | No estimate | | | 6 RCTs
| Bleeding, Leading to reoperation | 1 | No estimate | | | 1 RCT
| Bleeding, Surgical site/joint | 2 | 0.14 (0.02, 1.17) | 0.73 (0.16, 3.46)
| Mortality, 30 day or in-hospital | 6 | 0.20 (0.01, 4.27) | 0.34 (0.01, 8.45) | | 4 RCTs
| Heparin-induced thrombocytopenia | 3 | 0.05 (<0.01, 0.88) | 0.34 (0.01, 8.43) | | 1 RCT
LMWH vs. VKA | VTE, Symptomatic | 2 | 0.97 (0.66, 1.41) | 3.02 (0.61, 15.1)
| PE, Total | 3 | 1.24 (0.58, 2.65) | 3.00 (0.12, 73.9) | | 1 RCT
| PE, Fatal | 3 | 2.96 (0.12, 72.7) | | | 2 RCTs
| DVT, Total | 3 | 0.48 (0.32, 0.72) | 0.49 (0.29, 0.82) | 0.87 (0.60, 1.25)
| DVT, Symptomatic | 2 | 0.66 (0.29, 1.49) | 1.03 (0.69, 1.55)
| DVT, Proximal | 3 | 0.27 (0.07, 0.98) | 0.60 (0.26, 1.35) | 1.27 (0.60, 2.69)
| Bleeding, Major | 4 (MA) | 1.96 ( 1.10, 3.38 )
| Bleeding, Fatal | 2 | No estimate | | | 2 RCTs
| Bleeding, Leading to reoperation | 1 | 3.10 (0.13, 76.4)
| Bleeding, Surgical site/joint | 3 | 1.63 (0.88, 3.03) | 2.78 (1.00, 7.73) | 4.26 (1.19, 15.3)
| Mortality, 30 day or in-hospital | 1 | No estimate | | | 1 RCT
| Heparin-induced thrombocytopenia | 1 | No estimate | | | 1 RCT
Mechanical Devices vs. UFH | DVT, Total | 1 | 0.28 (0.12, 0.67)
| Bleeding, Fatal | 1 | No estimate | | | 1 RCT
| Mortality, 30 day or in-hospital | 1 | 0.32 (0.01, 7.96)
Mechanical Devices vs. VKA | PE, Total | 1 | No estimate | | | 1 RCT
| DVT, Total | 3 | 0.18 (0.05, 0.67) | 0.80 (0.43, 1.48) | 1.00 (0.41, 2.45)
| DVT, Proximal | 3 | 2.39 (0.77, 7.41) | 4.65 (1.27, 17.0) | 4.69 (0.22, 100)
| Bleeding, Major | 1 | No estimate | | | 1 RCT
| Bleeding, Fatal | 2 | No estimate | | | 2 RCTs
| Bleeding, Leading to reoperation | 1 | No estimate | | | 1 RCT
| Mortality, 30 day or in-hospital | 2 | 1.05 (0.06, 17.1) | | | 1 RCT

All outcomes for all pairwise comparisons with data from at least one study. If 3 or fewer randomized controlled trials (RCT) with analyzable data (i.e., at least 1 event per study) then each study’s odds ratio (OR) is listed in ascending order from left to right. If there were ≥4 analyzable studies, then meta-analysis was conducted and summary OR is reported. These are indicated by italics and by MA (meta-analysis) in the study number column. Statistically significant OR estimates are in bold text. The corresponding studies for each analysis can be found in Appendix F.

Other abbreviations: DVT = deep vein thrombosis, PE = pulmonary embolism, VTE = venothromboembolism, Antiplatelet = antiplatelet agent, VKA = vitamin K antagonist, DTI = direct thrombin inhibitor, FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, FEI = factor VIII inhibitor, UFH = unfractionated heparin.

* If meta-analysis was not conducted (if there were <4 meta-analyzable trials), the individual studies’ results are presented across OR 1, 2, and 3, from lowest to highest. Statistically significant estimates are in bold. OR <1 favor the first intervention (e.g., for Antiplatelet vs. VKA, OR = 0.71 favors antiplatelet).

† Summary odds ratios (from meta-analysis) are italicized. Statistically significant estimates are in bold.

‡ Number of RCTs with no events in both arms.

#### Key Question 1 (THR): Antiplatelet Drug Versus VKA

Two RCTs (N=274) and one NRCS (N=887) compared an antiplatelet drug to a VKA;^31, 43, 44^ in one RCT a mechanical device was used in all patients. One RCT reported on total and proximal DVTs; the other reported total PE and proximal DVTs. In all analyses, there was no significant difference between intervention classes. The NRCS found a higher rate of bleeding events in the VKA group compared to the antiplatelet group (1.7% vs. 0.3%), without statistical analysis (Appendix Table F4).^31^ Neither study reported on adherence.

#### Key Question 1 (THR): Antiplatelet Drug Versus Mechanical Device

A U.S.-based registry NRCS of 14,657 THR patients found no significant difference in total PE between aspirin and mechanical devices (OR 1.41, 95% CI 0.37 to 5.34), controlling for age, sex, anesthesia risk category, and use of general anesthesia (Appendix Table F4).^29^

#### Key Question 1 (THR): DTI Versus FXaI

One RCT compared DTI versus FXaI, in which all patients were also treated with LMWH.^45^ The study reported only on total DVT, finding no difference between the two intervention classes.

#### Key Question 1 (THR): DTI Versus UFH

Two RCTs (N=999) compared DTI versus UFH.^46, 47^ Both studies found no significant differences in total PE events and neither reported a fatal PE event. Both found statistically significant differences in total and proximal DVTs, favoring DTI (total DVT: OR 0.26 [95% CI 0.13 to 0.50] and 0.44 [95% CI 0.28 to 0.69]; proximal DVT: OR 0.13 [95% CI 0.05 to 0.31] and 0.18 [95% CI 0.05 to 0.62]).

Neither study reported a fatal bleed. One study found no significant difference in bleeding leading to reoperation and one had no such events. One study found no significant difference in surgical site bleeding. Both studies found no significant difference in 30-day mortality.

Neither study reported on adherence.

#### Key Question 1 (THR): FEI Versus FXaI

One RCT (N=415) compared FEI versus FXaI.^48^ The study found no significant difference in rates of total VTE, total DVT, and proximal DVT, but no events in either arm for symptomatic VTE, fatal PE, symptomatic PE, or symptomatic DVT.

The study found no significant difference in rate of major bleeding but significantly more surgical site bleeding with FEI. There was no significant difference in 30-day mortality.

The study did not report on adherence.

#### Key Question 1 (THR): LMWH Versus Antiplatelet Drug

Two NRCSs compared LMWH with an antiplatelet drug (Appendix Table F4).^28, 29^ Both evaluated total PE. One very large study found identical rates of PE among 85,642 patients given LMWH and 22,942 patients given aspirin (0.68%)^28^; adjusted OR = 0.97, 95% CI 0.81 to 1.17; propensity-adjusted OR [in a matched subset] = 0.94, 95% CI 0.75 to 1.17, P=0.56). The second smaller study (N=1533) found a higher PE rate in the antiplatelet drug group (1.7%) than the LMWH group (0.2%), without statistical analysis.^29^ The large NRCS also found no significant difference in symptomatic (diagnosed) DVT that somewhat favored LMWH (LMWH 0.94%, aspirin 0.99%; adjusted OR = 0.91, 95% CI 0.79 to 1.06; propensity-adjusted OR [in a matched subset] = 0.84, 95% CI 0.70 to 1.03 favoring LMWH, P=0.10) and no difference in major bleeding events, defined as cerebrovascular accident or gastrointestinal hemorrhage (LMWH 0.72%, aspirin 0.77%; adjusted OR = 0.92, 95% CI 0.77 to 1.09; propensity-adjusted OR [in a matched subset] = 0.95, 95% CI 0.77 to 1.17, P=0.63).

#### Key Question 1 (THR): LMWH Versus DTI

Four RCTs (N=6900) compared LMWH versus DTI.^49–52^ All reported on VTE-related outcomes.

##### VTE Outcomes

No VTE-related outcome was analyzed by more than three RCTs. One study found no significant difference in symptomatic VTE.^50^ Two studies found no significant differences in total PEs or fatal PEs (one study had no fatal PE events).^49, 51^ Three studies analyzed total DVT; all found more total DVTs with LMWH, but the difference was statistically significant in only one study (range of ORs 1.14 [95% CI 0.79 to 1.64] to 1.52 [95% CI 1.19 to 1.94]).^49, 50, 52^ The same three studies found similar results for proximal DVT (range of ORs 1.35 [95% CI 0.53 to 3.42] to 1.89 [95% CI 1.04 to 3.44]). Two of the studies found no significant difference in symptomatic DVT events.^49, 50, 52^

##### Major Bleeding

Four RCTs (N=6900) that compared LMWH and DTI reported major bleeding (0.9% to 2.2% in LMWH, 1.4 to 3.8% in DTI).^49–52^ The rate was lower in the LMWH group in three RCTs.^50–52^ Meta-analysis of the four RCTs found no significant difference between the two drug classes for the risk of major bleeding (summary OR=0.79; 95% CI 0.55 to 1.14). Study results were homogeneous (I^2^ = 0%, P = 0.77) (Figure 3).

Figure 3 Forest plot: Total hip replacement, major bleeding, LMWH versus DTI

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result) and equivalent summary estimate from corresponding network meta-analysis (NMA). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: DTI = direct thrombin inhibitor, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 4 RCTs of major bleeding with LMWH versus DTI for total hip replacement. Pairwise meta-analysis summary OR = 0.79 (95% CI 0.55, 1.14), nominally favoring LMWH, with I-squared = 0% and P heterogeneity = 0.768. Network meta-analysis summary OR = 0.78 (95% CrI 0.50, 1.19).

###### Subgroup Analysis

One RCT reported results for serious bleeding by level of chronic kidney disease.^49, 53^ Event rates were low for all participants (2% in both the enoxaparin and desirudin arms). They reported that for chronic kidney disease category 3B (n=569), more patients experienced a major bleed in the desirudin arm than in the enoxaparin arm, although the difference was not statistically significant (1.8% vs. 0.3%; P = 0.11). For chronic kidney disease category 3A (n=758), the rates were the same (0.3% in both arms). For chronic kidney disease categories 1–2 (n=700), DVT rates were also lower in the enoxaparin arm (0.6% vs. 0%).^53^

##### Other Adverse Events

Two RCTs evaluated fatal bleeding;^50, 51^ one found no significant difference, one had no fatal bleeding events. One study each found no significant difference in bleeding leading to reoperation or surgical site bleeding. Three RCTs found no significant difference in 30-day mortality (range of ORs 0.14 [95% CI 0.01 to 2.75] to 3.03 [95% CI 0.12 to 74.5]).^49–51^

##### Adherence

No study reported on adherence.

#### Key Question 1 (THR): LMWH Versus FXaI

Eleven RCTs (N=12,472) compared LMWH versus FXaI;^24, 26, 54–62^ one NRCS also evaluated this comparison.^27^ All 12 studies reported on VTE-related outcomes.

##### Total VTE

Six RCTs (N=5801) compared LMWH and FXaI and reported the occurrence of total VTE with a wide range of event rates across studies (1.1 to 43.8% with LMWH, 0.5 to 21.2% with FXaI).^24, 26, 54–56, 58^ No pattern or clear explanation could be found for differences in rates of VTE across studies. It is likely that studies differed in their definitions and methods for diagnosing VTE; however, they did not report sufficient data to explain the differences. Both the studies with the lowest and highest rates of VTE used mandatory bilateral venography. The rate was significantly lower in the FXaI group in three RCTs.^24, 26, 54^ Meta-analysis of the six RCTs yielded a summary OR of 2.18 (95% CI 1.52 to 3.13) for the risk of total VTE, significantly favoring FXaI. Studies were homogeneous (I^2^ = 13%, P = 0.24) (Figure 4) even though specific drugs, doses, regimens, and risks of VTE varied across RCTs.

Figure 4 Forest plot: Total hip replacement, total venothromboembolism, LMWH versus FXaI

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 6 RCTs of total VTE with LMWH versus FXaI for total hip replacement. Pairwise meta-analysis summary OR = 2.18 (95% CI 1.52, 3.13), favoring FXaI, with I-squared = 13% and P heterogeneity = 0.239.

##### Symptomatic VTE

Seven RCTs (N=6157) reported on symptomatic VTE for comparisons of LMWH and FXaI (0% to 15.3% in LMWH, 0% to 13.1% in FXaI).^54, 56–58, 60–62^ The rate was lower in the FXaI group in four RCTs,^58, 60–62^ statistically significant so in one.^61^ Two RCTs^54, 56^ reported no occurrence of symptomatic VTE in either group. Meta-analysis of the other five RCTs yielded a summary OR of 0.72 (95% CI 0.40 to 1.30) for the risk of symptomatic VTE, significantly favoring FXaI. Study results were homogeneous (I^2^ = 46%, P = 0.16) (Figure 5).

Figure 5 Forest plot: Total hip replacement, symptomatic venothromboembolism, LMWH versus FXaI

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 7 RCTs of symptomatic VTE with LMWH versus FXaI for total hip replacement. Two RCTs had no events and were excluded. Pairwise meta-analysis summary OR = 0.72 (95% CI 0.40, 1.30), favoring LMWH, with I-squared = 46% and P heterogeneity = 0.161.

##### Total DVT

Ten RCTs (N=9346) that compared LMWH and FXaI reported total DVT (2.4 to 18.9% in LMWH, 0% to 13.3% in FXaI).^24, 54–56, 58, 60–64^ The rate was significantly lower in the FXaI group in four RCTs.^24, 54, 61, 62^ Meta-analysis of the nine RCTs yielded a summary OR of 1.71 (95% CI 1.22 to 2.39) for the risk of total DVT, significantly favoring FXaI. There was significant heterogeneity across the RCTs (I^2^ = 51%, P = 0.025) (Figure 6). No clear explanation of the statistical heterogeneity could be found; however, specific drugs, doses, and regimens varied across RCTs. A single NRCS found no significant difference between intervention classes (Appendix Table F4).^27^

Figure 6 Forest plot: Total hip replacement, total deep vein thrombosis, LMWH versus FXaI

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result) and equivalent summary estimate from corresponding network meta-analysis (NMA). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 11 RCTs of total DVT with LMWH versus FXaI for total hip replacement. Pairwise meta-analysis summary OR = 1.71 (95% CI 1.22, 2.39), favoring FXaI, with I-squared = 51% and P heterogeneity = 0.025. Network meta-analysis summary OR = 1.66 (95% CrI 1.11, 2.44).

##### Symptomatic DVT

Nine RCTs (N=11,954) that assessed LMWH and FXaI reported symptomatic DVT (0% to 0.3% in LMWH, 0% to 1.2% in FXaI).^24, 54–56, 58, 60–63^ Patients who received LMWH had a lower rate in four RCTs.^58, 60–62^ Three RCTs^54–56^ had no patients with symptomatic DVT in either study arm. Meta-analysis of the other six RCTs found an imprecise estimate of OR with no significant difference between the two drug classes for the risk of symptomatic DVT (summary OR=0.76; 95% CI 0.37 to 1.57). There was significant statistical heterogeneity across the RCTs (I^2^ = 47%, P = 0.01) (Figure 7). Because of the relative rarity of the outcome (generally <1%), meta-analysis was conducted with Peto’s fixed effect model; sensitivity analysis with the Mantel-Haenszel method yielded similar results. No clear explanation of the statistical heterogeneity could be found; however, specific drugs, doses, and regimens varied across RCTs.

Figure 7 Forest plot: Total hip replacement, symptomatic deep vein thrombosis, LMWH versus FXaI

Forest plot of randomized controlled trials with calculated Peto odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with Peto fixed effect model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 10 RCTs of symptomatic DVT with LMWH versus FXaI for total hip replacement. Peto odds ratio was evaluated. Three RCTs had no events and were excluded. Pairwise meta-analysis summary OR = 0.76 (95% CI 0.37, 1.57), nominally favoring LMWH, with I-squared = 13% and P heterogeneity = 0.111.

##### Proximal DVT

Ten RCTs (N=9622) comparing LMWH and FXaI reported proximal DVT (0% to 13.9% in LMWH, 0% to 3.3% in FXaI).^24, 26, 54–56, 58, 60–62, 64^ The rate was significantly lower in patients who received FXaI in three RCTs.^24, 26, 62^ Two RCTs reported no proximal DVT in either comparison group.^55, 56^ Meta-analysis of the other eight RCTs yielded a summary OR of 2.40 (95% CI 1.23 to 4.69), finding a significantly lower risk of proximal DVT in the FXaI group. Significant heterogeneity was shown across the RCTs (I^2^ = 51%, P = 0.037) (Figure 8). No clear explanation of the statistical heterogeneity could be found; however, specific drugs, doses, and regimens varied across RCTs.

Figure 8 Forest plot: Total hip replacement, proximal deep vein thrombosis, LMWH versus FXaI

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 10 RCTs of proximal DVT with LMWH versus FXaI for total hip replacement. Two RCTs had no events and were excluded. Pairwise meta-analysis summary OR = 2.40 (95% CI 1.23, 4.69), favoring FXaI, with I-squared = 51% and P heterogeneity = 0.037.

##### Other VTE Outcomes

Four RCTs^24, 60–62^ and one NRCS^27^ reported on total PE, but there were no PE events in one RCT and in the NRCS. Among the remaining three studies, no significant differences were found (range of ORs 0.33 [95% CI 0.11 to 1.03] to 1.67 [95% CI 0.40 to 7.01]).^b^ Nine studies^24, 54, 56–58, 60–63^ reported on fatal PEs, but only two studies had fatal PE events; the two studies found no significant differences (range of ORs 0.33 [95% CI 0.01 to 8.21] to 2.00 [95% CI 0.18 to 22.1]). Similarly, six studies reported on symptomatic PEs, of which only three studies had symptomatic PE events, finding no significant difference between intervention classes (range of ORs 0.33 to 0.99).

##### Major Bleeding

Ten RCTs (N=12,457) reported major bleeding for the comparison of LMWH and FXaI (0% to 3.0% in LMWH, 0% to 4.1% in FXaI).^24, 26, 54–56, 58, 60–63^ The rate was lower in the LMWH group in seven RCTs.^24, 26, 56, 58, 61–63^ Two RCTs^55, 60^ reported no major bleeding in either comparison group. Meta-analysis of the remaining eight RCTs yielded a just-significant difference between the two classes for the risk of major bleeding (summary OR=0.74; 95% CI 0.54 to 0.99), favoring LMWH. Study results were homogeneous (I^2^ = 0%, P = 0.79) (Figure 9).

Figure 9 Forest plot: Total hip replacement, major bleeding, LMWH versus FXaI

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result) and equivalent summary estimate from corresponding network meta-analysis (NMA). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 11 RCTs of major bleeding with LMWH versus FXaI for total hip replacement. Two RCTs had no events and were excluded. Pairwise meta-analysis summary OR = 0.74 (95% CI 0.54, 0.99), favoring LMWH, with I-squared = 0% and P heterogeneity = 0.794. Network meta-analysis summary OR = 0.74 (95% CrI 0.52, 1.08).

##### Other Bleeding Events

Three RCTs reported that no patients had fatal bleeding events.^24, 61, 62^ The three RCTs reported no significant difference in bleeding leading to reoperation (range of ORs 0.60 [95% CI 0.14 to 2.53] to 1.01 [95% CI 0.06 to 16.1]).^24, 61, 62^ Similarly, three studies reported no significant difference in surgical site bleeding (range of ORs 0.50 [95% CI 0.12 to 2.00] to 0.89 [95% CI 0.45 to 1.75]).

##### Serious Adverse Events (Study-Defined)

Five RCTs (N=6727) comparing LMWH versus FXaI reported serious adverse events (1.2 to 6.5% in LMWH, 0% to 6.9% in FXaI).^24, 26, 54, 55, 65^ Two studies reported a lower rate in the LMWH group.^24, 26^ No significant difference was shown in the meta-analysis of the five studies for the risk of serious adverse events between the two drug classes (summary OR=0.95, 95% CI 0.78 to 1.17). Study results were homogeneous (I^2^ = 0%, P = 0.53) (Figure 10).

Figure 10 Forest plot: Total hip replacement, serious adverse events, LMWH versus FXaI

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 5 RCTs of serious adverse events with LMWH versus FXaI for total hip replacement. Pairwise meta-analysis summary OR = 0.95 (95% CI 0.78, 1.17), nominally favoring LMWH, with I-squared = 0% and P heterogeneity = 0.526.

##### Other Adverse Events

Five RCTs reported on 30-day mortality,^24, 55, 61–63^ but two had no mortality events; the remaining three studies found no significant difference between intervention classes. One study reported no joint or wound infections.

##### Adherence

Two RCTs found conflicting results regarding adherence.^24, 56^ One study found significantly better adherence with LMWH (OR 2.64, 95% CI 1.35 to 5.14); one study found no significant difference, nominally favoring FXaI (OR 0.11, 95% CI 0.01 to 2.05).

#### Key Question 1 (THR): LMWH Versus Mechanical Devices

Three RCTs (N=732) compared LMWH versus mechanical devices.^66–68^ No significant differences were found for VTE outcomes. One RCT found no significant difference in total VTE. One RCT each found no significant differences in total PE or symptomatic PE. A U.S.-based registry NRCS of 14,657 THR patients found no significant difference in total PE between mechanical devices and LMWH (OR 1.20, 95% CI 0.46 to 3.53), controlling for age, sex, anesthesia risk category, and use of general anesthesia (Appendix Table F4).^29^ Two RCTs had no fatal PEs. Three studies found no significant differences in total DVT (range of ORs 0.70 [95% CI 0.36 to 1.36] to 1.03 [95% CI 0.38 to 2.81]). The same three studies found no significant differences in proximal DVTs (range of ORs 0.67 [95% CI 0.31 to 1.45] to 1.00 [95% CI 0.06 to 16.9]). Two studies reported on proximal DVTs; one had no proximal DVT events and the other found no significant difference in event rates.

One study found much more frequent major bleeding with LMWH than mechanical devices (11/194 vs. 0/198; OR 24.9, 95% CI 1.46 to 425),^67^ but no significant difference in total serious adverse events. Another study had no fatal bleeding events or 30-day deaths.

No study reported on adherence.

#### Key Question 1 (THR): LMWH Versus UFH

Ten RCTs (N=2387) reported on comparisons of LMWH versus UFH.^69–78^ All 10 reported VTE-related outcomes.

##### Total PE

Eight RCTs (N=1878) that compared LMWH and UFH reported total PE (0% to 12.3% in LMWH, 0% to 30.6% in UFH).^69–71, 74–78^ The rate was lower in the LMWH group in five RCTs,^69–71, 74, 78^ which was statistically significant in one.^70^ Three RCTs reported no occurrence of PE in either comparison group.^75–77^ Meta-analysis of the remaining five RCTs yielded a summary OR of 0.29 (95% CI 0.13 to 0.63) for the risk of total PE, statistically significantly favoring LMWH. Study results were homogeneous (I^2^ = 0%, P = 0.97) (Figure 11).

Figure 11 Forest plot: Total hip replacement, total pulmonary embolism, LMWH versus UFH

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: LMWH = low molecular weight heparin, PMID = PubMed identifier, UFH = unfractionated heparin.

Random effects model meta-analysis of 8 RCTs of total PE with LMWH versus UFH for total hip replacement. Three RCTs had no events and were excluded. Pairwise meta-analysis summary OR = 0.29 (95% CI 0.13, 0.63), favoring LMWH, with I-squared = 0% and P heterogeneity = 0.973.

##### Total DVT

Ten RCTs (N=2219) reported total DVT in comparisons of LMWH and UFH (0% to 30.2% in LMWH, 4.0% to 42.4% in UFH).^69–78^ The rate was lower in the LMWH group in seven RCTs,^69–72, 76–78^ which was statistically significant in one.^71^ Meta-analysis of the 10 RCTs found no significant difference between the two drug classes for the risk of total DVT (summary OR=0.84; 95% CI 0.60 to 1.18). Study results were homogeneous (I^2^ = 36%, P = 0.16) (Figure 12).

Figure 12 Forest plot: Total hip replacement, total deep vein thrombosis, LMWH versus UFH

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: LMWH = low molecular weight heparin, PMID = PubMed identifier, UFH = unfractionated heparin.

Random effects model meta-analysis of 10 RCTs of total DVT with LMWH versus UFH for total hip replacement. Pairwise meta-analysis summary OR = 0.84 (95% CI 0.60, 1.18), favoring LMWH, with I-squared = 36% and P heterogeneity = 0.158. Network meta-analysis summary OR = 0.64 (95% CrI 0.43, 0.93).

##### Symptomatic DVT

Four RCTs (N=488) reported on symptomatic DVT comparing LMWH and UFH (1.2 to 5.8% in LMWH, 0% to 6.4% in UFH).^70, 76–78^ Patients who received LMWH had a lower event rate in three RCTs. Meta-analysis of the four RCTs found an imprecise estimate of OR with no significant difference for the risk of symptomatic DVT between the two comparison groups (summary OR=0.83, 95% CI 0.30 to 2.35). Study results were homogeneous (I^2^ = 0%, P = 0.46) (Figure 13).

Figure 13 Forest plot: Total hip replacement, symptomatic deep vein thrombosis, LMWH versus UFH

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: LMWH = low molecular weight heparin, PMID = PubMed identifier, UFH = unfractionated heparin.

Random effects model meta-analysis of 4 RCTs of symptomatic DVT with LMWH versus UFH for total hip replacement. Pairwise meta-analysis summary OR = 0.83 (95% CI 0.30, 2.35), nominally favoring LMWH, with I-squared = 0% and P heterogeneity = 0.461.

##### Proximal DVT

Six RCTs (N=1506) compared LMWH and UFH and reported proximal DVT (1.2 to 7.7% in LMWH, 4.8 to 18.5% in UFH).^69, 71, 72, 74, 77, 78^ The event rate was significantly lower in the LMWH group in one RCT.^71^ Meta-analysis of the six RCTs yielded a summary OR of 0.59 (95% CI 0.38 to 0.93) for the risk of proximal DVT, significantly favoring LMWH. Study results were homogeneous (I^2^ = 3%, P = 0.60) (Figure 14).

Figure 14 Forest plot: Total hip replacement, proximal deep vein thrombosis, LMWH versus UFH

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: LMWH = low molecular weight heparin, PMID = PubMed identifier, UFH = unfractionated heparin.

Random effects model meta-analysis of 6 RCTs of proximal DVT with LMWH versus UFH for total hip replacement. Pairwise meta-analysis summary OR = 0.59 (95% CI 0.38, 0.93), favoring LMWH, with I-squared = 3% and P heterogeneity = 0.604.

##### Other VTE Outcomes

One RCT found no significant difference in symptomatic VTE.^76^ Seven studies reported no fatal PE events.^69–71, 74–77^

##### Major Bleeding

Six RCTs (N=1960) that examined LMWH and UFH reported major bleeding (0% to 4.0% in LMWH, 0% to 6.2% in UFH).^69–71, 73, 74, 76^ The rate was lower in patients who received LMWH in three RCTs,^69, 73, 74^ statistically significantly so in two.^73, 74^ One RCT reported no major bleeding in either group. Meta-analysis of the other five RCTs yielded a summary OR of 0.46 (95% CI 0.23 to 0.92) for the risk of major bleeding, significantly favoring LMWH. Study results were homogeneous (I^2^ = 20%, P = 0.12) (Figure 15).

Figure 15 Forest plot: Total hip replacement, major bleeding, LMWH versus UFH

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result) and equivalent summary estimate from corresponding network meta-analysis (NMA). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: LMWH = low molecular weight heparin, PMID = PubMed identifier, UFH = unfractionated heparin.

Random effects model meta-analysis of 6 RCTs of major bleeding with LMWH versus UFH for total hip replacement. One RCT had no events and was excluded. Pairwise meta-analysis summary OR = 0.46 (95% CI 0.23, 0.92), favoring LMWH, with I-squared = 20% and P heterogeneity = 0.123. Network meta-analysis summary OR = 0.46 (95% CrI 0.26, 0.82).

##### Other Bleeding Events

Six RCTs had no fatal bleeding events,^69–71, 75–77^ one of which also reported no bleeding events leading to reoperation. Two studies found no significant differences in rates of surgical site bleeding. Six studies reported on 30-day mortality but four of the studies had no deaths^c^ and the remaining two found no significant differences in mortality rates.^69–71, 74, 76, 77^

##### Other Adverse Events

Three RCTs found no significant differences in rates of heparin-induced thrombocytopenia, but one of the studies had no events.^69, 74, 76^

##### Adherence

No study reported on adherence.

#### Key Question 1 (THR): LMWH Versus VKA

Four RCTs (N=5332) compared LMWH and VKA.^79–82^ All reported on VTE-related outcomes.

##### VTE Outcomes

Two RCTs found no significant difference in symptomatic VTE.^79, 80^ Three RCTs found no significant differences in total PE (with no events in one study) and in fatal PE (with no events in two studies).^79–81^ The three studies found no significant differences in total DVTs, two of which also found no significant differences in symptomatic DVTs.^79–81^ However, one of the three studies found significantly fewer proximal DVTs with LMWH than VKA, but the three studies were not consistent (range of ORs 0.27 [95% CI 0.07 to 0.98] to 1.27 [95% CI 0.60 to 2.69]).

##### Major Bleeding

Four RCTs (N=5332) reported major bleeding which assessed LMWH and VKA (0.8 to 2.8% in LMWH, 0.4 to 1.5% in VKA).^79–82^ The rate was lower in the VKA group in all the RCTs. Meta-analysis of the four RCTs showed a significantly lower risk of major bleeding in the VKA group (summary OR=1.96, 95% CI 1.14 to 3.38). Study results were homogeneous (I^2^ = 0%, P = 0.97) (Figure 16).

Figure 16 Forest plot: Total hip replacement, major bleeding, LMWH versus VKA

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result) and equivalent summary estimate from corresponding network meta-analysis (NMA). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: LMWH = low molecular weight heparin, PMID = PubMed identifier, VKA = vitamin K antagonist.

Random effects model meta-analysis of 4 RCTs of major bleeding with LMWH versus VKA for total hip replacement. Pairwise meta-analysis summary OR = 1.96 (95% CI 1.14, 3.38), favoring VKA, with I-squared = 0% and P heterogeneity = 0.972. Network meta-analysis summary OR = 1.96 (95% CrI 1.10, 3.68).

##### Other Bleeding

Two RCTs reported no fatal bleeding events.^80, 81^ One study found no significant difference in bleeding events leading to reoperation.^82^ Two of three studies found significant differences in surgical site bleeding, with all three studies favoring VKA (range of ORs 1.63 [95% CI 0.88 to 3.03] to 4.26 [95% CI 1.19 to 15.3]).^79, 81, 82^ One study reported no 30-day mortality events and one study reported no incidents of heparin-induced thrombocytopenia.^81^

##### Adherence

No study reported on adherence.

#### Key Question 1 (THR): Mechanical Device Versus UFH

One RCT (N=132) compared a mechanical device and UFH.^83^ The study found significantly fewer total DVTs with the mechanical device, no fatal bleeding events, and no significant difference in 30-day mortality.

#### Key Question 1 (THR): Mechanical Devices Versus VKA

Three RCTs (N=434) compared a mechanical device with VKA.^84–86^ One study reported no PE events in either arm. A U.S.-based registry NRCS of 14,657 THR patients found no significant difference in total PE between mechanical devices and LMWH (OR 1.34, 95% CI 0.51 to 3.53), controlling for age, sex, anesthesia risk category, and use of general anesthesia (Appendix Table F4).^29^ One of three RCTs found a statistically significant difference in total DVTs favoring mechanical devices, but the other two RCTs found no significant difference; the range of OR estimates was 0.18 (95% CI 0.05 to 0.67) to 1.00 (95% CI 0.41 to 2.45). However, the same three RCTs consistently found more proximal DVTs mechanical devices than VKA, but again only one study was statistically significant; the range of OR estimates was 2.39 (95% CI 0.77 to 7.41) to 4.69 (95% CI 0.22 to 100.4).

No bleeding events were found for major bleeding (1 RCT), fatal bleeding (2 RCTs), or bleeding leading to reoperation (1 RCT). Two RCTs reported on 30-day mortality; one had no deaths and one found no significant difference between intervention classes.

#### Cross-Study Subgroup Analyses

As noted at the start of the Results section, studies were generally homogeneous in terms of patient eligibility criteria, such that most studies included all-comers without eligibility restrictions based on demographics, or other major patient or surgery subtypes. While some studies were restricted based on past bleeding history or chronic antiplatelet or VKA use, no RCTs were restricted to the converse populations (only patients with bleeding history or on antithrombotic medication). Thus, across-study comparisons of subgroup factors are limited.

Among THR RCTs, differences between studies based on industry funding was analyzable for only the comparison of LMWH versus UFH. For total DVT, by random effects model metaregression no significant difference (P=0.51) was found between the eight industry-funded studies (summary OR 0.91, 95% CI 0.59 to 1.41) and the two studies without reported industry support (summary OR 0.71, 95% CI 0.38 to 1.32). Similarly, for major bleeding, no significant difference (P=0.95) was found between the four industry-funded studies (summary OR 0.62, 95% CI 0.13 to 2.93) and the two studies without industry support (summary OR 0.56, 95% CI 0.26 to 1.20).

For the comparison of Asian versus non-Asian RCTs, only the comparison of LMWH versus FXaI was analyzable. For total DVT, no significant difference (P=0.56) was found between the five Asian studies (summary OR 1.63, 95% CI 0.81 to 3.31) and the four non-Asian studies (summary OR 2.08, 95% CI 1.40 to 3.09) by random effects model metaregression. The non-Asian studies included more patients, largely explaining the difference in statistical significance between the two sets of studies. Overall, the same percentage of Asian and non-Asian study participants had a DVT among these RCTs (4.7%). Similarly, for major bleeding, no significant difference (P=0.16) was found between the four Asian RCTs with major bleeding events (summary OR 1.95, 95% CI 0.46 to 8.22) and the five non-Asian studies (OR 0.68, 95% CI 0.49 to 0.94). Again, the non-Asian studies included more patients, largely explaining the difference in statistical significance between the two sets of studies. The Asian RCTs had relatively few events, with an overall major bleeding rate of 0.7 percent compared to 1.5 percent among all non-Asian RCTs (P=0.041); however, if the European study with an atypically high reported major bleeding rate (3.5%) is excluded, the non-Asian RCTs have a major bleeding rate of 0.9 percent, similar to the reported Asian rate (P=0.59).

### Key Question 1: Total Knee Replacement

The results summary table (Table 2) includes results for all reported comparisons and outcomes from TKR RCTs. The reader should refer to this table for each results section summary even though the table is not repeatedly cited in each section. Where data are summarized only in appendix tables or are summarized in figures, these are cited.

Table 2 Results summary: Total knee replacement, intervention class versus class comparisons

Comparison | Outcome | Studies, N | OR (95% CI), 1^*^ or Summary OR (95% CI) ^†^ | OR (95% CI), 2^*^ | OR (95% CI), 3^*^ | No Events^‡^
Antiplatelet vs. FXaI | PE, Total | 1 | No estimate | | | 1 RCT
| DVT, Total | 1 | 6.46 (1.84, 22.6)
| DVT, Symptomatic | 1 | 4.72 (0.22, 99.6)
| Wound complication | 1 | 0.36 (0.07, 1.89)
Antiplatelet vs. Mechanical Device | DVT, Total | 1 | 2.52 (1.20, 5.31)
| DVT, Proximal | 1 | 0.52 (0.05, 5.87)
Antiplatelet vs. VKA | DVT, Total | 1 | 0.88 (0.47, 1.66)
| DVT, Proximal | 1 | 1.08 (0.42, 2.74)
DTI vs. FXaI | PE, Total | 1 | No estimate | | | 1 RCT
| DVT, Total | 1 | No estimate | | | 1 RCT
| Bleeding, Major | 1 | No estimate | | | 1 RCT
LMWH vs. Antiplatelet | PE, Total | 1 | No estimate | | | 1 RCT
| DVT, Total | 1 | 0.73 (0.34, 1.55)
| DVT, Symptomatic | 1 | 0.49 (0.04, 5.44)
| Wound complication | 1 | 1.49 (0.24, 9.07)
LMWH vs. DTI | PE, Total | 2 | 2.96 (0.12, 72.8) | | | 1 RCT
| PE, Fatal | 2 | 2.96 (0.12, 72.8)
| PE, Symptomatic | 1 | No estimate | | | 1 RCT
| DVT, Total | 2 | 2.30 (1.21, 4.38) | | | 1 RCT
| DVT, Symptomatic | 3 | 0.67 (0.21, 2.12) | 1.00 (0.06, 16.5) | 7.96 (0.99, 63.9)
| DVT, Proximal | 2 | 0.67 (0.29, 1.51) | 5.58 (0.66, 47.4)
| Bleeding, Major | 5 (MA) | 0.96 (0.43, 2.16) | | | 1 RCT
| Bleeding, Fatal | 2 | No estimate | | | 2 RCTs
| Bleeding, Leading to reoperation | 1 | 0.33 (0.03, 3.13)
| Bleeding, Surgical site/joint | 1 | 5.49 (1.21, 24.8)
| Mortality, 30 day or in-hospital | 1 | 0.99 (0.06, 15.8)
LMWH vs. FXaI | VTE, Total | 4 (MA) | 1.33 (0.89, 1.99)
| VTE, Symptomatic | 3 | 0.25 (0.03, 2.26) | 0.82 (0.21, 3.12) | 2.02 (0.69, 5.95)
| PE, Total | 5 | 0.14 (0.02, 1.16) | 1.67 (0.40, 7.04) | 2.59 (0.29, 23.4) | 2 RCTs
| PE, Fatal | 5 | 0.20 (0.01, 4.16) | 1.00 (0.06, 16.0) | | 3 RCTs
| PE, Symptomatic | 3 | 2.07 (0.19, 23.2) | 2.97 (0.12, 73.8) | | 1 RCT
| DVT, Total | 7 (MA) | 2.09 ( 1.70, 2.58 ) | | | 1 RCT
| DVT, Symptomatic | 8 (MA) | 0.99 (0.51, 1.91)
| DVT, Proximal | 6 (MA) | 1.84 ( 1.07, 3.16 )
| Bleeding, Major | 7 (MA) | 0.74 (0.42, 1.30) | | | 1 RCT
| Bleeding, Fatal | 1 | No estimate | | | 1 RCT
| Bleeding, Leading to reoperation | 1 | 0.50 (0.05, 5.52)
| Bleeding, Surgical site/joint | 2 | 0.33 (0.07, 1.67) | 1.37 (0.55, 3.42)
| Mortality, 30 day or in-hospital | 3 | 0.20 (0.01, 4.16) | 1.50 (0.25, 9.03) | | 1 RCT
| Adverse event, Serious | 4 (MA) | 1.51 (0.80, 2.85)
| Readmission, bleeding or infection (combined) | 1 | 0.24 (0.03, 2.18)
| Wound complication | 1 | 0.53 (0.12, 2.29)
LMWH vs. FXIi | VTE, Total | 1 | 1.28 (0.68, 2.41)
| VTE, Symptomatic | 1 | 0.98 (0.09, 11.0)
| PE, Fatal | 1 | No estimate | | | 1 RCT
| PE, Symptomatic | 1 | No estimate | | | 1 RCT
| DVT, Total | 1 | 1.28 (0.68, 2.41)
| DVT, Symptomatic | 1 | 0.98 (0.09, 11.0)
| DVT, Proximal | 1 | 1.43 (0.44, 4.67)
| Bleeding, Major | 1 | | | | 1 RCT
| Adverse event, Serious | 1 | 0.28 (0.01, 5.47)
LMWH vs. Mechanical Device | PE, Fatal | 1 | 0.21 (0.01, 4.32)
| DVT, Total | 1 | 0.86 (0.48, 1.54)
| DVT, Proximal | 1 | 0.12 (0.01, 2.23)
| Bleeding, Fatal | 1 | No estimate | | | 1 RCT
| Mortality, 30 day or in-hospital | 1 | 0.34 (0.04, 3.34)
LMWH vs. UFH | PE, Total | 2 | 0.20 (0.01, 4.10) | | | 1 RCT
| PE, Fatal | 2 | 0.33 (0.01, 8.08)
| DVT, Total | 2 | 0.63 (0.42, 0.94) | 0.80 (0.41, 1.57)
| DVT, Symptomatic | 1 | 0.33 (0.01, 8.29)
| DVT, Proximal | 2 | 0.21 (0.08, 0.56) | 0.59 (0.14, 2.56)
| Bleeding, Major | 1 | 0.99 (0.20, 4.94)
| Bleeding, Surgical site/joint | 1 | 1.81 (0.60, 5.48)
LMWH vs. VKA | VTE, Symptomatic | 2 | 1.02 (0.06, 16.4) | 3.00 (0.31, 29.0)
| PE, Total | 4 (MA) | 0.61 (0.15, 2.43)
| PE, Fatal | 3 | No estimate | | | 3 RCTs
| DVT, Total | 3 | 0.42 (0.27, 0.66) | 0.60 (0.43, 0.85) | 0.67 (0.48, 0.94)
| DVT, Symptomatic | 1 | 1.00 (0.06, 16.2)
| DVT, Proximal | 4 (MA) | 0.51 (0.21, 1.28)
| Bleeding, Major | 4 | 1.16 (0.39, 3.50) | 2.36 (0.71, 7.81) | 3.13 (0.84, 11.7) | 1 RCT
| Bleeding, Fatal | 3 | 0.34 (0.01, 8.33) | | | 2 RCTs
| Bleeding, Leading to reoperation | 1 | No estimate | | | 1 RCT
| Bleeding, Surgical site/joint | 1 | 2.11 (0.77, 5.76)
| Mortality, 30 day or in-hospital | 1 | 0.34 (0.03, 3.25)
| Return to OR, bleeding or infection (combined) | 1 | No estimate | | | 1 RCT
| Infection, Leading to reoperation | 1 | No estimate | | | 1 RCT
FXaI vs. VKA | VTE, Total | 1 | 0.44 (0.21, 0.91)
| Mortality, 30 day or in-hospital | 1 | 0.19 (0.01, 4.02)

All outcomes for all pairwise comparisons with data from at least one study. If 3 or fewer randomized controlled trials (RCT) with analyzable data (i.e., at least 1 event per study) then each study’s odds ratio (OR) is listed in ascending order from left to right. If there were ≥4 analyzable studies, then meta-analysis was conducted and summary OR is reported. These are indicated by italics and by MA (meta-analysis) in the study number column. Statistically significant OR estimates are in bold text. The corresponding studies for each analysis can be found in Appendix F.

Other abbreviations: DVT = deep vein thrombosis, PE = pulmonary embolism, VTE = venothromboembolism, Antiplatelet = antiplatelet agent, FXaI = factor Xa inhibitor, VKA = vitamin K antagonist, DTI = direct thrombin inhibitor, LMWH = low molecular weight heparin, FXIi = factor XI inhibitor, UFH = unfractionated heparin.

* If meta-analysis was not conducted (if there were <4 meta-analyzable trials), the individual studies’ results are presented across OR 1, 2, and 3, from lowest to highest. Statistically significant estimates are in bold. OR <1 favor the first intervention (e.g., for Antiplatelet vs. FXaI, OR = 6.46 favors FXaI).

† Summary odds ratios (from meta-analysis) are italicized. Statistically significant estimates are in bold.

‡ Number of RCTs with no events in both arms.

#### Key Question 1 (TKR): Antiplatelet Drug Versus FXaI

One RCT (N=212) compared an antiplatelet drug versus an FXaI.^87^ The study had no PE events, but found significantly fewer total DVT in the FXaI group and no significant difference in symptomatic DVT.

The study found no significant difference in wound complications between the two groups. The study did not report on adherence.

#### Key Question 1 (TKR): Antiplatelet Drug Versus Mechanical Devices

One RCT (N=119) compared an antiplatelet drug versus a mechanical device.^88^ The study reported a significantly fewer total DVT in patients who received mechanical prophylaxis, but no significant difference in proximal DVT between the two classes. The study did not report adverse events or adherence data.

A U.S.-based registry NRCS of 25,388 TKR patients found no significant difference in total PE between aspirin and mechanical devices (OR 0.63, 95% CI 0.32 to 1.26), controlling for age, sex, anesthesia risk category, and use of general anesthesia (Appendix Table F5).^35^

##### Subgroup Analysis

The RCT compared subgroups of patients who received unilateral or bilateral TKR surgery. They found that in the unilateral surgery group (n=72) the percent of patients with a DVT was lower for those receiving mechanical prophylaxis through a compression boot (22%) compared to those receiving aspirin (47%, P<0.03). In the bilateral surgery group (n=47), DVT incidence was also lower in patients who used compression boots (48%) compared with those who received aspirin (68%), but this difference was not significant (P<0.20).^88^ Whether the treatment effect differed between unilateral and bilateral surgery subgroups was not analyzed.

#### Key Question 1 (TKR): Antiplatelet Drug Versus VKA

One RCT (N=189) comparing an antiplatelet drug versus a VKA found no significant difference in either total DVT or proximal DVT between the two classes.^43^ The study did not report adverse events or adherence data.

#### Key Question 1 (TKR): DTI Versus FXaI

One RCT (N=80) compared DTI versus FXaI.^89^ The study reported no total PE, no total DVT, and no major bleeding in either group. The study did not report adherence data.

#### Key Question 1 (TKR): LMWH Versus Antiplatelet Drug

Two RCTs (N=497) compared LMWH versus an antiplatelet drug.^87, 90^ One study reported no total PEs in either group. It found no significant difference in total DVT and symptomatic DVT between the intervention classes. The study also found no significant difference in wound complications. The other study also found no significant differences between the two classes in total PE, total DVT, and proximal DVT. The study reported adherence of over 90 percent in both groups.

#### Key Question 1 (TKR): LMWH Versus DTI

Five RCTs (N=3514) compared LMWH versus DTI.^52, 89, 91–93^ All reported on VTE-related outcomes.

##### VTE Outcomes

Two RCTs reported total PE;^89, 91^ one had no PE events and the other found no significant difference between the two comparison groups. One study found no significant difference in fatal PE between arms, and one reported no fatal PE in either arm.^91, 93^ Two studies reported total DVT;^52, 89^ one had no DVT events but the other found significantly fewer total DVTs in the DTI group. Three RCTs found no significant differences in symptomatic DVT between the two drug classes with inconsistent estimates across studies, but one near-significant OR favoring DTI (range of ORs 0.67 [95% CI 0.21 to 2.12] to 7.96 [95% CI 0.99 to 63.9]).^91–93^ Two RCTs found no significant difference in proximal DVT between arms.^52, 92^

##### Major Bleeding

Five RCTs (N=3514) that compared LMWH and DTI reported major bleeding (0% to 4.4% in LMWH, 0% to 6.7% in DTI).^52, 89, 91–93^ The rate was lower in the LMWH group in three RCTs.^52, 91, 93^ One RCT reported no occurrence of major bleeding in either of the groups. Meta-analysis of the other four RCTs found an imprecise estimate of OR with no significant difference between the two drug classes for the risk of major bleeding (summary OR=0.96; 95% CI 0.43 to 2.16). Study results were homogeneous (I^2^ = 39%, P = 0.19) (Figure 17).

Figure 17 Forest plot: Total knee replacement, major bleeding, LMWH versus DTI

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result) and equivalent summary estimate from corresponding network meta-analysis (NMA). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: DTI = direct thrombin inhibitor, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 5 RCTs of major bleeding with LMWH versus DTI for total knee replacement. Pairwise meta-analysis summary OR = 0.96 (95% CI 0.43, 2.16), nominally favoring LMWH, with I-squared = 39% and P heterogeneity = 0.191. Network meta-analysis summary OR = 0.78 (95% CrI 0.22, 2.31).

##### Other Adverse Events

Two RCTs reported no fatal bleeding.^91, 92^ One study found no significant difference in bleeding leading to reoperation between the two classes.^91^ One study reported significantly lower rate of bleeding at surgical site or joint in the DTI group.^92^ One study found no significant difference in 30-day mortality.^91^

##### Adherence

No studies reported adherence data.

#### Key Question 1 (TKR): LMWH Versus FXaI

Ten RCTs (N=6350) compared LMWH versus FXaI.^55, 87, 89, 94–100^ All 10 reported VTE-related outcomes.

##### Total VTE

Four RCTs^55, 98–100^ (N=1260) reported the outcome of total VTE for the comparison of LMWH and FXaI (13.9% to 22.7% in LMWH, 7.4 to 21.4% in FXaI). Three RCTs^55, 98, 99^ had a lower event rate in the FXaI group, which was statistically significant in one.^98^ No significant difference was shown for the risk of total VTE between the two drug classes in the meta-analysis of the four RCTs (summary OR=1.33, 95% CI 0.89 to 1.99). Study results were homogeneous (I^2^ = 37%, P = 0.21) (Figure 18).

Figure 18 Forest plot: Total knee replacement, total venothromboembolism, LMWH versus FXaI

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 4 RCTs of total VTE with LMWH versus FXaI for total knee replacement. Pairwise meta-analysis summary OR = 1.33 (95% CI 0.89, 1.99), nominally favoring FXaI, with I-squared = 37% and P heterogeneity = 0.211.

##### Total DVT

Seven RCTs (N=3805) reported total DVT for comparisons of LMWH and FXaI (0% to 27.2% in LMWH, 0% to 15.5% in FXaI).^55, 87, 89, 95–98^ The DVT rate was lower in the FXaI group in six RCTs,^55, 87, 95–98^ statistically significantly so in four.^87, 96–98^ One RCT reported no occurrence of DVT events in either comparison group.^89^ Meta-analysis of the other six RCTs yielded a summary OR of 2.09 (95% CI 1.70 to 2.58) for the risk of total DVT, significantly favoring FXaI. Study results were homogeneous (I^2^ = 9%, P = 0.46) (Figure 19).

Figure 19 Forest plot: Total knee replacement, total deep vein thrombosis, LMWH versus FXaI

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result) and equivalent summary estimate from corresponding network meta-analysis (NMA). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 7 RCTs of total DVT with LMWH versus FXaI for total knee replacement. One RCT had no events and was excluded. Pairwise meta-analysis summary OR = 2.09 (95% CI 1.70, 2.58), favoring FXaI, with I-squared = 9% and P heterogeneity = 0.459. Network meta-analysis summary OR = 2.12 (95% CrI 1.70, 2.71).

##### Symptomatic DVT

Eight RCTs (N=5715) comparing LMWH and FXaI reported symptomatic DVT (0.3 to 1.9% in LMWH, 0% to 3.6% in FXaI).^55, 87, 94, 96–100^ The DVT rate was somewhat lower in the FXaI group in five RCTs.^55, 87, 96, 97, 100^ Meta-analysis of the eight RCTs showed no significant difference between the two drug classes for the risk of symptomatic DVT (summary OR=0.99; 95% CI 0.51 to 1.91). Study results were homogeneous (I^2^ = 0%, P = 0.57) (Figure 20). Because of the relative rarity of the outcome (generally <1%), meta-analysis was conducted with Peto’s fixed effect model; sensitivity analysis with the Mantel-Haenszel method yielded similar results.

Figure 20 Forest plot: Total knee replacement, symptomatic deep vein thrombosis, LMWH versus FXaI

Forest plot of randomized controlled trials with calculated Peto odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with Peto fixed effect model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 8 RCTs of symptomatic DVT with LMWH versus FXaI for total knee replacement. Peto odds ratio was evaluated. Pairwise meta-analysis summary OR = 0.99 (95% CI 0.51, 1.91), nominally favoring LMWH, with I-squared = 0% and P heterogeneity = 0.572.

##### Proximal DVT

Six RCTs (N=4402) reported proximal DVT for the comparison of LMWH and FXaI (0.3 to 5.4% in LMWH, 0% to 3.6% in FXaI).^55, 96–100^ The rate was lower in the FXaI group in three RCTs;^96–98^ statistically significant in two.^96, 97^ Overall, the difference for the risk of proximal DVT was statistically significant between the two groups in the meta-analysis of the six RCTs (summary OR=1.84, 95% CI 1.07 to 3.16), favoring FXaI. Study results were homogeneous (I^2^ = 14%, P = 0.45) (Figure 21).

Figure 21 Forest plot: Total knee replacement, proximal deep vein thrombosis, LMWH versus FXaI

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 6 RCTs of proximal DVT with LMWH versus FXaI for total knee replacement. Pairwise meta-analysis summary OR = 1.84 (95% CI 1.07, 3.16), favoring FXaI, with I-squared = 14% and P heterogeneity = 0.453.

##### Other VTE Outcomes

Three RCTs found no significant difference in symptomatic VTE between the two classes (range of ORs 0.25 [95% CI 0.03 to 2.26] to 2.02 [95% CI 0.69 to 5.95])^d,97–99^ Five RCTs reported total PE, but two had no PE events; the remaining three found no significant difference (range of ORs 0.14 [95% CI 0.02 to 1.16] to 2.59 [95% CI 0.29 to 23.4]).^87, 89, 96, 97, 100^ Five RCTs reported fatal PE, but three had no fatal PE events; the two remaining found no significant difference.^96–100^ Three RCTs reported on symptomatic PE, one with no symptomatic PE events; two found no significant difference in symptomatic PE between arms.^55, 98, 99^

##### Major Bleeding

Seven RCTs (N=5926) evaluating LMWH and FXaI reported major bleeding (0% to 1.9% in LMWH, 0% to 2.1% in FXaI).^55, 89, 96–100^ The rate was lower in the LMWH group in three RCTs,^55, 97, 98^ which was statistically significant in one.^97^ No major bleeding occurred in either of the groups in one RCT.^89^ Meta-analysis of the remaining six RCTs found no significant difference between the two classes for the risk of major bleeding (summary OR=0.74; 95% CI 0.42 to 1.30). There was significant heterogeneity across the RCTs (I^2^ = 48%, P = 0.042) (Figure 22). Because of the relative rarity of the outcome (generally <1%), meta-analysis was conducted with Peto’s fixed effect model; sensitivity analysis with the Mantel-Haenszel method yielded similar results. No clear explanation of the statistical heterogeneity could be found; however, specific drugs, doses, and regimens varied across RCTs.

Figure 22 Forest plot: Total knee replacement, major bleeding, LMWH versus FXaI

Forest plot of randomized controlled trials with calculated Peto odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with Peto fixed effect model summary estimate (Pairwise meta-analysis [MA] result) and equivalent summary estimate from corresponding network meta-analysis (NMA). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 7 RCTs of major bleeding with LMWH versus FXaI for total knee replacement. Peto odds ratio was evaluated. One RCT had no events and was excluded. Pairwise meta-analysis summary OR = 0.74 (95% CI 0.42, 1.30), nominally favoring LMWH, with I-squared = 48% and P heterogeneity = 0.042. Network meta-analysis summary OR = 0.56 (95% CrI 0.16, 1.64).

##### Other Bleeding Events

One RCT reported no fatal bleeding, and found no significant difference in bleeding leading to reoperation between the two classes.^97^ Two RCTs found no significant difference in bleeding at surgical site or joint.^96, 98^

##### Serious Adverse Events (Study-Defined)

Four RCTs (N=1803) reported serious adverse events comparing LMWH (0.8 to 9.9%) versus FXaI (0% to 4.3%).^55, 98–100^ Three studies reported a lower rate in the FXaI group.^98–100^ Meta-analysis of the four studies yielded no significant difference for the risk of serious adverse events between the two drug classes (summary OR=1.51, 95% CI 0.80 to 2.85). Study results were homogeneous (I^2^ = 9%, P = 0.44) (Figure 23).

Figure 23 Forest plot: Total knee replacement, serious adverse events, LMWH versus FXaI

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 4 RCTs of serious adverse events with LMWH versus FXaI for total knee replacement. Pairwise meta-analysis summary OR = 1.51 (95% CI 0.80, 2.85), nominally favoring FXaI, with I-squared = 9% and P heterogeneity = 0.442.

##### Other Adverse Events

Three RCTs provided data of 30-day mortality, but one had no deaths; two found no significant difference between intervention classes.^55, 96, 97^ One study reported no significant difference in wound complications.^87^ One study found no significant difference in readmission due to bleeding or infection.^94^

##### Adherence

Two RCTs reported adherence for the comparison of LMWH and FXaI (Appendix Table F2). Adherence was defined as taking over 80 percent of the drugs as prescribed in one RCT.^24^ The rate of adherence in this RCT was 99 percent (2595/2626) in the FXaI group, and 100 percent (2647/2659) in the LMWH group at 34 days of followup. The other RCT^56^ did not define adherence, but reported 100 percent adherence (85/85 in the 15 mg group and 89/89 in the 30 mg group) in the FXaI group and 95 percent (83/87) in the LMWH group during followup for 11 to 14 days.

#### Key Question 1 (TKR): LMWH Versus FXIi

One RCT (N=216) compared LMWH versus FXIi.^101^ The study found no significant difference between the two classes in total VTE, symptomatic VTE, total DVT, symptomatic DVT, and proximal DVT. The study had no occurrences of fatal PE or symptomatic PE.

The study had no major bleeding events. It found no difference in serious adverse events between intervention classes. The study did not report adherence data.

#### Key Question 1 (TKR): LMWH Versus Mechanical Devices

One RCT (N=229) compared LMWH versus a mechanical device.^102^ The study found no significant difference in fatal PE, total DVT, and proximal DVT. There were no fatal bleeding events and 30-day mortality was not significantly different between interventions. No adherence data were reported.

A U.S.-based registry NRCS of 25,388 TKR patients found no significant difference in total PE between LMWH and mechanical devices (OR 0.72, 95% CI 0.42 to 1.23), controlling for age, sex, anesthesia risk category, and use of general anesthesia (Appendix Table F5).^35^

#### Key Question 1 (TKR): LMWH Versus UFH

Two RCTs (N=638) compared LMWH versus UFH.^103, 104^ Both reported on total PE, but one had no PE events; the other study found no significant difference between classes. This latter study also found no significant difference in fatal PE. Both studies found no significant difference in total DVT and proximal DVT. One study also reported no significant difference in symptomatic DVT.

One study found no significant difference between the two classes in major bleeding and bleeding at surgical site or joint. No adherence data were reported.

#### Key Question 1 (TKR): LMWH Versus VKA

Four RCTs (N=1960) compared LMWH versus VKA.^80, 105, 106^ All four reported on VTE-related outcomes.

##### Total PE

Four RCTs (N=1878) reported total PE for the comparison of LMWH and VKA (0% to 1.8% in LMWH, 0% to 0.9% in VKA).^80, 105–107^ Three RCTs^80, 105, 106^ had a lower rate in the LMWH group. Meta-analysis of the four RCTs found an imprecise, nonsignificant estimate of OR for the risk of total PE between the two drug classes (summary OR=0.61, 95% CI 0.15 to 2.43). Study results were homogeneous (I^2^ = 33%, P = 0.21) (Figure 24). Because of the relative rarity of the outcome (generally <1%), meta-analysis was conducted with Peto’s fixed effect model; sensitivity analysis with the Mantel-Haenszel method yielded similar results.

Figure 24 Forest plot: Total knee replacement, total pulmonary embolism, LMWH versus VKA

Forest plot of randomized controlled trials with calculated Peto odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with Peto fixed effect model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: LMWH = low molecular weight heparin, PMID = PubMed identifier, VKA = vitamin K antagonist.

Random effects model meta-analysis of 4 RCTs of total PE with LMWH versus VKA for total knee replacement. Peto odds ratio was evaluated. Pairwise meta-analysis summary OR = 0.61 (95% CI 0.15, 2.43), nominally favoring LMWH, with I-squared = 33% and P heterogeneity = 0.213.

##### Proximal DVT

Four RCTs^80, 105–107^ (N=1772) comparing LMWH and VKA reported the occurrence of proximal DVT (0.9% to 7.8% in LMWH, 1.8 to 12.3% in VKA). The event rate was lower in the LMWH group in three RCTs,^80, 105, 107^ statistically significantly so in one.^105^ No significant difference was shown for the risk of proximal DVT between the two groups in the meta-analysis of the four RCTs (summary OR=0.51, 95% CI 0.21 to 1.28). There was substantial heterogeneity across the RCTs (I^2^ = 74%, P = 0.028) (Figure 25). No clear explanation of the statistical heterogeneity could be found; however, doses and regimens varied across RCTs.

Figure 25 Forest plot: Total knee replacement, proximal deep vein thrombosis, LMWH versus VKA

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: LMWH = low molecular weight heparin, PMID = PubMed identifier, VKA = vitamin K antagonist.

Random effects model meta-analysis of 4 RCTs of proximal DVT with LMWH versus VKA for total knee replacement. Pairwise meta-analysis summary OR = 0.51 (95% CI 0.21, 1.28), nominally favoring LMWH, with I-squared = 74% and P heterogeneity = 0.028. OR estimates ranged from 0.14 to 1.09.

##### Other VTE Events

Two RCTs found no significant difference between the two classes in symptomatic VTE.^80, 106^ Three RCTs reported no fatal PE events.^80, 105, 106^ Three RCTs all found significantly fewer total DVT in the LMWH group (range of ORs 0.42 [95% CI 0.27 to 0.66] to 0.67 [95% CI 0.48 to 0.94]).^80, 105, 106^ One RCT found no significant difference in symptomatic DVT.^107^

##### Adverse Events

Four RCTs reported major bleeding, but one had no major bleeding events;^e^ the remaining three studies found no significant difference between classes.^80, 105–107^ Three RCTs reported fatal bleeding, but two studies had no fatal bleeding events; the remaining study found no significant difference between intervention classes.^80, 105, 106^ One study reported no episodes of bleeding leading to reoperation, infection leading to reoperation, or reoperation due to bleeding or infection.^105^ This study also found no significant differences in bleeding at surgical site and 30-day mortality.^105^

##### Adherence

No studies reported adherence data.

#### Key Question 1 (TKR): VKA Versus Mechanical Devices

A U.S.-based registry NRCS of 25,388 TKR patients found a significant difference in total PE between warfarin and mechanical devices, favoring warfarin (OR 0.46, 95% CI 0.26 to 0.83), controlling for age, sex, anesthesia risk category, and use of general anesthesia (Appendix Table F5).^35^

#### Key Question 1 (TKR): VKA Versus FXaI

One RCT (N=270) comparing VKA and FXaI found no significant difference in 30-day or in-hospital mortality, and total VTE between the two groups.^108^

#### Cross-Study Subgroup Analyses

As noted at the start of the Results section, studies were generally homogeneous in terms of patient eligibility criteria, such that most across-study comparisons of subgroup factors are limited.

Among TKR RCTs, differences between studies based on industry funding was analyzable for only the comparison of LMWH versus FXaI. For total DVT, by random effects model metaregression no significant difference (P=0.21) was found between the six industry-funded studies (summary OR 2.04, 95% CI 1.68 to 2.49) and the single study without industry support (OR 4.71, 95% CI 1.31 to 16.9).

For the comparison of Asian versus non-Asian RCTs, only the comparison of LMWH versus FXaI was analyzable. For total DVT, no significant difference (P=0.97) was found between the four Asian studies (summary OR 2.15, 95% CI 1.35 to 3.41) and three non-Asian studies (summary OR 2.12, 95% CI 1.59 to 2.82) by random effects model metaregression. However, the total DVT rate was lower in the Asian RCTs (9.6%) than the non-Asian studies (16.0%, P<0.01). Similarly, for major bleeding, no significant difference (P=0.34) was found between the two Asian studies (summary OR 0.27, 95% CI 0.03 to 2.32) and the five non-Asian studies (OR 0.89, 95% CI 0.29 to 2.72). Major bleeding rates were similar between Asian studies (0.7%) and non-Asian studies (0.9%, P=0.57).

### Key Question 1: Hip Fracture Surgery

The results summary table (Table 3) includes results for all reported comparisons and outcomes from HFx surgery RCTs. The reader should refer to this table for each results section summary even though the table is not repeatedly cited in each section. Where data are summarized only in appendix tables or are summarized in figures, these are cited.

Table 3 Results summary: Hip fracture surgery, intervention class versus class comparisons

Comparison | Outcome | Studies, N | OR (95% CI), 1^*^ or Summary OR (95% CI) ^†^ | OR (95% CI), 2^*^ | OR (95% CI), 3^*^ | No Events^‡^
Antiplatelet vs. Mechanical Devices | PE, Total | 1 | 2.92 (0.12, 72.8)
| DVT, Total | 1 | 1.75 (0.49, 6.26)
| DVT, Symptomatic | 1 | 1.97 (0.35, 11.2)
Antiplatelet vs. VKA | PE, Total | 1 | 3.00 (0.12, 75.0)
| PE, Fatal | 1 | 3.00 (0.12, 75.0)
| Bleeding, Major | 1 | 0.18 (0.02, 1.63)
| Bleeding, Fatal | 1 | No estimate | | | 1 RCT
LMWH vs. FXaI | VTE, Total | 1 | 0.55 (0.05, 5.58)
| VTE, Symptomatic | 2 | 0.75 (0.36, 1.56) | | | 1 RCT
| PE, Total | 1 | 0.99 (0.43, 2.29)
| PE, Fatal | 2 | 0.86 (0.31, 2.39) | | | 1 RCT
| PE, Symptomatic | 2 | No estimate | | | 2 RCTs
| DVT, Total | 3 | 0.55 (0.05, 5.58) | 2.71 (1.90, 3.87) | 3.81 (1.22, 11.9)
| DVT, Symptomatic | 2 | 0.99 (0.06, 15.8) | | | 1 RCT
| DVT, Proximal | 3 | 2.00 (0.17, 23.4) | 4.86 (2.00, 11.8) | | 1 RCT
| Bleeding, Major | 3 | 0.18 (0.01, 3.91) | 1.04 (0.54, 2.00) | 2.07 (0.12, 34.4)
| Bleeding, Fatal | 2 | 2.96 (0.12, 72.9) | | | 1 RCT
| Bleeding, Leading to reoperation | 1 | 0.66 (0.11, 3.94)
| Mortality, 30 day or in-hospital | 1 | 1.10 (0.70, 1.72)
| Adverse event, Serious | 1 | 2.15 (0.41, 11.4)
LMWH vs. UFH | PE, Total | 1 | 14.3 (0.78, 262)
| PE, Fatal | 1 | No estimate | | | 1 RCT
| DVT, Total | 1 | 3.11 (1.00, 9.68)
| DVT, Proximal | 1 | 3.00 (0.91, 9.94)
| Bleeding, Fatal | 1 | 0.31 (0.01, 7.86)
| Mortality, 30 day or in-hospital | 1 | 0.62 (0.10, 3.91)

All outcomes for all pairwise comparisons with data from at least one study. If 3 or fewer randomized controlled trials (RCT) with analyzable data (i.e., at least 1 event per study) then each study’s odds ratio (OR) is listed in ascending order from left to right. If there were ≥4 analyzable studies, then meta-analysis was conducted and summary OR is reported. These are indicated by italics and by MA (meta-analysis) in the study number column. Statistically significant OR estimates are in bold text. The corresponding studies for each analysis can be found in Appendix F.

Other abbreviations: DVT = deep vein thrombosis, PE = pulmonary embolism, VTE = venothromboembolism, Antiplatelet = antiplatelet agent, VKA = vitamin K antagonist, FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin.

* If meta-analysis was not conducted (if there were <4 meta-analyzable trials), the individual studies’ results are presented across OR 1, 2, and 3, from lowest to highest. Statistically significant estimates are in bold. OR <1 favor the first intervention (e.g., for Antiplatelet vs. Mechanical Devices, OR = 2.92 favors mechanical devices).

† Summary odds ratios (from meta-analysis) are italicized. Statistically significant estimates are in bold.

‡ Number of RCTs with no events in both arms.

#### Key Question 1 (HFx): Antiplatelet Drug Versus Mechanical Devices

One RCT compared an antiplatelet drug versus a mechanical device.^109^ No significant differences were found between arms for total PE, total DVT, and symptomatic DVT. No adverse events or adherence data were reported.

#### Key Question 1 (HFx): Antiplatelet Drug Versus VKA

One RCT compared an antiplatelet drug versus VKA.^110^ The study found no significant differences in total PE and fatal PE (all patients with PE died). There was no significant difference in major bleeding events and no patient had a fatal bleed. Adherence data were not reported.

#### Key Question 1 (HFx): LMWH Versus FXaI

Three RCTs (N=1816) compared LMWH versus FXaI.^25, 111, 112^ Two studies evaluated VTE; one found no significant difference in total VTE and no symptomatic VTE events; the other found no significant difference in symptomatic VTE. All three reported on PE. One found no significant difference in total PE; two had no symptomatic PE events; and one study found no difference in fatal PE while another had no fatal PE events. The three studies also reported on DVT. Two of three studies found that patients treated with LMWH were significantly more likely to have total DVTs, but the third study found no significant difference in which more patients treated with FXaI had total DVT (range of ORs 0.55 [95% CI 0.05 to 5.58] to 3.81 [95% CI 1.22 to 11.9]).

All three studies found no significant difference in major bleeding (range of ORs 0.18 [95% CI 0.01 to 3.91] to 2.07 [95% CI 0.12 to 34.4]). One study found no significant difference in fatal bleeding while a second reported no occurrences of fatal bleeding. One study found no significant difference in bleeding leading to reoperation.

One study found no significant difference in serious adverse events^112^ and another no significant difference in 30-day mortality.^111^

No study reported adherence data.

#### Key Question 1 (HFx): LMWH Versus UFH

One RCT compared LMWH versus UFH.^113^ The study found no significant difference in total PEs, with no fatal PEs occurring. Total DVTs were just-significantly more likely to occur in patients treated with LMWH. The study found a similar, but nonsignificant estimate of effect for proximal DVTs.

The study found nonsignificant differences between arms for fatal bleeding and 30-day mortality. No adherence data were reported.

## Key Question 2 Comparison of Within-Class Thromboprophylaxis Interventions

Note that network meta-analyses comparing individual interventions in regard to total DVT and major bleeds are presented under Key Question 5.

### Key Question 2: Total Hip Replacement

The results summary table (Table 4) includes results for all reported comparisons and outcomes from THR RCTs. The reader should refer to this table for each results section summary even though the table is not repeatedly cited in each section. Where data are summarized only in appendix tables or are summarized in figures, these are cited.

Table 4 Results summary: Total hip replacement, within-class intervention versus intervention comparisons

Comparison | Outcome | Studies, N | OR (95% CI), 1^*^ or Summary OR (95% CI) ^†^ | OR (95% CI), 2^*^ | OR (95% CI), 3^*^ | No Events^‡^
LMWH: Enoxaparin vs. Semuloparin | DVT, Total | 1 | 1.85 (1.32, 2.60)
| DVT, Proximal | 1 | 1.15 (0.54, 2.42)
| Bleeding, Major | 1 | 3.52 (1.16, 10.7)
| Bleeding, Fatal | 1 | No estimate | | | 1 RCT
| Mortality, 30 day or in-hospital | 1 | 2.00 (0.18, 22.1)
| Adverse event, Serious | 1 | 1.35 (0.85, 2.16)
LMWH: Enoxaparin vs. Tinzaparin | PE, Total | 1 | 2.03 (0.18, 22.6)
| PE, Fatal | 1 | 3.05 (0.12, 75.2)
| DVT, Total | 1 | 0.91 (0.57, 1.44)
| DVT, Symptomatic | 1 | 1.52 (0.25, 9.19)
| DVT, Proximal | 1 | 1.12 (0.60, 2.08)
| Bleeding, Major | 1 | 2.04 (0.37, 11.3)
| Bleeding, Fatal | 1 | No estimate | | | 1 RCT
| Bleeding, Surgical site/joint | 1 | 2.04 (0.37, 11.3)
| Mortality, 30 day or in-hospital | 1 | 3.05 (0.12, 75.2)
| Heparin-induced thrombocytopenia | 1 | 3.05 (0.12, 75.2)
Mechanical Devices: GCS vs. IPC | PE, Total | 1 | No estimate | | | 1 RCT
| DVT, Symptomatic | 1 | No estimate | | | 1 RCT
| DVT, Total | 1 | 12.3 (0.63, 239)
| DVT, Proximal | 2 | 3.24 (0.96, 11.0) | 3.65 (0.14, 93.3)

All outcomes for all pairwise comparisons with data from at least one study. If 3 or fewer randomized controlled trials (RCT) with analyzable data (i.e., at least 1 event per study) then each study’s odds ratio (OR) is listed in ascending order from left to right. If there were ≥4 analyzable studies, then meta-analysis was conducted and summary OR is reported. These are indicated by italics and by MA (meta-analysis) in the study number column. Statistically significant OR estimates are in bold text. The corresponding studies for each analysis can be found in Appendix F.

Other abbreviations: DVT = deep vein thrombosis, PE = pulmonary embolism, VTE = venothromboembolism, LMWH = low molecular weight heparin, GCS = graduated compression stockings, IPC = Intermittent Pneumatic Compression.

* If meta-analysis was not conducted (if there were <4 meta-analyzable trials), the individual studies’ results are presented across OR 1, 2, and 3, from lowest to highest. Statistically significant estimates are in bold. OR <1 favor the first intervention (e.g., for Enoxaparin vs. Semuloparin, OR = 1.85 favors semuloparin).

† Summary odds ratios (from meta-analysis) are italicized. Statistically significant estimates are in bold.

‡ Number of RCTs with no events in both arms.

#### Key Question 2 (THR): LMWH: Enoxaparin Versus Semuloparin

One RCT compared the LMWHs enoxaparin versus semuloparin.^114^ The study found significantly more total DVTs with enoxaparin than semuloparin, but no significant difference in proximal DVTs.

The study also found significantly more episodes of major bleeding with enoxaparin than semuloparin. No study participants had a fatal bleed. There were no significant differences in 30-day mortality or serious adverse events.

The study did not evaluate adherence.

#### Key Question 2 (THR): LMWH: Enoxaparin Versus Tinzaparin

One RCT compared the LMWHs enoxaparin versus tinzaparin.^115^ All VTE-related outcomes were not significantly different in both arms, including total PE, fatal PE, total DVT, symptomatic DVT, and proximal DVT.

There were also no significant differences in major bleeding and surgical site bleeding, and no fatal bleeding events. There were no significant differences in 30-day mortality or heparin-induced thrombocytopenia.

The study did not evaluate adherence.

#### Key Question 2 (THR): Mechanical Devices: GCS Versus IPC

Two RCTs (N=161) compared GCS versus IPC; in one RCT all participants also received enoxaparin.^116, 117^ One NRCS (N=1533) also compared GCS versus active compression devices (Appendix Table F4).^29^ One RCT reported no PEs or symptomatic DVTs. The other RCT found no significant difference in total DVTs. Both RCTs found no significant difference in proximal DVTs. The NRCS did not run statistical analyses, but the 0.4 percent had a PE with an active compression device and 0 percent for GCS.

The studies did not report bleeding, other adverse events, or adherence results.

### Key Question 2: Total Knee Replacement

The results summary table (Table 5) includes results for all reported comparisons and outcomes from TKR RCTs. The reader should refer to this table for each results section summary even though the table is not repeatedly cited in each section. Where data are summarized only in appendix tables or are summarized in figures, these are cited.

Table 5 Results summary: Total knee replacement, within-class intervention versus intervention comparisons

Comparison | Outcome | Studies, N | OR (95% CI), 1^*^ or Summary OR (95% CI) ^†^ | OR (95% CI), 2^*^ | OR (95% CI), 3^*^ | No Events^‡^
LMWH: Enoxaparin vs. Semuloparin | DVT, Total | 1 | 1.20 (0.89, 1.63)
| DVT, Proximal | 1 | 0.57 (0.26, 1.27)
| Bleeding, Major | 1 | 1.35 (0.30, 6.05)
| Bleeding, Fatal | 1 | No estimate | | | 1 RCT
| Mortality, 30 day or in-hospital | 1 | No estimate | | | 1 RCT
| Adverse event, Serious | 1 | 1.33 (0.64, 2.76)
LMWH: Enoxaparin vs. Tinzaparin | PE, Total | 1 | No estimate | | | 1 RCT
| DVT, Total | 1 | No estimate | | | 1 RCT
| Bleeding, Major | 1 | No estimate | | | 1 RCT
Mechanical Devices: GCS vs. IPC (+Enoxaparin both arms) | DVT, Total | 1 | 47.9 (2.72, 844)
| DVT, Proximal | 1 | 3.09 (0.12, 78.4)

All outcomes for all pairwise comparisons with data from at least one study. If 3 or fewer randomized controlled trials (RCT) with analyzable data (i.e., at least 1 event per study) then each study’s odds ratio (OR) is listed in ascending order from left to right. If there were ≥4 analyzable studies, then meta-analysis was conducted and summary OR is reported. These are indicated by italics and by MA (meta-analysis) in the study number column. Statistically significant OR estimates are in bold text. The corresponding studies for each analysis can be found in Appendix F.

Other abbreviations: DVT = deep vein thrombosis, PE = pulmonary embolism, VTE = venothromboembolism, LMWH = low molecular weight heparin, GCS = graduated compression stockings, IPC = Intermittent Pneumatic Compression.

* If meta-analysis was not conducted (if there were <4 meta-analyzable trials), the individual studies’ results are presented across OR 1, 2, and 3, from lowest to highest. Statistically significant estimates are in bold. OR <1 favor the first intervention (e.g., for Enoxaparin vs. Semuloparin, OR = 1.20 favors semuloparin).

† Summary odds ratios (from meta-analysis) are italicized. Statistically significant estimates are in bold.

‡ Number of RCTs with no events in both arms.

#### Key Question 2 (TKR): LMWH: Enoxaparin Versus Semuloparin

One RCT compared the LMWHs enoxaparin versus semuloparin.^114^ The study found no significant differences in total or proximal DVTs.

The study also found no significant difference in major bleeding. No study participants had a fatal bleed or 30-day mortality. There was no significant difference in serious adverse events.

The study did not evaluate adherence.

#### Key Question 2 (TKR): LMWH: Enoxaparin Versus Tinzaparin

One RCT compared the LMWHs enoxaparin versus tinzaparin.^89^ However, the study participants had no PEs, DVTs, or major bleeding events. The study did not evaluate adherence.

#### Key Question 2 (TKR): Mechanical Devices: GCS Versus IPC

One RCT compared GCS versus IPC, in which all participants also received enoxaparin.^117^ The study found many more total DVTs in the GCS group than the IPC group (14/35 vs. 0/35; OR 47.9, 95% CI 2.72 to 844), but no significant difference in proximal DVTs (although still favoring IPC).

The study did not report bleeding, other adverse events, or adherence results.

#### Key Question 2 (TKR): Mechanical Devices: TED Hose Versus Non-TED Mechanical Devices

A U.S.-based registry NRCS of 25,388 TKR patients found no significant difference in total PE between those using TED hose and other mechanical devices (OR 0.48, 95% CI 0.06 to 3.51), controlling for age, sex, anesthesia risk category, and use of general anesthesia (Appendix Table F5).^35^

### Key Question 2: Hip Fracture Surgery

The results summary table (Table 6) includes results for all reported comparisons and outcomes from HFx surgery RCTs. The reader should refer to this table for each results section summary even though the table is not repeatedly cited in each section. Where data are summarized only in appendix tables or are summarized in figures, these are cited.

Table 6 Results summary: Hip fracture surgery, within-class intervention versus intervention comparisons

Comparison | Outcome | Studies, N | OR (95% CI), 1^*^ or Summary OR (95% CI) ^†^ | OR (95% CI), 2^*^ | OR (95% CI), 3^*^ | No Events^‡^
LMWH: Enoxaparin vs. Dalteparin | PE, Total | 1 | No estimate | | | 1 RCT
| DVT, Total | 1 | 1.89 (0.58, 6.20)
| DVT, Symptomatic | 1 | No estimate | | | 1 RCT
| DVT, Proximal | 1 | 0.72 (0.12, 4.49)
| Bleeding, Major | 1 | 2.03 (0.18, 23.0)
| Bleeding, Surgical site/joint | 1 | 0.33 (0.01, 8.21)
LMWH: Enoxaparin vs. Semuloparin | DVT, Total | 1 | 1.38 (0.95, 1.99)
| DVT, Proximal | 1 | 2.10 (1.06, 4.14)
| Bleeding, Major | 1 | 0.58 (0.14, 2.46)
| Bleeding, Fatal | 1 | No estimate | | | 1 RCT
| Mortality, 30 day or in-hospital | 1 | 0.49 (0.09, 2.67)
| Adverse event, Serious | 1 | 0.94 (0.55, 1.62)

All outcomes for all pairwise comparisons with data from at least one study. If 3 or fewer randomized controlled trials (RCT) with analyzable data (i.e., at least 1 event per study) then each study’s odds ratio (OR) is listed in ascending order from left to right. If there were ≥4 analyzable studies, then meta-analysis was conducted and summary OR is reported. These are indicated by italics and by MA (meta-analysis) in the study number column. Statistically significant OR estimates are in bold text. The corresponding studies for each analysis can be found in Appendix F.

Other abbreviations: DVT = deep vein thrombosis, PE = pulmonary embolism, VTE = venothromboembolism, LMWH = low molecular weight heparin.

* If meta-analysis was not conducted (if there were <4 meta-analyzable trials), the individual studies’ results are presented across OR 1, 2, and 3, from lowest to highest. Statistically significant estimates are in bold. OR <1 favor the first intervention (e.g., for Enoxaparin vs. Dalteparin, OR = 1.89 favors dalteparin).

† Summary odds ratios (from meta-analysis) are italicized. Statistically significant estimates are in bold.

‡ Number of RCTs with no events in both arms.

#### Key Question 2 (HFx): LMWH: Enoxaparin Versus Dalteparin

One RCT compared the LMWHs enoxaparin versus dalteparin.^118^ The study participants had no PEs or symptomatic DVTs. The rates of total DVT and proximal DVT were not significantly different between drugs.

The study found no significant difference in major bleeding or surgical site bleeding between LMWHs.

The study did not evaluate adherence.

#### Key Question 2 (HFx): LMWH: Enoxaparin Versus Semuloparin

One RCT compared the LMWHs enoxaparin and semuloparin.^114^ The study found no significant difference in total DVTs, but significantly more proximal DVTs with enoxaparin.

There was no significant difference in major bleeding between LMWHs and no fatal bleeding events in either arm. Serious adverse events and 30-day mortality were not significantly different between arms.

The study did not evaluate adherence.

## Key Question 3 Comparison of Dosages and Treatment Durations of Thromboprophylaxis Interventions

### Key Question 3: Different Doses or Regimens

The narrative here describes comparisons of doses for each intervention that were addressed by two or more studies. Each of the more than 300 specific comparison-outcome pairs that were evaluated by only a single study are presented only in Appendix F.

#### Key Question 3 (Dose): Total Hip Replacement

The results summary table (Table 7) includes results for reported comparisons and outcomes from THR RCTs with at least two studies. The reader should refer to this table for each results section summary even though the table is not repeatedly cited in each section. The reader should also refer to Appendix F for comparisons evaluated by only one study.

Table 7 Results summary: Total hip replacement, dose comparisons

Comparison (Daily Dose) | Outcome | Studies, N | Patients, N | OR (95% CI), 1^*^ or Summary OR (95% CI) ^†^ | OR (95% CI), 2^*^ | OR (95% CI), 3^*^ | No Events^‡^
FXaI: Darexaban 5, 10, 30, 60, 120 mg Edoxaban 15, 30, 60, 90 mg | VTE, Total | 4 (MA) | 981 | 1.55 (0.78, 3.06)
LMWH: Certoparin 3000, 5000 IU Dalteparin 2500, 5000 IU Enoxaparin 40, 60 mg | DVT, Total | 5 (MA) | 1441 | 1.33 (0.56, 3.18)
| DVT, Proximal | 4 (MA) | 1047 | 1.04 (0.55, 1.98)
| Bleeding, Major | 4 (MA) | 1498 | 0.42 ( 0.21, 0.86 )
Dabigatran 150 mg vs. Dabigatran 220 or 225 mg | Bleeding, Major | 2 | 2845 | 0.64 (0.33, 1.23) | 0.84 (0.36, 1.98)
Darexaban 15 mg BID vs. Darexaban 30 mg BID | VTE, Total | 2 | 835 | 0.55 (0.16, 1.92) | 1.47 (0.90, 2.41)
Darexaban 30 mg qD vs. Darexaban 60 mg qD | VTE, Total | 2 | 801 | 1.02 (0.62, 1.65) | 1.55 (0.77, 3.14)
| PE, Fatal | 2 | 801 | No estimate | | | 2 RCTs
Edoxaban 15 mg vs. Edoxaban 30 mg | VTE, Total | 2 | 471 | 1.40 (0.23, 8.63) | 1.46 (0.88, 2.45)
| PE, Symptomatic | 2 | 471 | No estimate | | | 2 RCTs
| DVT, Proximal | 2 | 471 | 2.02 (0.69, 5.95) | | | 1 RCT
| Bleeding, Major | 2 | 536 | 0.31 (0.01, 7.83) | 0.88 (0.05, 14.3)
| Adverse event, serious | 2 | 536 | 1.43 (0.46, 4.47) | | | 1 RCT
Enoxaparin 30 mg vs. Enoxaparin 40 mg | DVT, Total | 2 | 791 | 0.28 (0.13, 0.61) | 0.28 (0.13, 0.61)
| Bleeding, Major | 2 | 792 | 2.85 (0.75, 10.9) | 2.88 (0.75, 11.0)

All outcomes for all pairwise comparisons with data from at least one study. If 3 or fewer randomized controlled trials (RCT) with analyzable data (i.e., at least 1 event per study) then each study’s odds ratio (OR) is listed in ascending order from left to right. If there were ≥4 analyzable studies, then meta-analysis was conducted and summary OR is reported. These are indicated by italics and by MA (meta-analysis) in the study number column. Statistically significant OR estimates are in bold text. The corresponding studies for each analysis can be found in Appendix F.

Other abbreviations: BID = twice daily, DVT = deep vein thrombosis, PE = pulmonary embolism, qD = daily, VTE = venothromboembolism.

* If meta-analysis was not conducted (if there were <4 meta-analyzable trials), the individual studies’ results are presented across OR 1, 2, and 3, from lowest to highest. Statistically significant estimates are in bold. OR <1 favor the first intervention (e.g., for FXaI, OR = 1.55 favors higher dose).

† Summary odds ratios (from meta-analysis) are italicized. Statistically significant estimates are in bold.

‡ Number of RCTs with no events in both arms.

##### Key Question 3 (Dose, THR): FXaI

Four RCTs (N=981) comparing FXaI low versus high doses reported total VTE (2.9% to 31.7% for low dose, 2.8 to 21.2% for high dose), as elaborated in Figure 26 and Table 7.^26, 55, 56, 58^ The rate was significantly lower in the high dose group in one study.^58^ Meta-analysis of the four studies found no significant difference between the two dose groups for the risk of total VTE (summary OR=1.55, 95% CI 0.78 to 3.06) (Figure 26). There was heterogeneity across the studies (I^2^ = 58%, P = 0.09). The four RCTs all found only rare instances of major bleeding, between 0 and 2 events (0 to 1.2%) per intervention; therefore no accurate estimates of relative major bleeding rates could be determined.

Figure 26 Forest plot: Total hip replacement, total venothromboembolism, FXaI, low versus high dose

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: FXaI = factor Xa inhibitor, PMID = PubMed identifier, VTE = venothromboembolism.

Random effects model meta-analysis of 4 RCTs of total VTE with low versus high dose FXaI for total hip replacement. Low dose FXaI included darexaban 10 to 15 mg per day, and edoxaban 15 mg per day. High dose FXaI included darexaban 30 to 60 mg per day and edoxaban 30 mg per day. Pairwise meta-analysis summary OR = 1.55 (95% CI 0.78, 3.06), nominally favoring high dose FXaI, with I-squared = 58% and P heterogeneity = 0.092.

##### Key Question 3 (Dose, THR): LMWH

###### Total DVT

Five RCTs (N=1441) reported total DVT for the comparison of low versus high doses of LMWH (4.9% to 20.0% for low dose, 4.6 to 33.8% for high dose), as elaborated in Figure 27 and Table 7.^72–74, 119, 120^ The rate was lower in the low dose group in three of the RCTs and statistically significant in one.^120^ The rates were statistically higher for the low dose group in two RCTs.^73, 74^ Meta-analysis of the five RCTs yielded an imprecise summary OR of 1.33 (95% CI 0.56 to 3.18) for the risk of total DVT (Figure 27). There was statistical heterogeneity across the RCTs (I^2^ = 83%, P <0.01). No clear explanation of the statistical heterogeneity could be found; however, specific drugs, doses, and regimens varied across RCTs.

Figure 27 Forest plot: Total hip replacement, total deep vein thrombosis, LMWH, low versus high dose

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: DVT = deep vein thrombosis, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 5 RCTs of total DVT with low versus high dose LMWH for total hip replacement. Low dose LMWH included certoparin 3000 IU per day, enoxaparin 40 mg per day (total), and dalteparin 2500 IU twice daily. High dose LMWH included certoparin 5000 IU per day, enoxaparin 40 to 60 mg per day (total), and dalteparin 5000 IU daily. Pairwise meta-analysis summary OR = 1.33 (95% CI 0.56, 3.18), nominally favoring high dose LMWH, with I-squared = 83% and P heterogeneity < 0.001.

###### Proximal DVT

Four RCTs (N=1047) that assessed relative effectiveness of low versus high doses of LMWH reported proximal DVT (2.4 to 4.7% for low dose, 2.1 to 7.5% for high dose), as elaborated in Figure 28 and Table 7.^72, 74, 119, 120^ One RCT showed a lower rate in the low dose group.^120^ No significant difference was shown for the risk of proximal DVT between the two doses in the meta-analysis of the four RCTs (summary OR=1.04, 95% CI 0.55 to 1.98). Study results were homogeneous (I^2^ = 0%, P = 0.47) (Figure 28).

Figure 28 Forest plot: Total hip replacement, proximal deep vein thrombosis, LMWH, low versus high dose

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: DVT = deep vein thrombosis, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 4 RCTs of proximal DVT with low versus high dose LMWH for total hip replacement. Low dose LMWH included certoparin 3000 IU per day, enoxaparin 40 mg per day (total), and dalteparin 2500 IU twice daily. High dose LMWH included certoparin 5000 IU per day, enoxaparin 40 to 60 mg per day (total), and dalteparin 5000 IU daily. Pairwise meta-analysis summary OR = 1.04 (95% CI 0.55, 1.98), nominally favoring high dose LMWH, with I-squared = 0% and P heterogeneity = 0.466.

###### Major Bleeding

Four RCTs (N=1498) that compared low versus high doses of LMWH reported major bleeding (1.2 to 2.9% in low dose group, 2.0% to 4.2% in high dose group), as elaborated in Figure 29 and Table 7.^73, 74, 119, 120^ The rate of bleeding was lower in the low dose group in three RCTs.^73, 74, 119^ Meta-analysis of the four RCTs yielded a summary OR of 0.42 (95% CI 0.21 to 0.86) for the risk of major bleeding, significantly favoring the low dose group. Study results were homogeneous (I^2^ = 0%, P = 0.54) (Figure 29).

Figure 29 Forest plot: Total hip replacement, major bleeding, LMWH, low versus high dose

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 4 RCTs of major bleeding with low versus high dose LMWH for total hip replacement. Low dose LMWH included certoparin 3000 IU per day and enoxaparin 40 mg per day (total). High dose LMWH included certoparin 5000 IU per day and enoxaparin 40 to 60 mg per day (total). Pairwise meta-analysis summary OR = 0.42 (95% CI 0.21, 0.86), favoring low dose LMWH, with I-squared = 0% and P heterogeneity = 0.536.

##### Key Question 3 (Dose, THR): Dabigatran

Two RCTs (N=2845) compared different doses (150 mg vs. 220 or 225 mg) of dabigatran.^51, 52^ The studies found no significant difference between the two dose groups regarding major bleeding.

##### Key Question 3 (Dose, THR): Darexaban

Two RCTs (N=835) compared darexaban 15 mg versus 30 mg twice daily.^55, 57^ No significant difference was found in total VTE in the two studies.

Two RCTs (N=801) compared darexaban 30 mg versus 60 mg once daily.^57, 58^ The studies found no significant difference in total VTE, and reported no fatal PEs.

##### Key Question 3 (Dose, THR): Edoxaban

Two RCTs (N=536) compared edoxaban 15 mg and 30 mg once daily.^26, 56^ The two studies found no significant difference in total VTE and major bleeding, and reported no symptomatic PE events. One RCT reported no proximal DVTs and no serious adverse events.^53^ The other found no significant differences in proximal DVTs or in serious adverse events.^59^

##### Key Question 3 (Dose, THR): Enoxaparin

Two RCTs (N=792) compared enoxaparin 40 mg once daily and 30 mg every 12 hours.^73, 74^ The two studies found significantly fewer total DVT in the low dose group, while no significant difference was found in major bleeding.

##### Key Question 3 (Dose, THR): Intermittent Pneumatic Compression

Three RCTs compared three different regimens of mechanical devices (Appendix Table F1). One RCT (N=54) compared IPC with adjusted versus fixed cycling rates reported adherence.^121^ The rate was adjusted every 30 minutes according to the individual refill time of both legs in the first group, while the rate was fixed at 90 cycles per hour in the other group. The study found no significant difference in total DVT, proximal DVT, and adherence between the two groups. During followup, 100 percent of patients received full-time pneumatic compression as scheduled (good adherence) in both groups.

One RCT (N=24) compared IPC with alternate sequential compression versus continuous sequential compression of both legs.^122^ The study found no significant difference in total DVT, and reported no proximal DVT and no symptomatic DVT events.

One RCT (N=423) compared two different IPC devices with different methods of compression (rapid inflation, asymmetrical compression vs. sequential circumferential compression).^123^ The study found significant fewer total DVT with the rapid inflation, asymmetrical compression device, but found no significant difference in total PE, proximal DVT, and 30-day mortality. The study reported no fatal PE, symptomatic DVT, and no fatal bleeding.

#### Key Question 3 (Dose): Total Knee Replacement (TKR)

The results summary table (Table 8) is presented at the end of the TKR section. It includes results for reported comparisons and outcomes from TKR RCTs with at least two studies. The reader should refer to this table for each results section summary even though the table is not repeatedly cited in each section. The reader should also refer to Appendix Table F2 for comparisons evaluated by only one study.

Table 8 Results summary: Total knee replacement, dose comparisons

Comparison (Daily Dose) | Outcome | Studies, N | Patients, N | OR (95% CI), 1^*^ or Summary OR (95% CI) ^†^ | OR (95% CI), 2^*^ | OR (95% CI), 3^*^ | No Events^‡^
DTI: Dabigatran 50, 110, 150, 220 mg | PE, Total | 3 | 1888 | 2.91 (0.12, 71.7) | | | 2 RCTs
| DVT, Total | 3 | 577 | 1.54 (0.83, 2.87) | 1.85 (0.97, 3.54) | 2.08 (1.13, 3.83)
| DVT, Symptomatic | 4 (MA) | 3141 | 1.14 (0.49, 2.65)
| DVT, Proximal | 4 (MA) | 1860 | 1.57 (0.83, 2.96)
| Bleeding, Major | 5 (MA) | 3875 | 0.65 (0.34, 1.24)
| Mortality, 30 day or in-hospital | 3 | 3354 | 0.97 (0.06, 15.5) | 0.98 (0.06, 15.8) | | 1 RCT
| Bleeding, Surgical site/Joint | 2 | 1990 | 0.32 (0.01, 7.95) | 1.48 (0.25, 8.86)
FXaI: Darexaban 15, 30 mg Edoxaban 5, 15, 30, 60 mg Erixaban 0.1, 0.3, 0.5, 1, 2.5, 4, 10 mg TAK-442 20, 40, 80, 160 mg | VTE, Total | 5 (MA) | 1053 | 2.06 ( 1.48, 2.86 )
| DVT, Symptomatic | 4 | 806 | 2.93 (0.12, 73.0) | 3.26 (0.13, 80.9) | 4.37 (0.48, 39.7) | 1 RCT
| DVT, Proximal | 4 (MA) | 779 | 2.51 (0.85, 7.42)
| Bleeding, Major | 4 | 1095 | 0.32 (0.01, 7.84) | 2.2 (0.2, 24.5) | 5.03 (0.24, 106) | 1 RCT
| Mortality, 30 day or in-hospital | 2 | 454 | No estimate | | | 2 RCT
Dabigatran 150 mg vs. Dabigatran 220 mg | PE, Total | 2 | 1626 | 2.91 (0.12, 71.7) | | | 1 RCT
| PE, Fatal | 2 | 1626 | No estimate | | | 2 RCTs
| DVT, Symptomatic | 3 | 2879 | 0.80 (0.27, 2.38) | 2.06 (0.18, 23.1) | 2.92 (0.30, 28.1)
| DVT, Proximal | 2 | 1468 | 1.34 (0.67, 2.68) | 4.60 (0.22, 96.9)
| Bleeding, Major | 3 | 3365 | 0.14 (0.01, 2.79) | 0.87 (0.35, 2.15) | 0.98 (0.28, 3.41)
| Bleeding, Fatal | 3 | 3365 | No estimate | | | 3 RCTs
| Bleeding, Leading to reoperation | 3 | 3365 | 0.32 (0.03, 3.09) | 0.34 (0.01, 8.39) | | 1 RCT
| Bleeding, Surgical site/Joint | 2 | 1990 | 0.32 (0.01, 7.95) | 1.48 (0.25, 8.86)
| Mortality, 30 day or in-hospital | 3 | 3354 | 0.97 (0.06, 15.5) | 0.98 (0.06, 15.8) | | 1 RCT

All outcomes for all pairwise comparisons with data from at least one study. If 3 or fewer randomized controlled trials (RCT) with analyzable data (i.e., at least 1 event per study) then each study’s odds ratio (OR) is listed in ascending order from left to right. If there were ≥4 analyzable studies, then meta-analysis was conducted and summary OR is reported. These are indicated by italics and by MA (meta-analysis) in the study number column. Statistically significant OR estimates are in bold text. The corresponding studies for each analysis can be found in Appendix F.

Other abbreviations: DVT = deep vein thrombosis, PE = pulmonary embolism, VTE = venothromboembolism, mg = milligram.

* If meta-analysis was not conducted (if there were <4 meta-analyzable trials), the individual studies’ results are presented across OR 1, 2, and 3, from lowest to highest. Statistically significant estimates are in bold. OR <1 favor the first intervention (e.g., for DTI, OR = 2.91 favors higher dose).

† Summary odds ratios (from meta-analysis) are italicized. Statistically significant estimates are in bold.

‡ Number of RCTs with no events in both arms.

##### Key Question 3 (Dose, TKR): DTI

###### Total DVT

Three RCTs^52, 65, 124^ (N=577) comparing high versus doses of DTIs (dabigatran 150 mg daily vs. 220 mg daily) reported on total DVT. Two studies showed nonsignificant differences between groups (range of ORs 1.54 [95% CI 0.83 to 2.87] to 1.85 [95% CI 0.97 3.54]), while one study found significantly increased risk in the low dose group (OR=2.08, 95% CI 1.13 to 3.83).

###### Symptomatic DVT

Four RCTs^65, 91, 92, 124^ (N=3141) reported symptomatic DVT for the comparison of low versus high doses of DTI (0.4 to 1.6% in low dose, 0.1 to 1.2% in high dose), as elaborated in Figure 30 and Table 8. The event rate was higher in the low dose group in two studies.^65, 91^ No difference was shown between the two groups by meta-analysis of the four RCTs (summary OR=1.14, 95% CI 0.49 to 2.65). The study results were homogeneous (I^2^=0%, P value=0.71) (Figure 30). Because of the relative rarity of the outcome (generally <1%), meta-analysis was conducted with Peto’s fixed effect model; sensitivity analysis with the Mantel-Haenszel method yielded similar results.

Figure 30 Forest plot: Total knee replacement, symptomatic deep vein thrombosis, DTI, low versus high dose

Forest plot of randomized controlled trials with calculated Peto odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with Peto fixed effect model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: DTI = direct thrombin inhibitor, PMID = PubMed identifier.

Random effects model meta-analysis of 4 RCTs of symptomatic DVT with low versus high dose DTI for total knee replacement. Low dose DTI included dabigatran 110 to 150 mg daily. High dose DTI was dabigatran 220 mg daily in all studies. Pairwise meta-analysis summary OR = 1.14 (95% CI 0.49, 2.65), nominally favoring high dose DTI, with I-squared = 0% and P heterogeneity = 0.713.

###### Proximal DVT

Four RCTs^52, 65, 92, 124^ (N=1860) comparing low versus high doses of DTI reported proximal DVT (1.7 to 3.2% in low dose, 0% to 2.3% in high dose), as elaborated in Figure 31 and Table 8. The rate of proximal DVT was higher in the low dose group in all four studies. Meta-analysis of the four RCTs yielded a nonsignificant difference between the two dose groups (summary OR=1.57, 95% CI 0.83 to 2.96). The study results were homogeneous (I^2^=0%, P value=0.72) (Figure 31).

Figure 31 Forest plot: Total knee replacement, proximal deep vein thrombosis, DTI, low versus high dose

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: DTI = direct thrombin inhibitor, PMID = PubMed identifier.

Random effects model meta-analysis of 4 RCTs of proximal DVT with low versus high dose DTI for total knee replacement. Low dose DTI included dabigatran 100 to 150 mg daily (total). High dose DTI included dabigatran 220 to 300 mg daily (total) in all studies. Pairwise meta-analysis summary OR = 1.57 (95% CI 0.83, 2.96), nominally favoring high dose DTI, with I-squared = 0% and P heterogeneity = 0.72.

###### Other VTE

One RCT comparing different doses of DTI found no significant difference in total VTE between the two dose groups. Three RCTs^65, 91, 124^ reported on total PE for the comparison of low versus high dose of DTI (N=1888). Two studies reported no PE events, and one study found no significant difference between groups (OR=2.91, 95% CI 0.12 to 71.7). Two studies reported no fatal PE in either comparison groups.^65, 91^

###### Major Bleeding

Five RCTs (N=3875) reported major bleeding for the comparison of low versus high doses for DTI (0% to 1.3% in low dose, 0.6 to 4.8% in high dose), as elaborated in Figure 32 and Table 8.^52, 65, 91, 92, 124^ Three RCTs^52, 92, 124^ had a lower rate in the low dose group. No significant difference was shown for the risk of major bleeding between the two doses by meta-analysis of the five RCTs (summary OR=0.65, 95% CI 0.34 to 1.24). Study results were homogeneous (I^2^ = 0%, P = 0.43) (Figure 32).

Figure 32 Forest plot: Total knee replacement, major bleeding, DTI, low versus high dose

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: DTI = direct thrombin inhibitor, PMID = PubMed identifier.

Random effects model meta-analysis of 5 RCTs of major bleeding with low versus high dose DTI for total knee replacement. Low dose DTI included dabigatran 100 to 150 mg daily (total). High dose DTI included dabigatran 220 to 300 mg daily (total) in all studies. Pairwise meta-analysis summary OR = 0.65 (95% CI 0.34, 1.24), nominally favoring low dose DTI, with I-squared = 0% and P heterogeneity = 0.426.

###### Adverse Events

Four RCTs^65, 91, 92, 125^ (N=3354) that compared DTIs of difference doses (dabigatran 150 mg daily vs. 220 mg daily) reported 30-day or in-hospital mortality; one reported no events, and the other two found no significant difference between the two dose groups (range of ORs 0.97 [95% CI 0.06 to 15.5] to 0.98 [95% CI 0.06 to 15.8]). Two RCTs (N=1990) that reported surgical site or joint bleeding found no significant difference between groups (range of ORs 0.32 [95% CI 0.01 to 7.95] to 1.48 [95% CI 0.25 to 8.86]).^92, 125^ One RCT reported no wound infection in either dose groups.^124^

##### Key Question 3 (Dose, TKR): FXaI

###### Total VTE

Five RCTs (N=1053) that examined relative effectiveness of low versus high doses of FXaI reported total VTE (15.3 to 28.8% in low dose, 8.8 to 15.5% in high dose), as elaborated in Figure 33 and Table 8.^55, 99, 100, 126, 127^ Patients who received FXaI at high doses had a lower rate of VTE in all the RCTs, which was statistically significant in two.^100, 126^ Meta-analysis of the five RCTs yielded a summary OR of 2.06 (95% CI 1.48 to 2.86) for the risk of total VTE, significantly favoring the high dose group. Study results were homogeneous (I^2^ = 0%, P = 0.92) (Figure 33).

Figure 33 Forest plot: Total knee replacement, total venothromboembolism, FXaI, low versus high dose

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: FXaI = factor Xa inhibitor, PMID = PubMed identifier, VTE = venous thromboembolism.

Random effects model meta-analysis of 5 RCTs of total VTE with low versus high dose FXaI for total knee replacement. Low dose FXaI included eribaxaban 0.5 mg daily, edoxaban 15 mg daily, darexaban 30 mg daily (total), and TAK-442 80 mg daily (total). High dose FXaI included eribaxaban 2.5 mg daily, edoxaban 30 mg daily, darexaban 60 mg daily (total), and TAK-442 160 mg daily (total). Pairwise meta-analysis summary OR = 2.06 (95% CI 1.48, 2.86), favoring high dose FXaI, with I-squared = 0% and P heterogeneity = 0.921.

###### Symptomatic DVT

Four RCTs (N=802) assessing low versus high doses of FXaI reported the outcome of symptomatic DVT (1.0% to 3.6% in low dose, 0% to 0.8% in high dose).^55, 99, 100, 126^ One RCT reported no events; the other three had a lower rate in the high dose group (range of ORs 2.93 [95% CI 0.12 to 73.0] to 4.38 [95% CI 0.48 to 39.7]).

###### Proximal DVT

Four RCTs (N=784) that assessed low versus high doses of FXaI reported proximal DVT (0% to 6.0% in low dose, 0.8 to 1.8% in high dose), as elaborated in Figure 34 and Table 8.^55, 99, 100, 126^ The rate was lower in the high dose group in three RCTs.^55, 99, 100^ Meta-analysis of the four RCTs yielded no significant difference for the risk of proximal DVT between the two doses (summary OR=2.51, 95% CI 0.85 to 7.42). Study results were homogeneous (I^2^ = 0%, P = 0.54) (Figure 34).

Figure 34 Forest plot: Total knee replacement, proximal DVT, FXaI, low versus high dose

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: DVT = deep vein thrombosis, FXaI = factor Xa inhibitor, PMID = PubMed identifier.

Random effects model meta-analysis of 4 RCTs of proximal DVT with low versus high dose FXaI for total knee replacement. Low dose FXaI included eribaxaban 0.5 mg daily, edoxaban 15 mg daily, darexaban 30 mg daily (total), and TAK-442 80 mg daily (total). High dose FXaI included eribaxaban 2.5 mg daily, edoxaban 30 mg daily, darexaban 60 mg daily (total), and TAK-442 160 mg daily (total). Pairwise meta-analysis summary OR = 2.51 (95% CI 0.85, 7.42), nominally favoring high dose FXaI, with I-squared = 0% and P heterogeneity = 0.536.

###### Major Bleeding

Four RCTs (N=1095) that compared low versus high doses of FXaI reported major bleeding (0% to 1.2% in low dose, 0% to 1.1% in high dose).^55, 99, 100, 126^ One study reported no events; the rate was lower in the high dose group in two RCTs^99, 100^ but lower in one RCT (range of ORs 0.32 [95% CI 0.01 to 7.84 to 5.03 [95% CI 0.24 to 105]).^55^

###### Other Adverse Events

Two RCTs (N=454) that compared different doses of FXaIs reported no 30-day or in-hospital mortality in either arms.^55, 127^

##### Key Question 3 (Dose, TKR): Dabigatran

Three RCTs (N=3365) compared dabigatran 150 mg daily and 220 mg daily.^65, 91, 92^ Two studies reported total PEs, but one had no PE events; the other found no significant difference in PE events. Two studies reported no fatal PE events. The three RCTs found no significant difference in symptomatic DVT (range of ORs 0.80 [95% CI 0.27 to 2.38] to 2.92 [95% CI 0.30 to 28.1]). Two studies found no significant difference in proximal DVT.

The three RCTs found no significant difference in major bleeding (range of ORs 0.14 [95% CI 0.01 to 2.79] to 0.98 [95% CI 0.28 to 3.41]), and reported no fatal bleeding. The three studies reported bleeding leading to reoperation, but one had no such events; the remaining two found no significant differences. The three studies also reported 30-day mortality, with no mortality in one and no significant difference in two.

##### Key Question 3 (Dose, TKR): Edoxaban

One RCT^56^ comparing high versus low doses of edoxaban reported adherence. At 11 to 14 days of followup, 100 percent of patients were adherent to their prescriptions in both dose groups.

#### Key Question 3 (Dose): Hip Fracture Surgery

None of the studies of HFx surgery compared different intervention doses or regimens.

### Key Question 3: Different Treatment Durations

#### Key Question 3 (Duration): Total Hip Replacement

The results summary table (Table 9) includes results for reported comparisons and outcomes from THR RCTs. The reader should refer to this table for each results section summary even though the table is not repeatedly cited in each section. NRCS are summarized in Appendix Table F4

Table 9 Results summary: Total hip replacement, duration comparisons

Comparison | Outcome | Studies, N | Patients, N | OR (95% CI), 1^*^ or Summary OR (95% CI) ^†^ | OR (95% CI), 2^*^ | OR (95% CI), 3^*^ | No Events^‡^
FXaI, short vs. long duration | DVT, Total | 1 | 40 | No estimate | | | 1 RCT
LMWH, short vs. long duration | VTE, Symptomatic | 2 | 697 | 3.46 (1.94, 6.17) | 5.33 (1.14, 24.8)
| PE, Total | 5 (MA) | 1128 | 2.35 (0.83, 6.62) | | | 1 RCT
| PE, Fatal | 4 | 1087 | 3.17 (0.13, 78.7) | | | 3 RCTs
| DVT, Total | 6 (MA) | 1308 | 2.87 ( 2.08, 3.96 )
| DVT, Symptomatic | 3 | 521 | 0.53 (0.15, 1.81) | 0.95 (0.06, 16.3) | 4.20 (0.87, 20.2)
| DVT, Proximal | 5 (MA) | 1300 | 2.94 ( 1.62, 5.33 )
| Bleeding, Major | 3 | 895 | 3.00 (0.12, 74.3) | | | 2 RCTs
| Bleeding, Fatal | 4 | 1135 | No estimate | | | 4 RCTs
| Mortality, 30 day or in-hospital | 3 | 873 | 1.02 (0.06, 16.5) | | | 2 RCTs
| Return to OR, bleeding or infection | 1 | 41 | 5.26 (0.24, 117)
VKA, short vs. long duration | VTE, Symptomatic | 1 | 360 | 3.25 (0.87, 12.2)
| PE, Total | 1 | 360 | 3.15 (0.13, 77.9)
| PE, Fatal | 1 | 360 | No estimate | | | 1 RCT
| DVT, Total | 1 | 360 | 2.87 (0.75, 11.0)
| DVT, Symptomatic | 1 | 360 | 1.58 (0.26, 9.56)
| DVT, Proximal | 1 | 360 | 3.17 (0.33, 30.8)
| Bleeding, Major | 1 | 360 | 0.35 (0.01, 8.56)
| Bleeding, Fatal | 1 | 360 | No estimate | | | 1 RCT

All outcomes for all pairwise comparisons with data from at least one study. If 3 or fewer randomized controlled trials (RCT) with analyzable data (i.e., at least 1 event per study) then each study’s odds ratio (OR) is listed in ascending order from left to right. If there were ≥4 analyzable studies, then meta-analysis was conducted and summary OR is reported. These are indicated by italics and by MA (meta-analysis) in the study number column. Statistically significant OR estimates are in bold text. The corresponding studies for each analysis can be found in Appendix F.

Other abbreviations: DVT = deep vein thrombosis, PE = pulmonary embolism, VTE = venothromboembolism, FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, VKA = vitamin K antagonist, Short vs. Long = short therapeutic duration versus long duration.

* If meta-analysis was not conducted (if there were <4 meta-analyzable trials), the individual studies’ results are presented across OR 1, 2, and 3, from lowest to highest. Statistically significant estimates are in bold. OR <1 favor the first intervention (e.g., for LMWH, OR = 3.46 favors long duration).

† Summary odds ratios (from meta-analysis) are italicized. Statistically significant estimates are in bold.

‡ Number of RCTs with no events in both arms.

##### Key Question 3 (Duration, THR): Various Anticoagulation Interventions

Two NRCSs reported on total VTE in patients undergoing THR (Appendix Table F4). Both evaluated different durations of treatment in large cohorts who had received a variety of anticoagulation types. Wells 2010 reported no significant differences among anticoagulation durations of 14, 21, and 28 days that favored longer prophylaxis.^40^ Pedersen 2015 reported slightly fewer VTE events with anticoagulation of more than 28 days than with short (0 to 6 days) or standard (7 to 27 days) duration. Once adjusted for age, sex, Charlson Comorbidity Index score, anticoagulation drug and use of acetylsalicylic acid, other antiplatelet drugs, and warfarin use prior to THR, no significant differences were found between short and extended duration (>28 days; HR 0.83, 95% CI 0.52 to 1.31) or between standard and extended durations (HR 0.82, 95% CI 0.50 to 1.33).^30^

In an NRCS, Wells 2010 compared PE rates across timepoints of varied anticoagulant interventions (Appendix Table F4). The NRCS reported no significant differences among anticoagulation durations of 14, 21, and 28 days.^40^

In a NRCS, Wells 2010 compared DVT rates across timepoints of varied anticoagulant interventions.^40^ The NRCS reported no significant differences among anticoagulation durations of 14, 21, and 28 days (Appendix Table F4).

##### Key Question 3 (Duration, THR): FXaI

One RCT (N=40) compared rivaroxaban given for short and long durations,^59^ but reported no total DVTs.

##### Key Question 3 (Duration, THR): LMWH

Six RCTs (N=1463) compared LMWH of short versus long durations.^128–133^

###### Total PE

Five RCTs (N=1128) reported total PE for the comparison of short versus long therapeutic durations of LMWH (0% to 6.6% for short duration, 0% to 3.6% for long duration), as elaborated in Figure 35.^128–132^ One RCT reported no occurrence of PE in either comparison group.^130^ Patients who received LMWH for long duration had a lower event rate in the remaining four RCTs. Meta-analysis of the four RCTs found an almost-significant difference between the two treatment durations for the risk of total PE (summary OR=2.35, 95% CI 0.83 to 6.62), favoring long duration (Figure 35). Study results were homogeneous (I^2^ = 0%, P = 0.94).

Figure 35 Forest plot: Total hip replacement, total pulmonary embolism, LMWH, short versus long duration

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: LMWH = low molecular weight heparin, PE = pulmonary embolism, PMID = PubMed identifier.

Random effects model meta-analysis of 5 RCTs of total PE with short versus long duration LMWH for total hip replacement. Short duration LMWH was given through hospital discharge or up to 7 to 10 days. Long duration LMWH was given 21 days post-discharge or up to 35 days total. Pairwise meta-analysis summary OR = 2.35 (95% CI 0.83, 6.62), nominally favoring long duration LMWH, with I-squared = 0% and P heterogeneity = 0.937.

###### Total DVT

Six RCTs (N=1308) reported total DVT and examined short versus long therapeutic durations of LMWH (11.8% to 32.8% for short duration, 4.4 to 16.0% for long duration).^128–133^ Patients who received LMWH of long duration had a lower event rate in all the RCTs, statistically significantly so in four.^128–131^ Meta-analysis of the six RCTs yielded a summary OR of 2.87 (95% CI 2.08 to 3.96) for the risk of total DVT, significantly favoring the long duration group. Study results were homogeneous (I^2^ = 0%, P = 0.96) (Figure 36).

Figure 36 Forest plot: Total hip replacement, total deep vein thrombosis, LMWH, short versus long duration

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: DVT = deep vein thrombosis, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 6 RCTs of total DVT with short versus long duration LMWH for total hip replacement. Short duration LMWH was given through hospital discharge or up to 5 to 10 days (or not defined). Long duration LMWH was given 21 days post-discharge or up to 35 days total (or described as “extended”). Pairwise meta-analysis summary OR = 2.87 (95% CI 2.08, 3.96), favoring long duration LMWH, with I-squared = 0% and P heterogeneity = 0.955.

###### Proximal DVT

Five RCTs (N=1300) reported proximal DVT for the comparison of short versus long therapeutic durations of LMWH (5.0% to 21.4% for short duration, 0.9% to 8.8% for long duration).^128–131, 133^ The rate was lower in the long duration group in all the RCTs, which was statistically significant in two.^128, 129^ Meta-analysis of the five RCTs yielded a summary OR of 2.94 (95% CI 1.62 to 5.33) for the risk of proximal DVT, significantly favoring the long duration group. Study results were homogeneous (I^2^ = 38%, P = 0.19) (Figure 37).

Figure 37 Forest plot: Total hip replacement, proximal deep vein thrombosis, LMWH, short versus long duration

Forest plot of randomized controlled trials with calculated odds ratio and 95% confidence interval (CI) based on numbers of events (n) and sample sizes (N), with random effects model summary estimate (Pairwise meta-analysis [MA] result). I^2 = percentage of total variation across studies due to heterogeneity; P value = chi-square P value for heterogeneity.

Other abbreviations: DVT = deep vein thrombosis, LMWH = low molecular weight heparin, PMID = PubMed identifier.

Random effects model meta-analysis of 5 RCTs of proximal DVT with short versus long duration LMWH for total hip replacement. Short duration LMWH was given through hospital discharge or up to 7 to 10 days (or not defined). Long duration LMWH was given 21 days post-discharge or up to 35 days total (or described as “extended”). Pairwise meta-analysis summary OR = 2.94 (95% CI 1.62, 5.33), favoring long duration LMWH, with I-squared = 38% and P heterogeneity = 0.19.

###### Other VTE Events

Two RCTs found significantly fewer symptomatic VTE in the long duration group.^128, 129^ Four RCTs reported fatal PE; one found no significant difference, and three reported no incidents of fatal PE.^128–131^ Three RCTs found no significant difference in symptomatic DVT.^129, 131, 132^

###### Adverse Events

Three RCTs reported on major bleeding, with no significant difference in one and no incidents of major bleeding in two studies.^128, 130, 133^ Four studies reported no fatal bleeding. Three RCTs reported 30-day mortality; one found no significant difference, and two reported no mortality.^128, 130, 131^ One study found no significant difference in reoperation due to bleeding or infection.^132^

###### Adherence

No study reported on adherence

##### Key Question 3 (Duration, THR): VKA

One RCT (N=360) compared short versus long therapeutic durations of warfarin.^134^ The study found no significant difference in symptomatic VTE, total PE, total DVT, symptomatic DVT, proximal DVT, and major bleeding, and reported no fatal PE and no fatal bleeding. The study did not report on adherence.

#### Key Question 3 (Duration): Total Knee Replacement

The results summary table (Table 10) includes results for reported comparisons and outcomes from TKR RCTs. The reader should refer to this table for each results section summary even though the table is not repeatedly cited in each section. As noted, NRCS are summarized in Appendix Table F5.

Table 10 Results summary: Total knee replacement, duration comparisons

Comparison | Outcome | Studies, N | Patients, N | OR (95% CI), 1^*^ or Summary OR (95% CI) ^†^ | OR (95% CI), 2^*^ | OR (95% CI), 3^*^ | No Events^‡^
LMWH, short vs. long duration | VTE, Symptomatic | 1 | 438 | 1.24 (0.77, 2.00)
| PE, Total | 1 | 438 | 4.95 (0.24, 104)
| PE, Fatal | 1 | 438 | No estimate | | | 1 RCT
| DVT, Total | 1 | 438 | 1.24 (0.77, 2.00)
| DVT, Proximal | 1 | 438 | 1.93 (0.84, 4.42)
| Bleeding, Major | 1 | 438 | 2.96 (0.12, 73.0)
| Bleeding, Fatal | 1 | 438 | No estimate | | | 1 RCT
| Mortality, 30 day or in-hospital | 1 | 438 | No estimate | | | 1 RCT

All outcomes for all pairwise comparisons with data from at least one study. If 3 or fewer randomized controlled trials (RCT) with analyzable data (i.e., at least 1 event per study) then each study’s odds ratio (OR) is listed in ascending order from left to right. If there were ≥4 analyzable studies, then meta-analysis was conducted and summary OR is reported. These are indicated by italics and by MA (meta-analysis) in the study number column. Statistically significant OR estimates are in bold text. The corresponding studies for each analysis can be found in Appendix F.

Other abbreviations: DVT = deep vein thrombosis, PE = pulmonary embolism, VTE = venothromboembolism, LMWH = low molecular weight heparin, Short vs. Long = short therapeutic duration versus long duration.

* If meta-analysis was not conducted (if there were <4 meta-analyzable trials), the individual studies’ results are presented across OR 1, 2, and 3, from lowest to highest. Statistically significant estimates are in bold. OR <1 favor the first intervention (e.g., for VTE, Symptomatic, OR = 1.24 favors long duration).

† Summary odds ratios (from meta-analysis) are italicized. Statistically significant estimates are in bold.

‡ Number of RCTs with no events in both arms.

##### Key Question 3 (Duration, TKR): LMWH

One RCT (N=438) compared enoxaparin of short versus long therapeutic durations.^128^ The study found no significant difference in symptomatic VTE, total PE, total DVT, proximal DVT, and major bleeding, and reported no fatal PE, no fatal bleeding, and no 30-day mortality. The study did not report on adherence.

##### Key Question 3 (Duration): Hip Fracture (HFx) Surgery

The results summary table (Table 11) is also presented at the end of the Key Question 3 section. It includes results for reported comparisons and outcomes from HFx surgery RCTs. The reader should refer to this table for each results section summary even though the table is not repeatedly cited in each section. As noted, NRCS are summarized in Appendix Table F6.

Table 11 Results summary: Hip fracture surgery, duration comparisons

Comparison | Outcome | Studies, N | Patients, N | OR (95% CI), 1^*^ or Summary OR (95% CI) ^†^ | OR (95% CI), 2^*^ | OR (95% CI), 3^*^ | No Events^‡^
FXaI, short vs. long duration | VTE, Symptomatic | 1 | 656 | 9.11 (1.15, 72.3)
| PE, Total | 1 | 656 | 6.98 (0.36, 136)
| PE, Fatal | 1 | 656 | 2.97 (0.12, 73.2)
| DVT, Total | 1 | 426 | 35.1 (10.9, 114)
| DVT, Symptomatic | 1 | 656 | 6.02 (0.72, 50.3)
| DVT, Proximal | 1 | 443 | 20.5 (4.86, 86.4)
| Bleeding, Major | 1 | 656 | 0.24 (0.05, 1.16)
| Bleeding, Fatal | 1 | 656 | 1.33 (0.46, 3.89)
| Bleeding, Leading to reoperation | 1 | 656 | 0.99 (0.14, 7.10)
| Bleeding, Surgical site/joint | 1 | 656 | 0.08 (<0.01, 1.34)
| Bleeding, Leading to infection | 1 | 656 | No estimate | | | 1 RCT
LMWH, short vs. long duration | PE, Fatal | 1 | 469 | 5.99 (0.24, 148)
| DVT, Total | 1 | 330 | 5.03 (2.16, 11.7)
| DVT, Proximal | 1 | 394 | 6.23 (1.94, 20.0)
| Bleeding, Major | 1 | 469 | 0.66 (0.03, 16.3)
| Mortality, 30 day or in-hospital (AE) | 1 | 469 | 10.1 (0.48, 211)
| Serious adverse event (study-defined) | 1 | 469 | 2.38 (0.79, 7.21)

All outcomes for all pairwise comparisons with data from at least one study. If 3 or fewer randomized controlled trials (RCT) with analyzable data (i.e., at least 1 event per study) then each study’s odds ratio (OR) is listed in ascending order from left to right. If there were ≥4 analyzable studies, then meta-analysis was conducted and summary OR is reported. These are indicated by italics and by MA (meta-analysis) in the study number column. Statistically significant OR estimates are in bold text. The corresponding studies for each analysis can be found in Appendix F.

Other abbreviations: DVT = deep vein thrombosis, PE = pulmonary embolism, VTE = venothromboembolism, FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, Short vs. Long = short therapeutic duration versus long duration.

* If meta-analysis was not conducted (if there were <4 meta-analyzable trials), the individual studies’ results are presented across OR 1, 2, and 3, from lowest to highest. Statistically significant estimates are in bold. OR <1 favor the first intervention (e.g., for FXaI, OR = 9.11 favors long duration).

† Summary odds ratios (from meta-analysis) are italicized. Statistically significant estimates are in bold.

‡ Number of RCTs with no events in both arms.

##### Key Question 3 (Duration, HFx): FXaI

One RCT (N=656) compared fondaparinux for short and long therapeutic durations.^135^ The study found significantly more frequent symptomatic VTE (OR 9.11, 95% CI 1.15 to 72.3), total DVT (OR 35.1, 95% CI 10.9 to 113.6), and proximal DVT (OR 20.5, 95% 4.86 to 86.4) in the short duration group. No significant differences were found for total PE, fatal PE, and symptomatic DVT.

The study found no significant difference in major bleeding, fatal bleeding, bleeding leading to reoperation, and bleeding at surgical site or joint, and reported no bleeding leading to infection. The study did not report on adherence.

##### Key Question 3 (Duration, HFx): LMWH

One RCT (N=469) compared semuloparin of short versus long durations.^136^ The study found significantly fewer total DVT and proximal DVT in the long duration group. No significant difference was found in fatal PE, major bleeding, 30-day mortality, and serious adverse events. The study did not report on adherence.

## Key Question 4 Comparison of Single Versus Combination Thromboprophylaxis Intervention Classes

Note that network meta-analyses comparing individual interventions (including combination interventions) in regard to total DVT and major bleeds are presented under Key Question 5.

### Key Question 4: Total Hip Replacement

The results summary table (Table 12) includes results for all reported comparisons and outcomes from THR RCTs. The reader should refer to this table for each results section summary even though the table is not repeatedly cited in each section.

Table 12 Results summary: Total hip replacement, single versus combination class comparisons

Comparison | Outcome | Studies, N | OR (95% CI), 1^*^ or Summary OR (95% CI) ^†^ | OR (95% CI), 2^*^ | OR (95% CI), 3^*^ | No Events^‡^
Antiplatelet vs. Antiplatelet+Mechanical Devices | PE, Total | 1 | 0.96 (0.06, 15.5)
| PE, Fatal | 1 | No estimate | | | 1 RCT
| DVT, Proximal | 1 | 15.9 (0.90, 281)
| Bleeding, Fatal | 1 | No estimate | | | 1 RCT
| Mortality, 30 day or in-hospital | 1 | 0.32 (0.01, 7.85)
LMWH vs. LMWH+Antiplatelet | VTE, Symptomatic | 1 | 5.80 (0.70, 48.4)
| PE, Fatal | 1 | No estimate | | | 1 RCT
| PE, Symptomatic | 1 | 6.73 (0.35, 131)
| DVT, Symptomatic | 1 | 2.88 (0.30, 27.8)
| DVT, Proximal | 1 | 1.91 (0.17, 21.2)
| Bleeding, Major | 1 | 2.89 (0.12, 71.3)
| Bleeding, Surgical site/joint | 1 | 1.21 (0.32, 4.52)
| Infection, Wound | 1 | 0.80 (0.34, 1.87)
LMWH vs. LMWH+DTI | DVT, Total | 1 | 2.36 (0.55, 10.2)
LMWH vs. LMWH+FXaI | DVT, Total | 1 | 1.27 (0.35, 4.57)
LMWH vs. LMWH+Mechanical Devices | PE, Total | 1 | No estimate | | | 1 RCT
| DVT, Total | 3 | 1.80 (0.62, 5.27) | 2.25 (0.20, 25.4) | 22.7 (1.27, 407)
| DVT, Proximal | 2 | 2.74 (0.75, 10.1) | | | 1 RCT
| Bleeding, Fatal | 1 | No estimate | | | 1 RCT
| Mortality, 30 day or in-hospital | 1 | No estimate | | | 1 RCT
Mechanical Device vs. Antiplatelet+Mechanical Device | PE, Total | 1 | 0.32 (0.01, 7.87)
| DVT, Proximal | 1 | 1.25 (0.44, 3.55)
Mechanical Device vs. Mechanical Device+UFH+Antiplatelet | DVT, Total | 1 | No estimate | | | 1 RCT
| DVT, Symptomatic | 1 | No estimate | | | 1 RCT
| DVT, Proximal | 1 | No estimate | | | 1 RCT
| Bleeding, Fatal | 1 | No estimate | | | 1 RCT
| Mortality, 30 day or in-hospital | 1 | No estimate | | | 1 RCT
Mechanical Device vs. Mechanical Device+VKA | PE, Total | 1 | No estimate | | | 1 RCT
| DVT, Proximal | 1 | 1.41 (0.47, 4.19)
UFH vs. UFH+LMWH | DVT, Total | 1 | 0.62 (0.05, 7.00)
UFH+Antiplatelet vs. UFH+Antiplatelet+Mechanical Device | DVT, Total | 1 | 13.7 (0.71, 262)
| DVT, Symptomatic | 1 | 7.93 (0.39, 162)
| DVT, Proximal | 1 | 13.7 (0.71, 262)
| Bleeding, Fatal | 1 | No estimate | | | 1 RCT
| Mortality, 30 day or in-hospital | 1 | No estimate | | | 1 RCT

All outcomes for all pairwise comparisons with data from at least one study. If 3 or fewer randomized controlled trials (RCT) with analyzable data (i.e., at least 1 event per study) then each study’s odds ratio (OR) is listed in ascending order from left to right. If there were ≥4 analyzable studies, then meta-analysis was conducted and summary OR is reported. These are indicated by italics and by MA (meta-analysis) in the study number column. Statistically significant OR estimates are in bold text. The corresponding studies for each analysis can be found in Appendix F.

Other abbreviations: DVT = deep vein thrombosis, PE = pulmonary embolism, VTE = venothromboembolism, Antiplatelet = antiplatelet agent, LMWH = low molecular weight heparin, DTI = direct thrombin inhibitor, FXaI = factor Xa inhibitor, UFH = unfractionated heparin, VKA = vitamin K antagonist.

* If meta-analysis was not conducted (if there were <4 meta-analyzable trials), the individual studies’ results are presented across OR 1, 2, and 3, from lowest to highest. Statistically significant estimates are in bold. OR <1 favor the first intervention (e.g., for Antiplatelet vs. Antiplatelet+Mechanical Devices, OR = 0.96 (marginally) favors antiplatelet).

† Summary odds ratios (from meta-analysis) are italicized. Statistically significant estimates are in bold.

‡ Number of RCTs with no events in both arms.

#### Key Question 4 (THR): Antiplatelet Drug Versus Combination Antiplatelet Drug and Mechanical Device

One RCT compared an antiplatelet drug alone versus combination antiplatelet drug and mechanical device.^137^ The study found no significant difference in total PEs and no occurrences of fatal PE. The study also found no significant difference in proximal DVTs.

The study reported no episodes of fatal bleeding and found no significant difference in 30-day mortality between arms.

The study did not evaluate adherence.

#### Key Question 4 (THR): LMWH Versus Combination LMWH and Antiplatelet Drug

One RCT compared LMWH to a combination of LMWH and an antiplatelet drug.^138^ The study found no significant differences in VTE outcomes, including symptomatic VTE, symptomatic PE, symptomatic DVT, and proximal DVT. No patient had a fatal PE.

The study also found no significant difference in major bleeding, surgical site bleeding, or wound infection.

The study did not evaluate adherence.

#### Key Question 4 (THR): LMWH Versus Combination LMWH and DTI

One RCT compared LMWH to a combination of LMWH and DTI.^45^ The study reported only no significant difference in total DVT. Adverse events and adherence were not reported.

#### Key Question 4 (THR): LMWH Versus Combination LMWH and FXaI

The same RCT compared LMWH to a combination of LMWH and FXaI.^45^ The study reported only that there was no significant difference in total DVT. Adverse events and adherence were not reported.

#### Key Question 4 (THR): LMWH Versus Combination LMWH and Mechanical Device

Three RCTs compared LMWH to a combination of LMWH and a mechanical device.^139–141^ One of the studies reported no PEs. One study found significantly decreased risk of total DVT in the combined intervention group (OR=22.7, 95% CI 1.27 to 407), while the other two studies found no significant difference between groups. Regarding proximal DVT, one study had no such events and the other found no significant difference between arms.

One study reported no fatal bleeding or 30-day mortality. Neither study evaluated adherence.

#### Key Question 4 (THR): Mechanical Device Versus Combination Mechanical Device and Antiplatelet Drug

One RCT compared a mechanical device alone versus a combination of a mechanical device and an antiplatelet drug.^44^ The study found no significant difference in total PE or proximal DVTs. Adverse events and adherence were not reported.

#### Key Question 4 (THR): Mechanical Device Versus Combination Mechanical Device and Antiplatelet Drug and UFH

One RCT compared a mechanical device alone versus a combination of a mechanical device, an antiplatelet drug, and UFH.^142^ The study found no occurrences of DVT (total, symptomatic, or proximal), fatal bleeding, or 30-day mortality. The study did not report on adherence.

#### Key Question 4 (THR): Mechanical Device Versus Combination Mechanical Device and VKA

One RCT compared a mechanical device versus a combination of a mechanical device and a VKA.^44^ The study had no PEs and found no significant difference in proximal DVTs. Adverse events and adherence were not reported.

#### Key Question 4 (THR): UFH Versus Combination UFH and LMWH

One RCT compared UFH alone versus combination UFH and LMWH.^143^ The study reported only no significant difference in total DVT. Adverse events and adherence were not reported.

#### Key Question 4 (THR): Combination UFH and Antiplatelet Drug Versus Combination UFH and Antiplatelet Drug and Mechanical Device

One RCT compared combination UFH and an antiplatelet drug with the further addition of a mechanical device.^142^ The study found no significant differences in total DVT, symptomatic DVT, and proximal DVT.

The study reported no fatal bleeding or 30-day mortality. It did not evaluate adherence.

### Key Question 4: Total Knee Replacement

The results summary table (Table 13) includes results for all reported comparisons and outcomes from THR RCTs. The reader should refer to this table for each results section summary even though the table is not repeatedly cited in each section. Where data are summarized only in appendix tables or are summarized in figures, these are cited.

Table 13 Results summary: Total knee replacement, single versus combination class comparisons

Comparison | Outcome | Studies, N | OR (95% CI), 1^*^ or Summary OR (95% CI) ^†^ | OR (95% CI), 2^*^ | OR (95% CI), 3^*^ | No Events^‡^
Antiplatelet vs. Antiplatelet+Mechanical Device | DVT, Total | 1 | 5.45 (2.09, 14.2)
| DVT, Proximal | 1 | 13.2 (0.71, 248)
| Bleeding, Major | 1 | No estimate | | | 1 RCT
LMWH vs. LMWH+FEI | PE, Total | 1 | No estimate | | | 1 RCT
| DVT, Total | 1 | 3.19 (1.48, 6.90)
| DVT, Symptomatic | 1 | No estimate | | | 1 RCT
| DVT, Proximal | 1 | 2.88 (0.29, 28.3)
| Bleeding, Major | 1 | No estimate | | | 1 RCT
LMWH vs. LMWH+Mechanical Device | VTE, Total | 1 | No estimate | | | 1 RCT
| PE, Total | 1 | 0.99 (0.06, 16.1)
| PE, Symptomatic | 1 | No estimate | | | 1 RCT
| DVT, Total | 3 | 1.65 (0.51, 5.28) | 2.03 (0.43, 9.44) | | 1 RCT
| DVT, Proximal | 1 | No estimate | | | 1 RCT
| Bleeding, Fatal | 1 | No estimate | | | 1 RCT
| Mortality, 30 day or in-hospital | 1 | No estimate | | | 1 RCT
UFH vs. UFH+LMWH | DVT, Total | 1 | 0.15 (0.02, 1.31)
FXaI vs. FXaI+Mechanical Device | VTE, Total | 1 | 0.48 (0.20, 1.13)
| VTE, Symptomatic | 1 | 0.30 (0.03, 2.97)
| PE, Total | 1 | No estimate | | | 1 RCT
| PE, Fatal | 1 | No estimate | | | 1 RCT
| PE, Symptomatic | 1 | No estimate | | | 1 RCT
| DVT, Total | 1 | 0.48 (0.20, 1.13)
| DVT, Symptomatic | 1 | 0.30 (0.03, 2.97)
| DVT, Proximal | 1 | No estimate | | | 1 RCT
| Bleeding, Major | 1 | 0.93 (0.18, 4.81)
| Bleeding, Fatal | 1 | No estimate | | | 1 RCT
| Bleeding, Surgical site/joint | 1 | 0.93 (0.13, 6.85)
LMWH+Mechanical Device vs. Antiplatelet+Mechanical Device | PE, Total | 1 | 0.32 (0.01, 7.83)
| DVT, Total | 1 | 0.75 (0.39, 1.46)
| DVT, Proximal | 1 | 1.62 (0.38, 6.90)
| Adherent/Compliant | 1 | 0.06 (<0.01, 1.01)

All outcomes for all pairwise comparisons with data from at least one study. If 3 or fewer randomized controlled trials (RCT) with analyzable data (i.e., at least 1 event per study) then each study’s odds ratio (OR) is listed in ascending order from left to right. If there were ≥4 analyzable studies, then meta-analysis was conducted and summary OR is reported. These are indicated by italics and by MA (meta-analysis) in the study number column. Statistically significant OR estimates are in bold text. The corresponding studies for each analysis can be found in Appendix F.

Other abbreviations: DVT = deep vein thrombosis, PE = pulmonary embolism, VTE = venothromboembolism, Antiplatelet = antiplatelet agent, LMWH = low molecular weight heparin, FEI = factor VIII inhibitor, UFH = unfractionated heparin.

* If meta-analysis was not conducted (if there were <4 meta-analyzable trials), the individual studies’ results are presented across OR 1, 2, and 3, from lowest to highest. Statistically significant estimates are in bold. OR <1 favor the first intervention (e.g., for Antiplatelet vs. Antiplatelet+Mechanical Device, OR = 5.45 favors Antiplatelet+Mechanical Device).

† Summary odds ratios (from meta-analysis) are italicized. Statistically significant estimates are in bold.

‡ Number of RCTs with no events in both arms.

#### Key Question 4 (TKR): Antiplatelet Drug Versus Combination Antiplatelet Drug and Mechanical Device

One RCT compared an antiplatelet drug alone versus a combination of an antiplatelet drug and a mechanical device.^144^ The study found significantly more total DVTs in the antiplatelet drug alone arm, but no significant difference in proximal DVT (although still favoring the combination arm).

The study had no episodes of major bleeding and did not report on adherence.

#### Key Question 4 (TKR): FXaI Versus Combination FXaI and Mechanical Device

One RCT (N=120) compared FXaI with combined FXaI and mechanical device. It found no significant differences in total VTE, symptomatic VTE, total DVT, symptomatic DVT, major bleeding, or surgical site or joint bleeding between the two comparison groups. The study reported no PE, proximal DVT, or fatal bleeding in either groups.^108^

#### Key Question 4 (TKR): Combination LMWH Drug and Mechanical Device Versus Combination Antiplatelet and Mechanical Device

One RCT (N=275) compared combination of LMWH and mechanical device versus combination of antiplatelet and mechanical device. No significant differences were found in total DVT, proximal DVT, or total PE between the two combined interventions. The study reported rates of good adherence (to drugs only) higher than 90% in both groups.^90^

#### Key Question 4 (TKR): LMWH Versus Combination LMWH and FEI

One RCT compared LMWH alone versus combination LMWH and FEI.^145^ The study found that significantly more patients in the LMWH alone arm had total DVT. The studies reported no PE or episodes of symptomatic DVT. There was no significant difference in proximal DVT. The study had no episodes of major bleeding and did not report on adherence.

#### Key Question 4 (TKR): LMWH Versus Combination LMWH and Mechanical Device

Four RCTs compared LMWH and combination LMWH and a mechanical device;^139, 141, 146, 147^ however, events were rare across the studies. One study reported no total VTE events, another found no significant difference in total PEs, while the third reported no symptomatic PEs. Total DVT was reported by three studies, one with no events and two with no significant difference between arms. Proximal DVT events also did not occur in one study.

One RCT reported no fatal bleeding events or 30-day mortality. No study reported on adherence.

#### Key Question 4 (TKR): UFH Versus Combination UFH and LMWH

One RCT compared UFH alone and UFH combined with LMWH.^143^ No significant difference was reported in total DVTs. No adverse event or adherence data were reported.

### Key Question 4: Hip Fracture Surgery

No studies compared single class and combination class interventions after HFx surgery.

## Key Question 5 Network Meta-Analyses Across Classes of Thromboprophylaxis Interventions

For all three major orthopedic surgeries, network meta-analyses that included more than sparse connections could be constructed only for total DVT and major bleeding. Sensitivity analyses with informative priors, added due to network sparseness, yielded similar findings (Appendix G). Due to incomplete and selective outcome reporting by most articles, other outcomes were too sparsely populated to allow interpretable networks (networks for symptomatic DVT and total PE are provided in Appendix H). Overall, network meta-analysis findings were consistent with direct, pairwise comparisons, with the caveat that they pertain only to total DVT and major bleeding.

When interpreting the findings of the network meta-analyses, it is important to recognize that the exact ranking of interventions is susceptible to change with the addition of more studies. Interventions with relatively sparse data are likely to have imprecise rankings (i.e., to have flat rank graphs with similar likelihood across a range of ranks); see rank graphs for each network. Furthermore, while the pairwise comparisons with a network yield summary estimates and confidence intervals, the ranking of interventions is not supported by evaluations of statistical significance. Conclusions on total DVT may not translate to other, clinically significant, VTE outcomes, as suggested by the lack of correlation across studies between rates of total DVT and total PE.

### Key Question 5: Total Hip Replacement

#### Key Question 5 (THR): Deep Vein Thrombosis, Total

##### Comparison of Classes

There were 53 RCTs that evaluated interventions in at least two classes and reported total DVT after THR.^24, 43, 46–50, 52, 54–56, 58, 60–64, 66–76, 78, 80–86, 120, 139–141, 148–159^ The RCTs compared pairs of intervention classes (47 RCTs) or triplets of intervention classes (3 RCTs). Across this study set, 10 classes were evaluated (antiplatelet drug [aspirin], DTI, FEI, FXaI, LMWH, LMWH plus mechanical device, mechanical devices, UFH, VKA, placebo). Of the 45 possible pairwise comparisons, 17 are covered by direct study comparisons. Figure 38 illustrates the topology of the network. LMWH was the most common comparator, being directly compared with seven other intervention classes, most frequently with FXaI (9 RCTs), UFH (10 RCTs) and placebo (12 RCTs). Antiplatelet drug was directly compared with placebo and VKA only; FEI was directly compared with FXaI only.

Figure 38 Network of comparison of intervention classes for total deep vein thrombosis in total hip replacement

Topology map for network meta-analysis of different classes of thromboprophylaxis interventions for total deep vein thrombosis outcome after total hip replacement. Nodes represent different classes of interventions included in the analysis. Lines between nodes indicate the pairs of intervention classes that were compared directly within trials. The thickness of the lines is proportional to the number of trials directly comparing pairs of interventions, as indicated by the associated number.

Abbreviations: DTI = direct thrombin inhibitor, FEI = factor VIII inhibitor, FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin, VKA = vitamin K antagonist.

A topology map of the network meta-analysis of different classes of thromboprophylaxis interventions for total deep vein thrombosis outcome after total hip replacement. Ten classes are displayed including antiplatelet drugs, direct thrombin inhibitors, factor 8 inhibitors, factor 10-a inhibitors, low molecular weight heparin, combined low molecular weight heparin and mechanical devices, mechanical devices, unfractionated heparin, vitamin K antagonists, and placebo. Of the 45 possible pairwise comparisons, 17 are covered by direct study comparisons. Low molecular weight heparin was the most common comparator, being directly compared with 7 other intervention classes, most frequently with factor 10-a inhibitors (9 studies), unfractionated heparin (10 studies) and placebo (12 studies). Antiplatelet drugs were directly compared with placebo and vitamin K antagonists only; factor 8 inhibitors was directly compared with factor 10-a inhibitors only.

Appendix Table F7.1 shows the network meta-analysis pairwise results for all combinations of interventions classes. The statistically significant differences between classes are highlighted here.

- FXaI had a lower odds of DVT compared with
  ○ LMWH (OR=0.601; 95% CrI 0.409 to 0.900)
  ○ UFH (OR=0.387; 95% CrI 0.224 to 0.669)
  ○ VKA (OR=0.404; 95% CrI 0.215 to 0.78)
- DTI had a lower odds of DVT compared with
  ○ UFH (OR=0.437; 95% CrI 0.248 to 0.750)
  ○ VKA (OR=0.455; 95% CrI 0.222 to 0.941)
- LMWH had a lower odds of DVT compared with
  ○ UFH (OR=0.644; 95% CrI 0.434 to 0.934)
- Mechanical Devices had lower odds of DVT versus
  ○ UFH (OR=0.522; 95% CrI 0.270 to 0.962)
  ○ VKA (OR=0.544; 95% CrI 0.299 to 0.968)
- The combination of LMWH plus mechanical device had lower odds of DVT compared with
  ○ Antiplatelet drug (aspirin) (OR=0.242; 95% CrI 0.056 to 0.965)
  ○ DTI (OR=0.289; 95% CrI 0.080 to 0.927)
  ○ FXaI (OR=0.327; 95% CrI 0.094 to 0.999)
  ○ LMWH (OR=0.196; 95% CrI 0.061 to 0.566)
  ○ Mechanical devices (OR=0.241; 95% CrI 0.069 to 0.802)
  ○ UFH (OR=0.126; 95% CrI 0.037 to 0.386)
  ○ VKA (OR=0.132; 95% CrI 0.037 to 0.422)

###### Summary

Overall, the combination of LMWH plus mechanical device had the highest probability of being among the top three intervention classes (99%) to prevent DVT in patients undergoing THR, followed by FXaI (64%). The interventions likely to be among the bottom three interventions were placebo (>99%), UFH (86%), and VKA (80%) (Table 14). The distribution of intervention ranks is provided in Figure 39.

Table 14 Class ranking: Total hip replacement, intervention class comparisons to prevent deep vein thrombosis

| Top 3 Ranks | Bottom 3 Ranks
LMWH+Mechanical Device | 99% | 0%
FXaI | 64% | 0%
DTI | 42% | 1%
FEI | 48% | 16%
Mechanical Device | 19% | 2%
Antiplatelet Drug | 29% | 11%
LMWH | 0% | 4%
VKA | 0% | 80%
UFH | 0% | 86%
Placebo | 0% | >99%

Percent likelihood that each class falls within the top 3 or bottom 3 classes in efficacy.

Abbreviations: DTI = direct thrombin inhibitor, DVT = deep vein thrombosis, FEI = factor VIII inhibitor, FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin, VKA = vitamin K antagonist.

Figure 39 Network meta-analysis ranks of intervention classes to prevent total deep vein thrombosis in total hip replacement

Distribution of probability (y-axis) of treatment rankings (x-axis) by intervention class based on network meta-analysis. Lower ranks indicate lower odds of outcome (greater benefit) with the given intervention compared with others.

Abbreviations: DTI = direct thrombin inhibitor, FEI = factor VIII inhibitor, FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, SUCRA = surface under the cumulative ranking curve, UFH = unfractionated heparin, VKA = vitamin K antagonist.

Rank graphs for each of the 10 intervention classes included in the network meta-analysis of total DVT in total hip replacement patients. Each graph has the ranks (1–10) along the x-axis and the probability of treatment ranking along the y-axis. Lower ranks indicate greater benefit with the given intervention compared to other interventions. Combination low molecular weight heparins plus mechanical devices have a peak rank probability of about 0.8 at rank 1. Factor 8 inhibitors have peak rank probability of about 0.3 at rank 2. Factor 10-a inhibitors have a peak rank probability of about 0.4 at rank 3. Direct thrombin inhibitors have a peak rank probability of about 0.4 at rank 4. Mechanical devices have a peak rank probability of about 0.3 at rank 5. Low molecular weight heparins have peak rank probabilities of about 0.4 at ranks 6 and 7. Vitamin K antagonists have peak ranks with probability of about 0.4 at ranks 8 and 9. Unfractionated heparin has peak ranks with probability of about 0.6 at ranks 8 and 9. Antiplatelet drugs have peak rank probabilities of about 0.2 between ranks 2 and 7. Placebo has a peak rank probability of 0.9 at rank 10.

However, omitting interventions that are directly linked to two or fewer other interventions with two or fewer RCTs each (antiplatelet drug [aspirin], FEI, and combined LMWH and mechanical devices), FXaI is most effective to prevent total DVT, followed by DTI, compared with mechanical devices, LMWH, VKA, and UFH.

#### Comparison of Specific Interventions

In the analysis by drug (or mechanical device), there were 54 RCTs that evaluated at least two interventions and reported total DVT after THR. However, one RCT of certoparin versus certoparin plus IPC did not connect to the network of evidence and was not included.^141^ Hence, there were 53RCTs in the network meta-analysis.^24, 43, 46–50, 52, 54–56, 58, 60–63, 66–76, 78, 80–86, 114, 115, 117, 120, 139, 140, 148–151, 153–159^ These RCTs compared pairs of interventions (49 RCTs) or triplets of interventions (4 RCTs). Across this study set, 20 interventions were evaluated (apixaban, aspirin, dabigatran, dalteparin, darexaban, desirudin, edoxaban, enoxaparin, enoxaparin plus GCS, enoxaparin plus IPC, fondaparinux, UFH, IPC, rivaroxaban, semuloparin, TB402, tinzaparin, VFP, warfarin, placebo). Of the 190 possible pairwise comparisons, 33 are covered by direct study comparisons. Figure 40 illustrates the topology of the network. Enoxaparin was the most common comparator, being directly compared with 14 other interventions; most frequently with UFH (7 RCTs) and placebo (7 RCTs). Dalteparin was directly compared with UFH, warfarin, and placebo only; warfarin was also directly compared with aspirin and IPC; aspirin was also directly compared with placebo; TB402 was directly compared with rivaroxaban only.

Figure 40 Network of comparison of specific interventions for total deep vein thrombosis in total hip replacement

Topology map for network meta-analysis of different interventions of thromboprophylaxis for total deep vein thrombosis outcome after total hip replacement. Nodes represent different interventions included in the analysis. Lines between nodes indicate the pairs of intervention classes that were compared directly within trials. The thickness of the lines is proportional to the number of trials directly comparing pairs of interventions, as indicated by the associated number.

Abbreviations: GCS = graduated compression stocking, IPC = intermittent pneumatic compression, VFP = venous foot pump.

A topology map of the network meta-analysis of different specific thromboprophylaxis interventions for total deep vein thrombosis outcome after total hip replacement. Twenty interventions are displayed, including apixaban, aspirin, dabigatran, dalteparin, darexaban, desirudin, edoxaban, enoxaparin, enoxaparin plus graduated compression stockings, enoxaparin plus intermittent pneumatic compression, fondaparinux, unfractionated heparin, intermittent pneumatic compression, rivaroxaban, semuloparin, TB402, tinzaparin, venous foot pump, warfarin, placebo. Of the 190 possible pairwise comparisons, 33 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with 14 other interventions; most frequently with unfractionated heparin (7 RCTs) and placebo (7 RCTs). Dalteparin was directly compared with unfractionated heparin, warfarin, and placebo only; warfarin was also directly compared with aspirin and intermittent pneumatic compression; aspirin was also directly compared with placebo; TB402 was directly compared with rivaroxaban only.

Appendix Table F7.2 shows the network meta-analysis pairwise results for all combinations of interventions. The statistically significant differences between active interventions are highlighted here.

- The combination of enoxaparin plus IPC had statistically significant lower odds of DVT compared with 13 active interventions
- Apixaban had a lower odds of DVT compared with
  ○ enoxaparin (OR=0.306; 95% CrI 0.114 to 0.813)
  ○ UFH (OR=0.213; 95% CrI 0.071 to 0.593)
  ○ rivaroxaban (OR=0.238; 95% CrI 0.067 to 0.863)
  ○ tinzaparin (OR=0.208; 95% CrI 0.063 to 0.625)
  ○ warfarin (OR=0.177; 95% CrI 0.053 to 0.552)
- Desirudin had a lower odds of DVT compared with
  ○ UFH (OR=0.390; 95% CrI 0.212 to 0.678)
  ○ tinzaparin (OR=0.380; 95% CrI 0.161 to 0.844)
  ○ warfarin (OR=0.324; 95% CrI 0.137 to 0.738)
- Edoxaban had a lower odds of DVT compared with
  ○ UFH (OR=0.264; 95% CrI 0.080 to 0.815)
  ○ tinzaparin (OR=0.256; 95% CrI 0.071 to 0.854)
  ○ warfarin (OR=0.219; 95% CrI 0.060 to 0.758)
- The combination of enoxaparin plus GCS had a lower odds of DVT compared with
  ○ UFH (OR=0.288; 95% CrI 0.078 to 0.991)
  ○ warfarin (OR=0.239; 95% CrI 0.059 to 0.890)
- Fondaparinux had a lower odds of DVT compared with
  ○ UFH (OR=0.451; 95% CrI 0.227 to 0.932)
  ○ warfarin (OR=0.376; 95%CrI 0.16 to 0.907)
- Semuloparin had a lower odds of DVT compared with
  ○ UFH (OR=0.375; 95% CrI 0.132 to 0.989)
  ○ warfarin (OR=0.311; 95% CrI 0.098 to 0.9238)
- VFP had a lower odds of DVT compared with
  ○ UFH (OR=0.483; 95% CrI 0.223 to 0.984)
  ○ warfarin (OR=0.401; 95% CrI 0.157 to 0.976)

##### Summary

Overall, the combination of enoxaparin plus IPC had the highest probability of being among the top three interventions (96%) to prevent DVT after THR, followed by apixaban (67%). The interventions likely to be among the bottom three interventions were placebo (97%) and warfarin (58%) (Table 15). The distribution of intervention ranks is provided in Figure 41.

Table 15 Intervention ranking: Total hip replacement, intervention comparisons to prevent deep vein thrombosis

| Top 3 Ranks | Bottom 3 Ranks
Enoxaparin+IPC | 96% | 0%
Apixaban | 67% | 0%
Edoxaban | 47% | 0%
Enoxaparin+GCS | 41% | 1%
Desirudin | 9% | 0%
Semuloparin | 18% | 1%
Fondaparinux | 4% | 0%
Darexaban | 7% | 2%
VFP | 4% | 1%
Dabigatran | 1% | 3%
Aspirin | 2% | 6%
Dalteparin | 0% | 2%
Enoxaparin | 0% | 0%
IPC | 1% | 7%
Rivaroxaban | 0% | 23%
TB402 | 3% | 42%
UFH | 0% | 25%
Tinzaparin | 0% | 31%
Warfarin | 0% | 58%
Placebo | 0% | 97%

Percent likelihood that each intervention falls within the top 3 or bottom 3 interventions in efficacy.

Abbreviations: GCS = graduated compression stocking, IPC = intermittent pneumatic compression, UFH = unfractionated heparin, VFP = venous foot pump.

Figure 41 Network meta-analysis ranks of specific interventions to prevent total deep vein thrombosis in total hip replacement

Distribution of probability (y-axis) of treatment rankings (x-axis) by intervention based on network meta-analysis. Lower ranks indicate lower odds of outcome (greater benefit) with the given intervention compared with others.

Abbreviations: GCS = graduated compression stocking, IPC = intermittent pneumatic compression, SUCRA = surface under the cumulative ranking curve, VFP = venous foot pump.

Rank graphs for each of the 20 interventions included in the network meta-analysis of total DVT in total hip replacement patients. Each graph has the ranks (1–20) along the x-axis and the probability of treatment ranking along the y-axis. Lower ranks indicate greater benefit with the given intervention compared to other interventions. Apixaban has a rank probability of about 0.4 at rank 3. Aspirin has a rank probability of about 0.15 at ranks 9 through 15. Dabigatran has a rank probability of about 0.15 at rank 10. Dalteparin has a rank probability of about 0.2 at ranks 10 to 14. Darexaban has a rank probability of about 0.15 at ranks 5 to 9. Desirudin has a rank probability of about 0.2 at ranks 5 to 6. Edoxaban has a rank probability of about 0.2 at ranks 2 and 3. Enoxaparin has a rank probability of about 0.25 at ranks 12 and 13. Combination enoxaparin and graduated compression stocking has a rank probability of about 0.2 at ranks 2 to 4. Combination enoxaparin and intermittent pneumatic compression has a rank probability of about 0.9 at rank 1. Fondaparinux has a rank probability of about 0.2 at ranks 5 to 9. Unfractionated heparin has a rank probability of about 0.2 at ranks 15 and 16. Intermittent pneumatic compression have a rank probability of about 0.15 at ranks 12 to 15. Placebo has a rank probability of about 1.0 at rank 20. Rivaroxaban has a rank probability of about 0.15 at ranks 16 to 18. Semuloparin has a rank probability of about 0.15 at ranks 4 and 5. TB402 has a rand probability of 0.2 and rank 20. Tinzaparin has a rank probability of about 0.2 at ranks 17 and 18. Venous foot pumps have a rank probability of about 0.15 at ranks 6 to 9. Warfarin has a rank probability of about 0.25 at ranks 18 and 19.

However, omitting interventions that are directly linked to two or fewer other interventions with two or fewer RCTs each (most interventions), dalteparin is most effective to prevent total DVTs, compared with enoxaparin, IPC, UFH, and warfarin.

#### Key Question 5 (THR): Major Bleeding

##### Comparison of Classes

There were 32 RCTs that evaluated interventions in at least two classes and reported major bleeding after THR.^24, 26, 48–52, 54–56, 58, 60–63, 67, 69–71, 73, 74, 76, 79–82, 86, 120, 150, 153, 157^ The RCTs compared pairs of intervention classes (29 RCTs) or triplets of intervention classes (3 RCTs). Across this study set, nine classes were evaluated (antiplatelet drug [aspirin], DTI, FEI, FXaI, LMWH, mechanical devices, UFH, VKA, placebo). Of the 36 possible pairwise comparisons, 10 are covered by direct study comparisons. Figure 42 illustrates the topology of the network. LMWH was the most common comparator, being directly compared with six other intervention classes; most frequently with FXaI (11 RCTs), UFH (6 RCTs), and placebo (6 RCTs). Antiplatelet drug was directly compared with placebo only; FEI was directly compared with FXaI only.

Figure 42 Network of comparison of intervention classes for major bleeding in total hip replacement

Topology map for network meta-analysis of different classes of thromboprophylaxis interventions for major bleeding outcome after total hip replacement. Nodes represent different classes of interventions included in the analysis. Lines between nodes indicate the pairs of intervention classes that were compared directly within trials. The thickness of the lines is proportional to the number of trials directly comparing pairs of interventions, as indicated by the associated number.

Abbreviations: DTI = direct thrombin inhibitor, FEI = factor VIII inhibitor, FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin, VKA = vitamin K antagonist.

A topology map of the network meta-analysis of different classes of thromboprophylaxis interventions for major bleeding outcome after total hip replacement. Nine classes are displayed, including antiplatelet drugs, direct thrombin inhibitor, factor 8 inhibitor, factor 10-a inhibitor, low molecular weight heparin, mechanical devices, unfractionated heparin, vitamin K antagonist, and placebo. Of the 36 possible pairwise comparisons, 10 are covered by direct study comparisons. Low molecular weight heparin was the most common comparator, being directly compared with six other intervention classes; most frequently with factor 10-a inhibitor (11 studies), unfractionated heparin (6 studies) and placebo (6 studies). Antiplatelet drugs were directly compared with placebo only; factor 8 inhibitor was directly compared with factor 10-a inhibitor only.

Appendix Table F7.3 shows the network meta-analysis pairwise results for all combinations of interventions. Results for comparisons with antiplatelet drug, FEI, and mechanical devices were not estimable (due to the following: there was only one RCT of antiplatelet drug versus placebo, which had zero events; there was only one RCT of FEI versus FXaI, which had rare events [5/208 vs. 0/208]; there were two RCTs of mechanical devices, which both had zero events). The statistically significant differences between classes are highlighted here.

- VKA had lower odds of major bleeding compared with
  ○ DTI (OR=0.393; 95% CrI 0.184 to 0.799)
  ○ FXaI (OR=0.377; 95% CrI 0.185 to 0.761)
  ○ LMWH (OR=0.509; 95% CrI 0.272 to 0.906)
  ○ UFH (OR=0.234; 95% CrI 0.099 to 0.522)
- LMWH had lower odds of major bleeding compared with
  ○ UFH (OR=0.459; 95% CrI 0.256 to 0.820)

###### Summary

Overall, the mechanical devices had the highest probability of being among the top three intervention classes (>99%) to avoid major bleeding with thromboprophylaxis after THR, followed by antiplatelet drug (89%) and VKA (78%). The interventions likely to be among the bottom three interventions were FEI (>99%) and UFH (88%) (Table 16). The distribution of intervention ranks is provided in Figure 43.

Table 16 Class ranking: Total hip replacement, intervention comparisons to avoid major bleeding

| Top 3 Ranks | Bottom 3 Ranks
Mechanical Devices | >99% | 0%
Antiplatelet | 89% | 10%
VKA | 78% | 0%
Placebo | 29% | 11%
LMWH | 3% | 1%
DTI | 1% | 37%
FXaI | 0% | 47%
UFH | 0% | 94%
FEI | 0% | >99%

Percent likelihood that each class falls within the top 3 or bottom 3 classes in efficacy.

Abbreviations: DTI = direct thrombin inhibitor, FEI = factor VIII inhibitor, FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin, VKA = vitamin K antagonist.

Figure 43 Network meta-analysis ranks of intervention classes to avoid major bleeding in total hip replacement

Distribution of probability (y-axis) of treatment rankings (x-axis) by intervention class based on network meta-analysis. Lower ranks indicate lower odds of outcome (greater benefit) with the given intervention compared with others.

Abbreviations: DTI = direct thrombin inhibitor, FEI = factor VIII inhibitor, FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, SUCRA = surface under the cumulative ranking curve, UFH = unfractionated heparin, VKA = vitamin K antagonist.

Rank graphs for each of the 9 intervention classes included in the network meta-analysis of major bleeding in total hip replacement patients. Each graph has the ranks (1–9) along the x-axis and the probability of treatment ranking along the y-axis. Lower ranks indicate greater benefit with the given intervention compared to other interventions. Antiplatelet drugs have a rank probability of about 0.65 at rank 1 and another probability peak of about 0.1 at rank 8. Direct thrombin inhibitors have a rank probability of about 0.35 at ranks 6 and 7. Factor 8 inhibitors have a rank probability of about 1.0 at rank 9. Factor 10-a inhibitors have a rank probability of about 0.4 at ranks 6 and 7. Low molecular weight heparins have a rank probability of about 0.5 at rank 5. Mechanical devices have a rank probability of about 0.65 at rank 2. Placebo has a rank probability of about 0.4 at rank 4. Unfractionated heparin has a rank probability of about 0.75 at rank 8. Vitamin K antagonists have a rank probability of about 0.7 at rank 3.

However, omitting interventions that are directly linked to two or fewer other interventions with two or fewer RCTs each (all classes except LMWH and FXaI—and placebo), LMWH was more likely to result in fewer major bleeding events than FXaI.

##### Comparison of Specific Interventions

In the analysis by drug (or mechanical device), there were 34 RCTs that evaluated at least two interventions and reported major bleeding after THR.^24, 26, 48–52, 54–56, 58, 60–63, 67, 69–71, 73, 74, 76, 79–82, 86, 114, 115, 120, 150, 153, 157^ These studies compared pairs of interventions (31 RCTs) or triplets of interventions (3 RCTs). Across this study set, 17 interventions were evaluated (apixaban, aspirin, dabigatran, dalteparin, darexaban, desirudin, edoxaban, enoxaparin, fondaparinux, UFH, IPC, rivaroxaban, semuloparin, TB402, tinzaparin, warfarin, placebo). Of the 136 possible pairwise comparisons, 23 are covered by direct study comparisons. Figure 44 illustrates the topology of the network. Enoxaparin was the most common comparator, being directly compared with 13 other interventions; most frequently with UFH (5 RCTs) and placebo (6 RCTs). Dalteparin was directly compared with UFH, warfarin, and edoxaban only; aspirin was directly compared with placebo only; TB402 was directly compared with rivaroxaban only.

Figure 44 Network of comparison of specific interventions for major bleeding in total hip replacement

Topology map for network meta-analysis of different interventions of thromboprophylaxis for major bleeding outcome after total hip replacement. Nodes represent different interventions included in the analysis. Lines between nodes indicate the pairs of intervention classes that were compared directly within trials. The thickness of the lines is proportional to the number of trials directly comparing pairs of interventions, as indicated by the associated number.

Abbreviations: IPC = intermittent pneumatic compression.

A topology map of the network meta-analysis of different specific thromboprophylaxis interventions for major bleeding outcome after total hip replacement. Seventeen interventions are displayed, including apixaban, aspirin, dabigatran, dalteparin, darexaban, desirudin, edoxaban, enoxaparin, fondaparinux, unfractionated heparin, intermittent pneumatic compression, rivaroxaban, semuloparin, TB402, tinzaparin, warfarin, placebo. Of the 136 possible pairwise comparisons, 23 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with 13 other interventions; most frequently with unfractionated heparin (5 studies) and placebo (6 studies). Dalteparin was directly compared with unfractionated heparin, warfarin, and edoxaban only; aspirin was directly compared with placebo only. TB402 was directly compared with rivaroxaban only.

Appendix Table F7.4 shows the network meta-analysis pairwise results for all combinations of interventions. Results for comparisons with aspirin, IPC, and TB402 were not estimable (due to the following: there was one RCT of aspirin versus placebo which had zero events; there were two RCTs of IPC which both had zero events; there was only one RCT of TB402 versus rivaroxaban which had rare events [5/208 versus 0/208]). The statistically significant differences between active interventions are highlighted here.

- Semuloparin had a lower odds of major bleeding compared with
  ○ dabigatran (OR=0.179; 95% CrI 0.037 to 0.731)
  ○ enoxaparin (OR=0.264; 95% CrI 0.062 to 0.932)
  ○ fondaparinux (OR=0.164; 95% CrI 0.033 to 0.682)
  ○ UFH (OR=0.125; 95% CrI 0.023 to 0.529)
- Warfarin had a lower odds of major bleeding compared with
  ○ dabigatran (OR=0.242; 95% CrI 0.069 to 0.718)
  ○ enoxaparin (OR=0.356; 95% CrI 0.123 to 0.884)
  ○ fondaparinux (OR=0.221; 95% CrI 0.063 to 0.666)
  ○ UFH (OR=0.167; 95% CrI 0.049 to 0.524)
- Enoxaparin had a lower odds of major bleeding compared with
  ○ UFH (OR=0.471; 95% CrI 0.247 to 0.965)

###### Summary

Overall, IPC had the highest probability of being among the top three interventions (>99%) to avoid major bleeding with thromboprophylaxis after THR, followed by semuloparin (63%). The interventions likely to be among the bottom three interventions were TB402 (>99%) and aspirin (86%) (Table 17). The distribution of intervention ranks is provided in Figure 45.

Table 17 Intervention ranking: Total hip replacement, intervention comparisons to avoid major bleeding

| Top 3 Ranks | Bottom 3 Ranks
IPC | >99% | 0%
Semuloparin | 63% | 0%
Warfarin | 44% | 0%
Dalteparin | 17% | 2%
Tinzaparin | 10% | 1%
Edoxaban | 17% | 3%
Placebo | 9% | 2%
Enoxaparin | 0% | 0%
Darexaban | 24% | 30%
Desirudin | 2% | 3%
Rivaroxaban | 1% | 7%
Apixaban | 1% | 7%
Dabigatran | 0% | 8%
Fondaparinux | 0% | 12%
UFH | 0% | 41%
Aspirin | 13% | 86%
TB402 | 0% | >99%

Percent likelihood that each intervention falls within the top 3 or bottom 3 interventions in efficacy.

Abbreviations: IPC = intermittent pneumatic compression, UFH = unfractionated heparin.

Figure 45 Network meta-analysis ranks of specific interventions to avoid major bleeding in total hip replacement

Distribution of probability (y-axis) of treatment rankings (x-axis) by intervention based on network meta-analysis. Lower ranks indicate lower odds of outcome (greater benefit) with the given intervention compared with others.

Abbreviations: IPC = intermittent pneumatic compression, SUCRA = surface under the cumulative ranking curve.

Figure 45. Network meta-analysis ranks of specific interventions to avoid major bleeding in total hip replacement. Rank graphs for each of the 17 interventions included in the network meta-analysis of major bleeding in total hip replacement patients. Each graph has the ranks (1–17) along the x-axis and the probability of treatment ranking along the y-axis. Lower ranks indicate greater benefit with the given intervention compared to other interventions. Apixaban has a rank probability of about 0.15 at ranks 10 to 13. Aspirin has a rank probability of about 0.15 at ranks 1 and 2 and another probability peak of about 0.5 at rank 17. Dabigatran has a rank probability of about 0.2 at ranks 12 to 14. Dalteparin has a rank probability of about 0.15 at ranks 5 and 6. Darexaban has a rank probability of about 0.15 at rank 2 and another probability peak of about 0.25 at rank 15. Desirudin has a rank probability of about 0.15 at ranks 7 to 11. Edoxaban has a rank probability of about 0.15 at ranks 3 to 6. Enoxaparin has a rank probability of about 0.25 at rank 9. Fondaparinux has a rank probability of about 0.2 at ranks 13 and 14. Unfractionated heparin has a rank probability of about 0.3 at rank 15. Intermittent pneumatic compression has a rank probability of about 0.85 at rank 1. Placebo has a rank probability of about 0.15 at ranks 6 and 7. Rivarxoaban has a flat rank probability of about 0.1 from ranks 7 to 14. Semuloparin has a rank probability of about 0.35 at rank 2. TB402 has a rank probability of about 0.5 at ranks 16 and 17. Tinzaparin has a rank probability of about 0.2 at ranks 5 to 7. Warfarin has a rank probability of about 0.3 at ranks 3 and 4.

However, except for LMWH (and placebo) no intervention was directly compared to more than two other interventions by at least two RCTs each.

### Key Question 5: Total Knee Replacement

#### Key Question 5 (TKR): Deep Vein Thrombosis, Total

##### Comparison of Classes

There were 31 RCTs that evaluated interventions in at least two classes and reported total DVT after TKR.^43, 52, 55, 65, 80, 87–90, 95–98, 101–106, 108, 120, 126, 139, 141, 144, 147, 160–164^ The RCTs compared pairs of intervention classes (28 RCTs) or triplets of intervention classes (3 RCTs). Across this study set, 12 classes were evaluated (antiplatelet drug [aspirin], antiplatelet drug plus mechanical device, DTI, FXaI, FXaI plus mechanical device, FXIi, LMWH, LMWH plus mechanical device, mechanical devices, UFH, VKA, placebo). Of the 66 possible pairwise comparisons, 20 are covered by direct study comparisons. Figure 46 illustrates the topology of the network. LMWH was the most common comparator, being directly compared with nine other intervention classes; most frequently with FXaI (7 RCTs). The combination of antiplatelet drug (aspirin) plus mechanical device was directly compared with antiplatelet drug and LMWH plus mechanical device; the combination of FXaI plus mechanical device was directly compared with FXaI only.

Figure 46 Network of comparison of intervention classes for total deep vein thrombosis in total knee replacement

Topology map for network meta-analysis of different classes of thromboprophylaxis interventions for total deep vein thrombosis outcome after total knee replacement. Nodes represent different classes of interventions included in the analysis. Lines between nodes indicate the pairs of intervention classes that were compared directly within trials. The thickness of the lines is proportional to the number of trials directly comparing pairs of interventions, as indicated by the associated number.

Abbreviations: DTI = direct thrombin inhibitor, FXaI = factor Xa inhibitor, FXIi = factor XI inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin, VKA = vitamin K antagonist.

A topology map of the network meta-analysis of different classes of thromboprophylaxis interventions for total deep vein thrombosis outcome after total knee replacement. Twelve classes are displayed, including antiplatelet drugs, antiplatelet drugs and mechanical devices, direct thrombin inhibitor, factor 10-a inhibitor, factor 10-a inhibitor plus mechanical device, factor 11 inhibitor, low molecular weight heparin, low molecular weight heparin and mechanical devices, mechanical devices, unfractionated heparin, vitamin K antagonist, and placebo. Of the 66 possible pairwise comparisons, 20 are covered by direct study comparisons. Low molecular weight heparin was the most common comparator, being directly compared with nine other intervention classes; most frequently with factor 10-a inhibitor (7 studies). The combination of antiplatelet drugs plus mechanical devices was directly compared with antiplatelet drugs and LMWH plus mechanical device; the combination of FXaI plus mechanical device was directly compared with FXaI only.

Appendix Table F7.5 shows the network meta-analysis pairwise results for all combinations of interventions classes. The statistically significant differences between classes are highlighted here.

- The combination of LMWH plus mechanical device had a lower odds of DVT versus
  ○ antiplatelet drug (OR=0.285; 95% CrI 0.093 to 0.807)
  ○ LMWH (OR=0.417; 95% CrI 0.188 to 0.920)
  ○ mechanical devices (OR=0.393; 95% CrI 0.161 to 0.977)
  ○ UFH (OR=0.281; 95% CrI 0.118 to 0.686)
  ○ VKA (OR=0.229; 95% CrI 0.101 to 0.530)
- FXaI had a lower odds of DVT compared with
  ○ antiplatelet drug (OR=0.231; 95% CrI 0.140 to 0.370)
  ○ LMWH (OR=0.473; 95% CrI 0.370 to 0.587)
  ○ mechanical devices (OR=0.446; 95% CrI 0.261 to 0.747)
  ○ UFH (OR=0.320; 95% CrI 0.197 to 0.504)
  ○ VKA (OR=0.261; 95% CrI 0.18 to 0.361)
- DTI had a lower odds of DVT compared with
  ○ antiplatelet drug (OR=0.276; 95% CrI 0.138 to 0.534)
  ○ LMWH (OR=0.568; 95% CrI 0.330 to 0.938)
  ○ UFH (OR=0.386; 95% CrI 0.194 to 0.728)
  ○ VKA (OR=0.312; 95% CrI 0.170 to 0.549)
- The combination of antiplatelet drug plus mechanical devices had a lower odds of DVT compared with
  ○ antiplatelet drug (OR=0.234; 95% CrI 0.105 to 0.506)
  ○ UFH (OR=0.326; 95% CrI 0.128 to 0.800)
  ○ VKA (OR=0.263; 95% CrI 0.112 to 0.612)
- FXIi had a lower odds of DVT compared with
  ○ antiplatelet drug (OR=0.383; 95% CrI 0.167 to 0.877)
  ○ VKA (OR=0.435; 95% CrI 0.206 to 0.909)
- LMWH had a lower odds of DVT compared with
  ○ antiplatelet drug (OR=0.488; 95% CrI 0.313 to 0.752)
  ○ VKA (OR=0.553; 95% CrI 0.421 to 0.709)
- Mechanical devices had lower odds of DVT versus
  ○ antiplatelet drug (OR=0.513; 95% CrI 0.298 to 0.890)
  ○ VKA (OR=0.584; 95% CrI 0.341 to 0.987)

###### Summary

Overall, FXaI had the highest probability of being among the top three intervention classes (84%) to prevent DVT after TKR, followed closely by the combination of LMWH plus mechanical device (81%), then the combination of antiplatelet drug (aspirin) plus mechanical device (66%). The interventions likely to be among the bottom three interventions were placebo (>99%), antiplatelet drug (86%), and VKA (76%) (Table 18). The distribution of intervention ranks is provided in Figure 47.

Table 18 Class ranking: Total knee replacement, intervention class comparisons to prevent deep vein thrombosis

| Top 3 Ranks | Bottom 3 Ranks
LMWH+Mechanical Device | 81% | 0%
FXaI | 84% | 0%
Antiplatelet+Mechanical Device | 66% | 0%
DTI | 43% | 0%
FXIi | 15% | 1%
LMWH | 0% | 0%
FXaI+Mechanical Device | 9% | 12%
Mechanical Devices | 1% | 2%
UFH | 0% | 23%
VKA | 0% | 76%
Antiplatelet | 0% | 86%
Placebo | 0% | 100%

Percent likelihood that each class falls within the top 3 or bottom 3 classes in efficacy.

Abbreviations: DTI = direct thrombin inhibitor, FXaI = factor Xa inhibitor, FXIi = factor XI inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin, VKA = vitamin K antagonist.

Figure 47 Network meta-analysis ranks of intervention classes to prevent total deep vein thrombosis in total knee replacement

Distribution of probability (y-axis) of treatment rankings (x-axis) by intervention class based on network meta-analysis. Lower ranks indicate lower odds of outcome (greater benefit) with the given intervention compared with others.

Abbreviations: DTI = direct thrombin inhibitor, FXaI = factor Xa inhibitor, FXIi = factor XI inhibitor, LMWH = low molecular weight heparin, SUCRA = surface under the cumulative ranking curve, UFH = unfractionated heparin, VKA = vitamin K antagonist.

Rank graphs for each of the 12 intervention classes included in the network meta-analysis of total DVT in total knee replacement patients. Each graph has the ranks (1–12) along the x-axis and the probability of treatment ranking along the y-axis. Lower ranks indicate greater benefit with the given intervention compared to other interventions. Antiplatelet drugs have a rank probability of about 0.5 at rank 11. Combination antiplatelet drugs and mechanical devices have a rank probability of about 0.3 at rank 2. Direct thrombin inhibitors have a rank probability of about 0.35 at rank 4. Factor 10-a inhibitors have a rank probability of about 0.4 at rank 3. Factor 10-a inhibitors plus mechanical devices have a flat rank probability of about 0.2 from ranks 5 to 8. Factor 11 inhibitors have a rank probability of about 0.3 at rank 5. Low molecular weight heparins have a rank probability of about 0.4 at rank 7. Combination low molecular weight heparins and mechanical devices have a rank probability of about 0.4 at rank 1. Mechanical devices have a rank probability of about 0.3 at rank 8. Placebo has a rank probability of about 0.95 at rank 12. Unfractionated heparin has a rank probability of about 0.4 at rank 9. Vitamin K antagonists have a rank probability of about 0.5 at rank 10.

However, except for LMWH and FXaI (and placebo) no intervention was directly compared to more than two other interventions by at least two RCTs each. FXaI is more effective to prevent total DVTs than LMWH.

##### Comparison of Specific Interventions

In the analysis by drug (or mechanical device), there were 33 RCTs that evaluated at least two interventions and reported total DVT after TKR. However, one RCT of certoparin versus certoparin plus IPC did not connect to the network of evidence and was not included.^141^ Hence, there were 32 RCTs in the network meta-analysis.^43, 52, 55, 65, 80, 87–90, 95–98, 101–106, 108, 114, 117, 120, 126, 139, 144, 147, 160–164^ The RCTs compared pairs of interventions (29 RCTs), triplets of interventions (2 RCTs), or quadruplets of interventions (1 RCT). Across this study set, 23 interventions were evaluated (apixaban, aspirin, aspirin plus IPC, aspirin plus VFP, dabigatran, darexaban, edoxaban, edoxaban plus VFP, enoxaparin, enoxaparin plus GCS, enoxaparin plus IPC, enoxaparin plus VFP, flexion, fondaparinux, FXIASO, UFH, IPC, rivaroxaban, semuloparin, tinzaparin, VFP, warfarin, placebo). Of the 253 possible pairwise comparisons, 34 are covered by direct study comparisons. Figure 48 illustrates the topology of the network. Enoxaparin was the most common comparator, being directly compared with 16 other interventions. Flexion was directly compared with placebo only; enoxaparin plus GCS was directly compared with enoxaparin plus IPC only; IPC and aspirin plus VFP were directly compared with aspirin only; aspirin plus IPC was directly compared with enoxaparin plus IPC, edoxaban plus VFP was directly compared with edoxaban only.

Figure 48 Network of comparison of specific interventions for total deep vein thrombosis in total knee replacement

Topology map for network meta-analysis of different interventions of thromboprophylaxis for total deep vein thrombosis outcome after total knee replacement. Nodes represent different interventions included in the analysis. Lines between nodes indicate the pairs of intervention classes that were compared directly within trials. The thickness of the lines is proportional to the number of trials directly comparing pairs of interventions, as indicated by the associated number.

Abbreviations: FXIASO = factor XI antisense oligonucleotide, GCS = graduated compression stocking, IPC = intermittent pneumatic compression, VFP = venous foot pump.

A topology map of the network meta-analysis of different specific thromboprophylaxis interventions for total deep vein thrombosis outcome after total knee replacement. Twenty-three interventions are displayed, including apixaban, aspirin, aspirin plus venous foot pump, dabigatran, darexaban, edoxaban, edoxaban plus venous foot pump, enoxaparin, enoxaparin plus graduated compression stockings, enoxaparin plus intermittent pneumatic compression device, enoxaparin plus venous foot pump, flexion, fondaparinux, factor 11 antisense oligonucleotide, unfractionated heparin, intermittent pneumatic compression device, rivaroxaban, semuloparin, tinzaparin, venous foot pump, warfarin, and placebo. Of the 253 possible pairwise comparisons, 34 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with 16 other interventions. Flexion was directly compared with placebo only; enoxaparin plus graduated compression stockings was directly compared with enoxaparin plus intermittent pneumatic compression device only; intermittent pneumatic compression devices and combined aspirin plus venous foot pump were directly compared with aspirin only; aspirin plus intermittent pneumatic compression was directly compared with enoxaparin plus intermittent pneumatic compression, edoxaban plus venous foot pump was directly compared with edoxaban only..

Appendix Table F7.6 shows the network meta-analysis pairwise results for all combinations of interventions. Results for the combination of enoxaparin plus GCS, the combination of enoxaparin plus VFP, and flexion devices were not estimable (due to the following: there was one RCT of enoxaparin plus GCS versus enoxaparin plus IPC which had small sample size and rare events [14/35 vs. 0/35]; there was one RCT of enoxaparin plus VFP versus enoxaparin which had zero events; there was one RCT of flexion device versus placebo which had zero events). The statistically significant differences between active interventions are highlighted here.

- Rivaroxaban had a lower odds of DVT compared with 8 active interventions.
- The combination of aspirin plus VFP had a lower odds of DVT compared with 6 active interventions
- Apixaban had a lower odds of DVT compared with 6 active interventions
- Fondaparinux had a lower odds of DVT compared with 6 active interventions
- Edoxaban had a lower odds of DVT compared with 6 active interventions
- Dabigatran had a lower odds of DVT compared with
  ○ aspirin (OR=0.348; 95% CrI 0.156 to 0.750)
  ○ enoxaparin (OR=0.569; 95% CrI 0.325 to 0.982)
  ○ UFH (OR=0.385; 95% CrI 0.189 to 0.777)
  ○ tinzaparin (OR=0.448; 95% CrI 0.189 to 0.998)
  ○ warfarin (OR=0.298; 95% CrI 0.152 to 0.569)
- Darexaban had a lower odds of DVT compared with
  ○ aspirin (OR=0.334; 95% CrI 0.12 to 0.913)
  ○ UFH (OR=0.371; 95% CrI 0.142 to 0.946)
  ○ warfarin (OR=0.288; 95% CrI 0.113 to 0.703)
- IPC had a lower odds of DVT compared with
  ○ aspirin (OR=0.386; 95% CrI 0.168 to 0.914)
  ○ warfarin (OR=0.333; 95% CrI 0.12 to 0.921)
- FXIASO had a lower odds of DVT compared with
  ○ warfarin (OR=0.410; 95% CrI 0.181 to 0.937)
- Semuloparin had a lower odds of DVT compared with
  ○ warfarin (OR=0.437; 95% CrI 0.234 to 0.789)
- Enoxaparin had a lower odds of DVT compared with
  ○ warfarin (OR=0.523; 95% CrI 0.361 to 0.742)

###### Summary

Overall, rivaroxaban had the highest probability (68%) of being among the top three interventions to prevent DVT after TKR, followed by flexion (65A%) and the combination of enoxaparin plus VFP (63%). The interventions likely to be among the bottom three interventions were the combination of enoxaparin plus GCS (>99%) and placebo (76%) (Table 19). The distribution of intervention ranks is provided in Figure 49.

Table 19 Intervention ranking: Total knee replacement, intervention class comparisons to prevent deep vein thrombosis

| Top 3 Ranks | Bottom 3 Ranks
Rivaroxaban | 68% | 0%
Aspirin+VFP | 46% | 0%
Fondaparinux | 15% | 0%
Edoxaban | 7% | 0%
Apixaban | 3% | 0%
Darexaban | 7% | 0%
Flexion | 65% | 33%
Dabigatran | 2% | 0%
Enoxaparin+VFP | 63% | 35%
Enoxaparin+IPC | 11% | 1%
IPC | 5% | 1%
FXIASO | 1% | 0%
Aspirin+IPC | 6% | 6%
Semuloparin | 0% | 0%
Edoxaban+VFP | 1% | 5%
Enoxaparin | 0% | 0%
VFP | 0% | 2%
Tinzaparin | 0% | 2%
UFH | 0% | 5%
Aspirin | 0% | 11%
Warfarin | 0% | 23%
Placebo | 0% | 76%
Enoxaparin+GCS | 0% | >99%

Percent likelihood that each intervention falls within the top 3 or bottom 3 interventions in efficacy.

Abbreviations: FXIASO = factor XI antisense oligonucleotide, GCS = graduated compression stocking, IPC = intermittent pneumatic compression, UFH = unfractionated heparin, VFP = venous foot pump.

Figure 49 Network meta-analysis ranks of specific interventions to prevent total deep vein thrombosis in total knee replacement

Distribution of probability (y-axis) of treatment rankings (x-axis) by intervention based on network meta-analysis. Lower ranks indicate lower odds of outcome (greater benefit) with the given intervention compared with others.

Abbreviations: FXIASO = factor XI antisense oligonucleotide, GCS = graduated compression stocking, IPC = intermittent pneumatic compression, SUCRA = surface under the cumulative ranking curve, VFP = venous foot pump.

Rank graphs for each of the 23 interventions included in the network meta-analysis of total DVT in total knee replacement patients. Each graph has the ranks (1–23) along the x-axis and the probability of treatment ranking along the y-axis. Lower ranks indicate greater benefit with the given intervention compared to other interventions. Apixaban has a rank probability of about 0.2 at ranks 6 to 8. Aspirin has a rank probability of about 0.25 at ranks 16 to 18. Combination aspirin and venous foot pump has a rank probability of about 0.25 at ranks 2 and 3. Dabigatran has a rank probability of about 0.2 at ranks 7 to 9. Darexaban has a rank probability of about 0.15 from ranks 3 to 11. Edoxaban has a rank probability of about 0.2 at ranks 5 and 6. Enoxaparin has a rank probability of about 0.35 at ranks 12 and 13. Combination enoxaparin and graduated compression stockings has a rank probability of about 0.5 at rank 21. Combination enoxaparin and intermittent pneumatic compression has a rank probability of about 0.1 from ranks 3 to 12. Combination enoxaparin and venous foot pumps has a rank probability of about 0.5 at rank 1 and a probability peak of about 0.15 at ranks 19 and 20. Flexion has a rank probability of about 0.15 at ranks 1 and 2 and another probability peak of about 0.35 at ranks 20 and 21. Fondiparinux has a rank probability of about 0.25 at ranks 4 and 5. Factor 11 antisense oligonuclide has a rank probability of about 0.2 at ranks 10 to 12. Heparin has a rank probability of about 0.3 at rank 16. Intermittent pneumatic compression has a rank probability of about 0.1 from ranks 4 to 12. Placebo has a rank probability of about 0.5 at rank 18. Rivaroxaban has a rank probability of about 0.4 at rank 2. Semuloparin has a rank probability of about 0.25 at rank 11. Tinzaparin has a rank probability of about 0.25 at ranks 14 and 15. Venous foot pump has a rank probability of about 0.2 at ranks 14 and 15. Warfarin has a rank probability of about 0.4 at ranks 17 and 18.

However, except for enoxaparin (and placebo) no intervention was directly compared to more than two other interventions by at least two RCTs each.

#### Key Question 5 (TKR): Major Bleeding

##### Comparison of Classes

There were 23 RCTs that evaluated interventions in at least two classes and reported major bleeding after TKR. However, one RCT of antiplatelet drug (aspirin) versus the combination of antiplatelet drug plus mechanical device did not connect to the network of evidence and was not included.^144^ Hence, there were 22 RCTs in the network meta-analysis.^52, 55, 65, 80, 89, 91–93, 96–101, 104–108, 120, 126, 162^ These RCTs compared pairs of intervention classes (19 RCTs) or triplets of intervention classes (2 RCTs). Across this study set, eight classes were evaluated (DTI, FXaI, FXaI plus mechanical device, FXIi, LMWH, UFH, VKA, placebo). Of the 28 possible pairwise comparisons, 10 are covered by direct study comparisons. Figure 50 illustrates the topology of the network. LMWH was the most common comparator, being directly compared with each of six other intervention classes; most frequently with FXaI (7 RCTs), DTI (5 RCTs), and VKA (4 RCTs). The combination of FXaI plus mechanical device was directly compared to FXaI only.

Figure 50 Network of comparison of intervention classes for major bleeding in total knee replacement

Topology map for network meta-analysis of different classes of thromboprophylaxis interventions for major bleeding outcome after total knee replacement. Nodes represent different classes of interventions included in the analysis. Lines between nodes indicate the pairs of intervention classes that were compared directly within trials. The thickness of the lines is proportional to the number of trials directly comparing pairs of interventions, as indicated by the associated number.

Abbreviations: DTI = direct thrombin inhibitor, FXaI = factor Xa inhibitor, FXIi = factor XI inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin, VKA = vitamin K antagonist.

A topology map of the network meta-analysis of different classes of thromboprophylaxis interventions for major bleeding outcome after total knee replacement. Eight classes are displayed, including direct thrombin inhibitor, factor 10-a inhibitor, factor 10-a inhibitor plus mechanical device, factor 11 inhibitor, low molecular weight heparin, unfractionated heparin, vitamin K antagonist, and placebo. Of the 28 possible pairwise comparisons, 10 are covered by direct study comparisons. Low molecular weight heparin was the most common comparator, being directly compared with each of six other intervention classes; most frequently with factor 10-a inhibitor (7 studies), direct thrombin inhibitor (5 studies), and vitamin K antagonist (4 studies). The combination of factor 10-a inhibitor plus mechanical device was directly compared to factor 10-a inhibitor only.

Appendix Table F7.7 shows the network meta-analysis pairwise results for all combinations of interventions classes. Results for comparisons versus FXIi were not estimable (due to the following: there was one RCT of FXIi versus enoxaparin which had zero events). There were no statistically significant differences between other classes (DTI, FXaI, FXaI plus mechanical device, FXIi, LMWH, UFH, VKA).

###### Summary

Across all comparisons, there were no statistically significant differences. Overall, VKA had the highest probability of being among the top three intervention classes (84%) to avoid major bleeding with thromboprophylaxis after TKR. Notably, though the mechanical device RCTs did not provide major bleeding data except for the one study of FXaI plus mechanical device versus FXaI. The interventions likely to be among the bottom three interventions were FXIi (68%) and FXaI (60%) (Table 20). The distribution of intervention ranks is provided in Figure 51.

Table 20 Class ranking: Total knee replacement, intervention class comparisons to avoid major bleeding

| Top 3 Ranks | Bottom 3 Ranks
VKA | 84% | 4%
LMWH | 38% | 10%
UFH | 46% | 35%
Placebo | 42% | 32%
DTI | 23% | 35%
FXaI+Mechanical Device | 27% | 56%
FXaI | 9% | 60%
FXIi | 31% | 68%

Percent likelihood that each class falls within the top 3 or bottom 3 classes in efficacy.

Abbreviations: DTI = direct thrombin inhibitor, FXaI = factor Xa inhibitor, FXIi = factor XI inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin, VKA = vitamin K antagonist.

Figure 51 Network meta-analysis ranks of intervention classes to avoid major bleeding in total knee replacement

Distribution of probability (y-axis) of treatment rankings (x-axis) by intervention class based on network meta-analysis. Lower ranks indicate lower odds of outcome (greater benefit) with the given intervention compared with others.

Abbreviations: DTI = direct thrombin inhibitor, FXaI = factor Xa inhibitor, FXIi = factor XI inhibitor, LMWH = low molecular weight heparin, SUCRA = surface under the cumulative ranking curve, UFH = unfractionated heparin, VKA = vitamin K antagonist.

Rank graphs for each of the 8 intervention classes included in the network meta-analysis of major bleeding in total knee replacement patients. Each graph has the ranks (1–8) along the x-axis and the probability of treatment ranking along the y-axis. Lower ranks indicate greater benefit with the given intervention compared to other interventions. Direct thrombin inhibitors have a rank probability of about 0.2 at ranks 3 to 5. Factor 10-a inhibitors have a rank probability of about 0.3 at ranks 5 and 6. Factor 11 inhibitors have a rank probability of about 0.3 at rank 1 and another probability peak of about 0.65 at rank 7. Low molecular weight heparins have a rank probability of about 0.3 at ranks 3 and 4. Placebo has a rank probability of about 0.15 from ranks 1 to 7, with a peak of about 0.2 at rank 6. Unfractionated heparin has a rank probability of about 0.2 at rank 2 and another probability peak of about 0.2 at rank 6. Vitamin K antagonists have a rank probability of about 0.4 at ranks 1 and 2.

However, except for LMWH and FXaI (and placebo) no intervention was directly compared to more than two other interventions by at least two RCTs each. LMWH was more likely to result in fewer major bleeding events than FXaI.

##### Comparison of Specific Interventions

In the analysis by drug (or mechanical device), there were 24 RCTs that evaluated at least two interventions and reported major bleeding after TKR. However, one RCT of aspirin versus the combination of aspirin plus VFP did not connect to the network of evidence and was not included.^144^ Hence, there were 23 RCTs in the network meta-analysis.^52, 55, 65, 80, 89, 91–93, 96–101, 104–108, 114, 120, 126, 162^ The RCTs compared pairs of interventions (21 RCTs), triplets of interventions (1 RCT), or quadruplets of interventions (1 RCT). Across this study set, 15 interventions were evaluated (apixaban, dabigatran, darexaban, edoxaban, edoxaban plus VFP, enoxaparin, eribaxaban, fondaparinux, FXIASO, UFH, semuloparin, TAK422, tinzaparin, warfarin, placebo). Of the 105 possible pairwise comparisons, 22 are covered by direct study comparisons. Figure 52 illustrates the topology of the network. Enoxaparin was the most common comparator, being directly compared with 13 other interventions; most frequently with dabigatran (5 RCTs). The combination of edoxaban plus VFP was directly compared with edoxaban only.

Figure 52 Network of comparison of specific interventions for major bleeding in total knee replacement

Topology map for network meta-analysis of different interventions of thromboprophylaxis to avoid major bleeding outcome after total knee replacement. Nodes represent different interventions included in the analysis. Lines between nodes indicate the pairs of intervention classes that were compared directly within trials. The thickness of the lines is proportional to the number of trials directly comparing pairs of interventions, as indicated by the associated number.

Abbreviations: FXIASO = factor XI antisense oligonucleotide.

A topology map of the network meta-analysis of different specific thromboprophylaxis interventions for major bleeding outcome after total knee replacement. Fifteen interventions are displayed, including apixaban, dabigatran, darexaban, edoxaban, edoxaban plus venous foot pump, enoxaparin, eribaxaban, fondaparinux, factor eleven antisense oligonucleotide, heparin, semuloparin, TAK422, tinzaparin, warfarin, and placebo. Of the 105 possible pairwise comparisons, 22 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with 13 other interventions; most frequently with dabigatran (5 studies). The combination of edoxaban plus venous foot pump was directly compared with edoxaban only.

Appendix Table F7.8 shows the network meta-analysis pairwise results for all combinations of interventions. Results for comparisons with darexaban, edoxaban, edoxaban plus VFP, fondaparinux, and FXIASO were not estimable (due to the following: there was one RCT of darexaban versus enoxaparin versus placebo which had rare events [1/88 vs. 0/90 vs. 0/96]; there was one RCT of edoxaban versus placebo with zero events, another RCT of edoxaban versus enoxaparin with rare events [4/354 vs. 1/349], and a third RCT of edoxaban versus the combination of edoxaban plus VFP with rare events [3/62 versus 3/58]; two RCTs of fondaparinux had zero events and a third RCT versus enoxaparin had rare events [11/517 vs. 1/517]; there was one RCT of FXIASO versus enoxaparin that had zero events).

Among interventions with sufficient data to allow reliable estimates (apixaban, dabigatran, enoxaparin, eribaxaban, UFH, semuloparin, TAK422, tinzaparin, and warfarin), no comparisons between interventions were found to have statistically significant differences in rates of major bleeding.

###### Summary

Across all comparisons, there were no statistically significant differences. Overall, FXIASO had the highest probability of being among the top three interventions (67%) to avoid major bleeding with thromboprophylaxis after TKR. Notably, though the mechanical device RCTs did not provide major bleeding data except for one study of the combination of edoxaban plus VFP versus edoxaban. The interventions likely to be among the bottom three interventions were darexaban (96%) and fondaparinux (65%) (Table 21). The distribution of intervention ranks is provided in Figure 53.

Table 21 Intervention ranking: Total knee replacement, intervention comparisons to avoid major bleeding

| Top 3 Ranks | Bottom 3 Ranks
Warfarin | 31% | 0%
FXIASO | 67% | 28%
Eribaxaban | 46% | 3%
Apixaban | 32% | 1%
TAK442 | 38% | 3%
Semuloparin | 31% | 3%
Enoxaparin | 2% | 0%
UFH | 22% | 6%
Dabigatran | 3% | 1%
Placebo | 10% | 6%
Tinzaparin | 9% | 15%
Edoxaban+VFP | 7% | 41%
Edoxaban | 2% | 33%
Fondaparinux | 0% | 65%
Darexaban | 1% | 96%

Percent likelihood that each intervention falls within the top 3 or bottom 3 interventions in efficacy.

Abbreviations: FXIASO = factor XI antisense oligonucleotide, UFH = unfractionated heparin.

Figure 53 Network meta-analysis ranks of specific interventions to avoid major bleeding in total knee replacement

Distribution of probability (y-axis) of treatment rankings (x-axis) by intervention based on network meta-analysis. Lower ranks indicate lower odds of outcome (greater benefit) with the given intervention compared with others.

Abbreviations: IPC = intermittent pneumatic compression, SUCRA = surface under the cumulative ranking curve.

Rank graphs for each of the 15 interventions included in the network meta-analysis of major bleeding in total knee replacement patients. Each graph has the ranks (1–15) along the x-axis and the probability of treatment ranking along the y-axis. Lower ranks indicate greater benefit with the given intervention compared to other interventions. Apixaban has a rank probability of about 0.2 at ranks 3 to 5. Dabigatran has a rank probability of about 0.2 at ranks 7 to 9. Darexaban has a rank probability of about 0.8 at rank 14. Edoxaban has a rank probability of about 0.35 at rank 12. Enoxaparin has a rank probability of about 0.25 at ranks 6 to 8. Eribaxaban has a rank probability of about 0.25 at rank 2. Fondaparinux has a rank probability of about 0.45 at rank 13. Factor 11 antisense oligonuclide has a rank probability of about 0.55 at rank 1 and another probability peak of about 0.2 at rank 13. Heparin has a flat probability distribution with rank probabilities of about 0.1 from ranks 2 to 11. Placebo has a rank probability of about 0.2 at rank 10. Semuloparin has a flat probability distribution with rank probabilities of about 0.1 to 0.15 from ranks 2 to 10. TAK422 has a rank probability of about 0.2 at rank 2. Tinzaparin has a rank probability of about 0.3 at ranks 10 and 11. Warfarin has a rank probability of about 0.2 at ranks 3 and 4.

However, except for enoxaparin no intervention was directly compared to more than two other interventions by at least two RCTs each.

### Key Question 5: Hip Fracture Surgery

#### Key Question 5 (HFx): Deep Vein Thrombosis, Total

##### Comparison of Classes

There were six RCTs that evaluated interventions in at least two classes and reported total DVT after HFx surgery. However, one RCT of antiplatelet drug (aspirin) versus a mechanical device did not connect to the network of evidence.^109^ Hence there were five RCTs included in the network meta-analysis.^25, 111–113, 165^ These RCTs compared pairs of intervention classes (four RCTs) or triplets of intervention classes (one RCT). Across this study set, four classes were evaluated (FXaI, LMWH, UFH, placebo). Of the six possible pairwise comparisons, four are covered by direct study comparisons. Figure 54 illustrates the topology of the network. LMWH was directly compared with each of the three other intervention classes; FXaI was also directly compared with placebo.

Figure 54 Network of comparison of intervention classes for total deep vein thrombosis in hip fracture surgery

Topology map for network meta-analysis of different classes of thromboprophylaxis interventions for total deep vein thrombosis outcome after hip fracture surgery. Nodes represent different classes of interventions included in the analysis. Lines between nodes indicate the pairs of intervention classes that were compared directly within trials. The thickness of the lines is proportional to the number of trials directly comparing pairs of interventions, as indicated by the associated number.

Abbreviations: FXaI = factor Xa inhibitor, HFx = hip fracture, LMWH = low molecular weight heparin, UFH = unfractionated heparin.

A topology map of the network meta-analysis of different classes of thromboprophylaxis interventions for total deep vein thrombosis outcome after hip fracture surgery. Four classes are displayed, including factor 10-a inhibitor, low molecular weight heparin, unfractionated heparin, and placebo. Of the six possible pairwise comparisons, four are covered by direct study comparisons. Low molecular weight heparin was directly compared with each of the three other intervention classes; factor 10-a inhibitor was also directly compared with placebo.

Appendix Table F7.9 shows the network meta-analysis pairwise results for all combinations of interventions classes. There were no statistically significant differences between classes.

###### Summary

There were no statistically significant differences. Overall, FXaI and UFH were likely to be among the top two interventions whereas placebo and LMWH were likely to be among the bottom two interventions (Table 22). The distribution of intervention ranks is provided in Figure 55. However, data were sparse and only LMWH was directly compared to more than two other interventions by at least two RCTs each (for two comparisons).

Table 22 Class ranking: Hip fracture surgery, intervention class comparisons to prevent deep vein thrombosis

| Top 2 Ranks | Bottom 2 Ranks
UFH | 91% | 9%
FXaI | 93% | 7%
LMWH | 14% | 86%
Placebo | 2% | 98%

Percent likelihood that each class falls within the top 2 or bottom 2 classes in efficacy.

Abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin.

Figure 55 Network meta-analysis ranks of intervention classes to prevent total deep vein thrombosis in hip fracture surgery

Distribution of probability (y-axis) of treatment rankings (x-axis) by intervention class based on network meta-analysis. Lower ranks indicate lower odds of outcome (greater benefit) with the given intervention compared with others.

Abbreviations: FXaI = factor Xa inhibitor, HFx = hip fracture, LMWH = low molecular weight heparin, SUCRA = surface under the cumulative ranking curve, UFH = unfractionated heparin.

Rank graphs for each of the 4 intervention classes included in the network meta-analysis of total DVT in hip fracture surgery patients. Each graph has the ranks (1–4) along the x-axis and the probability of treatment ranking along the y-axis. Lower ranks indicate greater benefit with the given intervention compared to other interventions. Factor 10-a inhibitors have a rank probability of about 0.6 at rank 2. Low molecular weight heparins have a rank probability of about 1.0 at rank 3. Placebo has a rank probability of about 1.0 at rank 4. Unfractionated heparin has a rank probability of about 0.6 at rank 1.

##### Comparison of Specific Interventions

In the analysis by drug (or mechanical device), there were eight RCTs that evaluated at least two interventions and reported total DVT after HFx surgery. As with the analysis by class, there was one RCT of aspirin versus VFP which did not connect to the network of evidence.^109^ Hence there were seven RCTs included in the network meta-analysis.^25, 111–114, 118, 165^ These RCTs compared pairs of interventions (six RCTs) or triplets of interventions (one RCT). Across this study set, seven interventions were evaluated (dalteparin, edoxaban, enoxaparin, fondaparinux, UFH, semuloparin, placebo). Of the 21 possible pairwise comparisons, 8 are covered by direct study comparisons. Figure 56 illustrates the topology of the network. Enoxaparin was the most common comparator, being directly compared with five other interventions. UFH was directly compared with dalteparin only.

Figure 56 Network of comparison of specific interventions for total deep vein thrombosis in hip fracture surgery

Topology map for network meta-analysis of different interventions of thromboprophylaxis for total deep vein thrombosis outcome after hip fracture surgery. Nodes represent different interventions included in the analysis. Lines between nodes indicate the pairs of intervention classes that were compared directly within trials. The thickness of the lines is proportional to the number of trials directly comparing pairs of interventions, as indicated by the associated number.

A topology map of the network meta-analysis of different specific thromboprophylaxis interventions for total deep vein thrombosis outcome after hip fracture surgery. Seven interventions are displayed, including dalteparin, edoxaban, enoxaparin, fondaparinux, heparin, semuloparin, and placebo. Of the 21 possible pairwise comparisons, 8 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with five other interventions. Heparin was directly compared with dalteparin only.

Appendix Table F7.10 shows the network meta-analysis pairwise results for all combinations of interventions. The statistically significant differences between active interventions are highlighted here.

- Fondaparinux had a lower odds of DVT compared with
  ○ enoxaparin (OR=0.340; 95% CrI 0.105 to 0.970).

###### Summary

Overall, UFH (95%) had the highest probability of being among the top three interventions to prevent DVT after HFx surgery, followed by fondaparinux (89%) and dalteparin (70%). The other three interventions were likely to be among the bottom three interventions: placebo (92%), enoxaparin (79%), and edoxaban (79%) (Table 23). The distribution of intervention ranks is provided in Figure 57. However, no intervention was directly compared to two other interventions by at least two RCTs.

Table 23 Intervention ranking: Hip fracture surgery, intervention comparisons to prevent deep vein thrombosis

| Top 3 Ranks | Bottom 3 Ranks
UFH | 95% | 3%
Fondaparinux | 89% | 3%
Dalteparin | 70% | 12%
Semuloparin | 27% | 33%
Enoxaparin | 4% | 79%
Edoxaban | 13% | 79%
Placebo | 2% | 92%

Percent likelihood that each intervention falls within the top 3 or bottom 3 interventions in efficacy.

Abbreviation: UFH = unfractionated heparin.

Figure 57 Network meta-analysis ranks of specific interventions to prevent total deep vein thrombosis in hip fracture surgery

Distribution of probability (y-axis) of treatment rankings (x-axis) by intervention based on network meta-analysis. Lower ranks indicate lower odds of outcome (greater benefit) with the given intervention compared with others. Abbreviations: SUCRA = surface under the cumulative ranking curve.

Rank graphs for each of the 7 interventions included in the network meta-analysis of total DVT in hip fracture surgery patients. Each graph has the ranks (1–7) along the x-axis and the probability of treatment ranking along the y-axis. Lower ranks indicate greater benefit with the given intervention compared to other interventions. Dalteparin has a rank probability of about 0.45 at rank 3. Edoxaban has a rank probability of about 0.55 at rank 7. Enoxaparin has a rank probability of about 0.65 at rank 5. Fondaparinux has a rank probability of about 0.55 at rank 2. Heparin has a rank probability of about 0.9 at rank 1. Placebo has a rank probability of about 0.5 at rank 6. Semuloparin has a rank probability of about 0.65 at rank 4.

#### Key Question 5 (HFx): Major Bleeding

##### Comparison of Classes

There were four RCTs that evaluated interventions in at least two classes and reported major bleeding after HFx surgery.^25, 110–112^ The RCTs compared pairs of intervention classes (2 RCTs) or triplets of intervention classes (two RCTs). Across this study set, five classes were evaluated (antiplatelet drug [aspirin], FXaI, LMWH, VKA, placebo). Of the 10 possible pairwise comparisons, 6 are covered by direct study comparisons. Figure 58 illustrates the topology of the network. Placebo was the most common comparator, being directly compared with each of the five other intervention classes.

Figure 58 Network of comparison of intervention classes for major bleeding in hip fracture surgery

Topology map for network meta-analysis of different classes of thromboprophylaxis interventions for major bleeding outcome after hip fracture surgery. Nodes represent different classes of interventions included in the analysis. Lines between nodes indicate the pairs of intervention classes that were compared directly within trials. The thickness of the lines is proportional to the number of trials directly comparing pairs of interventions, as indicated by the associated number.

Abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, VKA = vitamin K antagonist.

A topology map of the network meta-analysis of different classes of thromboprophylaxis interventions for major bleeding outcome after hip fracture surgery. Five classes are displayed, including antiplatelet drugs, factor 10-a inhibitor, low molecular weight heparin, vitamin K antagonist, and placebo. Of the 10 possible pairwise comparisons, 6 are covered by direct study comparisons. Placebo was the most common comparator, being directly compared with each of the five other intervention classes.

Appendix Table F7.11 shows the network meta-analysis pairwise results for all combinations of interventions. Results for comparisons versus antiplatelet drug and VKA were not estimable (due to the following: there was one RCT of antiplatelet drug versus VKA versus placebo which had a small sample size and rare events [1/66 vs. 5/65 vs. 5/63]). Among interventions with sufficient data to allow reliable estimates (FXaI and LMWH), the comparison between interventions was not statistically significant regarding risk of major bleeding.

###### Summary

There were no statistically significant differences. Overall, antiplatelet drug (aspirin) had the highest probability of being among the top two interventions (96%) to avoid major bleeding with thromboprophylaxis after HFx surgery, followed by VKA (52%). The interventions likely to be among the bottom two interventions were FXaI (98%) and LMWH (96%) (Table 24). The distribution of intervention ranks is provided in Figure 59. However, except for the comparison of LMWH and FXaI, only single RCTs compared intervention classes.

Table 24 Class ranking: Hip fracture surgery, intervention comparisons to avoid major bleeding

| Top 2 Ranks | Bottom 2 Ranks
Antiplatelet | 96% | 0%
VKA | 52% | 3%
Placebo | 49% | 2%
LMWH | 2% | 96%
FXaI | 1% | 98%

Percent likelihood that each class falls within the top 2 or bottom 2 classes in efficacy.

Abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, VKA = vitamin K antagonist.

Figure 59 Network meta-analysis ranks of intervention classes to avoid major bleeding in hip fracture surgery

Distribution of probability (y-axis) of treatment rankings (x-axis) by intervention class based on network meta-analysis. Lower ranks indicate lower odds of outcome (greater benefit) with the given intervention compared with others.

Abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, SUCRA = surface under the cumulative ranking curve, VKA = vitamin K antagonist.

Rank graphs for each of the 5 intervention classes included in the network meta-analysis of major bleeding in hip fracture surgery patients. Each graph has the ranks (1–5) along the x-axis and the probability of treatment ranking along the y-axis. Lower ranks indicate greater benefit with the given intervention compared to other interventions. Antiplatelet drugs have a rank probability of about 0.95 at rank 1. Factor 10-a inhibitors have a rank probability of about 0.45 at rank 4 and 0.5 at rank 5. Low molecular weight heparins have a rank probability of about 0.5 at rank 4 and 0.45 at rank 5. Placebo has a rank probability of about 0.45 at ranks 2 and 3.

##### Comparison of Specific Interventions

In the analysis by drug (or mechanical device), there were six RCTs that evaluated at least two interventions and reported major bleeding after HFx surgery.^25, 110–112, 114, 118^ The RCTs compared pairs of interventions (four RCTs) or triplets of interventions (two RCTs). Across this study set, eight interventions were evaluated (aspirin, dalteparin, edoxaban, enoxaparin, fondaparinux, semuloparin, warfarin, placebo). Of the 28 possible pairwise comparisons, 9 are covered by direct study comparisons. Figure 60 illustrates the topology of the network. Enoxaparin was the most common comparator, being directly compared with five other interventions. Aspirin and warfarin were directly compared with each other and placebo only.

Figure 60 Network of comparison of specific interventions for major bleeding in hip fracture surgery

Topology map for network meta-analysis of different interventions of thromboprophylaxis for major bleeding outcome after hip fracture surgery. Nodes represent different interventions included in the analysis. Lines between nodes indicate the pairs of intervention classes that were compared directly within trials. The thickness of the lines is proportional to the number of trials directly comparing pairs of interventions, as indicated by the associated number.

A topology map of the network meta-analysis of different specific thromboprophylaxis interventions for major bleeding outcome after hip fracture surgery. Eight interventions are displayed, including aspirin, dalteparin, edoxaban, enoxaparin, fondaparinux, semuloparin, warfarin, and placebo. Of the 28 possible pairwise comparisons, 9 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with five other interventions. Aspirin and warfarin were directly compared with each other and placebo only.

Appendix Table F7.12 shows the network meta-analysis pairwise results for all combinations of interventions. Results for comparisons with aspirin and warfarin were not estimable (due to the following: there was one RCT of aspirin versus warfarin versus placebo which had a small sample size and rare events [1/66 vs. 5/65 vs. 5/63]). Among interventions with sufficient data to allow reliable estimates (dalteparin, edoxaban, fondaparinux, and semuloparin), all comparisons between interventions were not statistically significant regarding risk of major bleeding.

###### Summary

There were no statistically significant differences. Overall, aspirin had the highest probability of being among the top three interventions (>99%) to avoid major bleeding with thromboprophylaxis after HFx surgery, followed by placebo (95%) and warfarin (94%). The interventions likely to be among the bottom three interventions were fondaparinux (82%), semuloparin (77%), and enoxaparin (67%) (Table 25). The distribution of intervention ranks is provided in Figure 61.

Table 25 Intervention ranking: Hip fracture surgery, intervention comparisons to avoid major bleeding

| Top 3 Ranks | Bottom 3 Ranks
Aspirin | 99% | 0%
Warfarin | 94% | 2%
Placebo | 95% | 2%
Dalteparin | 5% | 32%
Edoxaban | 4% | 38%
Enoxaparin | 1% | 67%
Semuloparin | 1% | 77%
Fondaparinux | 0% | 82%

Percent likelihood that each intervention falls within the top 3 or bottom 3 interventions in efficacy.

Figure 61 Network meta-analysis ranks of specific interventions to avoid major bleeding in hip fracture surgery

Distribution of probability (y-axis) of treatment rankings (x-axis) by intervention based on network meta-analysis. Lower ranks indicate lower odds of outcome (greater benefit) with the given intervention compared with others.

Abbreviations: SUCRA = surface under the cumulative ranking curve.

Rank graphs for each of the 8 interventions included in the network meta-analysis of major bleeding in hip fracture surgery patients. Each graph has the ranks (1–8) along the x-axis and the probability of treatment ranking along the y-axis. Lower ranks indicate greater benefit with the given intervention compared to other interventions. Aspirin has a rank probability of about 0.9 at rank 1. Dalteparin has a rank probability of about 0.45 at rank 4. Edoxaban has a rank probability of about 0.4 at rank 4. Enoxaparin has a rank probability of about 0.4 at rank 6. Fondaparinux has a rank probability of about 0.3 at ranks 6 and 7. Placebo has a rank probability of about 0.45 at ranks 2 and 3. Semuloparin has a rank probability of about 0.5 at rank 8. Warfarin has a rank probability of about 0.45 at ranks 2 and 3.

However, only enoxaparin and fondaparinux were directly compared by two RCTs, with similar risk of major bleeding.

### Key Question 5 (All Surgeries): Total DVT and Major Bleeding Absolute Rate Estimates, by Surgery and Class

Based on RCTs included in the network meta-analysis, we estimated rates of total DVT and major bleeding for each intervention class (with estimable data), by surgery type. These estimates are based on the summary estimates (median, minimum, and maximum) of total DVT and major bleeding for patients who received LMWH (the class with the most RCT data) and the OR for each available class compared to LMWH. The estimates are presented in Table 26.

Table 26 Estimated proportion of patients with total deep vein thrombosis after surgery, by intervention class

Surgery | Class | Total DVT Event Proportion, Median (Range) | Major Bleeding Event Proportion, Median (Range)
THR | LMWH + Mechanical Device | 0.026 (<0.001, 0.193) | No data
| FXaI | 0.076 (0.001, 0.423) | 0.023 (0.002, 0.075)
| FEI | 0.084 (0.001, 0.449) | Not estimable
| DTI | 0.085 (0.001, 0.451) | 0.022 (0.002, 0.072)
| Mechanical Devices | 0.100 (0.001, 0.497) | Not estimable
| Antiplatelet | 0.100 (0.001, 0.495) | Not estimable
| LMWH | 0.121 (0.002, 0.548) | 0.017 (0.001, 0.057)
| VKA | 0.170 (0.002, 0.644) | 0.009 (0.001, 0.030)
| UFH | 0.176 (0.002, 0.653) | 0.037 (0.003, 0.116)
TKR | LMWH + Mechanical Device | 0.099 (0.001, 0.328)
| FXaI | 0.111 (0.001, 0.356) | 0.026 (0.004, 0.089)
| Antiplatelet + Mechanical Device | 0.113 (0.001, 0.360) | No data
| LMWH + Mechanical Device | 0.126 (0.002, 0.390) | No data
| DTI | 0.131 (0.002, 0.400) | 0.019 (0.003, 0.066)
| FXIi | 0.172 (0.002, 0.480) | Not estimable
| FXaI + Mechanical Device | 0.207 (0.003, 0.537) | 0.028 (0.004, 0.096)
| LMWH | 0.209 (0.003, 0.539) | 0.015 (0.002, 0.052)
| Mechanical Devices | 0.218 (0.003, 0.553) | No data
| UFH | 0.281 (0.004, 0.634) | 0.015 (0.002, 0.053)
| VKA | 0.323 (0.005, 0.679) | 0.007 (0.001, 0.026)
| Antiplatelet | 0.351 (0.006, 0.706) | No data
HFx | UFH | 0.095 (0.002, 0.291) | No data
| FXaI | 0.124 (0.002, 0.357) | 0.028 (0.004, 0.043)
| LMWH | 0.254 (0.005, 0.571) | 0.023 (0.004, 0.035)
| Antiplatelet | No data | Not estimable
| VKA | No data | Not estimable

Within surgery type, intervention classes ordered from lowest to highest estimated DVT rates.

Abbreviations: CI = confidence interval, DTI = direct thrombin inhibitor, DVT = deep vein thrombosis, FEI = factor VIII inhibitor, FXaI = factor Xa inhibitor, FXIi = factor XI inhibitor, HFx = hip fracture surgery, LMWH = low molecular weight heparin, THR = total hip replacement, TKR = total knee replacement, UFH = unfractionated heparin, VKA = vitamin K antagonist.

## Key Question 6 Comparison of Different Start Times of Thromboprophylaxis Interventions

### Key Question 6: Total Hip Replacement

#### Key Question 6 (THR): LMWH Preoperative Versus Postoperative Start

Two RCTs (N=1063) compared LMWH started preoperatively versus postoperatively (Table 27).^81, 166^ One study found no significant difference in total DVT and proximal DVT, and reported no total PE, and no fatal PE. The other study found no significant difference in symptomatic PE. The two studies reported symptomatic DVT; one found no significant difference, and the other reported no events.

Table 27 Results summary: Total hip replacement, treatment initiation time comparisons

Comparison | Outcome | Studies, N | Patients, N | OR (95% CI), 1^*^ or Summary OR (95% CI) ^†^ | OR (95% CI), 2^*^ | OR (95% CI), 3^*^ | No Events^‡^
LMWH, preop vs. postop | PE, Total | 1 | 983 | No estimate | | | 1 RCT
| PE, Fatal | 1 | 983 | No estimate | | | 1 RCT
| PE, Symptomatic | 1 | 80 | 0.33 (0.01, 8.22)
| DVT, Total | 1 | 673 | 0.79 (0.50, 1.27)
| DVT, Symptomatic | 2 | 753 | 0.49 (0.17, 1.45) | | | 1 RCT
| DVT, Proximal | 1 | 712 | 1.01 (0.20, 5.05)
| Bleeding, Major | 1 | 983 | 1.17 (0.69, 1.97)
| Bleeding, Fatal | 1 | 983 | No estimate | | | 1 RCT
| Bleeding, Leading to reoperation | 1 | 80 | 3.08 (0.12, 77.8)
| Bleeding, Surgical site/joint | 2 | 1063 | 0.73 (0.15, 3.49) | 1.17 (0.69, 1.99)
| Mortality, 30 day or in-hospital | 1 | 983 | 4.93 (0.24, 103)

All outcomes for all pairwise comparisons with data from at least one study. If 3 or fewer randomized controlled trials (RCT) with analyzable data (i.e., at least 1 event per study) then each study’s odds ratio (OR) is listed in ascending order from left to right. If there were ≥4 analyzable studies, then meta-analysis was conducted and summary OR is reported. These are indicated by italics and by MA (meta-analysis) in the study number column. Statistically significant OR estimates are in bold text. The corresponding studies for each analysis can be found in Appendix F.

Other abbreviations: DVT = deep vein thrombosis, PE = pulmonary embolism, VTE = venothromboembolism, LMWH = low molecular weight heparin, Preop = preoperative, Postop = postoperative.

* If meta-analysis was not conducted (if there were <4 meta-analyzable trials), the individual studies’ results are presented across OR 1, 2, and 3, from lowest to highest. Statistically significant estimates are in bold. OR <1 favor the first intervention (e.g., for PE, Symptomatic, OR = 0.33 favors preoperative start).

† Summary odds ratios (from meta-analysis) are italicized. Statistically significant estimates are in bold.

‡ Number of RCTs with no events in both arms.

One RCT found no significant difference in major bleeding and 30-day mortality, and reported no fatal bleeding. The other study found no significant difference in bleeding leading to reoperation. Two studies found no significant difference in bleeding at surgical site or joint.

The studies did not report on adherence.

### Key Question 6: Total Knee Replacement

No eligible studies evaluated patients with TKR.

### Key Question 6: Hip Fracture Surgery

No eligible studies evaluated patients with HFx surgery.

## Overall Summary and Strength of Evidence

### Total Hip Replacement

Across Key Questions, 85 eligible studies evaluated thromboprophylaxis interventions in patients who underwent THR. The largest number compared different classes of interventions (relevant to Key Questions 1 and 5). The most commonly evaluated intervention class was LMWH, mostly in comparison with DTI, FXaI, UFH, and VKA. Other interventions were relatively infrequently evaluated in comparative effectiveness trials (i.e., comparisons of active, nonplacebo interventions). The most commonly evaluated outcomes were total DVT and major bleeding. Strength of evidence (SoE) is summarized in Table 28.

Table 28 Evidence profile for total hip replacement surgery

Key Question | Intervention(s) | Outcome^A^ | Design: No. Studies (N) | Study Limitations | Consistency | Precision | Reporting Bias | Other Issues | Findings^B^ —Favors: Summary OR (95% CI) or Range of Estimates | SoE Grade
1 (Class vs. class, direct comparisons) | LMWH vs. DTI | DVT, total | RCT: 3 (4600) | Low | Consistent | Imprecise | Undetected | None | Favors DTI: range 1.14 to 1.52 | Moderate
| | DVT, proximal | RCT: 3 (4600) | Low | Consistent | Imprecise | Undetected | None | Favors DTI: range 1.35 to 1.89 | Moderate
| | Bleeding, major | RCT: 4 (6900) | Low | Consistent | Imprecise | Undetected | None | Favors LMWH: 0.79 (0.55, 1.14) | Low
| | Mortality, 30 day or in-hospital | RCT: 3 (4600) | Low | Consistent | Highly imprecise | Undetected | None | Unclear: range 0.14 to 3.03 | Insufficient
| | VTE vs. AE^C^ (reported) | RCT: 4 (6900) | | | | | | Tradeoff: Favors DTI to prevent DVT. Favors LMWH to minimize major bleeding.
| LMWH vs. FXaI | VTE, total | RCT: 6 (5801) | Medium^D^ | Inconsistent | Precise | Suspected^E^,^F^ | None | Favors FXaI: 2.18 (1.52, 3.13) | Low
| | VTE, symptomatic | RCT: 7 (6157) | Medium^D^ | Consistent | Imprecise | Suspected^E^,^F^ | None | Favors LMWH: 0.72 (0.40, 1.30) | Low
| | PE, total | RCT: 4 (10080)^G^ NRCS: 1 (1056) | RCT: Low NRCS: High | Inconsistent | Highly Imprecise | Suspected^E^ | None | Unclear: range 0.33 to 1.67 | Insufficient
| | PE, fatal | RCT: 9 (11564)^G^ | Medium^D^ | Unknown | Highly imprecise | Suspected^E^ | Rare events | Unclear | Insufficient
| | PE, symptomatic | RCT: 5 (1468)^G^ | Medium^D^ | Unknown | Highly imprecise | Suspected^E^ | Rare events | Unclear | Insufficient
| | DVT, total | RCT: 10 (9346) NRCS: 1 (1056) | RCT: Medium^D^ NRCS: High | RCT: Inconsistent | RCT: Precise | Undetected | None | RCT: Favors FXaI: 1.71 (1.22, 2.39) NRCS: Either | Moderate
| | DVT, symptomatic | RCT: 9 (11,954) | Medium^D^ | Inconsistent | Imprecise | Suspected^E^ | None | Favors LMWH: 0.76 (0.37, 1.57) | Low
| | DVT, proximal | RCT: 10 (9622) | Medium^D^ | Inconsistent | Precise | Undetected | None | Favors FXaI: 2.40 (1.23, 4.69) | Moderate
| | Bleeding, major | RCT: 10 (12,457) | Medium^D^ | Consistent | Precise | Undetected | None | Favors LMWH: 0.74 (0.54, 0.99) | High
| | Bleeding, fatal | RCT: 3 (8900) | Low | Consistent | Highly imprecise | Undetected | No events | Unclear | Insufficient
| | Bleeding → reoperation | RCT: 3 (8900) | Low | Consistent | Highly imprecise | Undetected | None | Unclear | Insufficient
| | Bleeding, joint | RCT: 3 (8900) | Low | Inconsistent | Highly imprecise | Undetected | Rare events | Unclear: range 0.50 to 0.89 | Insufficient
| | Mortality, 30 day | RCT: 6 (10915)^G^ | Low | Inconsistent | Highly imprecise | Undetected | Rare events | Unclear | Insufficient
| | Serious adverse events (study-defined) | RCT: 5 (6727) | Medium^D^ | Consistent | Precise | Suspected^E^ | None | Either: 0.95 (0.78, 1.17) | Moderate
| | VTE vs. AE^C^ (reported) | RCT: 13 (13,173) | | | | | | Unclear: Inconsistent findings across VTE outcomes, but favors LMWH to minimize major bleeding.
| LMWH vs. Mechanical Devices | DVT, total | RCT: 3 (732) | Low | Consistent | Highly imprecise | Undetected | None | Unclear | Insufficient
| | DVT, proximal | RCT: 3 (732) | Low | Consistent | Highly imprecise | Undetected | None | Unclear | Insufficient
| LMWH vs. UFH | PE, total | RCT: 8 (1878) | Low | Consistent | Precise | Undetected | None | Favors LMWH: 0.29 (0.13, 0.63) | High
| | PE, fatal | RCT: 7 (1711)^G^ | Low | Consistent | Highly imprecise | Suspected^E^ | No events | Unclear | Insufficient
| | DVT, total | RCT: 10 (2219) | Low | Consistent | Imprecise | Undetected | None | Either: 0.84 (0.60, 1.18) | Moderate
| | DVT, symptomatic | RCT: 4 (488) | Low | Consistent | Highly imprecise | Suspected^E^ | None | Unclear: 0.83 (0.30, 2.35) | Insufficient
| | DVT, proximal | RCT: 6 (1506) | Low | Consistent | Precise | Suspected^E^ | None | Favors LMWH: 0.59 (0.38, 0.93) | Moderate
| | Bleeding, major | RCT: 6 (1960) | Low | Consistent | Precise | Suspected^E^ | None | Favors LMWH: 0.46 (0.23, 0.92) | Moderate
| | Bleeding, fatal | RCT: 6 (1308)^G^ | Low | Consistent | Highly imprecise | Undetected | No events | Unclear | Insufficient
| | Mortality, 30-day or in-hospital | RCT: 6 (1640)^G^ | Low | Consistent | Highly imprecise | Undetected | Rare events | Unclear | Insufficient
| | Heparin-induced thrombocytopenia | RCT: 3 (1163) | Low | Consistent | Highly imprecise | Undetected | Rare events | Unclear | Insufficient
| | VTE vs. AE^C^ (reported) | RCT: 10 (2387) | | | | | | Favors LMWH: Lower risk VTE outcomes and major bleeding.
| LMWH vs. VKA | PE, total | RCT: 3 (4537) | Low | Consistent | Highly imprecise | Undetected | Rare events | Unclear | Insufficient
| | PE fatal | RCT: 3 (4537) | Low | Consistent | Highly imprecise | Undetected | Rare events | Unclear | Insufficient
| | DVT, total | RCT: 3 (4537) | Low | Inconsistent | Imprecise | Undetected | None | Unclear: range 0.48 to 0.87 | Insufficient
| | DVT, proximal | RCT: 3 (4537) | Low | Inconsistent | Highly imprecise | Undetected | None | Unclear: range 0.27 to 1.27 | Insufficient
| | Bleeding, major | RCT: 4 (5332) | Low | Consistent | Precise | Undetected | None | Favors VKA: 1.96 (1.14, 3.38) | High
| LMWH vs. antiplatelet (ASA) drug | PE, total | NRCS: 2 (110,117)^H^ | Low | Inconsistent | Precise | Undetected | Sparse, Large NRCS | Either: 0.94 (0.75, 1.17) | Low
| | DVT, symptomatic | NRCS: 1 (108,584)^H^ | Low | N/A | Imprecise | Undetected | Sparse, Large NRCS | Either: 0.84 (0.70, 1.03) | Low
| | Bleeding, major | NRCS: 1 (108,584)^H^ | Low | N/A | Precise | Undetected | Sparse, Large NRCS | Either: 0.95 (0.77, 1.17) | Low
| | VTE vs. AE^C^ (reported) | NRCS: 2 (110,117) | | | | Undetected | | Either: Similar VTE outcomes and major bleeding with LMWH and aspirin.
| Mechanical Devices vs. VKA | DVT, total | RCT: 3 (434) | Low | Inconsistent | Imprecise | Undetected | None | Unclear: range 0.18 to 1.00 | Insufficient
| | DVT, proximal | RCT: 3 (434) | Low | Consistent | Precise | Undetected | None | Favors VKA: range 2.39 to 4.69 | High
2 (Intervention vs. intervention, direct comparisons) | All comparisons | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
3 (Different doses) | FXaI low vs. high dose | VTE, total | RCT: 4 (981) | High^I^ | Inconsistent | Precise | Undetected | None | Favors high dose: 1.55 (0.78, 3.06) | Low
| LMWH low vs. high dose | DVT, total | RCT: 5 (1441) | Medium^D^ | Inconsistent | Imprecise | Undetected | None | Favors high dose: 1.33 (0.56, 3.18) | Low
| | DVT, proximal | RCT: 4 (1047) | Medium^D^ | Consistent | Highly imprecise | Undetected | None | Either:1.04 (0.55, 1.98) | Low
| | Bleeding, major | RCT: 4 (1498) | Medium^D^ | Consistent | Precise | Undetected | None | Favors low dose: 0.42 (0.21 to 0.86) | Moderate
| | VTE vs. AE^C^ (reported) | RCT: 5 (1580) | | | | | | Tradeoff: Favors higher dose to prevent total DVT. Favors lower dose to minimize major bleeding.
| Other comparisons | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
3 (Different durations) | LMWH short vs. long duration | PE, total | RCT: 5 (1128) | Low | Consistent | Imprecise | Undetected | None | Favors long duration: 2.35 (0.83, 6.62) | Low
| | PE, fatal | RCT: 4 (1087)^G^ | Low | Consistent | Highly imprecise | Suspected^E^ | Rare events | Unclear | Insufficient
| | DVT, total | RCT: 6 (1463) | Low | Consistent | Precise | Undetected | None | Favors long duration: 2.87 (2.08, 3.96) | High
| | DVT, symptomatic | RCT: 3 (1258) | Low | Inconsistent | Highly imprecise | Suspected^E^ | None | Unclear: range 0.53 to 4.20 | Insufficient
| | DVT, proximal | RCT: 5 (1300) | Low | Consistent | Precise | Suspected^E^ | None | Favors long duration: 2.94 (1.62, 5.35) | Moderate
| | Bleeding, major | RCT: 3 (895) | Low | Consistent | Highly imprecise | Suspected^E^ | None | Unclear | Insufficient
| | Bleeding, fatal | RCT: 4 (1135)^G^ | Low | Consistent | Highly imprecise | Undetected | No events | Unclear | Insufficient
| | Mortality, 30 day | RCT: 3 (873) | Low | Consistent | Highly imprecise | Undetected | None | Unclear | Insufficient
| Other comparisons | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
4 (Single vs. combination classes) | All comparisons | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
5 (Ranking of class vs. class, per NMA) | All classes ^jJ^ | DVT, total | RCT: 53 | Low^K^ | Consistent^K^ | Precise^jK^ | Undetected^K^ | Few direct comparisons | FXaI and DTI most effective^L^ Mechanical devices and LMWH middle effectiveness^L^ UFH and VKA least effective^L^ | Moderate
| | Bleeding, major | RCT: 32 | Low^K^ | Consistent^K^ | Precise^K^ | Suspected^E^,^K^ | Very few direct comparisons | Favors LMWH over FXaI^L^ | Low
5 (Ranking of intervention vs. intervention, per NMA) | All interventions ^ M ^ | DVT, total | RCT: 54 | Low^K^ | Consistent^K^ | Precise^K^ | Undetected^K^ | Few direct comparisons | Favors dalteparin > enoxaparin > IPC > UFH > warfarin^L^ | Moderate
| | Bleeding, major | RCT: 34 | Low^K^ | Consistent^K^ | Imprecise^K^ | Suspected^E^,^K^ | Sparse direct comparisons | Unclear | Insufficient
6 (Different start times) | All comparisons | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient

This table presents the pairwise results of comparisons for which there was sufficient evidence. It does not include pairwise results for which the evidence was graded “insufficient” strength of evidence [SoE]). Italicized rows summarize across both venothromboembolism (VTE) outcomes and adverse events (for which there are sufficient evidence). Other abbreviations: AE = adverse events; CI = confidence interval, DTI = direct thrombin inhibitor, DVT = deep vein thrombosis, FXaI = factor Xa inhibitor, IPC = intermittent pneumatic compression devices, LMWH = low molecular weight heparin, NMA = network meta-analysis, NRCS = nonrandomized comparative study, OR = odds ratio, PE = pulmonary embolism, RCT = randomized controlled trials, UFH = unfractionated heparin, VKA = vitamin K inhibitor.

A Evaluated outcomes included total VTE, symptomatic VTE, total PE, fatal PE, symptomatic PE, total DVT, symptomatic DVT, proximal DVT, postthrombotic syndrome, pulmonary hypertension, major bleeding (total), surgical site or wound bleeding, other major bleeding (specific), surgical site or wound infection, surgical site or wound complications (other than bleeding or infection), heparin-induced thrombocytopenia, mechanical device complications, inferior vena cava filter complications, and other clinically significant adverse events. For each comparison, omitted outcomes had insufficient data with two or fewer studies.

B “Unclear” should be interpreted as no evidence of a difference (in contrast to evidence of no difference).

C Comparison of reported outcomes with sufficient evidence (i.e., not graded “insufficient” SoE). This row omitted if there is sufficient evidence for only VTE outcomes (not for adverse events) or only for adverse events (not for VTE outcomes).

D High risk of bias in 1 or 2 of 5 or more RCTs.

E <80% of studies of drug comparison reported given outcome, unless only one missing study (data on all VTE and major bleeding outcomes should have been available in almost all trials; therefore, outcomes were excluded selectively suggesting high risk of bias of reporting bias).

F Different trials reported either total VTE or symptomatic VTE resulting in conflicting findings between the two outcomes (FXaI results in fewer total VTE, but LMWH results in fewer symptomatic VTE).

G Fewer than 4 RCTs per comparison for individual outcome were analyzable, because other RCTs had no events.

H Although ≤2 studies, one is a very large nonrandomized comparative study that used propensity score analysis. A post hoc determination was made that this allowed for low strength of evidence.

I High risk of bias in 2 of 4 RCTs.

J Antiplatelet drug, direct thrombin inhibitors, factor VIII inhibitors, factor Xa inhibitors, low molecular weight heparin, mechanical devices, unfractionated heparin, vitamin K antagonist, and combination low molecular weight heparin and mechanical devices.

K Among classes (or interventions) compared to at least two other classes (or interventions) by at least 2 trials.

L Among the described interventions. Too few RCTs evaluated other interventions, which resulted in insufficient evidence.

M Apixaban, aspirin, dabigatran, dalteparin, darexaban, desirudin, edoxaban, enoxaparin, fondaparinux, unfractionated heparin, intermittent pneumatic compression device, semuloparin, tinzaparin, venous foot pump, warfarin, combination enoxaparin and graduated compression stocking, and combination enoxaparin and intermittent pneumatic compression.

#### Key Question 1: Comparison of Intervention Classes in THR Studies

Note that network meta-analyses comparing classes in regard to total DVT and major bleeds are presented under Key Question 5. The results of comparisons with what was deemed to have sufficient evidence are summarized here; other comparisons are noted, but were deemed to have insufficient evidence.

##### Key Points

- There were 46 RCTs and 5 NRCSs that compared classes of interventions in patients undergoing THR.
- Pairwise comparisons between classes had sufficient data (i.e., not “nsufficient” for only six pairs of classes.
  ○ LMWH vs. DTI: Across outcomes there is a tradeoff between the two drug classes. Moderate SoE favors DTI to prevent total DVT and, separately, proximal DVT, but low SoE favors LMWH to avoid major bleeding.
  ○ LMWH vs. FXaI: Across outcomes, the evidence is inconsistent. The studies found that FXaI better lowers the risk of total VTE (low SoE), total DVT (moderate SoE), and proximal DVT (moderate SoE), but LMWH better lowers the risk of symptomatic VTE (low SoE) and symptomatic DVT (low SoE). There was high SoE that LMWH is better to prevent major bleeding, but both classes were similar in rates of study-defined serious adverse events (moderate SoE). The inconsistencies in these finding suggest important reporting bias.
  ○ LMWH vs. UFH: Overall, favors LMWH, with lower risk of total PE (high SoE), proximal DVT (moderate SoE), and major bleeding (moderate SoE); risk of total DVT was similar between drug classes (moderate SoE).
  ○ LMWH vs. VKA: Overall unclear. There is insufficient evidence regarding the relative benefit of either drug class to lower the risk of any VTE outcome, but VKA results in lower risk of major bleeding (high SoE).
  ○ LMWH vs. aspirin: Based primarily on a very large propensity-score-adjusted NRCS, LMWH and aspirin result in similar rates of total PE, symptomatic DVT, and major bleeding (all low SoE).
  ○ Mechanical devices vs. VKA: Overall, unclear. VKA results in lower risk of proximal DVT (high SoE), but insufficient evidence all favors mechanical devices to lower the risk of total DVT, and adverse events data have not been reported.
  ○ For all other class comparisons and outcomes there was insufficient evidence.
  ○ Although studies reasonably should have had data for all VTE-related outcomes and for major bleeding and other serious adverse events, most outcomes were not reported by many studies, resulting in a high risk of reporting bias across the evidence base.
- A within-study subgroup analysis by chronic kidney disease category was inconclusive regarding differential risks of bleeding with LMWH and DTI.
- Industry-funded studies had similar finding as other studies. Asian studies had similar findings as non-Asian studies.

##### Summary Results

Pairwise comparisons between classes had sufficient data for at least one outcome for six pairs of classes (Table 28). For the comparison of LMWH versus DTI, among four RCTs, three favored DTI to prevent total DVT and to prevent proximal DVT. Meta-analysis of the four trials found a nonsignificant difference between drug classes regarding major bleeding favoring LMWH.

For the comparison of LMWH versus FXaI, among 13 RCTs, there is high risk of reporting bias. Most meta-analyses of VTE outcomes significantly favored FXaI (total VTE [6 RCTs, low SoE], total DVT [10 RCTs, moderate SoE], and proximal DVT [10 RCTs, moderate SoE]). The meta-analyses of symptomatic VTE (7 RCTs, low SoE) and symptomatic DVT (9 RCTs, low SoE) found no significant differences between LMWH and FXaI, but favored LMWH; however, these RCTs mostly did not report other VTE outcomes. Major bleeding was significantly less likely with LMWH (10 RCTs, high SoE), but there was no significant difference in study-defined serious adverse events (5 RCTs, moderate SoE). Given the inconsistent findings across VTE outcomes, the relative benefit of either drug class is unclear.

Among 3 RCTs of LMWH versus mechanical devices, none found significant differences for heterogeneous VTE outcomes. A NRCS found no difference in total PE. A single RCT reported significantly more frequent major bleeding with LMWH. Overall, the evidence was deemed to be insufficient to make conclusions about relative effect or harms between the two intervention classes.

From 10 RCTs, meta-analyses of LMWH versus UFH significantly favored LMWH to prevent total PE (8 RCTs, high SoE) and proximal DVT (6 RCTs, moderate SoE) and to avoid major bleeding (6 RCTs, moderate SoE), but showed no statistically significant difference in total DVT (10 RCTs, moderate SoE). Overall, the evidence favors LMWH.

Meta-analysis of the 4 RCTs of LMWH versus VKA found significantly lower rates of major bleeding with VKA (high SoE); however, the evidence regarding VTE is insufficient.

One very large NRCS (N=108,584) and another smaller NRCS (N=1,533) compared LMWH versus antiplatelet drug (aspirin). The evidence suggests both drug classes have similar effects and harms. In both adjusted and propensity-score matched analyses, the very large NRCS found no differences in rates of total PE, symptomatic DVT, and major bleeding (all low SoE).

Three RCTs evaluated mechanical devices versus VKA, overall yielding unclear findings regarding relative benefits and harms. The studies favored VKA to prevent proximal DVTs (high SoE), but insufficient evidence for total DVT favored mechanical devices, and there was no evidence regarding adverse events.

Other intervention classes compared by fewer studies (with insufficient evidence) included antiplatelet drug versus VKA (2 RCTs, one NRCS), LMWH versus antiplatelet drug (2 NRCSs), antiplatelet drug versus mechanical device (1 NRCS), mechanical devices versus UFH (1 RCT), DTI versus FXaI (1 RCT), DTI versus UFH (2 RCTs), and FEI versus FXaI (1 RCT).

###### Subgroup Analysis

One RCT reported results for serious bleeding by level of chronic kidney disease in a comparison of LMWH and DTI. Event rates were low for all participants (2% in both the desirudin and the enoxaparin arms). They reported that for chronic kidney disease category 3B (n=569), more patients experienced a major bleed in the desirudin arm than in the enoxaparin arm, although the difference was not statistically significant (1.8% vs. 0.3%; P = 0.112). For chronic kidney disease category 3A (n=758), the rates were the same (0.3% in both arms). For chronic kidney disease categories 1–2 (n=700), DVT rates were lower in the enoxaparin arm (0.6% vs. 0%).

Studies were generally homogeneous in terms of patient eligibility criteria, such that most studies included all-comers without eligibility restrictions based on demographics, or other major patient or surgery subtypes. While some studies were restricted based on past bleeding history or chronic antiplatelet or VKA use, no RCTs were restricted to the converse populations (only patients with bleeding history or on antithrombotic medication). Thus, across-study comparisons of subgroup factors are limited.

Among THR RCTs, differences between studies based on industry funding was analyzable for only the comparison of LMWH versus UFH. For total DVT, by random effects model metaregression no significant difference (P=0.51) was found between the eight industry-funded studies (summary OR 0.91, 95% CI 0.59 to 1.41) and the two studies without reported industry support (summary OR 0.71, 95% CI 0.38 to 1.32). Similarly, for major bleeding, no significant difference (P=0.95) was found between the four industry-funded studies (summary OR 0.62, 95% CI 0.13 to 2.93) and the two studies without industry support (summary OR 0.56, 95% CI 0.26 to 1.20).

For the comparison of Asian versus non-Asian RCTs, only the comparison of LMWH versus FXaI was analyzable. For total DVT, no significant difference (P=0.56) was found between the five Asian studies (summary OR 1.63, 95% CI 0.81 to 3.31) and the four non-Asian studies (summary OR 2.08, 95% CI 1.40 to 3.09) by random effects model metaregression. The non-Asian studies included more patients, largely explaining the difference in statistical significance between the two sets of studies. Overall, the same percentage of Asian and non-Asian study participants had a DVT among these RCTs (4.7%). Similarly, for major bleeding, no significant difference (P=0.16) was found between the four Asian RCTs with major bleeding events (summary OR 1.95, 95% CI 0.46 to 8.22) and the five non-Asian studies (OR 0.68, 95% CI 0.49 to 0.94). Again, the non-Asian studies included more patients, largely explaining the difference in statistical significance between the two sets of studies. The Asian RCTs had relatively few events, with an overall major bleeding rate of 0.7 percent compared to 1.5 percent among all non-Asian RCTs (P=0.041); however, if the European study with an atypically high reported major bleeding rate (3.5%) is excluded, the non-Asian RCTs have a major bleeding rate of 0.9 percent, similar to the reported Asian rate (P=0.59).

#### Key Question 2: Comparison of Within-Class Interventions in THR Studies

Note that network meta-analyses comparing individual interventions in regard to total DVT and major bleeds are presented under Key Question 5.

Relatively few RCTs of thromboprophylaxis compared specific interventions within any given class (3 for THR) (Table 28). No comparison was evaluated by more than two studies.

In patients undergoing THR, one or two RCTs each evaluated enoxaparin versus semuloparin (LMWHs), enoxaparin versus tinzaparin (LMWHs), and graduated compression stockings versus intermittent pressure devices (mechanical devices). Evidence was insufficient to evaluate within-class intervention comparisons.

#### Key Question 3: Comparison of Dosages and Treatment Durations in THR Studies

##### Key Points

- There were 22 RCTs and 2 NRCSs that compared different intervention doses or durations in patients undergoing THR
- FXaI low vs. high dose: Evidence for high versus low dose FXaI is unclear. There is low SoE that higher dose FXaI (darexaban 30 to 60 mg, edoxaban 30 mg) has a lower risk of total VTE than lower dose FXaI (darexaban 10 to 15 mg, edoxaban 15 mg), but there is insufficient evidence for other outcomes, including adverse events.
- LMWH low vs. high dose: There is evidence of a tradeoff between low and high dose LMWH. Higher dose LMWH (e.g., enoxaparin 40 mg) results in a lower risk of total DVT than lower dose LMWH (e.g., enoxaparin 20 to 30 mg) (low SoE), but both high and low dose LMWH result in similar risk of proximal DVT. Lower dose LMWH has a lower risk of major bleeding than higher dose LMWH (moderate SoE).
- LMWH short vs. long duration: The evidence supports longer duration LMWH. Longer duration LMWH (>2 weeks) results in lower risk of total PE (low SoE), total DVT (high SoE), and proximal DVT (moderate SoE) than shorter duration LMWH (up to 10 days or to hospital discharge); bleeding events were rare in the LMWH studies yielding insufficient evidence regarding relative difference in risk.

##### Summary Results

More than 300 specific comparisons of different drug doses or device regimens have been reported; the large majority of specific comparisons were made by a single study only. Comparisons with sufficient evidence are summarized here. These all pertain to class-level analyses; specific intervention comparisons were not evaluated with sufficient frequency to allow a conclusion of sufficient evidence.

For three pairwise comparisons of dose or treatment duration, there was sufficient data (Table 28). Among four RCTs comparing FXaI low versus high doses, meta-analysis yielded a nonsignificant effect favoring high dose FXaI to prevent total VTE. Data were insufficient for other outcomes.

Five RCTs compared LMWH low versus high doses. Meta-analysis of the 5 RCTs found a nonsignificant effect on total DVT favoring higher dose LMWH. Meta-analysis found no difference in effect on proximal DVTs (4 RCTs). By meta-analysis, there was significantly less risk of major bleeding with lower dose LMWH (4 RCTs).

Among 6 RCTs of LMWH short versus long duration treatment, long duration LMWH resulted in fewer total PE (5 RCTs), but the summary OR was not statistically significant. Long duration LMWH resulted in statistically significantly lower risk of total DVT (6 RCTs) and proximal DVTs (5 RCTs). Data were insufficient for adverse events.

#### Key Question 4: Comparison of Single Versus Combination Classes in THR Studies

##### Key Points

- There were 7 RCTs and 2 NRCSs that compared single versus combined classes of intervention in patients undergoing THR.
- Overall, there was insufficient evidence regarding the differences between combined or single classes of interventions to prevent VTE overall or avoid adverse events.

##### Summary Results

Note that network meta-analyses comparing individual interventions (including combination interventions) in regard to total DVT and major bleeds are presented under Key Question 5. However, in pairwise comparisons, relatively few studies directly compared combination versus single interventions (Table 28). Most specific comparisons were made by one study only.

For THR, RCTs provided insufficient evidence for comparisons of antiplatelet drug versus combination antiplatelet drug and mechanical device; LMWH alone versus combinations of LMWH and antiplatelet drug, DTI, FXaI, and mechanical device; mechanical device alone versus the mechanical device and antiplatelet drug, both antiplatelet drug and UFH, and VKA; and UFH alone versus combination UFH and LMWH. In addition, one RCT compared combination antiplatelet drug and UFH versus combination antiplatelet device, UFH, and mechanical device.

#### Key Question 5: Network Meta-Analyses in THR Studies

##### Key Points

- Conclusions from all network meta-analyses are limited due to the sparseness of direct comparisons between most interventions within each network.
- Network meta-analyses that included more than sparse connections could be constructed for only total DVT and major bleeding. Other outcomes were too sparsely populated to allow interpretable networks.
- Findings were consistent with direct, pairwise comparisons of interventions to lower the risk of total DVT and major bleeding.
- Within network meta-analyses, the exact ranking of interventions is susceptible to change with the addition of more studies and the ranking orders are not supported by evaluations of statistical significance.
- Network meta-analysis suggests that
  ○ By class
    ■ Among 53 RCTs, FXaI and DTI are most likely to be most effective to prevent total DVT; mechanical devices, LMWH, VKA, and UFH are less effective (moderate SoE). Other intervention classes have too sparse evidence to provide sufficient conclusions.
    ■ Among 32 RCTs, LMWH is more likely to result in fewer major bleeding events than FXaI (low SoE). Other intervention classes have too sparse evidence to provide sufficient conclusions.
  ○ By intervention
    ■ Among 54 RCTs, dalteparin is most likely to be most effective to prevent total DVT, compared with enoxaparin, IPC, UFH, and, warfarin (moderate SoE). Other interventions have too sparse evidence to provide sufficient conclusions.
    ■ Despite 34 RCTs, comparisons between specific pairs of interventions were too sparse to yield sufficient conclusions regarding risk of major bleeding.

Network meta-analysis findings are summarized in Table 28.

##### Total DVT: Comparison of Classes in THR Studies

There were 53 RCTs that evaluated interventions in at least two classes and reported total DVT after THR. Across this study set, 10 classes were evaluated (antiplatelet drug [aspirin], DTI, FEI, FXaI, LMWH, LMWH plus mechanical device, mechanical devices, UFH, VKA, placebo). Of the 45 possible pairwise comparisons, 17 are covered by direct study comparisons. LMWH was the most common comparator, being directly compared with seven other intervention classes, most frequently with FXaI (11 RCTs), UFH (10 RCTs), and placebo (12 RCTs). Antiplatelet drug was directly compared with placebo and VKA only; FEI was directly compared with FXaI only.

Overall, the combination of LMWH plus mechanical device intervention had the highest probability of being among the top three intervention classes (99%) to prevent total DVT in patients undergoing THR, followed by FXaI (64%). The interventions likely to be among the bottom three interventions were placebo (>99%), UFH (86%), and VKA (80%) However, omitting interventions that are directly linked to two or fewer other interventions with two or fewer RCTs each (antiplatelet drug, FEI, and combined LMWH and mechanical devices), FXaI is most effective to prevent total DVT, followed by DTI, compared with mechanical devices, LMWH, VKA, and UFH.

##### DVT: Comparison of Specific Interventions in THR Studies

In the analysis by drug (or mechanical device), there were 54 RCTs that evaluated at least two interventions and reported total DVT after THR. However, one RCT of certoparin versus certoparin plus IPC did not connect to the network of evidence and was not included. Across this study set, 20 interventions were evaluated (apixaban, aspirin, dabigatran, dalteparin, darexaban, desirudin, edoxaban, enoxaparin, enoxaparin plus GCS, enoxaparin plus IPC, fondaparinux, UFH, IPC, rivaroxaban, semuloparin, TB402, tinzaparin, VFP, warfarin, placebo). Of the 190 possible pairwise comparisons, 33 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with 14 other interventions; most frequently with UFH (7 RCTs) and placebo (8 RCTs). Dalteparin was directly compared with UFH, warfarin, and placebo only; warfarin was also directly compared with aspirin and IPC; aspirin was directly compared with placebo; TB402 was directly compared with rivaroxaban only.

Overall, the combination of enoxaparin plus IPC had the highest probability of being among the top three interventions to prevent DVT after THR (96%), followed by apixaban (67%). The interventions likely to be among the bottom three interventions were placebo (97%) and warfarin (58%) However, omitting interventions that are directly linked to two or fewer other interventions with two or fewer RCTs each (most interventions), dalteparin is most effective to prevent total DVTs, compared with enoxaparin, IPC, UFH, and warfarin.

##### Major Bleeding: Comparison of Classes in THR Studies

There were 32 RCTs that evaluated interventions in at least two classes and reported major bleeding after THR. Across this study set, 9 classes were evaluated (antiplatelet drug [aspirin], DTI, FEI, FXaI, LMWH, mechanical devices, UFH, VKA, placebo). Of the 36 possible pairwise comparisons, 10 are covered by direct study comparisons. LMWH was the most common comparator, being directly compared with six other intervention classes; most frequently with FXaI (11 RCTs), UFH (6 RCTs) and placebo (6 RCTs). Antiplatelet drug was directly compared with placebo only; FEI was directly compared with FXaI only.

Overall, the mechanical devices had the highest probability of being among the top three intervention classes (>99%) to avoid major bleeding with thromboprophylaxis after THR, followed by VKA (89%) and VKA (78%). The interventions likely to be among the bottom three interventions were FEI (>99%) and UFH (88%). However, omitting interventions that are directly linked to two or fewer other interventions with two or fewer RCTs each (all classes except LMWH and FXaI—and placebo), LMWH was more likely to result in fewer major bleeding events than FXaI.

##### Major Bleeding: Comparison of Specific Interventions in THR Studies

In the analysis by drug (or mechanical device), there were 34 RCTs that evaluated at least two interventions and reported major bleeding after THR. Across this study set, 17 interventions were evaluated (apixaban, aspirin, dabigatran, dalteparin, darexaban, desirudin, edoxaban, enoxaparin, fondaparinux, UFH, IPC, rivaroxaban, semuloparin, TB402, tinzaparin, warfarin, placebo). Of the 136 possible pairwise comparisons, 23 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with 13 other interventions; most frequently with UFH (5 RCTs) and placebo (6 RCTs). Dalteparin was directly compared with UFH, warfarin, and edoxaban only; aspirin was directly compared with placebo only; TB402 was directly compared with rivaroxaban only.

Overall, IPC had the highest probability of being among the top three interventions (>99%) to avoid major bleeding with thromboprophylaxis after THR, followed by semuloparin (63%). The interventions likely to be among the bottom three interventions were TB402 (>99%) and aspirin (86%). However, except for LMWH (and placebo) no intervention was directly compared to more than two other interventions by at least two RCTs each.

#### Key Question 6: Thromboprophylaxis Timing in THR Studies

Only two RCTs compared LMWH started at different times relative to THR surgery (Table 28). There was insufficient evidence to yield conclusions.

### Total Knee Replacement

Across Key Questions, 60 eligible studies evaluated thromboprophylaxis interventions in patients who underwent TKR. The largest number compared different classes of interventions (relevant to Key Questions 1 and 5). The most commonly evaluated intervention class was LMWH, mostly in comparison with DTI, FXaI, and VKA. Other interventions were relatively infrequently evaluated in comparative effectiveness trials (i.e., comparisons of active, nonplacebo interventions). The most commonly evaluated outcomes were total DVT and major bleeding. SoE is summarized in Table 29.

Table 29 Evidence profile for total knee replacement surgery

Key Question | Intervention(s) | Outcome^A^ | Design: No. Studies (N) | Study Limitations | Consistency | Precision | Reporting Bias | Other Issues | Findings^B^ —Favors: Summary OR (95% CI) or Range of Estimates | SoE Grade
1 (Class vs. class, direct comparisons) | Antiplatelet vs. FXaI | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
| Antiplatelet vs. Mechanical Device | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
| Antiplatelet vs. VKA | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
| DTI vs. FXaI | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
| LMWH vs. antiplatelet | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
| LMWH vs. DTI | DVT, symptomatic | RCT: 3 (2906) | Low | Inconsistent | Highly imprecise | Suspected^C^ | None | Unclear: range 0.67 to 7.96 | Insufficient
| | Bleeding, major | RCT: 5 (3514) | Low | Consistent | Highly Imprecise | Undetected | None | Unclear: 0.96 (0.43, 2.16) | Insufficient
| LMWH vs. FXaI | VTE, total | RCT: 4 (1260) | Medium^D^ | Consistent | Imprecise | Suspected^C^ | None | Favors FXaI: 1.33 (0.89, 1.99) | Low
| | VTE, symptomatic | RCT: 3 (2058) | Medium^D^ | Inconsistent | Highly imprecise | Suspected^C^ | None | Unclear: range 0.25 to 2.02 | Insufficient
| | PE, total | RCT: 5 (4693)^E^ | Medium^D^ | Consistent | Highly imprecise | Suspected^C^ | Sparse | Unclear: range 0.14 to 2.59 | Insufficient
| | PE, fatal | RCT: 5 (5214)^E^ | Medium^D^ | Inconsistent | Highly imprecise | Suspected^C^ | None | Unclear: range 0.20 to 1.00 | Insufficient
| | PE, symptomatic | RCT: 3 (121) | Medium^D^ | Consistent | Highly imprecise | Suspected^C^ | None | Unclear | Insufficient
| | DVT, total | RCT: 7 (3805) | High^F^ | Consistent | Precise | Suspected^C^ | None | Favors FXaI: 2.09 (1.70, 2.58) | Low
| | DVT, symptomatic | RCT: 8 (5715) | High^F^ | Consistent | Imprecise | Undetected | None | Either: 0.99 (0.51, 1.91) | Low
| | DVT, proximal | RCT: 6 (4402) | Medium^D^ | Consistent | Precise | Suspected^C^ | None | Favors FXaI: 1.84 (1.07, 3.16) | Moderate
| | Bleeding, major | RCT: 7 (5926) | Medium^D^ | Inconsistent | Imprecise | Suspected^C^ | None | Favors LMWH: 0.74 (0.42, 1.30) | Low
| | Mortality, 30 day | RCT: 3 (3189) | Medium^D^ | Inconsistent | Highly imprecise | Undetected | None | Unclear | Insufficient
| | Serious adverse events (study-defined) | RCT: 4 (1803) | Medium^D^ | Consistent | Imprecise | Suspected^C^ | None | Favors FXaI: 1.51 (0.80, 2.85) | Low
| | VTE vs. AE^G^ (reported) | RCT: 10 (6350) | | | | | | Unclear Favors FXaI to prevent VTE outcomes, but inconsistent regarding major bleeding and serious adverse events.
| LMWH vs. FXIi | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
| LMWH vs. Mechanical Device | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
| LMWH vs. UFH | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
| LMWH vs. VKA | PE, total | RCT: 4 (1878) | Low | Consistent | Highly imprecise | Undetected | None | Unclear: 0.61 (0.15, 2.43) | Insufficient
| | PE, fatal | RCT: 3 (1742) | Low | Consistent | Highly imprecise | Undetected | No events | Unclear | Insufficient
| | DVT, total | RCT: 3 (1742) | Low | Consistent | Precise | Undetected | None | Favors LMWH: range 0.42 to 0.67 | High
| | DVT, proximal | RCT: 4 (1772) | Low | Inconsistent | Imprecise | Undetected | None | Favors LMWH: 0.51 (0.21, 1.28) | Low
| | Bleeding, major | RCT: 4 (1960)^E^ | Low | Consistent | Imprecise | Undetected | None | Favors VKA: range 1.16 to 3.13 | Low
| | Bleeding, fatal | RCT: 3 (1742) | Low | Consistent | Highly imprecise | Undetected | Sparse | Unclear | Insufficient
| | VTE vs. AE^G^ (reported) | RCT: 4 (1960) | | | | | | Tradeoff: Favors LMWH to prevent DVT. Favors VKA to minimize major bleeding.
| VKA vs. FXaI | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
2 (Intervention vs. intervention, direct comparisons) | All comparisons | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
3 (Different doses) | DTI low vs. high dose | DVT, total | RCT: 3 (577) | Medium^D^ | Consistent | Precise | Undetected | None | Favors high dose; range: 1.54 to 2.08 | High
| | DVT, symptomatic | RCT: 4 (3141) | Medium^D^ | Consistent | Highly imprecise | Undetected | None | Unclear: 1.14 (0.49, 2.65) | Insufficient
| | DVT, proximal | RCT: 4 (1860) | Medium^D^ | Consistent | Precise | Undetected | None | Favors high dose: 1.57 (0.83, 2.96) | Moderate
| | Bleeding, major | RCT: 5 (3875) | Medium^D^ | Consistent | Imprecise | Undetected | None | Favors low dose: 0.65 (0.34, 1.24) | Low
| | Mortality, 30 day or in-hospital | RCT: 4 (3628)^E^ | Medium^D^ | Inconsistent | Imprecise | Undetected | Sparse | Unclear | Insufficient
| | VTE vs. AE^G^ (reported) | RCT: 5 (3875) | | | | | | Tradeoff: Favors higher dose to prevent DVT. Favors lower dose to minimize major bleeding.
| FXaI low vs. high dose | VTE, total | RCT: 4 (779) | High^H^ | Consistent | Precise | Undetected | None | Favors high dose: 2.06 (1.48, 2.86) | Moderate
| | DVT, symptomatic | RCT: 4 (802) | High^H^ | Consistent | Precise | Undetected | Sparse | Favors high dose: range: 2.93 to 4.37 | Low
| | DVT, proximal | RCT: 4 (784) | High^H^ | Consistent | Imprecise | Undetected | None | Favors high dose: 2.51 (0.85, 7.42) | Low
| | Bleeding, major | RCT: 4 (1095) | High^H^ | Consistent | Highly imprecise | Undetected | Sparse | Either: range: 0.32 to 5.03 | Insufficient
| Dabigatran 150 mg vs. 220 mg | DVT, symptomatic | RCT: 3 (2879) | Low | Inconsistent | Highly imprecise | Undetected | None | Unclear | Insufficient
| | Bleeding, major | RCT: 3 (3365) | Low | Consistent | Highly imprecise | Undetected | None | Unclear | Insufficient
| | Bleeding, fatal | RCT: 3 (3365) | Low | Consistent | Highly imprecise | Undetected | No events | Unclear | Insufficient
| | Bleeding → reoperation | RCT: 3 (3365) | Low | Consistent | Highly imprecise | Undetected | None | Unclear | Insufficient
| | Mortality, 30 day | RCT: 3 (3365) | Low | Consistent | Highly imprecise | Undetected | None | Unclear | Insufficient
| Other comparisons | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
3 (Different durations) | All comparisons | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
4 (Single vs. combination classes) | LMWH vs. LMWH+Mechanical Device | DVT, total | RCT: 3 | | | | | Sparse | Unclear | Insufficient
| All other comparisons | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
5 (Ranking of class vs. class, per NMA) | All classes ^ I ^ | DVT, total | RCT: 31 | Low^J^ | Consistent^J^ | Precise^J^ | Undetected^J^ | Very few direct comparisons | Favors FXaI over LMWH^J^ | Low
| | Bleeding, major | RCT: 23 | Low^J^ | Consistent^J^ | Precise^J^ | Suspected^C^,^J^ | Very few direct comparisons | Favors LMWH over FXaI^J^ | Low
5 (Ranking of intervention vs. intervention, per NMA) | All interventions ^ K ^ | DVT, total | RCT: 33 | Low^J^ | Consistent^J^ | Imprecise^J^ | Undetected^J^ | Sparse direct comparisons | Unclear | Insufficient
| | Bleeding, major | RCT: 24 | Low^J^ | Consistent^J^ | Imprecise^J^ | Suspected^C^,^J^ | Sparse direct comparisons | Unclear | Insufficient
6 (Different start times) | All comparisons | All outcomes | RCT: 0 | | | | | Sparse | Unclear | Insufficient

This table presents the pairwise results of comparisons for which there was sufficient evidence. It does not include pairwise results for which the evidence was graded “insufficient” strength of evidence [SoE]). Italicized rows summarize across both venothromboembolism (VTE) outcomes and adverse events (for which there are sufficient evidence). Other abbreviations: AE = adverse events, CI = confidence interval, DTI = direct thrombin inhibitor, DVT = deep vein thrombosis, FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, NMA = network meta-analysis, NRCS = nonrandomized comparative study, OR = odds ratio, PE = pulmonary embolism, RCT = randomized controlled trials, UFH = unfractionated heparin, VKA = vitamin K inhibitor.

A Evaluated outcomes included total VTE, symptomatic VTE, total PE, fatal PE, symptomatic PE, total DVT, symptomatic DVT, proximal DVT, postthrombotic syndrome, pulmonary hypertension, major bleeding (total), surgical site or wound bleeding, other major bleeding (specific), surgical site or wound infection, surgical site or wound complications (other than bleeding or infection), heparin-induced thrombocytopenia, mechanical device complications, inferior vena cava filter complications, and other clinically significant adverse events. For each comparison, omitted outcomes had insufficient data with two or fewer studies.

B “Unclear” should be interpreted as no evidence of a difference (in contrast to evidence of no difference).

C <80% of studies of drug comparison reported given outcome, unless only one missing study (data on all VTE and major bleeding outcomes should have been available in almost all trials; therefore, outcomes were excluded selectively suggesting high risk of bias of reporting bias).

D High risk of bias in 1 or 2 of 5 or more RCTs.

E Fewer than 4 RCTs per comparison for individual outcome were analyzable, because other RCTs had no events.

F High risk of bias in 3 RCTs.

G Comparison of reported outcomes with sufficient evidence (i.e., not graded “insufficient” SoE). This row omitted if there is sufficient evidence for only VTE outcomes (not for adverse events) or only for adverse events (not for VTE outcomes).

H High risk of bias in 2 of 4 RCTs.

I Antiplatelet drug, direct thrombin inhibitors, factor VIII inhibitors, factor Xa inhibitors, low molecular weight heparin, mechanical devices, unfractionated heparin, vitamin K antagonist, and combination low molecular weight heparin and mechanical device.

J Among classes (or interventions) compared to at least two other classes (or interventions) by at least 2 trials.

K Apixaban, aspirin, dabigatran, dalteparin, darexaban, desirudin, edoxaban, enoxaparin, fondaparinux, heparin (unfractionated), intermittent pneumatic compression device, semuloparin, tinzaparin, venous foot pump, warfarin, combination enoxaparin and graduated compression stocking, and combination enoxaparin and intermittent pneumatic compression.

#### Key Question 1: Comparison of Intervention Classes in TKR Studies

Note that network meta-analyses comparing classes in regard to total DVT and major bleeds are presented under Key Question 5. The results of comparisons with what was deemed to have sufficient evidence are summarized here; other comparisons are noted, but were deemed to have insufficient evidence.

##### Key Points

- There were 29 RCTs and 6 NRCSs that compared classes of interventions in patients undergoing TKR.
- Pairwise comparisons between classes had sufficient data for meta-analyses for only two pairs of classes.
  ○ LMWH vs. FXaI: Overall, the evidence is unclear. FXaI results in a lower risk of total VTE (low SoE), total DVT (low SoE), and proximal DVT (moderate SoE), but similar risks for total VTE (moderate SoE) and symptomatic DVT (low SoE); risk of major bleeding is lower with LMWH (low SoE) but risk of study-defined serious adverse events is lower with FXaI (low SoE).
  ○ LMWH vs. VKA: There is a tradeoff in risks between the two drug classes, such that LMWH better lowers risk of total DVT (high SoE) and proximal DVT (low SoE), but VKA has a lower risk of major bleeding (low SoE).
  ○ For all other class comparisons and outcomes there was insufficient direct comparative evidence.
  ○ Although studies reasonably should have had data for all VTE-related outcomes and for major bleeding and other serious adverse events; most outcomes were not reported by many studies, resulting in a high risk of reporting bias across the evidence base.
- A within-study subgroup analysis did not find a substantial difference in relative effect of antiplatelet drug vs. mechanical device between unilateral or bilateral TKR surgery.
- Industry-funded studies had similar finding as other studies. Asian studies had similar findings as non-Asian studies.

##### Summary Results

Pairwise comparisons between classes had sufficient data for meta-analysis for only two pairs of classes (Table 29). For the comparison of LMWH versus FXaI, across 10 RCTs, meta-analysis significantly favored FXaI to prevent total DVT (7 RCTs) and proximal DVT (6 RCTs). While not statistically significant, the evidence favored FXaI to reduce the risk of total VTE (4 RCTs) with lower rates of study-defined serious adverse events (4 RCTs). Major bleeding occurred (nonsignificantly) less frequently with LMWH (7 RCTs). Rates of symptomatic DVT were the same with both drug classes (8 RCTs).

Among 4 RCTs that compared LMWH versus VKA, LMWH treatment resulted in less frequent total DVT (nonsignificantly) in 3 RCTs and proximal DVT across 4 RCTs (also not statistically significant); 4 RCTs found (nonsignificantly) lower risk of major bleeding with VKA.

Other intervention classes compared by fewer studies (with insufficient evidence) included antiplatelet drug (aspirin) versus FXaI (1 RCT), antiplatelet drug versus mechanical devices (1 RCT, 1 NRCS), antiplatelet drug versus VKA (1 RCT), DTI versus FXaI (1 RCT), LMWH versus antiplatelet drug (1 RCT), LMWH versus FXIi (1 RCT), LMWH versus mechanical devices (1 RCT and 1 NRCS), LMWH versus UFH (2 RCTs), and VKA versus mechanical devices (1 NRCS). Five RCTs evaluated LMWH vs. DTI but had highly inconsistent findings related to symptomatic DVT (3 RCTs) and rare episodes of major bleeding resulting in a highly imprecise effect estimate (5 RCTs).

##### Subgroup Analysis

One RCT compared subgroups of patients who received unilateral or bilateral TKR surgery in a comparison of antiplatelet drug (aspirin) versus mechanical device; the trial was conducted in the 1980s and included an unrestricted sample of adult patients undergoing TKR. They found that in the unilateral surgery group (n=72) the percent of patients with a DVT was lower for those receiving mechanical prophylaxis through a compression boot (22%) compared to those receiving aspirin (47%, P<0.03). In the bilateral surgery group (n=47), DVT incidence was also lower in patients who used compression boots (48%) compared with those who received aspirin (68%), but this difference was not significant (P<0.20). Whether the treatment effect differed between unilateral and bilateral surgery subgroups was not analyzed.

Studies were generally homogeneous in terms of patient eligibility criteria, such that most across-study comparisons of subgroup factors are limited.

Among TKR RCTs, differences between studies based on industry funding was analyzable for only the comparison of LMWH versus FXaI. For total DVT, by random effects model metaregression no significant difference (P=0.21) was found between the six industry-funded studies (summary OR 2.04, 95% CI 1.68 to 2.49) and the single study without industry support (OR 4.71, 95% CI 1.31 to 16.9).

For the comparison of Asian versus non-Asian RCTs, only the comparison of LMWH versus FXaI was analyzable. For total DVT, no significant difference (P=0.97) was found between the four Asian studies (summary OR 2.15, 95% CI 1.35 to 3.41) and three non-Asian studies (summary OR 2.12, 95% CI 1.59 to 2.82) by random effects model metaregression. However, the total DVT rate was lower in the Asian RCTs (9.6%) than the non-Asian studies (16.0%, P<0.01). Similarly, for major bleeding, no significant difference (P=0.34) was found between the two Asian studies (summary OR 0.27, 95% CI 0.03 to 2.32) and the five non-Asian studies (OR 0.89, 95% CI 0.29 to 2.72). Major bleeding rates were similar between Asian studies (0.7%) and non-Asian studies (0.9%, P=0.57).

#### Key Question 2: Comparison of Within-Class Interventions in TKR Studies

Note that network meta-analyses comparing individual interventions in regard to total DVT and major bleeds are presented under Key Question 5.

Relatively few RCTs of thromboprophylaxis compared specific interventions within any given class (2 for TKR) (Table 29). No comparison was evaluated by more than two studies. In patients undergoing TKR, one or two RCTs each evaluated enoxaparin versus semuloparin (LMWHs), enoxaparin versus tinzaparin (LMWHs), and graduated compression stockings versus intermittent pressure devices (mechanical devices). Evidence was insufficient to evaluate within-class intervention comparisons.

#### Key Question 3: Comparison of Dosages and Treatment Durations in TKR Studies

##### Key Points

- There were 18 RCTs and 1 NRCS that compared different intervention doses or durations in patients undergoing TKR.
  ○ DTI low vs. high dose: There is evidence of a tradeoff between low and high dose DTI. Higher dose DTI (dabigatran 220 to 225 mg) has a lower risk of total DVT (high SoE) and proximal DVT (moderate SoE) than lower dose (dabigatran 150 mg), but lower dose DTI has less risk of major bleeding (low SoE)
  ○ FXaI low vs. high dose: Overall, the evidence is unclear. Higher dose FXaI (e.g., edoxaban 60 mg, darexaban 30 mg) results in a lower risk of total VTE (moderate SoE), symptomatic DVT (low SoE), and proximal DVT (low SoE) than lower dose FXaI (e.g., edoxaban 5 mg, darexaban 15 mg); however, there was insufficient evidence for adverse events.

##### Summary Results

More than 300 specific comparisons of different drug doses or device regimens have been reported; the large majority of specific comparisons were made by a single study only. Comparisons with sufficient evidence are summarized here. These all pertain to class-level analyses; specific intervention comparisons were not evaluated with sufficient frequency to allow a conclusion of sufficient evidence.

For only two pairwise comparisons of dose or treatment duration were there sufficient data (Table 29). Among five RCTs of low versus high dose DTI, studies favored higher dose DTI (e.g., dabigatran 220 mg/day) over lower dose DTI (e.g., dabigatran 150 mg/day) to prevent total DVT (3 RCTs) and proximal DVT (4 RCTs). By meta-analysis the five RCTs nonsignificantly favored lower dose DTI to avoid major bleeding.

Among four RCTs of low versus high dose FXaI, studies favored higher dose FXaI (multiple drugs, mostly twice the lower dose) over lower dose FXaI to prevent total VTE (4 RCTs), symptomatic DVT (4 RCTs), and proximal DVT (4 RCTs). Four RCTs were highly imprecise and inconsistent regarding difference in major bleeding risk, thus providing insufficient evidence.

#### Key Question 4: Comparison of Single Versus Combination Classes in TKR Studies

##### Key Points

- There were 8 RCTs and 3 NRCSs that compared single versus combined classes of intervention in patients undergoing TKR.
- Overall, there was insufficient evidence regarding the differences between combined or single classes of interventions to prevent VTE overall or avoid adverse events.

##### Summary Results

Note that network meta-analyses comparing individual interventions (including combination interventions) in regard to total DVT and major bleeds are presented under Key Question 5. However, in pairwise comparisons, relatively few studies directly compared combination versus single interventions (Table 29). Most specific comparisons were made by one study only.

For TKR, RCTs provided insufficient evidence for comparisons of antiplatelet drug versus combination antiplatelet drug and mechanical device; LMWH alone versus combinations of LMWH and FEI or mechanical device, and UFH alone versus combination UFH and LMWH.

#### Key Question 5: Network Meta-Analyses in TKR Studies

##### Key Points

- Conclusions from all network meta-analyses are limited due to the sparseness of direct comparisons between most interventions within each network.
- Network meta-analyses that included more than sparse connections could be constructed for only total DVT and major bleeding. Other outcomes were too sparsely populated to allow interpretable networks.
- Network meta-analysis suggests that
  ○ By class
    ■ Among 31 RCTs, FXaI is more effective to prevent total DVT than LMWH (low SoE).
    ■ Among 23 RCTs, LMWH is more likely to result in fewer major bleeding events than FXaI (low SoE).
    ■ Other intervention classes have too sparse evidence to provide sufficient conclusions.
  ○ By intervention
    ■ Among 33 RCTs for total DVT and 24 RCTs for major bleeding., data were too sparse to yield sufficient conclusions.

Network meta-analysis findings are summarized in Table 29.

##### DVT: Comparison of Classes in TKR Studies

There were 31 RCTs that evaluated interventions in at least two classes and reported total DVT after TKR. Across this study set, 12 classes were evaluated (antiplatelet drug [aspirin], antiplatelet drug plus mechanical device, DTI, FXaI, FXaI plus mechanical device, FXIi, LMWH, LMWH plus mechanical device, mechanical devices, UFH, VKA, placebo). Of the 66 possible pairwise comparisons, 20 are covered by direct study comparisons. LMWH was the most common comparator, being directly compared with nine other intervention classes; most frequently with FXaI (7 RCTs). The combination of antiplatelet drug plus mechanical device was directly compared with antiplatelet drug and LMWH plus mechanical device; the combination of FXaI plus mechanical device was directly compared with FXaI only.

Overall, FXaI had the highest probability of being among the top three intervention classes (84%) to prevent DVT after TKR, followed closely by the combination of LMWH plus mechanical device (81%), then the combination of antiplatelet drug plus mechanical device (66%). The interventions likely to be among the bottom three interventions were placebo (>99%), antiplatelet drug (86%), and VKA (76%). However, except for LMWH and FXaI (and placebo) no intervention was directly compared to more than two other interventions by at least two RCTs each. FXaI is more effective to prevent total DVTs than LMWH.

##### DVT: Comparison of Specific Interventions in TKR Studies

In the analysis by drug (or mechanical device), there were 33 RCTs that evaluated at least two interventions and reported total DVT after TKR. However, one RCT of certoparin versus certoparin plus IPC did not connect to the network of evidence and was not included. Across this study set, 23 interventions were evaluated (apixaban, aspirin, aspirin plus IPC, aspirin plus VFP, dabigatran, darexaban, edoxaban, edoxaban plus VFP, enoxaparin, enoxaparin plus GCS, enoxaparin plus IPC, enoxaparin plus VFP, flexion, fondaparinux, FXIASO, UFH, IPC, rivaroxaban, semuloparin, tinzaparin, VFP, warfarin, placebo). Of the 253 possible pairwise comparisons, 34 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with 16 other interventions. Flexion was directly compared with placebo only; enoxaparin plus GCS was directly compared with enoxaparin plus IPC only; IPC and aspirin plus VFP were directly compared with aspirin only; aspirin plus IPC was directly compared with enoxaparin plus IPC only; and edoxaban plus VFP was directly compared with edoxaban only.

Overall, rivaroxaban had the highest probability (68%) of being among the top three interventions to prevent DVT after TKR, followed by flexion (65%) and the combination of enoxaparin plus VFP (63%) and the combination of aspirin plus VFP (59%). The interventions likely to be among the bottom three interventions were the combination of enoxaparin plus GCS (>99%) and placebo (76%). However, except for enoxaparin (and placebo) no intervention was directly compared to more than two other interventions by at least two RCTs each.

##### Major Bleeding: Comparison of Classes in TKR Studies

There were 23 RCTs that evaluated interventions in at least two classes and reported major bleeding after TKR. However, one RCT of antiplatelet drug (aspirin) versus the combination of antiplatelet drug (aspirin) plus mechanical device did not connect to the network of evidence and was not included. Across this study set, 8 classes were evaluated (DTI, FXaI, FXaI plus mechanical device, FXIi, LMWH, UFH, VKA, placebo). Of the 28 possible pairwise comparisons, 10 are covered by direct study comparisons. LMWH was the most common comparator, being directly compared with each of six other intervention classes; most frequently with FXaI (7 RCTs), DTI (5 RCTs), and VKA (4 RCTs). The combination of FXaI plus mechanical device was directly compared to FXaI only.

Across all comparisons, there were no statistically significant differences. Overall, VKA had the highest probability of being among the top three intervention classes (84%) to avoid major bleeding with thromboprophylaxis after TKR. Notably, though the mechanical device RCTs did not provide major bleeding data except for the one study of FXaI plus mechanical device versus FXaI. The interventions likely to be among the bottom three interventions were FXIi (68%) and FXaI (60%). However, except for LMWH (and placebo) no intervention was directly compared to more than two other interventions by at least two RCTs each. LMWH was more likely to result in fewer major bleeding events than FXaI.

##### Major Bleeding: Comparison of Specific Interventions in TKR Studies

In the analysis by drug (or mechanical device), there were 24 RCTs that evaluated at least two interventions and reported major bleeding after TKR. However, one RCT of aspirin versus the combination of aspirin plus VFP did not connect to the network of evidence and was not included. Across this study set, 15 interventions were evaluated (apixaban, dabigatran, darexaban, edoxaban, edoxaban plus VFP, enoxaparin, eribaxaban, fondaparinux, FXIASO, UFH, semuloparin, TAK422, tinzaparin, warfarin, placebo). Of the 105 possible pairwise comparisons, 22 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with each of 13 other interventions; most frequently with dabigatran (5 RCTs). The combination of edoxaban plus VFP was directly compared with edoxaban only.

Across all comparisons, there were no statistically significant differences. Overall, FXIASO had the highest probability of being among the top three interventions (67%) to avoid major bleeding with thromboprophylaxis after TKR. Notably, though the mechanical device RCTs did not provide major bleeding data except for one study of the combination of edoxaban plus VFP versus edoxaban. The interventions likely to be among the bottom three interventions were darexaban (96%) and fondaparinux (65%). However, except for enoxaparin no intervention was directly compared to more than two other interventions by at least two RCTs each.

#### Key Question 6: Thromboprophylaxis Timing in TKR Studies

No eligible studies evaluated patients with TKR (Table 29).

### Hip Fracture Surgery

Across Key Questions, 12 eligible studies evaluated thromboprophylaxis interventions in patients who underwent HFx surgery. No comparison between classes, interventions, or intervention regimens was evaluated by more than three studies, mostly by only one RCT. SoE is insufficient throughout and summarized in Table 30.

Table 30 Evidence profile for hip fracture surgery

Key Question | Intervention(s) | Outcome^*^ | Design: No. Studies (N) | Study Limitations | Consistency | Precision | Reporting Bias | Other Issues | Findings^†^ — Favors: Summary OR (95% CI) or Range of Estimates | SoE Grade
1 (Class vs. class, direct comparisons) | Antiplatelet vs. Mechanical Device | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
| Antiplatelet vs. VKA | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
| LMWH vs. FXaI | DVT, total | RCT: 3 (1816) | Low | Inconsistent | Precise | Undetected | None | Favors LMWH: 2.71 to 3.81^‡^ | Moderate
| | Bleeding, major | RCT: 3 (1816) | Low | Inconsistent | Highly imprecise | Undetected | None | Unclear: range 0.18 to 2.09 | Insufficient
| LMWH vs. UFH | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
2 (Intervention vs. intervention, direct comparisons) | All comparisons | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
3 (Different doses) | All comparisons | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
3 (Different durations) | All comparisons | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
4 (Single vs. combination classes) | All comparisons | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient
5 (Ranking of class vs. class, per NMA) | All classes ^ \|\| ^ | DVT, total | RCT: 5 (2003) | Low | Consistent | Imprecise | Undetected | Sparse direct comparisons | Unclear | Insufficient
| | Major bleeding | RCT: 4 (2039) | Low | Consistent | Imprecise | Suspected ^§^ | Sparse direct comparisons | Unclear | Insufficient
5 (Ranking of intervention vs. intervention, per NMA) | All interventions ^ # ^ | DVT, total | RCT: 8 (3122) | Low | Consistent | Imprecise | Undetected | Sparse direct comparisons | Unclear | Insufficient
| | Major bleeding | RCT: 6 (3158) | Low | Consistent | Imprecise | Suspected ^§^ | Sparse direct comparisons | Unclear | Insufficient
6 (Different start times) | All comparisons | All outcomes | RCT:≤2 per comparison | | | | | Sparse | Unclear | Insufficient

This table presents the pairwise results of comparisons for which there was sufficient evidence. It does not include pairwise results for which the evidence was graded “insufficient” strength of evidence [SoE]). Other abbreviations: CI = confidence interval, DVT = deep vein thrombosis, NMA = network meta-analysis, OR = odds ratio, RCT = randomized controlled trial.

* Evaluated outcomes included total venothromboembolism (VTE), symptomatic VTE, total pulmonary embolism (PE), fatal PE, symptomatic PE, total deep vein thrombosis (DVT), symptomatic DVT, proximal DVT, postthrombotic syndrome, pulmonary hypertension, major bleeding (total), surgical site or wound bleeding, other major bleeding (specific), surgical site or wound infection, surgical site or wound complications (other than bleeding or infection), heparin-induced thrombocytopenia, mechanical device complications, inferior vena cava filter complications, and other clinically significant adverse events. For each comparison, omitted outcomes had insufficient data with two or fewer studies.

† “Unclear” should be interpreted as no evidence of a difference (in contrast to evidence of no difference).

‡ A third highly imprecise trial had an odds ratio of 0.55 (95% CI 0.05, 5.58)

§ <80% of studies of drug comparison reported given outcome, unless only one missing study (data on all VTE and major bleeding outcomes should have been available in almost all trials; therefore, outcomes were excluded selectively suggesting high risk of bias of reporting bias).

|| Antiplatelet drug, direct thrombin inhibitors, factor VIII inhibitors, factor Xa inhibitors, low molecular weight heparin, mechanical devices, unfractionated heparin, vitamin K antagonist, and combination low molecular weight heparin and mechanical device.

# Apixaban, aspirin, dabigatran, dalteparin, darexaban, desirudin, edoxaban, enoxaparin, fondaparinux, heparin (unfractionated), intermittent pneumatic compression device, semuloparin, tinzaparin, venous foot pump, warfarin, combination enoxaparin and graduated compression stocking, and combination enoxaparin and intermittent pneumatic compression.

#### Key Question 1: Comparison of Intervention Classes in HFx Surgery Studies

Note that network meta-analyses comparing classes in regard to total DVT and major bleeds are presented under Key Question 5. The results of comparisons with what was deemed to have sufficient evidence are summarized here; other comparisons are noted, but were deemed to have insufficient evidence.

##### Key Points

- There were 6 RCTs that compared classes of interventions in patients undergoing HFx surgery.
- LMWH vs. FXaI: Overall, the evidence is unclear. There is moderate SoE that LMWH results in a lower risk of total DVT. There is insufficient evidence for all other outcomes, including adverse events.

##### Summary Results

Only 6 RCTs of thromboprophylaxis have been conducted comparing intervention classes in patients undergoing HFx surgery. Pairwise comparisons between classes had sufficient data only for the comparison of LMWH versus FXaI (Table 30). The 3 RCTs that compared LMWH versus FXaI found lower risk of total DVT with LMWH, but there was insufficient evidence regarding other outcomes. Other interventions classes compared included antiplatelet drug (aspirin) versus mechanical devices (1 RCT), antiplatelet drug versus VKA (1 RCT), and LMWH versus UFH (1 RCT); there was insufficient evidence regarding these comparisons.

#### Key Question 2: Comparison of Within-Class Interventions in HFx Surgery Studies

Note that network meta-analyses comparing individual interventions in regard to total DVT and major bleeds are presented under Key Question 5.

Only two RCTs compared specific interventions within any given class for patients undergoing HFx surgery (Table 30). In patients with HFx surgery, one RCT each compared enoxaparin versus dalteparin (LMWHs) and enoxaparin versus semuloparin (LMWHs). Evidence was insufficient to evaluate within-class intervention comparisons.

#### Key Question 3: Comparison of Dosages and Treatment Durations in HFx Surgery Studies

One RCT each compared different duration FXaI and LMWH, providing insufficient evidence (Table 30).

#### Key Question 4: Comparison of Single Versus Combination Classes in HFx Surgery Studies

No studies compared single class and combination class interventions after HFx surgery (Table 30).

#### Key Question 5: Network Meta-Analyses in HFx Surgery Studies

##### Key Points

- Conclusions from all network meta-analyses are limited due to the sparseness of direct comparisons between most interventions within each network.
- Network meta-analyses that included more than sparse connections could be constructed for only total DVT and major bleeding. Other outcomes were too sparsely populated to allow interpretable networks.
- Comparisons between specific pairs of classes or of interventions were too sparse to yield sufficient conclusions regarding risks of total DVT or major bleeding.
  ○ There were 6 RCTs that compared classes of interventions for total DVT and 21 compared classes of interventions for major bleeding; 8 RCTs compared specific interventions for total DVT and 6 for major bleeding.

Network meta-analysis findings are summarized in Table 30.

##### DVT: Comparison of Classes in HFx Surgery Studies

There were six RCTs that evaluated interventions in at least two classes and reported total DVT after HFx surgery. However, one RCT of antiplatelet drug (aspirin) versus mechanical device did not connect to the network of evidence. Across this study set, four classes were evaluated (FXaI, LMWH, UFH, placebo). Of the six possible pairwise comparisons, four are covered by direct study comparisons. LMWH was directly compared with each of the three other intervention classes; FXaI was also directly compared with placebo.

There were no statistically significant differences. Overall, FXaI and UFH were likely to be among the top two interventions whereas placebo and LMWH were likely to be among the bottom two interventions. However, data were sparse and only LMWH was directly compared to more than two other interventions by at least two RCTs each (for two comparisons).

##### DVT: Comparison of Specific Interventions in HFx Surgery Studies

In the analysis by drug (or mechanical device), there were eight RCTs that evaluated at least two interventions and reported total DVT after HFx surgery. One RCT of aspirin versus VFP did not connect to the network of evidence. Across this study set, seven interventions were evaluated (dalteparin, edoxaban, enoxaparin, fondaparinux, UFH, semuloparin, placebo). Of the 21 possible pairwise comparisons, 8 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with five other interventions. UFH was directly compared with dalteparin only.

Overall, UFH had the highest probability of being among the top three interventions to prevent DVT after HFx surgery (95%), followed by fondaparinux (89%) and dalteparin (70%). The other three interventions were likely to be among the bottom three interventions: placebo (92%), enoxaparin (79%), and edoxaban (79%) However, no intervention was directly compared to two other interventions by at least two RCTs.

##### Major Bleeding: Comparison of Classes in HFx Surgery Studies

There were four RCTs that evaluated interventions in at least two classes and reported major bleeding after HFx surgery. Across this study set, five classes were evaluated (antiplatelet drug [aspirin], FXaI, LMWH, VKA, placebo). Of the 10 possible pairwise comparisons, 6 are covered by direct study comparisons. Placebo was the most common comparator, being directly compared with each of the five other intervention classes.

There were no statistically significant differences. Overall, antiplatelet drug had the highest probability of being among the top two interventions (96%) to avoid major bleeding with thromboprophylaxis after HFx surgery, followed by VKA (52%). The interventions likely to be among the bottom two interventions were FXaI (98%) and LMWH (96%). However, except for the comparison of LMWH and FXaI, only single RCTs compared intervention classes.

##### Major Bleeding: Comparison of Specific Interventions in HFx Surgery Studies

In the analysis by drug (or mechanical device), there were six RCTs that evaluated at least two interventions and reported major bleeding after HFx surgery. Across this study set, eight interventions were evaluated (aspirin, dalteparin, edoxaban, enoxaparin, fondaparinux, semuloparin, warfarin, and placebo). Of the 28 possible pairwise comparisons, 9 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with five other interventions. Aspirin and warfarin were directly compared with each other and placebo only.

There were no statistically significant differences. Overall, aspirin had the highest probability of being among the top three interventions (>99%) to avoid major bleeding with thromboprophylaxis after HFx surgery, followed by placebo (95%) and warfarin (94%). The interventions likely to be among the bottom three interventions were fondaparinux (82%), semuloparin (77%), and enoxaparin (67%). However, only enoxaparin and fondaparinux were directly compared by two RCTs, with similar risk of major bleeding.

#### Key Question 6: Thromboprophylaxis Timing in HFx Surgery Studies

No eligible studies evaluated patients with HFx surgery (Table 30).

a The current review assessed risk of bias domains not consistently addressed by the 2012 VTE report. We did not assess these studies for these risk of bias domains, but instead marked them as “not reported”.

b Since fewer than four RCTs had analyzable data, we did not meta-analyze the comparisons in this section, per protocol.

c Since fewer than four RCTs had analyzable data, we did not meta-analyze this comparison, per protocol.

d Since fewer than four RCTs had analyzable data, we did not meta-analyze comparisons in this section, per protocol.

e Since fewer than four RCTs had analyzable data, we did not meta-analyze this comparison, per protocol.