# References

1 Falck-Ytter Y, Francis CW, Johanson NA, . Prevention of VTE in orthopedic surgery patients: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. 2012 Feb;141(2 Suppl):e278S–325S. doi: 10.1378/chest.11-2404. PMID: 22315265.22315265
2 Konstantinides SV, Torbicki A, Agnelli G, . 2014 ESC guidelines on the diagnosis and management of acute pulmonary embolism. Eur Heart J. 2014 Nov 14;35(43):3033–69, 69a–69k. doi: 10.1093/eurheartj/ehu283. PMID: 25173341.25173341
3 Fedullo P, Kerr KM, Kim NH, . Chronic thromboembolic pulmonary hypertension. Am J Respir Crit Care Med. 2011 Jun 15;183(12):1605–13. doi: 10.1164/rccm.201011-1854CI. PMID: 21330453.21330453
4 Piazza G, Goldhaber SZ. Chronic thromboembolic pulmonary hypertension. N Engl J Med. 2011 Jan 27;364(4):351–60. doi: 10.1056/NEJMra0910203. PMID: 21268727.21268727
5 Mont MA, Jacobs JJ. AAOS clinical practice guideline: preventing venous thromboembolic disease in patients undergoing elective hip and knee arthroplasty. J Am Acad Orthop Surg. 2011 Dec;19(12):777–8. PMID: 22134210.22134210
6 Kahn SR, Comerota AJ, Cushman M, . The postthrombotic syndrome: evidence-based prevention, diagnosis, and treatment strategies: a scientific statement from the American Heart Association. Circulation. 2014 Oct 28;130(18):1636–61. doi: 10.1161/cir.0000000000000130. PMID: 25246013.25246013
7 Vera-Llonch M, Hagiwara M, Oster G. Clinical and economic consequences of bleeding following major orthopedic surgery. Thromb Res. 2006;117(5):569–77. doi: 10.1016/j.thromres.2005.04.018. PMID: 15913715.15913715
8 Saleh K, Olson M, Resig S, . Predictors of wound infection in hip and knee joint replacement: results from a 20 year surveillance program. J Orthop Res. 2002 May;20(3):506–15. doi: 10.1016/s0736-0266(01)00153-x. PMID: 12038624.12038624
9 Lip GYH, Hull RD. Overview of the treatment of lower extremity deep vein thrombosis (DVT). UpToDate; 2016. http://www.uptodate.com/contents/overview-of-the-treatment-of-lower-extremity-deep-vein-thrombosis-dvt. Accessed on Apr. 25, 2016.
10 Kahn SR, Ginsberg JS. Relationship between deep venous thrombosis and the postthrombotic syndrome. Arch Intern Med. 2004 Jan 12;164(1):17–26. doi: 10.1001/archinte.164.1.17. PMID: 14718318.14718318
11 Kahn SR, Solymoss S, Lamping DL, . Long-term outcomes after deep vein thrombosis: postphlebitic syndrome and quality of life. J Gen Intern Med. 2000 Jun;15(6):425–9. PMID: 10886478.10886478
12 Cooper RM, Hayat SA. Phlegmasia cerulea dolens, a rare complication of deep vein thrombosis. Emerg Med J. 2008 Jun;25(6):334. doi: 10.1136/emj.2007.053330. PMID: 18499813.18499813
13 Sobieraj DM, Coleman CI, Tongbram V, . AHRQ Comparative Effectiveness Reviews. Venous Thromboembolism Prophylaxis in Orthopedic Surgery. Rockville (MD): Agency for Healthcare Research and Quality (US); 2012.
14 Balk EMA, G. A.;Ellis, A.G. Evidence-based Practice Center Systematic Review Protocol: Systematic Review Update of Venous Thromboembolism Prophylaxis in Orthopedic Surgery. https://effectivehealthcare.ahrq.gov/ehc/products/628/2184/thromboembolism-update-protocol-160217.pdf. 2015.
15 AHRQ Methods for Effective Health Care. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD): Agency for Healthcare Research and Quality (US); 2011.
16 Higgins JP, Altman DG, Gotzsche PC, . The Cochrane Collaboration’s tool for assessing risk of bias in randomised trials. Bmj. 2011;343:d5928. doi: 10.1136/bmj.d5928. PMID: 22008217.22008217
17 Wells GAS, B.;O’Connell, D.;Peterson, J; Welch, V; Losos, M; Tugwell, P. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp.
18 Bradburn MJ, Deeks JJ, Berlin JA, . Much ado about nothing: a comparison of the performance of meta-analytical methods with rare events. Stat Med. 2007 Jan 15;26(1):53–77. doi: 10.1002/sim.2528. PMID: 16596572.16596572
19 Rucker G, Schwarzer G, Carpenter J, . Why add anything to nothing? The arcsine difference as a measure of treatment effect in meta-analysis with zero cells. Stat Med. 2009 Feb 28;28(5):721–38. doi: 10.1002/sim.3511. PMID: 19072749.19072749
20 Sweeting MJ, Sutton AJ, Lambert PC. What to add to nothing? Use and avoidance of continuity corrections in meta-analysis of sparse data. Stat Med. 2004 May 15;23(9):1351–75. doi: 10.1002/sim.1761. PMID: 15116347.15116347
21 Dias S, Welton NJ, Caldwell DM, . Checking consistency in mixed treatment comparison meta-analysis. Stat Med. 2010 Mar 30;29(7–8):932–44. doi: 10.1002/sim.3767. PMID: 20213715.20213715
22 Turner RM, Jackson D, Wei Y, . Predictive distributions for between-study heterogeneity and simple methods for their application in Bayesian meta-analysis. Stat Med. 2015 Mar 15;34(6):984–98. doi: 10.1002/sim.6381. PMID: 25475839.25475839
23 Berkman ND, Lohr KN, Ansari MT, . Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2015 Nov;68(11):1312–24. doi: 10.1016/j.jclinepi.2014.11.023. PMID: 25721570.25721570
24 Lassen MR, Gallus A, Raskob GE, . Apixaban versus enoxaparin for thromboprophylaxis after hip replacement. N Engl J Med. 2010A Dec 23;363(26):2487–98. doi: 10.1056/NEJMoa1006885. PMID: 21175312.21175312
25 Fuji T, Fujita S, Kawai Y, . Safety and efficacy of edoxaban in patients undergoing hip fracture surgery. Thromb Res. 2014B Jun;133(6):1016–22. doi: 10.1016/j.thromres.2014.03.009. PMID: 24680549.24680549
26 Raskob G, Cohen AT, Eriksson BI, . Oral direct factor Xa inhibition with edoxaban for thromboprophylaxis after elective total hip replacement. A randomised double-blind dose-response study. Thromb Haemost. 2010 Sep;104(3):642–9. doi: 10.1160/th10-02-0142. PMID: 20589317.20589317
27 Ishibe M, Kariya S. Deep venous thrombosis after mini-posterior total hip arthroplasty in Japanese patients. Hip Int. 2011 Nov–Dec;21(6):684–7. doi: 10.5301/hip.2011.8825. PMID: 22101618.22101618
28 Jameson SS, Charman SC, Gregg PJ, . The effect of aspirin and low-molecular-weight heparin on venous thromboembolism after hip replacement: a non-randomised comparison from information in the National Joint Registry. J Bone Joint Surg Br. 2011 Nov;93(11):1465–70. doi: 10.1302/0301-620x.93b11.27622. PMID: 22058295.22058295
29 Khatod M, Inacio MC, Bini SA, . Prophylaxis against pulmonary embolism in patients undergoing total hip arthroplasty. J Bone Joint Surg Am. 2011 Oct 5;93(19):1767–72. doi: 10.2106/jbjs.j.01130. PMID: 22005861.22005861
30 Pedersen AB, Sorensen HT, Mehnert F, . Effectiveness and safety of different duration of thromboprophylaxis in 16,865 hip replacement patients--a real-word, prospective observational study. Thromb Res. 2015 Feb;135(2):322–8. doi: 10.1016/j.thromres.2014.11.029. PMID: 25511580.25511580
31 Vulcano E, Gesell M, Esposito A, . Aspirin for elective hip and knee arthroplasty: a multimodal thromboprophylaxis protocol. Int Orthop. 2012 Oct;36(10):1995–2002. doi: 10.1007/s00264-012-1588-4. PMID: 22684546.22684546
32 Bozic KJ, Vail TP, Pekow PS, . Does aspirin have a role in venous thromboembolism prophylaxis in total knee arthroplasty patients? J Arthroplasty. 2010 Oct;25(7):1053–60. doi: 10.1016/j.arth.2009.06.021. PMID: 19679434.19679434
33 Jameson SS, Baker PN, Charman SC, . The effect of aspirin and low-molecular-weight heparin on venous thromboembolism after knee replacement: a non-randomised comparison using National Joint Registry Data. J Bone Joint Surg Br. 2012 Jul;94(7):914–8. doi: 10.1302/0301-620x.94b7.29129. PMID: 22733945.22733945
34 Kang J, Jiang X, Wu B. Analysis of Risk Factors for Lower-limb Deep Venous Thrombosis in Old Patients after Knee Arthroplasty. Chin Med J (Engl). 2015 May 20;128(10):1358–62. doi: 10.4103/0366-6999.156782. PMID: 25963358.25963358
35 Khatod M, Inacio MC, Bini SA, . Pulmonary embolism prophylaxis in more than 30,000 total knee arthroplasty patients: is there a best choice? J Arthroplasty. 2012 Feb;27(2):167–72. doi: 10.1016/j.arth.2011.04.006. PMID: 21641758.21641758
36 Llau JV, ENOXACOR Study Group. Clinical use of enoxaparin as thromboprophylaxis after total knee arthroplasty (TKA) in daily practice: An observational multicentre study: 6AP3-2. European Journal of Anaesthesiology (EJA). 2011;28:85.
37 Rath NK, Goodson MW, White SP, . The use of rivaroxaban for chemical thromboprophylaxis following total knee replacement. The Knee. 2013;20(6):397–400.23566737
38 Bottle A OE, Pinder E, Aylin P, Loeffler M. The effect of new oral anticoagulants and extended thromboprophylaxis policy on hip and knee arthroplasty outcomes: observational study. Arthroplasty Today. 2015:45–50. doi: 10.1016/j.artd.2015.03.004.28326369
39 Bloch BV, Patel V, Best AJ. Thromboprophylaxis with dabigatran leads to an increased incidence of wound leakage and an increased length of stay after total joint replacement. Bone Joint J. 2014 Jan;96-B(1):122–6. doi: 10.1302/0301-620x.96b1.31569. PMID: 24395322.24395322
40 Wells PS, Borah BJ, Sengupta N, . Analysis of venous thromboprophylaxis duration and outcomes in orthopedic patients. Am J Manag Care. 2010 Nov;16(11):857–63. PMID: 21348557.21348557
41 Tsuda Y, Yasunaga H, Horiguchi H, . Effects of fondaparinux on pulmonary embolism following hemiarthroplasty for femoral neck fracture: a retrospective observational study using the Japanese Diagnosis Procedure Combination database. J Orthop Sci. 2014 Nov;19(6):991–6. doi: 10.1007/s00776-014-0607-2. PMID: 25034972.25034972
42 Seymour LW, Ulbrich K, Strohalm J, . The pharmacokinetics of polymer-bound adriamycin. Biochem Pharmacol. 1990 Mar 15;39(6):1125–31. PMID: 2322298.2322298
43 Lotke PA, Palevsky H, Keenan AM, . Aspirin and warfarin for thromboembolic disease after total joint arthroplasty. Clin Orthop Relat Res. 1996 Mar(324):251–8. PMID: 8595765.8595765
44 Woolson ST, Watt JM. Intermittent pneumatic compression to prevent proximal deep venous thrombosis during and after total hip replacement. A prospective, randomized study of compression alone, compression and aspirin, and compression and low-dose warfarin. J Bone Joint Surg Am. 1991 Apr;73(4):507–12. PMID: 2013589.2013589
45 Zhirova TA, Lykov MS, Zyrianov MN, . [New oral anticoagulants for thromboprophylaxis under routine use of tranexamic acid after hip joint arthroplasty]. Anesteziol Reanimatol. 2014 Nov–Dec;59(6):34–8. PMID: 25831700.25831700
46 Eriksson BI, Ekman S, Kalebo P, . Prevention of deep-vein thrombosis after total hip replacement: direct thrombin inhibition with recombinant hirudin, CGP 39393. Lancet. 1996 Mar 9;347(9002):635–9. PMID: 8596376.8596376
47 Eriksson BI, Ekman S, Lindbratt S, . Prevention of thromboembolism with use of recombinant hirudin. Results of a double-blind, multicenter trial comparing the efficacy of desirudin (Revasc) with that of unfractionated heparin in patients having a total hip replacement. J Bone Joint Surg Am. 1997 Mar;79(3):326–33. PMID: 9070519.9070519
48 Verhamme P, Gunn S, Sonesson E, . Single-dose TB-402 or rivaroxaban for the prevention of venous thromboembolism after total hip replacement. A randomised, controlled trial. Thromb Haemost. 2013 Jun;109(6):1091–8. doi: 10.1160/th13-01-0066. PMID: 23615791.23615791
49 Eriksson BI, Wille-Jorgensen P, Kalebo P, . A comparison of recombinant hirudin with a low-molecular-weight heparin to prevent thromboembolic complications after total hip replacement. N Engl J Med. 1997B Nov 6;337(19):1329–35. doi: 10.1056/nejm199711063371901. PMID: 9358126.9358126
50 Eriksson BI, Dahl OE, Huo MH, . Oral dabigatran versus enoxaparin for thromboprophylaxis after primary total hip arthroplasty (RE-NOVATE II*). A randomised, double-blind, non-inferiority trial. Thromb Haemost. 2011 Apr;105(4):721–9. doi: 10.1160/th10-10-0679. PMID: 21225098.21225098
51 Eriksson BI, Dahl OE, Rosencher N, . Dabigatran etexilate versus enoxaparin for prevention of venous thromboembolism after total hip replacement: a randomised, double-blind, non-inferiority trial. Lancet. 2007B Sep 15;370(9591):949–56. doi: 10.1016/s0140-6736(07)61445-7. PMID: 17869635.17869635
52 Eriksson BI, Dahl OE, Buller HR, . A new oral direct thrombin inhibitor, dabigatran etexilate, compared with enoxaparin for prevention of thromboembolic events following total hip or knee replacement: the BISTRO II randomized trial. J Thromb Haemost. 2005 Jan;3(1):103–11. doi: 10.1111/j.1538-7836.2004.01100.x. PMID: 15634273.15634273
53 Shorr AF, Eriksson BI, Jaffer AK, . Impact of stage 3B chronic kidney disease on thrombosis and bleeding outcomes after orthopedic surgery in patients treated with desirudin or enoxaparin: insights from a randomized trial. J Thromb Haemost. 2012 Aug;10(8):1515–20. doi: 10.1111/j.1538-7836.2012.04803.x. PMID: 22672318.22672318
54 Fuji T, Fujita S, Kawai Y, . Efficacy and safety of edoxaban versus enoxaparin for the prevention of venous thromboembolism following total hip arthroplasty: STARS J-V. Thromb J. 2015;13:27. doi: 10.1186/s12959-015-0057-x. PMID: 26269694.26269694
55 Fuji T, Nakamura M, Takeuchi M. Darexaban for the prevention of venous thromboembolism in Asian patients undergoing orthopedic surgery: results from 2 randomized, placebo-controlled, double-blind studies. Clin Appl Thromb Hemost. 2014D Mar;20(2):199–211. doi: 10.1177/1076029612457810. PMID: 22952213.22952213
56 Fuji T, Wang CJ, Fujita S, . Safety and efficacy of edoxaban, an oral factor xa inhibitor, for thromboprophylaxis after total hip arthroplasty in Japan and Taiwan. J Arthroplasty. 2014A Dec;29(12):2439–46. doi: 10.1016/j.arth.2014.05.029. PMID: 25047458.25047458
57 Eriksson BI, Agnelli G, Gallus AS, . Darexaban (YM150) versus enoxaparin for the prevention of venous thromboembolism after total hip arthroplasty: a randomised phase IIb dose confirmation study (ONYX-3). Thromb Haemost. 2014 Feb;111(2):213–25. doi: 10.1160/th13-04-0296. PMID: 24136153.24136153
58 Eriksson BI, Turpie AG, Lassen MR, . Prevention of venous thromboembolism with an oral factor Xa inhibitor, YM150, after total hip arthroplasty. A dose finding study (ONYX-2). J Thromb Haemost. 2010 Apr;8(4):714–21. doi: 10.1111/j.1538-7836.2010.03748.x. PMID: 20088935.20088935
59 Zhang H, Lin J, Li H, . [Effects of thromboprophylaxis duration on coagulation indicators after total hip replacement]. Zhonghua Yi Xue Za Zhi. 2014 Feb 25;94(7):525–8. PMID: 24767296.24767296
60 Yokote R, Matsubara M, Hirasawa N, . Is routine chemical thromboprophylaxis after total hip replacement really necessary in a Japanese population? J Bone Joint Surg Br. 2011 Feb;93(2):251–6. doi: 10.1302/0301-620x.93b2.25795. PMID: 21282767.21282767
61 Turpie AG, Bauer KA, Eriksson BI, . Postoperative fondaparinux versus postoperative enoxaparin for prevention of venous thromboembolism after elective hip-replacement surgery: a randomised double-blind trial. Lancet. 2002 May 18;359(9319):1721–6. doi: 10.1016/s0140-6736(02)08648-8. PMID: 12049860.12049860
62 Lassen MR, Bauer KA, Eriksson BI, . Postoperative fondaparinux versus preoperative enoxaparin for prevention of venous thromboembolism in elective hip-replacement surgery: a randomised double-blind comparison. Lancet. 2002 May 18;359(9319):1715–20. doi: 10.1016/s0140-6736(02)08652-x. PMID: 12049858.12049858
63 Kim SM, Moon YW, Lim SJ, . Effect of oral factor Xa inhibitor and low-molecular-weight heparin on surgical complications following total hip arthroplasty. Thromb Haemost. 2016 Mar;115(3):600–7. doi: 10.1160/th15-07-0527. PMID: 26790579.26790579
64 Zhang H, Wang D, Sun HY, . Efficacy and safety of rivaroxaban in the prevention of deep vein thrombosis after hip arthroplasty. Chinese Journal of Tissue Engineering Research. 2013;17(30):5440. PMID: EMBASE 2014592535.
65 Fuji T, Fuijita S, Ujihira T, . Dabigatran etexilate prevents venous thromboembolism after total knee arthroplasty in Japanese patients with a safety profile comparable to placebo. J Arthroplasty. 2010A Dec;25(8):1267–74. doi: 10.1016/j.arth.2009.08.010. PMID: 19854610.19854610
66 Stone MH, Limb D, Campbell P, . A comparison of intermittent calf compression and enoxaparin for thromboprophylaxis in total hip replacement. A pilot study. Int Orthop. 1996;20(6):367–9. PMID: 9049766.9049766
67 Colwell CW, Jr., Froimson MI, Mont MA, . Thrombosis prevention after total hip arthroplasty: a prospective, randomized trial comparing a mobile compression device with low-molecular-weight heparin. J Bone Joint Surg Am. 2010 Mar;92(3):527–35. doi: 10.2106/jbjs.i.00047. PMID: 20194309.20194309
68 Warwick D, Harrison J, Glew D, . Comparison of the use of a foot pump with the use of low-molecular-weight heparin for the prevention of deep-vein thrombosis after total hip replacement. A prospective, randomized trial. J Bone Joint Surg Am. 1998 Aug;80(8):1158–66. PMID: 9730125.9730125
69 Levine MN, Hirsh J, Gent M, . Prevention of deep vein thrombosis after elective hip surgery. A randomized trial comparing low molecular weight heparin with standard unfractionated heparin. Ann Intern Med. 1991 Apr 1;114(7):545–51. PMID: 1848054.1848054
70 Eriksson BI, Kalebo P, Anthymyr BA, . Prevention of deep-vein thrombosis and pulmonary embolism after total hip replacement. Comparison of low-molecular-weight heparin and unfractionated heparin. J Bone Joint Surg Am. 1991 Apr;73(4):484–93. PMID: 2013587.2013587
71 Planes A, Vochelle N, Mazas F, . Prevention of postoperative venous thrombosis: a randomized trial comparing unfractionated heparin with low molecular weight heparin in patients undergoing total hip replacement. Thromb Haemost. 1988 Dec 22;60(3):407–10. PMID: 2853459.2853459
72 Dechavanne M, Ville D, Berruyer M, . Randomized trial of a low-molecular-weight heparin (Kabi 2165) versus adjusted-dose subcutaneous standard heparin in the prophylaxis of deep-vein thrombosis after elective hip surgery. Haemostasis. 1989;19(1):5–12. PMID: 2537787.2537787
73 Menzin J, Richner R, Huse D, . Prevention of deep-vein thrombosis following total hip replacement surgery with enoxaparin versus unfractionated heparin: a pharmacoeconomic evaluation. Ann Pharmacother. 1994 Feb;28(2):271–5. PMID: 8173149.8173149
74 Colwell CW, Jr., Spiro TE, Trowbridge AA, . Use of enoxaparin, a low-molecular-weight heparin, and unfractionated heparin for the prevention of deep venous thrombosis after elective hip replacement. A clinical trial comparing efficacy and safety. Enoxaparin Clinical Trial Group. J Bone Joint Surg Am. 1994 Jan;76(1):3–14. PMID: 8288662.8288662
75 Barre J, Pfister G, Potron G, . [Comparison of the efficacy and tolerance of Kabi 2165 and standard heparin in the prevention of deep venous thrombosis in total hip prosthesis]. J Mal Vasc. 1987;12 Suppl B:90–5. PMID: 2834500.2834500
76 Senaran H, Acaroglu E, Ozdemir HM, . Enoxaparin and heparin comparison of deep vein thrombosis prophylaxis in total hip replacement patients. Arch Orthop Trauma Surg. 2006 Jan;126(1):1–5. doi: 10.1007/s00402-005-0079-0. PMID: 16333632.16333632
77 Schwartsmann C, Cavalieri C, Drumond S. Randomized, comparative, open study to assess the efficacy and safety of enoxaparin compared with unfractionated heparin in the prophylaxis of venous thromboembolism in patients undergoing total hip arthroplasty. Revista Brasileira De Ortopedia. 1996;31:797–808.
78 Avikainen V, von Bonsdorff H, Partio E, . Low molecular weight heparin (enoxaparin) compared with unfractionated heparin in prophylaxis of deep venous thrombosis and pulmonary embolism in patients undergoing hip replacement. Ann Chir Gynaecol. 1995;84(1):85–90. PMID: 7645915.7645915
79 Colwell CW, Jr., Collis DK, Paulson R, . Comparison of enoxaparin and warfarin for the prevention of venous thromboembolic disease after total hip arthroplasty. Evaluation during hospitalization and three months after discharge. J Bone Joint Surg Am. 1999 Jul;81(7):932–40. PMID: 10428124.10428124
80 Hull R, Raskob G, Pineo G, . A comparison of subcutaneous low-molecular-weight heparin with warfarin sodium for prophylaxis against deep-vein thrombosis after hip or knee implantation. N Engl J Med. 1993 Nov 4;329(19):1370–6. doi: 10.1056/nejm199311043291902. PMID: 8413432.8413432
81 Hull RD, Pineo GF, Francis C, . Low-molecular-weight heparin prophylaxis using dalteparin in close proximity to surgery vs warfarin in hip arthroplasty patients: a double-blind, randomized comparison. The North American Fragmin Trial Investigators. Arch Intern Med. 2000 Jul 24;160(14):2199–207. PMID: 10904464.10904464
82 Francis CW, Pellegrini VD, Jr., Totterman S, . Prevention of deep-vein thrombosis after total hip arthroplasty. Comparison of warfarin and dalteparin. J Bone Joint Surg Am. 1997 Sep;79(9):1365–72. PMID: 9314399.9314399
83 Santori FS, Vitullo A, Stopponi M, . Prophylaxis against deep-vein thrombosis in total hip replacement. Comparison of heparin and foot impulse pump. J Bone Joint Surg Br. 1994 Jul;76(4):579–83. PMID: 8027144.8027144
84 Bailey JP, Kruger MP, Solano FX, . Prospective randomized trial of sequential compression devices vs low-dose warfarin for deep venous thrombosis prophylaxis in total hip arthroplasty. J Arthroplasty. 1991;6 Suppl:S29–35. PMID: 1774568.1774568
85 Francis CW, Pellegrini VD, Jr., Marder VJ, . Comparison of warfarin and external pneumatic compression in prevention of venous thrombosis after total hip replacement. JAMA. 1992 Jun 3;267(21):2911–5. PMID: 1583760.1583760
86 Paiement G, Wessinger SJ, Waltman AC, . Low-dose warfarin versus external pneumatic compression for prophylaxis against venous thromboembolism following total hip replacement. J Arthroplasty. 1987;2(1):23–6. PMID: 3572408.3572408
87 Zou Y, Tian S, Wang Y, . Administering aspirin, rivaroxaban and low-molecular-weight heparin to prevent deep venous thrombosis after total knee arthroplasty. Blood Coagul Fibrinolysis. 2014 Oct;25(7):660–4. doi: 10.1097/mbc.0000000000000121. PMID: 24695091.24695091
88 Haas SB, Insall JN, Scuderi GR, . Pneumatic sequential-compression boots compared with aspirin prophylaxis of deep-vein thrombosis after total knee arthroplasty. J Bone Joint Surg Am. 1990 Jan;72(1):27–31. PMID: 2404020.2404020
89 Iliopoulos E, Fotiadis E, Kravas A, . Thromboprophylaxis Management in Total Knee Arthroplasty. 2011;22:120–1.
90 Westrich GH, Bottner F, Windsor RE, . VenaFlow plus Lovenox vs VenaFlow plus aspirin for thromboembolic disease prophylaxis in total knee arthroplasty. J Arthroplasty. 2006 Sep;21(6 Suppl 2):139–43. doi: 10.1016/j.arth.2006.05.017. PMID: 16950076.16950076
91 Eriksson BI, Dahl OE, Rosencher N, . Oral dabigatran etexilate vs. subcutaneous enoxaparin for the prevention of venous thromboembolism after total knee replacement: the RE-MODEL randomized trial. J Thromb Haemost. 2007 Nov;5(11):2178–85. doi: 10.1111/j.1538-7836.2007.02748.x. PMID: 17764540.17764540
92 Ginsberg JS, Davidson BL, Comp PC, . Oral thrombin inhibitor dabigatran etexilate vs North American enoxaparin regimen for prevention of venous thromboembolism after knee arthroplasty surgery. J Arthroplasty. 2009 Jan;24(1):1–9. doi: 10.1016/j.arth.2008.01.132. PMID: 18534438.18534438
93 Mirdamadi A, Dashtkar S, Kaji M, . Dabigatran versus Enoxaparin in the prevention of venous thromboembolism after total knee arthroplasty: A randomized clinical trial. ARYA Atheroscler. 2014 Nov;10(6):292–7. PMID: 25815018.25815018
94 Bonneux IM, Bellemans J, Fabry G. Evaluation of wound healing after total knee arthroplasty in a randomized prospective trial comparing fondaparinux with enoxaparin. Knee. 2006 Mar;13(2):118–21. doi: 10.1016/j.knee.2005.08.010. PMID: 16387501.16387501
95 Hu YP, D., Shen Y, Chen X. Different anticoagulant drugs during knee joint replacement:changes of hemorheology. Chinese Journal of Tissue Engineering Research. 2015 PMID: http://en.cnki.com.cn/Article_en/CJFDTOTAL-XDKF201513013.htm.
96 Lassen MR, Raskob GE, Gallus A, . Apixaban versus enoxaparin for thromboprophylaxis after knee replacement (ADVANCE-2): a randomised double-blind trial. Lancet. 2010B Mar 6;375(9717):807–15. doi: 10.1016/s0140-6736(09)62125-5. PMID: 20206776.20206776
97 Bauer KA, Eriksson BI, Lassen MR, . Fondaparinux compared with enoxaparin for the prevention of venous thromboembolism after elective major knee surgery. N Engl J Med. 2001 Nov 1;345(18):1305–10. doi: 10.1056/NEJMoa011099. PMID: 11794149.11794149
98 Fuji T, Wang CJ, Fujita S, . Safety and efficacy of edoxaban, an oral factor Xa inhibitor, versus enoxaparin for thromboprophylaxis after total knee arthroplasty: the STARS E-3 trial. Thromb Res. 2014C Dec;134(6):1198–204. doi: 10.1016/j.thromres.2014.09.011. PMID: 25294589.25294589
99 Weitz JI, Cao C, Eriksson BI, . A dose-finding study with TAK-442, an oral factor Xa inhibitor, in patients undergoing elective total knee replacement surgery. Thromb Haemost. 2010 Dec;104(6):1150–7. doi: 10.1160/th10-05-0273. PMID: 20886185.20886185
100 Cohen AT, Boyd RA, Mandema JW, . An adaptive-design dose-ranging study of PD 0348292, an oral factor Xa inhibitor, for thromboprophylaxis after total knee replacement surgery. J Thromb Haemost. 2013 Aug;11(8):1503–10. doi: 10.1111/jth.12328. PMID: 23782955.23782955
101 Buller HR, Bethune C, Bhanot S, . Factor XI antisense oligonucleotide for prevention of venous thrombosis. N Engl J Med. 2015 Jan 15;372(3):232–40. doi: 10.1056/NEJMoa1405760. PMID: 25482425.25482425
102 Warwick D, Harrison J, Whitehouse S, . A randomised comparison of a foot pump and low-molecular-weight heparin in the prevention of deep-vein thrombosis after total knee replacement. J Bone Joint Surg Br. 2002 Apr;84(3):344–50. PMID: 12002490.12002490
103 Fauno P, Suomalainen O, Rehnberg V, . Prophylaxis for the prevention of venous thromboembolism after total knee arthroplasty. A comparison between unfractionated and low-molecular-weight heparin. J Bone Joint Surg Am. 1994 Dec;76(12):1814–8. PMID: 7989386.7989386
104 Colwell CW, Jr, Spiro TE, Trowbridge AA, . Efficacy and safety of enoxaparin versus unfractionated heparin for prevention of deep venous thrombosis after elective knee arthroplasty. Enoxaparin Clinical Trial Group. Clin Orthop Relat Res. 1995 Dec(321):19–27. PMID: 7497668.7497668
105 Fitzgerald RH, Jr, Spiro TE, Trowbridge AA, . Prevention of venous thromboembolic disease following primary total knee arthroplasty. A randomized, multicenter, open-label, parallel-group comparison of enoxaparin and warfarin. J Bone Joint Surg Am. 2001 Jun;83-A(6):900–6. PMID: 11407799.11407799
106 Leclerc JR, Geerts WH, Desjardins L, . Prevention of venous thromboembolism after knee arthroplasty. A randomized, double-blind trial comparing enoxaparin with warfarin. Ann Intern Med. 1996 Apr 1;124(7):619–26. PMID: 8607589.8607589
107 Lassen MR, Davidson BL, Gallus A, . The efficacy and safety of apixaban, an oral, direct factor Xa inhibitor, as thromboprophylaxis in patients following total knee replacement. J Thromb Haemost. 2007 Dec;5(12):2368–75. doi: 10.1111/j.1538-7836.2007.02764.x. PMID: 17868430.17868430
108 Sakai T, Izumi M, Kumagai K, . Effects of a Foot Pump on the Incidence of Deep Vein Thrombosis After Total Knee Arthroplasty in Patients Given Edoxaban: A Randomized Controlled Study. Medicine (Baltimore). 2016 Jan;95(1):e2247. doi: 10.1097/md.0000000000002247. PMID: 26735531.26735531
109 Kennedy JG, Soffe KE, Rogers BW, . Deep vein thrombosis prophylaxis in hip fractures: a comparison of the arteriovenous impulse system and aspirin. J Trauma. 2000 Feb;48(2):268–72. PMID: 10697085.10697085
110 Powers PJ, Gent M, Jay RM, . A randomized trial of less intense postoperative warfarin or aspirin therapy in the prevention of venous thromboembolism after surgery for fractured hip. Arch Intern Med. 1989 Apr;149(4):771–4. PMID: 2650646.2650646
111 Sasaki S, Miyakoshi N, Matsuura H, . Prospective study on the efficacies of fondaparinux and enoxaparin in preventing venous thromboembolism after hip fracture surgery. J Orthop Sci. 2011 Jan;16(1):64–70. doi: 10.1007/s00776-010-0011-5. PMID: 21293896.21293896
112 Eriksson BI, Bauer KA, Lassen MR, . Fondaparinux compared with enoxaparin for the prevention of venous thromboembolism after hip-fracture surgery. N Engl J Med. 2001 Nov 1;345(18):1298–304. doi: 10.1056/NEJMoa011100. PMID: 11794148.11794148
113 Monreal M, Lafoz E, Navarro A, . A prospective double-blind trial of a low molecular weight heparin once daily compared with conventional low-dose heparin three times daily to prevent pulmonary embolism and venous thrombosis in patients with hip fracture. J Trauma. 1989 Jun;29(6):873–5. PMID: 2544742.2544742
114 Lassen MR, Fisher W, Mouret P, . Semuloparin for prevention of venous thromboembolism after major orthopedic surgery: results from three randomized clinical trials, SAVE-HIP1, SAVE-HIP2 and SAVE-KNEE. J Thromb Haemost. 2012 May;10(5):822–32. doi: 10.1111/j.1538-7836.2012.04701.x. PMID: 22429800.22429800
115 Planes A, Samama MM, Lensing AW, . Prevention of deep vein thrombosis after hip replacement--comparison between two low-molecular heparins, tinzaparin and enoxaparin. Thromb Haemost. 1999 Jan;81(1):22–5. PMID: 10348714.10348714
116 Ryan MG, Westrich GH, Potter HG, . Effect of mechanical compression on the prevalence of proximal deep venous thrombosis as assessed by magnetic resonance venography. J Bone Joint Surg Am. 2002 Nov;84-A(11):1998–2004. PMID: 12429761.12429761
117 Silbersack Y, Taute BM, Hein W, . Prevention of deep-vein thrombosis after total hip and knee replacement. Low-molecular-weight heparin in combination with intermittent pneumatic compression. J Bone Joint Surg Br. 2004 Aug;86(6):809–12. PMID: 15330019.15330019
118 The TIFDED Study Group. Thromboprophylaxis in hip fracture surgery: a pilot study comparing danaparoid, enoxaparin and dalteparin. The TIFDED Study Group. Haemostasis. 1999 Nov–Dec;29(6):310–7. doi: 10.1159/000022518. PMID: 10844404.10844404
119 Bramlage P, Michaelis HC, Melzer N. Comparison of 3,000 and 5,000 IU aXa/day certoparin in the prevention of deep-vein thrombosis after total hip replacement. Thromb J. 2012;10(1):10. doi: 10.1186/1477-9560-10-10. PMID: 22713698.22713698
120 Fuji T, Ochi T, Niwa S, . Prevention of postoperative venous thromboembolism in Japanese patients undergoing total hip or knee arthroplasty: two randomized, double-blind, placebo-controlled studies with three dosage regimens of enoxaparin. J Orthop Sci. 2008 Sep;13(5):442–51. doi: 10.1007/s00776-008-1264-0. PMID: 18843459.18843459
121 Choi JS, Han HS, Choi YH, . Comparison of Simultaneous and Alternate Bilateral Pneumatic Compression in Hemodynamic Effects and Thromboprophylaxis After Total Knee Arthroplasty. Clin Appl Thromb Hemost. 2015 Oct;21(7):653–60. doi: 10.1177/1076029613518366. PMID: 24408881.24408881
122 Koo KH, Choi JS, Ahn JH, . Comparison of clinical and physiological efficacies of different intermittent sequential pneumatic compression devices in preventing deep vein thrombosis: a prospective randomized study. Clin Orthop Surg. 2014 Dec;6(4):468–75. doi: 10.4055/cios.2014.6.4.468. PMID: 25436073.25436073
123 Lachiewicz PF, Kelley SS, Haden LR. Two mechanical devices for prophylaxis of thromboembolism after total knee arthroplasty. A prospective, randomised study. J Bone Joint Surg Br. 2004 Nov;86(8):1137–41. PMID: 15568526.15568526
124 NCT00246025.
125 NCT00595426.
126 Fuji T, Fujita S, Tachibana S, . A dose-ranging study evaluating the oral factor Xa inhibitor edoxaban for the prevention of venous thromboembolism in patients undergoing total knee arthroplasty. J Thromb Haemost. 2010B Nov;8(11):2458–68. doi: 10.1111/j.1538-7836.2010.04021.x. PMID: 20723033.20723033
127 A Study to Evaluate the Safety and Efficacy of YM150 in Patients With Knee Replacement Surgery (PEARL). 2013. https://clinicaltrials.gov/ct2/show/NCT00595426.
128 Comp PC, Spiro TE, Friedman RJ, . Prolonged enoxaparin therapy to prevent venous thromboembolism after primary hip or knee replacement. Enoxaparin Clinical Trial Group J. Bone Joint Surg Am. 2001 Mar;83-A(3):336–45. PMID: 11263636.11263636
129 Nilsson PE, Bergqvist D, Benoni G, . The post-discharge prophylactic management of the orthopedic patient with low-molecular-weight heparin: enoxaparin. Orthopedics. 1997 Feb;20 Suppl:22–5. PMID: 9048404.9048404
130 Planes A, Vochelle N. The post-hospital discharge venous thrombosis risk of the orthopedic patient. Orthopedics. 1997 Feb;20 Suppl:18–21. PMID: 9048403.9048403
131 Dahl OE, Andreassen G, Aspelin T, . Prolonged thromboprophylaxis following hip replacement surgery--results of a double-blind, prospective, randomised, placebo-controlled study with dalteparin (Fragmin). Thromb Haemost. 1997 Jan;77(1):26–31. PMID: 9031444.9031444
132 Andersen BS. Postoperative activation of the haemostatic system--influence of prolonged thromboprophylaxis in patients undergoing total hip arthroplasty. Haemostasis. 1997 Sep–Oct;27(5):219–27. PMID: 9690480.9690480
133 Lassen MR, Borris LC, Anderson BS, . Efficacy and safety of prolonged thromboprophylaxis with a low molecular weight heparin (dalteparin) after total hip arthroplasty--the Danish Prolonged Prophylaxis (DaPP) Study. Thromb Res. 1998 Mar 15;89(6):281–7. PMID: 9669750.9669750
134 Prandoni P, Bruchi O, Sabbion P, . Prolonged thromboprophylaxis with oral anticoagulants after total hip arthroplasty: a prospective controlled randomized study. Arch Intern Med. 2002 Sep 23;162(17):1966–71. PMID: 12230419.12230419
135 Eriksson BI, Lassen MR. Duration of prophylaxis against venous thromboembolism with fondaparinux after hip fracture surgery: a multicenter, randomized, placebo-controlled, double-blind study. Arch Intern Med. 2003 Jun 9;163(11):1337–42. doi: 10.1001/archinte.163.11.1337. PMID: 12796070.12796070
136 Fisher WD, Agnelli G, George DJ, . Extended venous thromboembolism prophylaxis in patients undergoing hip fracture surgery - the SAVE-HIP3 study. Bone Joint J. 2013 Apr;95-B(4):459–66. doi: 10.1302/0301-620x.95b4.30730. PMID: 23539696.23539696
137 Lieberman JR, Huo MM, Hanway J, . The prevalence of deep venous thrombosis after total hip arthroplasty with hypotensive epidural anesthesia. J Bone Joint Surg Am. 1994 Mar;76(3):341–8. PMID: 8126039.8126039
138 Anderson DR, Dunbar MJ, Bohm ER, . Aspirin versus low-molecular-weight heparin for extended venous thromboembolism prophylaxis after total hip arthroplasty: a randomized trial. Ann Intern Med. 2013 Jun 4;158(11):800–6. doi: 10.7326/0003-4819-158-11-201306040-00004. PMID: 23732713.23732713
139 Edwards JZ, Pulido PA, Ezzet KA, . Portable compression device and low-molecular-weight heparin compared with low-molecular-weight heparin for thromboprophylaxis after total joint arthroplasty. J Arthroplasty. 2008 Dec;23(8):1122–7. doi: 10.1016/j.arth.2007.11.006. PMID: 18534421.18534421
140 Kalodiki EP, Hoppensteadt DA, Nicolaides AN, . Deep venous thrombosis prophylaxis with low molecular weight heparin and elastic compression in patients having total hip replacement. A randomised controlled trial. Int Angiol. 1996 Jun;15(2):162–8. PMID: 8803642.8803642
141 Eisele R, Kinzl L, Koelsch T. Rapid-inflation intermittent pneumatic compression for prevention of deep venous thrombosis. J Bone Joint Surg Am. 2007 May;89(5):1050–6. doi: 10.2106/jbjs.e.00434. PMID: 17473143.17473143
142 Stannard JP, Harris RM, Bucknell AL, . Prophylaxis of deep venous thrombosis after total hip arthroplasty by using intermittent compression of the plantar venous plexus. Am J Orthop (Belle Mead NJ). 1996 Feb;25(2):127–34. PMID: 8640382.8640382
143 Rader CP, Kramer C, Konig A, . Low-molecular-weight heparin and partial thromboplastin time-adjusted unfractionated heparin in thromboprophylaxis after total knee and total hip arthroplasty. J Arthroplasty. 1998 Feb;13(2):180–5. PMID: 9526211.9526211
144 Westrich GH, Sculco TP. Prophylaxis against deep venous thrombosis after total knee arthroplasty. Pneumatic plantar compression and aspirin compared with aspirin alone. J Bone Joint Surg Am. 1996 Jun;78(6):826–34. PMID: 8666599.8666599
145 Verhamme P, Tangelder M, Verhaeghe R, . Single intravenous administration of TB-402 for the prophylaxis of venous thromboembolism after total knee replacement: a dose-escalating, randomized, controlled trial. J Thromb Haemost. 2011 Apr;9(4):664–71. doi: 10.1111/j.1538-7836.2011.04221.x. PMID: 21284801.21284801
146 Yilmaz S, Calbiyik M, Yilmaz BK, . Potential role of electrostimulation in augmentation of venous blood flow after total knee replacement: A pilot study. Phlebology. 2016 May;31(4):251–6. doi: 10.1177/0268355515580473. PMID: 25852131.25852131
147 Windisch C, Kolb W, Kolb K, . Pneumatic compression with foot pumps facilitates early postoperative mobilisation in total knee arthroplasty. Int Orthop. 2011 Jul;35(7):995–1000. doi: 10.1007/s00264-010-1091-8. PMID: 20652250.20652250
148 Alfaro MJ, Paramo JA, Rocha E. Prophylaxis of thromboembolic disease and platelet-related changes following total hip replacement: a comparative study of aspirin and heparin-dihydroergotamine. Thromb Haemost. 1986 Aug 20;56(1):53–6. PMID: 3535158.3535158
149 Fordyce MJ, Ling RS. A venous foot pump reduces thrombosis after total hip replacement. J Bone Joint Surg Br. 1992 Jan;74(1):45–9. PMID: 1732264.1732264
150 Kim YH, Choi IY, Park MR, . Prophylaxis for deep vein thrombosis with aspirin or low molecular weight dextran in Korean patients undergoing total hip replacement. A randomized controlled trial. Int Orthop. 1998;22(1):6–10. PMID: 9549575.9549575
151 Lassen MR, Borris LC, Christiansen HM, . Prevention of thromboembolism in 190 hip arthroplasties. Comparison of LMW heparin and placebo. Acta Orthop Scand. 1991 Feb;62(1):33–8. PMID: 1848385.1848385
152 Lou XK, Yan MJ. [Effect of different analgesia combined with low molecular heparin on hemorheology and coagulation in patients undergoing total hip replacement]. Zhonghua Yi Xue Za Zhi. 2010 May 4;90(17):1171–6. PMID: 20646562.20646562
153 Samama CM, Clergue F, Barre J, . Low molecular weight heparin associated with spinal anaesthesia and gradual compression stockings in total hip replacement surgery. Arar Study Group. Br J Anaesth. 1997 Jun;78(6):660–5. PMID: 9215015.9215015
154 Schwartsmann CR, Cavalieri CR, Drumond SN, . Randomized, comparative, open study to assess the efficacy and safety of enoxaparin compared with unfractionated heparin in the prophylaxis of venous thromboembolism in patients undergoing total hip arthroplasty. Randomized, comparative, open study to assess the efficacy and safety of enoxaparin compared with unfractionated heparin in the prophylaxis of venous thromboembolism in patients undergoing total hip arthroplasty. 1995;31:797–808. PMID: Embase 1996366023.
155 Sorensen JV, Borris LC, Lassen MR, . Levels of thrombin--antithrombin-III complex and factor VIII activity in relation to post-operative deep vein thrombosis and influence of prophylaxis with a low-molecular-weight heparin. Blood Coagul Fibrinolysis. 1990 Oct;1(4–5):389–92. PMID: 1966794.1966794
156 Torholm C, Broeng L, Jorgensen PS, . Thromboprophylaxis by low-molecular-weight heparin in elective hip surgery. A placebo controlled study. J Bone Joint Surg Br. 1991 May;73(3):434–8. PMID: 1670445.1670445
157 Turpie AG, Levine MN, Hirsh J, . A randomized controlled trial of a low-molecular-weight heparin (enoxaparin) to prevent deep-vein thrombosis in patients undergoing elective hip surgery. N Engl J Med. 1986 Oct 9;315(15):925–9. doi: 10.1056/nejm198610093151503. PMID: 3531851.3531851
158 Warwick D, Bannister GC, Glew D, . Perioperative low-molecular-weight heparin. Is it effective and safe. J Bone Joint Surg Br. 1995 Sep;77(5):715–9. PMID: 7559695.7559695
159 Welin-Berger T, Bygdeman S, Mebius C. Deep vein thrombosis following hip surgery. Relation to activated factor X inhibitor activity: effect of heparin and dextran. Acta Orthop Scand. 1982 Dec;53(6):937–45. PMID: 6184938.6184938
160 Alkire MR, Swank ML. Use of inpatient continuous passive motion versus no CPM in computer-assisted total knee arthroplasty. Orthop Nurs. 2010 Jan-Feb;29(1):36–40. doi: 10.1097/NOR.0b013e3181c8ce23. PMID: 20142693.20142693
161 Chin PL, Amin MS, Yang KY, . Thromboembolic prophylaxis for total knee arthroplasty in Asian patients: a randomised controlled trial. J Orthop Surg (Hong Kong). 2009 Apr;17(1):1–5. PMID: 19398783.19398783
162 Cho KY, Kim KI, Khurana S, . Is routine chemoprophylaxis necessary for prevention of venous thromboembolism following knee arthroplasty in a low incidence population? Arch Orthop Trauma Surg. 2013 Apr;133(4):551–9. doi: 10.1007/s00402-013-1691-z. PMID: 23381297.23381297
163 McKenna R, Galante J, Bachmann F, . Prevention of venous thromboembolism after total knee replacement by high-dose aspirin or intermittent calf and thigh compression. Br Med J. 1980 Feb 23;280(6213):514–7. PMID: 6989432.6989432
164 Wilson NV, Das SK, Kakkar VV, . Thrombo-embolic prophylaxis in total knee replacement. Evaluation of the A-V Impulse System. J Bone Joint Surg Br. 1992 Jan;74(1):50–2. PMID: 1732265.1732265
165 Jorgensen PS, Knudsen JB, Broeng L, . The thromboprophylactic effect of a low-molecular-weight heparin (Fragmin) in hip fracture surgery. A placebo-controlled study. Clin Orthop Relat Res. 1992 May(278):95–100. PMID: 1314147.1314147
166 Borgen PO, Dahl OE, Reikeras O. Blood loss in cemented THA is not reduced with postoperative versus preoperative start of thromboprophylaxis. Clin Orthop Relat Res. 2012 Sep;470(9):2591–8. doi: 10.1007/s11999-012-2320-9. PMID: 22476844.22476844
167 Bes-Rastrollo M, Schulze MB, Ruiz-Canela M, . Financial conflicts of interest and reporting bias regarding the association between sugar-sweetened beverages and weight gain: a systematic review of systematic reviews. PLoS Med. 2013 Dec;10(12):e1001578; dicsussion e. doi: 10.1371/journal.pmed.1001578. PMID: 24391479.24391479
168 Naci H, Dias S, Ades AE. Industry sponsorship bias in research findings: a network meta-analysis of LDL cholesterol reduction in randomised trials of statins. Bmj. 2014;349:g5741. doi: 10.1136/bmj.g5741. PMID: 25281681.25281681