# Methods

The present review updates and refines the 2012 Comparative Effectiveness Review on Venous Thromboembolism Prophylaxis in Orthopedic Surgery.^13^ It focuses on the Key Questions (KQ) listed at the end of the Introduction. Briefly, it evaluates the comparative effectiveness of different thromboprophylaxis modalities or interventions, not including placebo or no thromboprophylaxis, in patients undergoing major orthopedic surgery—total knee replacement (TKR), total hip replacement (THR), and hip fracture (HFx) surgeries—to prevent venous thromboembolism (VTE), including pulmonary embolism (PE) and deep vein thrombosis (DVT) and to minimize major complications, particularly bleeding.

The Brown Evidence-based Practice Center (EPC) conducted the review based on a systematic review of the published scientific literature, using established methodologies as outlined in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^15^

## Topic Refinement and Review Protocol

We conducted a surveillance review of the literature since the last search of the 2012 VTE report and discussed our findings with a Technical Expert Panel (TEP) and local domain experts. The TEP provided a range of insights to allow us to refine the KQs, eligibility criteria, and protocol, and regarding the currency and relevance of the 2012 VTE report and its KQs and eligibility criteria. The TEP included 10 members, including four orthopedic surgeons, two hematologists, one pulmonologist, one pharmacist, one physical therapist, and one nurse practitioner. The panel included committee members from the American Academy of Orthopaedic Surgeons clinical practice guidelines, committee members from the American College of Chest Physicians clinical practice guidelines, and an author of the 2012 VTE report.

Upon revision of the KQs for the updated systematic review, the TEP provided input to help refine the protocol, identify important issues, and define parameters for the review of evidence. The TEP was also asked to suggest additional studies for evaluation.

## Search Strategy

A comprehensive search of the scientific literature was conducted to identify relevant studies addressing the KQs that have been published since the 2012 VTE report, which included studies published from 1980 through May 2011. We searched PubMed®, both the Cochrane Central Trials Registry® and Cochrane Database of Systematic Reviews®, and Embase® databases. Searches were limited to January 2010 through June 3, 2016, which included an overlap of more than 1 year with the search done for the 2012 VTE report. The updated literature searches replicated the searches from the 2012 VTE report and added additional terms for new treatments (factor Xa inhibitors [FXaI]). See Appendix A for the complete search strategy. The search strategy was peer reviewed by an independent, experienced information specialist/librarian.

We also searched the ClinicalTrials.gov registry and the Food and Drug Administration, Healthy Canadians, and the U.K. Medicines & Healthcare products Regulatory Agency Web sites for relevant documents from 2011 through July 18, 2016. In addition, the reference lists of published clinical practice guidelines, systematic reviews, and Scientific Information Packages from manufacturers were hand-searched, and the TEP members were invited to provide references of new studies. Existing systematic reviews were used primarily as sources of new studies. With the exception of studies included in the 2012 VTE report, we extracted and incorporated any studies de novo and did not summarize or incorporate the existing systematic reviews. All articles identified through these sources were screened for eligibility using the same criteria as was used for articles identified through literature searches.

All studies cited and tabulated in the 2012 VTE report were screened for eligibility on a par with new studies. However, as noted below, we relied on the summary tables in the 2012 VTE report for data from these studies.

## Study Eligibility Criteria

The eligibility criteria for this update are mostly similar to the criteria used in the 2012 VTE report, as pertain to updated KQs.

### Populations of Interest

For all KQs, studies of patients undergoing major orthopedic surgery (THR, TKR, HFx) were eligible. In contrast with the 2012 VTE report, we excluded studies that included more than one type of surgery but did not report results separately by surgery type. This modification was implemented in part for clarity and precision across the three substantially different surgeries and also because of indications of different risks of VTE and major bleeding for the different surgeries, as suggested by the 2012 VTE report (total DVT on placebo: THR 39%, TKR 46%, and HFx surgery 47%; major bleeding on placebo: THR 1%, TKR 3%, and HFx surgery 8%).^1^ We did not exclude studies based on details regarding the type of eligible surgery, related anesthesia management, or perioperative care. Therefore, for example, both primary and revision arthroplasty and unicompartmental and tricompartmental TKR are included. Subpopulations of interest included those defined by specific surgery, age, race/ethnicity, health status, comorbidities, prior history of abnormal surgical bleeding or bleeding disorder, prior medications (e.g., antiplatelet drugs), kidney function, and treatment adherence/compliance.

### Interventions of Interest

The interventions of interest for all KQs included pharmacological VTE prophylaxis agents within the defined classes of antiplatelet agents, low molecular weight heparin (LMWH), unfractionated heparin (UFH), factor VIII inhibitors (FEI), factor Xa inhibitors (FXaI), factor XI inhibitors (FXIi), direct thrombin inhibitors (DTI), vitamin K antagonists (VKA), and mechanical VTE prophylaxis devices within the classes graduated compression stockings (GCS), intermittent pneumatic compression devices (IPC), and venous foot pumps (VFP). We also included studies of prophylactic inferior vena cava filters for KQs 1 and 5 (that compared classes of interventions). We included multimodality therapies KQ 3 (different doses, regimens, or treatment durations). We included studies of combination therapies (e.g., drug plus mechanical device) for KQs 4 and 5 and of different starting times relative to surgery for KQ 6.

### Comparators of Interest

We included any of the above interventions as comparators as pertinent, including

- KQ 1, 5 intervention in a different class (and placebo for KQ 5)
- KQ 2, 5 intervention within the same class (and placebo for KQ 5)
- KQ 3 same intervention with different (lower) dose (or anticoagulation goal), (less intensive) regimen, or (shorter) duration
- KQ 4 single modality intervention
- KQ 6 same intervention started at different (later) time relative to surgery

There is an important caveat regarding KQ 5, the network meta-analyses. In contrast to other KQs, we included placebo and no thromboprophylaxis study arms. This was done to enhance the power of the network meta-analysis. See below, under Study Design, regarding where no treatment arm data were derived.

## Outcomes of Interest

For all KQs, except KQ 5 (the network meta-analysis), we evaluated the outcomes in the following list. We did not use strict a priori definitions of the outcomes, but included all reported outcomes as defined by study researchers. When necessary, we used our best judgment to categorize outcomes when studies failed to clearly define their reported outcomes (e.g., whether reported DVTs were total or symptomatic, whether reported bleeding was major).

- VTE (combined PE and DVT)
  ○ Total VTE (symptomatic and asymptomatic)
  ○ Symptomatic VTE
- PE
  ○ Total PE (fatal and nonfatal; symptomatic and asymptomatic)
  ○ Fatal PE
  ○ Symptomatic PE
- DVT
  ○ Total DVT (symptomatic and asymptomatic; proximal and distal)
  ○ Symptomatic DVT
  ○ Proximal DVT
- Postthrombotic syndrome (PTS)
- Pulmonary hypertension (due to PE)
- Adherence (compliance) with treatment
- Adverse events due to intervention(s)
  ○ Major bleeding, including:
    ■ Fatal bleeding
    ■ Bleeding leading to transfusion
    ■ Major bleeding leading to reoperation
    ■ Major bleeding leading to readmission
    ■ Surgical site/joint bleeding
    ■ Bleeding leading to infection
    ■ As defined by authors
  ○ Surgical site/wound-related infections
  ○ Surgical site/wound complications (other than bleeding, infection)
  ○ Heparin-induced thrombocytopenia
  ○ Adverse events due to mechanical devices (as reported by authors)
  ○ Adverse events due to IVC filter (as reported by authors)
  ○ Other clinically significant adverse events reported by studies

For KQ 5 (the network meta-analysis), we fully evaluated only total DVT and major bleeding.

We included confirmed and unconfirmed VTE, but downgraded the risk of bias for those studies that analyzed unconfirmed VTE. If both confirmed and unconfirmed VTE were reported, we extracted only the confirmed VTE data. Other outcomes were considered but had insufficient evidence for network meta-analysis; however, they are described briefly in Appendix H.

### Study Design

For all KQs, we included randomized controlled trials (RCT) of any sample size. For KQs other than the network meta-analysis (KQ 5), we also included prospective or retrospective nonrandomized comparative studies (NRCS) with at least 750 patients per surgery type, per study. In contrast to the 2012 VTE report, we also required at least 50 patients in each included study arm (or intervention). NRCSs with fewer than 50 patients in any study arm (per surgery type) were still eligible if they compared at least two study arms with 50 or more patients and had 750 or more patients in the remaining study arms; however, the study arms with less than 50 patients were omitted from analysis.

We included published, peer-reviewed articles, conference abstracts and presentations, and studies reported only in the ClinicalTrials.gov Web site. Non-English language publications were extracted by researchers fluent or facile in the published languages. Unavailable publications were included and extracted only from their English language abstract.

### Timing

We included studies with any duration of followup. For VTE outcomes, we extracted results at all reported timepoints, but for meta-analyses we preferentially analyzed timepoints closest to 30 days postoperative (as being the most commonly reported timepoint).

### Setting

Studies performed in hospital (with or without continuation of intervention or followup after discharge)

## Study Selection

We assessed titles and abstracts of citations identified from literature searches for inclusion, using the above eligibility criteria. Abstract screening was done in the open-source, online software Abstrackr (http://abstrackr.cebm.brown.edu/). Full-text articles of potentially relevant abstracts were retrieved and a second review for inclusion was conducted by reapplying the eligibility criteria. Both abstract and full-text screening was conducted in duplicate with conflicts resolved by reconciliation among the whole research team. All rejected full-text articles were confirmed by the project lead.

Studies included in the 2012 VTE report were reassessed for inclusion based on the summarized data available in the 2012 VTE report. In general, we did not confirm eligibility criteria for these studies from the full-text articles.

## Data Extraction

Each study was extracted by one methodologist and confirmed by at least one other experienced methodologist. Disagreements were resolved by open, free-flowing discussion among the team to achieve consensus. Data extraction was conducted into customized forms in the Systematic Review Data Repository online system designed to capture all elements relevant to the KQs (http://srdr.ahrq.gov); the completed extraction forms are available for public review at this site. These included population characteristics, including description of patients’ surgery, descriptions of the interventions analyzed, descriptions of relevant outcomes, sample sizes, study design features, funding sources, results (including adverse events), and risk of bias assessment. The forms were tested on several studies and revised as necessary.

New studies added to the 2012 VTE report were extracted from the full-text articles and any available supplemental material. With few exceptions, eligible studies from the 2012 VTE report extracted and entered into SRDR based only on the available data presented in the 2012 VTE report.

## Risk of Bias Assessment

We based the methodological quality of each study on predefined criteria. For RCTs, we used the Cochrane risk of bias tool,^16^ which asks about risk of selection bias, performance bias, detection bias, attrition bias, reporting bias, and other potential biases. For observational studies, we used selected questions from the Newcastle Ottawa Scale about comparability of cohorts, representativeness of the population, and adjustment for different lengths of follow-up.^17^ The methodological quality of the eligible studies from the 2012 VTE report was based solely on what was reported in that report’s methodological quality tables. Risk of bias questions included in the current review that were not assessed in the 2012 VTE report were marked as “NR” (not reported).

## Data Synthesis

### Narrative and Tabular Synthesis

All included studies are presented in summary tables that include the important features of the study populations, design, intervention, and risk of bias. Study results are summarized in two ways, depending on the available evidence across studies. For specific comparisons that were analyzed by pairwise meta-analysis, results are reported graphically (in forest plots). For specific comparisons, for which pairwise meta-analysis was not appropriate or feasible (i.e., not conducted), outcome results are tabulated in Appendix F and summarized in high-level summary tables. Analyses with sufficient evidence for meta-analysis (including network meta-analysis) are described in the text. Other comparisons with inadequate evidence (for meta-analysis and from the perspective of strength of evidence [SoE]) are summarized more generally. All outcome results are available in SRDR and is publically available (http://srdr.ahrq.gov).

### Pairwise Meta-Analysis

For KQs 1 through 4 and 6, we conducted restricted maximum likelihood random effects model meta-analyses of four or more comparative studies that were sufficiently similar in population, interventions, and outcomes. Odds ratios (ORs) were chosen as the metric to analyze categorical outcomes. In the analysis of rare outcomes (<1%), we used Peto’s OR.^18–20^ Studies with no events in both trial arms were excluded as they do not contribute to the estimate of the summary effect. In the analysis by class (KQ 1), for trials containing arms with different doses of the same intervention, we included the arm with the dose that was most similar to other studies or the arm with the largest sample size in the event that it was the only study of that intervention. Pairwise meta-analyses were conducted in R using the metafor package. Results are presented in terms of summary ORs and the corresponding 95 percent confidence interval (CI).

### Network Meta-Analysis

To address KQ 5, we conducted network meta-analyses under a Bayesian framework. The specific model is described by Dias et al.^21^ Network meta-analysis is an extension of pairwise meta-analyses that simultaneously combines direct comparisons (where interventions are compared head-to-head) and indirect comparisons (where interventions are compared through other reference interventions). Combining the direct and indirect evidence not only improves precision of estimates, but also provides estimates for all pairwise comparisons, including those missing from the direct evidence. The key assumption of the network meta-analysis is that there is consistency of direct and indirect effects. Consistency is likely to hold when the distribution of effect modifiers is similar across trials, and thus, patients are similar across trials. If this assumption is violated, there may be inconsistency between the direct evidence and indirect evidence of treatment comparisons (where the direct and indirect comparisons contradict each other).

For binary outcomes (e.g., total DVT and major bleeding), the network meta-analysis model corresponds to a generalized linear mixed model with a logit link. We included random effects on the treatment parameters, which allowed each study to have a different but related treatment effect estimate versus a reference treatment. The amount of between-study variance (heterogeneity) was assumed to be constant across all treatment comparisons. We used noninformative prior distributions for the model parameters. The models initially discarded a set of 50,000 iterations as “burn-in,” and the inferences were based on additional 50,000 iterations (“runs”) using 4 chains. Convergence of the chains was assessed by the Gelman-Rubin statistic and visual inspection of trace plots. Due to the sparseness of data in some networks, we also conducted analyses with an informative log-normal prior for the heterogeneity parameter.^22^ The results of these analyses lead to similar conclusions as the base analysis, and are presented in Appendix G.

For each analysis, we empirically assessed if the network meta-analysis consistency assumption was violated by comparing the direct and indirect evidence using a node-splitting approach.^21^ This approach evaluates each treatment comparison in terms of its direct and indirect evidence estimates. Discrepancies between these estimates indicate inconsistency. Since we did not find any evidence of inconsistency, only results from the (consistency) network meta-analysis are presented. However, the inability of the models to detect inconsistency in our evidence base with sparse data may be due to the lack of power rather than suggestive of consistent networks.

We conducted a total of 12 network meta-analyses to compare all treatment alternatives across studies. For each of three surgeries (THR, TKR, and HFx surgery) and for the two outcomes (total DVT and major bleeding) we conducted two analyses: 1) comparisons of classes of thromboprophylaxis interventions (e.g., LMWH, antiplatelet drugs) and 2) comparisons of individual interventions. For trials containing arms with different doses of the same intervention, we included the arm with the dose that was most similar to other studies or the arm with the largest sample size in the event that it was the only study of that intervention. For all network meta-analyses (in contrast to KQ 1–4 and 6), we included placebo/no treatment as an intervention (or class) to strengthen the network of evidence. Placebo-controlled trials were included in the network if they included active interventions that were otherwise in the network. We omitted placebo-controlled trials that would be a spur in the network (if, across trials, the intervention was compared only to placebo, not to any active intervention). Network meta-analyses were conducted in R using the gemtc package. Results are presented in terms of summary ORs and the corresponding 95 percent credible interval (CrI).

#### Summarizing Findings Across Studies

For each comparison of interventions, we determined a conclusion (or summary of findings across studies) for each outcome with sufficient evidence (i.e., not insufficient evidence, see Grading the Strength of Evidence).

We concluded the evidence “favors” one intervention (over the other) when

- there was a statistically significant difference by meta-analysis,
- when the preponderance of studies found a statistically significant difference in the same direction (when no meta-analysis was conducted), or
- meta-analysis found a statistically nonsignificant effect size that was either greater than 1.20 or less than 0.80.
  ○ However, if the 95 percent confidence interval was highly imprecise (beyond both 0.50 and 2.00), the conclusion was “unclear” regardless of the magnitude of the point estimate.
  ○ If a conclusion was based on a statistically nonsignificant effect size, the strength of evidence (see below) was low (it could not be moderate or high).

We concluded that interventions had similar effects (noted in tables as favoring “either”) when summary effect sizes (by meta-analysis) or the preponderance of studies’ effect sizes (when not meta-analyzed) were between 0.80 and 1.20, were not statistically significant, and were not highly imprecise or inconsistent (across studies).

When studies were sparse, effect size estimates were highly imprecise (95% confidence intervals beyond both 0.50 and 2.00, usually due to sparse events), or studies were highly inconsistent (e.g., with point estimates ranging from 0.14 to 3.03), we deemed the findings to be “unclear” (with an insufficient strength of evidence).

### Subgroup Analyses and Metaregression

All studies were evaluated for within-study subgroup (or predictor) analyses. As feasible, studies were also categorized based on whether, as a whole, they evaluated particular populations of interest, such as studies that included at least 90 percent of a subgroup of interest, including sex, race/ethnicity, older age group, body weight category, tobacco use, chronic disease, varicosities, history of bleeding disorders or surgical bleeding, prior VTE, presurgical use of antiplatelet drugs or warfarin, or hormones, unilateral versus bilateral surgery, primary versus revision surgery, use of cemented fixation, tourniquet use, tranexamic acid use, anesthesia type, etc. We also investigated potential differences between studies based on industry funding and study region (Asia vs. other). We aimed to conduct random effects model metaregressions for many variables but data were too sparse to allow meaningful analyses for most.

## Grading the Strength of Evidence

We graded the strength of the body of evidence as per the AHRQ Methods Guide on -assessing the SoE.^23^ We assessed the SoE for each health outcome, as determined with input from the panel of technical experts: total VTE, symptomatic VTE, PE, DVT, and adverse events. Following the standard AHRQ approach, for each intervention and comparison of intervention, and for each outcome, we assessed the number of studies, their study designs, the study limitations (i.e., risk of bias and overall methodological quality), the directness of the evidence to the KQs, the consistency of study results, the precision of any estimates of effect, the likelihood of reporting bias, and the overall findings across studies. Throughout the report, all estimates with 95 percent CI or CrI beyond 0.5 and 2.0 were considered to be highly imprecise. Based on these assessments, we assigned a SoE rating as being either high, moderate, low, or there being insufficient evidence to estimate an effect. Conclusions based on statistically nonsignificant findings could have at best a low SoE. Outcomes with highly imprecise estimates, highly inconsistent findings across studies, or with data from only one or two studies were deemed to have insufficient evidence to allow for a conclusion (with the exception that particularly large, generalizable single studies could provide at least low SoE). The data sources, basic study characteristics, and each strength-of-evidence dimensional rating are summarized in a “Strength of Evidence” table detailing our reasoning for arriving at the overall SoE rating.^20^

## Peer Review

A draft version of this report was reviewed (from July 27 to August 23, 2016) by invited and public reviewers, including representatives from orthopedic societies, industry, our TEP, and the general public. These experts were either directly invited by the EPC or offered comments through a public review process. Revisions of the draft were made, where appropriate, based on their comments. The draft and final reports were also reviewed by the Task Order Officer and an Associate Editor from another EPC. However, the findings and conclusions are those of the authors, who are responsible for the contents of the report.