# Peer Reviewers

Prior to publication of the final evidence report, we sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Rongwei (Rochelle) Fu, Ph.D.
  Pacific Northwest Evidence-based Practice Center
  School of Public Health
  Oregon Health & Science University
  Portland, OR
- Courtland Lewis, M.D.
  Saint Francis Hospital and Medical Center
  Hartford, CT
- James Rickert, M.D.
  Indiana University School of Medicine, Bedford, IN
- Mary Kay Welle, M.S.N.
  St. Mary’s College Department of Nursing Science
  Notre Dame, IN