# Technical Expert Panel

In conducting a surveillance of the literature since the prior AHRQ report on venous thromboembolism prophylaxis in orthopedic surgery, we consulted several technical, content, and clinical experts. The Technical Experts provided comments on their interpretation of the current state of the evidence and of clinical questions that are currently pertinent to patient management and decisionmaking. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Lisa Boggio, M.D.^*^
  Rush University
  Chicago, IL
- Clifford Colwell, M.D.
  Scripps Clinic
  La Jolla, CA
- Charles Francis, M.D.^*^
  University of Rochester
  Rochester, NY
- Joshua J. Jacobs, M.D.^*^
  Rush University
  Chicago, IL
- Jay Lieberman, M.D.
  University of Southern California
  Los Angeles, CA
- Christine McDonough, Ph.D.^*^
  Boston University School of Medicine
  Boston, MA
- Michael Mont, M.D.
  Sinai Hospital
  Baltimore, MD
- Lisa Moores, M.D.
  Walter Reed National Military Medical Center
  Bethesda, MD
- C. Michael White, Pharm.D.^*^
  University of Connecticut Evidence-based Practice Center
  Farmington, CT
- Karen Wilk, M.S.^*^
  University of Massachusetts School of Medicine
  Worcester, MA

* Provided input on Draft Report.