# Acknowledgments

The authors gratefully acknowledge the following individuals for their invaluable assistance in scoping and refining the protocol; understanding the included surgeries, interventions, perioperative management, and outcomes; and interpreting the methodology used by studies:

- Roy Aaron, M.D.
  Lifespan Hospital (Brown University)
  Providence, RI
- Alok Kapoor, M.D., M.S.
  Memorial Medical Center (University of Massachusetts)
  Worcester, MA
- Jennifer Racine, M.B.A.
  Lifespan Hospital (Brown University)
  Providence, RI
- Eric Winer, M.D.
  Alpert Medical School (Brown University)
  Providence, RI

We would also like to thank the American Academy of Orthopaedic Surgeons, the American Association of Hip and Knee Surgeons, and Medtronic, Inc., who submitted comments on the draft report through the public comment mechanism.