# Discussion

As reviewed in the 2012 venothromboembolism (VTE) report, there is a high strength of evidence (SoE) from prior research that VTE prophylaxis after major orthopedic surgery reduces the incidence of total DVTs, in comparison to no (or placebo) prophylaxis; although the rarity of postoperative pulmonary embolism (PE) makes difficult a definitive answer to whether thromboprophylaxis is effective to reduce PE or death.^1^ Systemic (i.e., nonmechanical) interventions also in general increase the risk of postoperative bleeding, compared to no (or placebo) prophylaxis.^1^ Because of the presumed strong relationship between deep vein thrombosis (DVT; particularly proximal DVTs) and resultant PE, some form of thromboprophylaxis has become standard of care after major orthopedic surgery. The question of the relative effectiveness and safety of different thromboprophylaxis interventions remained uncertain as of the 2012 VTE report.

A large volume of evidence has been garnered comparing intervention options to prevent VTE in patients undergoing total hip replacement (THR), total knee replacement (TKR), and hip fracture (HFx) surgery. In total this systematic review addressing comparative effectiveness and harms of drug and mechanical interventions included 127 randomized controlled trials (RCTs) and 15 large nonrandomized comparative studies (NRCSs) examining head-to-head comparisons. The review explicitly evaluates direct comparative information and does not examine placebo-controlled effectiveness studies (with the exception of including placebo trials in the network meta-analyses). These studies pertain to three different surgeries and include nine different classes of intervention and 21 specific interventions (plus 6 combinations of classes or interventions). Furthermore, the studies disproportionately (78%) evaluated low molecular weight heparin (LMWH) and enoxaparin in particular (60%). Thromboprophylactic interventions that are most likely to have lower risk of major bleeding (particularly aspirin and mechanical devices, for which there is limited research funding support compared with newer pharmaceutical interventions) have been inadequately studied in direct comparison studies, severely limiting strong conclusions regarding their relative effectiveness and safety. In addition, studies implicitly used a variety of specific orthopedic surgical techniques, but generally failed to describe these sufficiently to allow cross-study comparisons based on surgical techniques (or VTE- or bleeding-risk status of patients); no study reported within-study comparisons of different patients based on these characteristics. Studies also differed in regard to the specific VTE outcomes that were reported. Most studies reported total DVT (82%), which includes asymptomatic DVTs and is thus not routinely diagnosed and may not be clinically important as pertains to PE and other clinical vascular outcomes. Between one-third and two-thirds of studies did not report the other, more clinically important, VTE outcomes (e.g., symptomatic DVT). Based on an imperfect analysis across generally relatively small studies, we found that rates of total DVT are not correlated with rates of total PE (r=0.07); although, this analysis is also hampered by the fortuitous fact that few study participants had a PE. Because PEs are relatively rare, total DVTs have become a common primary outcome for VTE prophylaxis studies in part to increase power (since total DVTs are more common than symptomatic DVTs); however, reliance on this outcome may result in biased conclusions if some interventions are more effective at preventing asymptomatic or distal DVTs (and thus total DVTs) but not more effective at preventing clinically significant DVTs. Because of (potentially biased) incomplete reporting of all VTE outcomes, it is not possible to assess whether total DVT is an appropriate proxy for PE, death, or long-term sequelae secondary to DVTs.

The current review summarizes several advances in the literature base and interpretation since the 2012 VTE report. Newer studies led to a clearer understanding that there is a tradeoff between VTE and major bleeding with either LMWH or direct thrombin inhibitors (DTIs). There are also new studies of factor Xa inhibitors (FXaI), but its relative effect compared to LMWH remains unclear due to inconsistencies across different VTE outcomes and adverse events. Observational studies allowed a new conclusion that LMWH and aspirin have similar effects on total PE, symptomatic DVT, and major bleeding, with low SoE. New evidence also supports tradeoffs between higher and lower dose LMWH and DTI in regards to VTE outcomes and major bleeding, and that higher dose FXaI results in lower risk of total VTE than lower dose. Compared to the 2012 VTE report, similar conclusions were reached regarding the relative benefits of LMWH over unfractionated heparin (UFH), the tradeoff between VTE and major bleeding with LMWH versus VKA, and the superiority of longer duration LMWH than shorter duration.

The large majority of studies compared different intervention classes (relevant to Key Question 1), but few compared specific interventions within a class (Key Question 2); different doses, regimens, or intervention durations (Key Question 3); combinations of intervention classes (Key Question 4); or different treatment start times (Key Question 6). Therefore, many of the conclusions (answers to the Key Questions) are highly limited due to insufficient evidence. In particular, conclusions are limited to the specific intervention comparisons and outcomes for which there was sufficient evidence. In addition, for most analyses, there is substantial concern about reporting bias (see Evidence and Analysis Limitations).

When summarizing a body of evidence, different approaches can be taken to draw conclusions from the evidence and to determine SoE. The choice of approach can have major impact on determining whether interventions differ in their effects, interventions have similar effects, or data are inconclusive (or insufficient) regarding relative effect. Specific users of the this evidence summary may differ in the assumptions they would make (e.g., whether statistically nonsignificant effects can be said to favor one intervention over another) or in the choice of minimal differences thought to be clinically important. This summary of the evidence uses a threshold of less than 0.80 or greater than 1.20 to suggest that an intervention is favored to reduce the risk of the given outcome, regardless of statistical significance, analogous to a minimal clinical important difference of approximately 20 percent. Notably, statistically nonsignificant effect sizes greater than 20 percent could yield (low SoE) conclusions of differences in effect between interventions.

## Evidence Summary

### Total Hip Replacement

In summary, from direct comparisons for THR the evidence suggests that

- There is a tradeoff between LMWH and DTI, such that DTI prevents more total DVTs (moderate SoE) and proximal DVTs (moderate SoE) but LMWH results in less major bleeding (low SoE)
- The evidence is inconsistent regarding LMWH and FXaI in that studies reported that FXaI better lowers risk of total VTE (low SoE), total DVT (moderate SoE), and proximal DVT (moderate SoE), but LMWH better lowers the risk of symptomatic VTE (low SoE) and symptomatic DVT (low SoE). There is high SoE that LMWH is better to prevent major bleeding, but both classes have similar rates of study-defined serious adverse events (moderate SoE). The inconsistencies in these finding suggest important reporting bias.
- Evidence regarding LMWH vs. UFH overall favors LMWH with lower risk of total PE (high SoE), proximal DVT (moderate SoE), and major bleeding (moderate SoE); risk of total DVT is similar between drug classes (moderate SoE).
- The relative effect of LMWH vs. vitamin K antagonists (VKA) is unclear. There is insufficient evidence regarding the relative benefit of either drug class to lower the risk of any VTE outcome, but VKA results in lower risk of major bleeding (high SoE).
- LMWH and aspirin result in similar rates of total PE, symptomatic DVT, and major bleeding (all low SoE, based on observational studies).
- The relative effect of VKA vs. mechanical devices is unclear. VKA results in lower risk of proximal DVT (high SoE), but insufficient evidence all favors mechanical devices to lower the risk of total DVT, and adverse events data have not been reported.
- The relative effect of lower vs. higher dose FXaI is unclear. Higher dose FXaI has a lower risk of total VTE (low SoE), but there is insufficient evidence for other outcomes, including adverse events.
- There is a tradeoff between lower and higher dose LMWH, such that higher dose LMWH has a lower risk of total DVT (low SoE), both dose levels have similar risks of proximal DVT (moderate SoE), and lower dose LMWH has a lower risk of major bleeding (moderate SoE).
- The evidence favors longer duration LMWH (>2 weeks) over shorter duration LMWH (up to 10 days or to hospital discharge), with lower risk of total PE (low SoE), total DVT (high SoE), and proximal DVT (moderate SoE) and rare occurrences of major bleeding with any duration.

Network meta-analyses pertain only to total DVT and major bleeding; they suggest that

- FXaI and DTI may be most effective to prevent total DVT compared with mechanical devices, LMWH, VKA, and UFH (moderate SoE)
- LMWH is more likely to result in fewer major bleeding events than FXaI (low SoE)
- Dalteparin is most likely to be most effective to prevent total DVTs compared with enoxaparin, intermittent pneumatic compression devices, UFH, and warfarin (moderate SoE)

Most outcomes were not reported by many studies, resulting in a high risk of reporting bias across the evidence base. A within-study subgroup analysis was inconclusive regarding differential risks of bleeding with LMWH and DTI by chronic kidney disease category. Industry-funded studies had similar finding as other studies. Asian studies had similar findings as non-Asian studies.

### Total Knee Replacement

Fewer studies of TKR (than THR) yielded fewer conclusions with sufficient evidence. In summary, from direct comparisons for TKR the evidence suggests that

- The relative effect of FXaI vs. LMWH is unclear. FXaI results in a lower risk of total VTE (low SoE), total DVT (low SoE), and proximal DVT (moderate SoE), but similar risks for symptomatic DVT (low SoE); risk of major bleeding is lower with LMWH (low SoE) but risk of study-defined serious adverse events is lower with FXaI (low SoE).
- There is a tradeoff between LMWH and VKA, such that LMWH better lowers risk of total DVT (high SoE) and proximal DVT (low SoE), but VKA has a lower risk of major bleeding (low SoE).
- There is a tradeoff between lower and higher dose DTI, such that higher dose DTI (dabigatran 220 to 225 mg) has a lower risk of total DVT (high SoE) and proximal DVT (moderate SoE) than lower dose (dabigatran 150 mg), but lower dose DTI has less risk of major bleeding (low SoE).
- The relative effect of lower vs. higher dose FXaI is unclear. Higher dose FXaI results in a lower risk of total VTE (moderate SoE), symptomatic DVT (low SoE), and proximal DVT (low SoE); however, there is insufficient evidence for adverse events.

From network meta-analyses,

- FXaI is more likely to be effective to prevent total DVT than LMWH (low SoE)

Most outcomes were not reported by many studies, resulting in a high risk of reporting bias across the evidence base. A within-study subgroup analysis did not find a substantial difference in relative effect of antiplatelet drug versus mechanical device between unilateral or bilateral TKR surgery. Industry-funded studies had similar finding as other studies. Asian studies had similar findings as non-Asian studies.

### Hip Fracture Surgery

Only 12 eligible studies evaluated thromboprophylaxis interventions in patients who underwent HFx surgery. Most specific comparisons were addressed by only one study.

- The relative effect of LMWH and FXaI is unclear. LMWH results in lower risk of total DVT than FXaI (moderate SoE), but there is insufficient evidence for other outcomes.
- For all other comparisons and for all other Key Questions the SoE is insufficient regarding HFx surgery.

## Evidence and Analysis Limitations

As noted in the evidence summary, despite the large number of trials addressing thromboprophylaxis in patients undergoing major orthopedic surgery, there is inadequate evidence to confidently compare the effectiveness and the major adverse events of the myriad treatment options. As noted, the large majority of evidence pertains to LMWH (specifically enoxaparin), limiting the ability to compare all interventions. In particular, there are sparse RCTs or NRCSs that evaluated antiplatelet drugs (e.g., aspirin), VKA (e.g., warfarin), or mechanical devices. However, the network meta-analyses are subject to important caveats. The sparseness of direct comparisons between most interventions within each network weakened the structure and the conclusions from the network meta-analyses. The only VTE outcome with sufficient evidence to allow network meta-analysis was total DVT, which is of questionable clinical significance since it includes asymptomatic and distal DVTs which have not been demonstrated to be associated with increased risk of PE. It is also important to recognize that the ranking of interventions by network meta-analysis may not be stable and may be susceptible to change with the addition of more studies; the ranking orders are also not supported by evaluations of statistical significance. However, network meta-analysis findings were consistent with direct, pairwise comparisons of interventions to lower the risk of total DVT and major bleeding.

The network meta-analyses provided greater power to compare all intervention classes and all interventions, but the sparseness of direct (within-study) comparisons for many of the interventions meant that meaningful conclusions could be derived for only a small subset of the interventions.

Further hampering evaluation of the trials, studies were not consistent in which specific outcomes were reported. Notably only total DVT was reported by more than 80 percent of the studies. However, as discussed, this outcome is of unclear clinical importance. Only about half of studies reported major bleeding, the adverse event of greatest concern for most interventions. Most of the VTE outcomes were reported by 50 percent or fewer of the studies. Only one study reported all VTE and adverse event outcomes of primary interest to our panel of stakeholders and only two studies reported all VTE outcomes. Full reporting of VTE outcomes and adverse events by trials would have allowed greater SoE for almost all intervention classes and several specific interventions. However, studies arbitrarily or selectively reported specific outcomes.

Our analyses did not find significant evidence of bias due to industry funding, based on subgroup meta-analysis comparisons of industry-funded vs. other studies. However, 54 percent of the trials were industry-supported and only 13 percent of RCTs explicitly reported no industry support, which might partially explain the selective outcome reporting.^167, 168^ The relatively small number of RCTs available for meta-analysis for any given comparison and the small percentage of studies explicitly with no industry support meant that our analyses of industry funded required us to combine RCTs with no industry support and those that did not report funding source. If many of the studies that did not report funding were in fact industry-funded, then any real funding-source bias would have been diluted by the misclassification of funding source. Under the assumption that industry is most likely to fund and publish studies designed to be favorable to their products, the fact that the majority of evidence is industry-supported may explain the selective outcome reporting across studies (if favorable outcomes were more likely to be reported and nonfavorable outcomes omitted), the preponderance of evidence regarding enoxaparin, the sparseness of evidence on aspirin and mechanical devices, and relative sparseness of head-to-head trials of newer drugs (as opposed to comparisons with UFH or placebo).

The RCTs were generally consistent in regard to their eligibility criteria, mostly including all-comers without contraindications. This approach improves the applicability of the individual trials (and thus of the systematic review). Nonetheless, effect sizes in subgroups were rarely reported in these RCTs, and it greatly hampered our ability to evaluate potential explanations for heterogeneity or to hypothesize about possible subgroup differences based on patient history or surgery or anesthesia characteristics. Other than funding source, we were able only to evaluate potential differences between Asian and non-Asian studies. Overall, we found no significant difference between studies conducted in different regions (among analyzable studies), except major bleeding for the comparison of LMWH and FXaI in patients undergoing THR (summary OR in Asian RCTs 1.95, 95% CI 0.46 to 8.22; summary OR in non-Asian studies 0.68, 95% CI 0.49 to 0.94). Nevertheless, the event rates in the Asian studies were generally lower than the non-Asian studies. It suggests incomparability in the two populations besides ethnicity, which might explain the potential difference in the treatment effects. Only two RCTs reported on within-study subgroup analyses based on chronic kidney disease category (major bleeding, enoxaparin vs. desirudin) and by unilateral versus bilateral TKR surgery (DVT, aspirin vs. compression boots). Neither study found a significant difference in treatment effect in the different subgroups. Differences in effectiveness and safety between numerous different subgroups could not be evaluated due to lack of reporting of such analyses, including by age, sex, race, thrombosis risk factors, bleeding risk factors, comorbidities, medication use, or surgery types or techniques.

Of note, this review evaluated the evidence as per the a priori protocol, which was built off of, and relied on, the 2012 VTE report.^13^ Acknowledging that evidence for some interventions (e.g., mechanical devices) was likely to be sparse, we included larger NRCS. However, the smaller NRCSs that were excluded may have provided additional evidence, particularly for mechanical devices. While we did not reevaluate (mostly old) placebo-controlled RCTs among the direct comparisons between interventions, these studies were included in the NMAs. This review also did not cover numerous pertinent clinically important questions including comparisons of different strategies (e.g., aspirin and mechanical devices for low-risk patients and LMWH for high-risk patients). There are multiple standard methods for accounting for evidence in three (or more) arm studies in meta-analyses, when two (or more) of the arms are the same intervention (e.g., at different doses). In these instances, we chose the simplest method, which may be most clinically relevant in that we chose to analyze only the U.S. Food and Drug Administration (FDA)-approved dose. When this was not possible, we selected the arm with the largest sample size (among FDA-approved or commonly used doses).

## Future Research Recommendations

Much of the evidence base is insufficient to allow confident conclusions. Much of this lack is due to a relative sparseness of evidence evaluating interventions other than LMWH, and enoxaparin in particular. A more complete evidence base for the other treatments would allow for a stronger ranking of intervention classes, and of specific interventions, in term of risk of VTE and risk of major bleeding (and other adverse events). Currently, there has been substantially more research conducted in patients undergoing THR than TKR; further studies regarding TKR may be warranted. In particular, few RCTs have been conducted in HFx surgery.

To avoid real and perceived bias (including, in particular concerns about reporting bias), ideally, a greater number of studies should be funded independently of industry. Furthermore, to minimize bias, all studies should report the full range of outcomes of interest, regardless of study results. Trial registration in priori and standard reporting compliant with the Consolidated Standards of Reporting Trials (CONSORT) statement also help reduce potential reporting bias. For VTE prophylaxis studies, there is a fairly standard list of VTE and adverse event outcomes that are generally accepted as being of interest. This systematic review covers a complete list of outcomes that should be reported by all studies. To reduce the risk of bias in systematic reviews, all outcomes, particularly symptomatic DVT and PE and including those with no events, should be reported. However, to improve applicability of future studies to real-world clinical practice (where radiographic searches for asymptomatic DVTs are not performed), we would recommend that RCT protocols not mandate postsurgical diagnostic testing for asymptomatic DVTs.

This review made no assumptions about unreported event rates. Therefore, since mechanical device studies rarely reported bleeding (or other adverse event) outcomes, our pairwise and network meta-analysis review of mechanical devices had insufficient evidence about risk of bleeding. Ideally, all existing RCTs should report their full set of outcome results. This can relatively easily be done by submitting trial results to a publicly-accessible registry such as ClinicalTrials.gov.

Larger RCTs should evaluate differences in treatment and adverse event effects in relevant subgroups of patients. Ideally, these analyses should be adequately powered. Based on our discussions with a panel of clinical experts and other key informants, the following subgroup analyses are of interest: sex, race/ethnicity, age, body weight, tobacco use, chronic disease, varicosities, history of bleeding disorders or surgical bleeding, prior VTE, presurgical use of antiplatelet drugs or warfarin, or hormones, unilateral versus bilateral surgery, use of cemented fixation, tourniquet use, tranexamic acid use, and anesthesia type. A small number of trials were explicitly limited to some of these subgroups (including no presurgical use of antithrombotics and unilateral surgery), the counterfactuals (e.g., only presurgical antithrombotics or bilateral surgery) have not been studied. Since it is unlikely that RCTs will focus on these rarer and higher-risk factors, it is more important for researchers to evaluate the subgroups within their studies, when available.

## Conclusions and Clinical Implications

While a large body of RCT evidence exists on comparative effectiveness and harms of thromboprophylaxis interventions after major orthopedic surgery, none of the Key Questions are fully and adequately addressed. For most Key Questions, the evidence base was too sparse to allow conclusions with sufficient SoE. For the comparisons of different interventions classes, only selective pairs of intervention classes had sufficient evidence, but often only for selective outcomes. The largest body of evidence exists for THR, with fewer studies of TKR, and very few studies of HFx surgery. The large majority of head-to-head studies evaluated LMWH (enoxaparin, in particular) with relatively few studies evaluating other intervention classes. Only a small minority of studies reported no industry support. Studies did not regularly report on all VTE-related and adverse effect outcomes, resulting in important possible reporting bias. Studies mostly reported total DVT, an outcome with unclear clinical significance. Almost no studies reported subgroup analyses. These limitations restrict the conclusions that can be drawn from the body of evidence.

Based on head-to-head comparisons for which there is sufficient evidence to make conclusions, LMWH is more effective to prevent VTE outcomes (with moderate to high SoE) and safer to prevent major bleeding (moderate SoE) than UFH (in patients undergoing THR). There are tradeoffs between LMWH and DTI (for THR) such that DTI is more effective to prevent total and proximal DVTs (moderate SoE), but LMWH results in less major bleeding (low SoE). Similarly there are tradeoffs between LMWH and VKA (for TKR) such that LMWH is more effective to prevent proximal and total DVTs (low and high SoE, respectively), but VKA results in less major bleeding (low SoE). Based primarily on a very large, well conducted observational study (with propensity score analyses), there is low SoE that LMWH and aspirin result in similar rates of total PE, symptomatic DVT, and major bleeding after THR. Comparisons between LMWH and FXaI, and between other pairs of treatment classes, are inconclusive due to either conflicting evidence across specific types of VTE or different adverse events or because of insufficient direct comparative evidence.

Two other findings of note are that for both LMWH (in THR) and DTI (in TKR) there is variable SoE that higher dose LMWH or DTI is more effective to prevent DVT but lower doses result in less major bleeding. Evidence is insufficient regarding different doses of other drug classes, different durations of treatment, comparisons of specific interventions, evaluations of combinations of interventions, and comparisons of timing of when to start thromboprophylaxis.

Of particular note, the inconsistent evidence LMWH versus FXaI was very likely due to selective outcome reporting. As an example, for THR, among 11 RCTs, only 6 reported on total VTE (favoring FXaI) and only 7 reported on symptomatic VTE (favoring LMWH), of which only 3 trials reported both outcomes. Selective outcome reporting was a major concern across all the analyses and in this case may have resulted in inconsistent conclusions across outcomes.

Due to a lack of sufficient direct comparisons between interventions for most outcomes of interest, we were able to construct network meta-analyses (to simultaneously evaluate both direct and indirect comparisons among all interventions) only for total DVT and major bleeding. For these outcomes network meta-analysis found that, for THR there is moderate SoE that FXaI is most effective to prevent total DVT; LMWH has lower risk of major bleeding that FXaI (low SoE). For TKR, by network meta-analysis we can conclude only that there is low SoE that FXaI is more effective to prevent total DVT than LMWH; there is insufficient evidence regarding major bleeding. Data are too sparse for HFx surgery to make conclusions from network meta-analysis. These analyses pertain to total DVT and major bleeding only.

In the face of incomplete and unclear evidence, patient and clinician preferences and values regarding the relative importance of avoiding VTE (primarily DVT) and major bleeding (and subsequent sequelae). While clinicians, policymakers, and clinical practice guideline developers should consider this evidence regarding relative effectiveness and safety of different thromboprophylaxis regimens (and its deficiencies), it may be reasonable to also consider other sources of evidence not covered here (e.g., other observational research and assumptions related to mechanisms of action) to aid with decisionmaking in the face of incomplete evidence.

Future studies, particularly of interventions other than enoxaparin, are needed to address most Key Questions. These studies, and if feasible existing studies, should report all VTE-related and adverse event outcomes. Larger trials should conduct and report subgroup analyses of interest. Ideally, more future studies should be funded independently of industry to avoid real and perceived bias.