# Appendix H Network Topologies for Symptomatic Deep Vein Thrombosis and Total Pulmonary Embolism

Figure H1 Network for total hip replacement, intervention class comparisons of symptomatic DVT

A topology map of the network meta-analysis of different classes of thromboprophylaxis interventions for symptomatic deep vein thrombosis outcome after total hip replacement. Fourteen classes or combinations of classes are displayed, of which 7 are compared to each other. These include direct thrombin inhibitors, factor 8 inhibitors, factor 10-a inhibitors, low molecular weight heparin, mechanical devices, unfractionated heparin, vitamin K antagonists, and placebo. Among the possible pairwise comparisons, 8 are covered by direct study comparisons. Low molecular weight heparin was the most common comparator, being directly compared with 6 other intervention classes, most frequently with factor 10-a inhibitors (10 studies).

Figure H2 Network for total hip replacement, specific intervention comparisons of symptomatic DVT

A topology map of the network meta-analysis of different specific thromboprophylaxis interventions for symptomatic deep vein thrombosis outcome after total hip replacement. Thirty-three interventions or combinations of interventions are displayed, of which 16 are compared to each other. These include apixaban, dabigatran, dalteparin, darexaban, edoxaban, enoxaparin, fondaparinux, graduated compression stockings, unfractionated heparin, intermittent pneumatic compression devices, rivaroxaban, TB402, tinzaparin, venous foot pumps, warfarin, and placebo. Among the possible pairwise comparisons, 20 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with 12 other intervention classes, most frequently with placebo (4 studies).

Figure H3 Network for total hip replacement, intervention class comparisons of total PE

A topology map of the network meta-analysis of different classes of thromboprophylaxis interventions for total pulmonary embolism after total hip replacement. Fourteen classes or combinations of classes are displayed, of which 11 are compared to each other. These include antiplatelet drugs, combined antiplatelet drugs and mechanical devices, direct thrombin inhibitors, factor 10-a inhibitors, low molecular weight heparin, combined low molecular weight heparin and mechanical devices, mechanical devices, unfractionated heparin, vitamin K antagonists, combined vitamin K antagonists and mechanical devices, and placebo. Among the possible pairwise comparisons, 16 are covered by direct study comparisons. Low molecular weight heparin was the most common comparator, being directly compared with 7 other intervention classes, most frequently with unfractionated heparin (8 studies).

Figure H4 Network for total hip replacement, specific intervention comparisons of total PE

A topology map of the network meta-analysis of different specific thromboprophylaxis interventions for total pulmonary embolism after total hip replacement. Thirty-three interventions or combinations of interventions are displayed, of which 19 are compared to each other. These include apixaban, aspirin, combined aspirin and intermittent pneumatic compression, dabigatran, dalteparin, darexaban, desirudin, edoxaban, enoxaparin, combined enoxaparin and intermittent pneumatic compression, fondaparinux, graduated compression stockings, unfractionated heparin, intermittent pneumatic compression devices, tinzaparin, venous foot pumps, warfarin, combined warfarin and intermittent pneumatic compression, and placebo. Among the possible pairwise comparisons, 26 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with 12 other intervention classes, most frequently with heparin (6 studies).

Figure H5 Network for total knee replacement, intervention class comparisons of symptomatic DVT

A topology map of the network meta-analysis of different classes of thromboprophylaxis interventions for symptomatic deep vein thrombosis outcome after total knee replacement. Fourteen classes or combinations of classes are displayed, of which 9 are compared to each other. These include antiplatelet drugs, direct thrombin inhibitors, factor 10-a inhibitors, combined factor 10-a inhibitors and mechanical devices, factors 11 inhibitors, low molecular weight heparin, combined low molecular weight heparin and mechanical devices, unfractionated heparin, vitamin K antagonists, and placebo. Among the possible pairwise comparisons, 12 are covered by direct study comparisons. Low molecular weight heparin was the most common comparator, being directly compared with 8 other intervention classes, most frequently with factor 10-a inhibitors (8 studies).

Figure H6 Network for total knee replacement, specific intervention comparisons of symptomatic DVT

A topology map of the network meta-analysis of different specific thromboprophylaxis interventions for symptomatic deep vein thrombosis outcome after total knee replacement. Thirty-three interventions or combinations of interventions are displayed, of which 16 are compared to each other. These include apixaban, aspirin, dabigatran, darexaban, edoxaban, combined edoxaban and venous foot pumps, enoxaparin, combined enoxaparin and venous foot pumps, eribaxaban, fondaparinux, factor 11 antisense oligonucleotide, heparin, rivaroxaban, TAK442, warfarin, and placebo. Among the possible pairwise comparisons, 19 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with 14 other intervention classes, most frequently with dabigatran (3 studies).

Figure H7 Network for total knee replacement, intervention class comparisons of total PE

A topology map of the network meta-analysis of different classes of thromboprophylaxis interventions for total pulmonary embolism after total knee replacement. Fourteen classes or combinations of classes are displayed, of which 11 are compared to each other. These include antiplatelet drugs, combined antiplatelet drugs and mechanical devices, direct thrombin inhibitors, factor 10-a inhibitors, combined factor 10-a inhibitors and mechanical devices, low molecular weight heparin, combined low molecular weight heparin and mechanical devices, mechanical devices, unfractionated heparin, vitamin K antagonists, and placebo. Among the possible pairwise comparisons, 13 are covered by direct study comparisons. Low molecular weight heparin was the most common comparator, being directly compared with 7 other intervention classes, most frequently with factor 10-a inhibitors (5 studies).

Figure H8 Network for total knee replacement, specific intervention comparisons of total PE

A topology map of the network meta-analysis of different specific thromboprophylaxis interventions for total pulmonary embolism after total knee replacement. Thirty-three interventions or combinations of interventions are displayed, of which 16 are compared to each other. These include apixaban, aspirin, combined aspirin and intermittent pneumatic compression, dabigatran, edoxaban, combined edoxaban and venous foot pumps, enoxaparin, combined enoxaparin and electrostimulation, combined enoxaparin and graduated compression stockings, combined enoxaparin and intermittent pneumatic compression, eribaxaban, fondaparinux, heparin, rivaroxaban, tinzaparin, venous foot pumps, warfarin, and placebo. Among the possible pairwise comparisons, 20 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with 11 other intervention classes, most frequently with warfarin (3 studies).

Figure H9 Network for hip fracture surgery, intervention class comparisons of symptomatic DVT

A topology map of the network meta-analysis of different classes of thromboprophylaxis interventions for symptomatic deep vein thrombosis outcome after hip fracture surgery. Fourteen classes or combinations of classes are displayed, of which 4 are compared to each other. These include antiplatelet drugs, factor 10-a inhibitors, low molecular weight heparin, and mechanical devices. Among the possible pairwise comparisons, 2 are covered by direct study comparisons: low molecular weight heparin versus factor 10-a inhibitors (2 studies) and antiplatelet versus mechanical devices (1 study).

Figure H10 Network for hip fracture surgery, specific intervention comparisons of symptomatic DVT

A topology map of the network meta-analysis of different specific thromboprophylaxis interventions for symptomatic deep vein thrombosis outcome after hip fracture surgery. Thirty-three interventions or combinations of interventions are displayed, of which 6 are compared to each other. These include aspirin, dalteparin, edoxaban, enoxaparin, fondaparinux, and venous foot pumps. Among the possible pairwise comparisons, 4 are covered by direct study comparisons. Enoxaparin was the most common comparator, being directly compared with 3 other intervention classes, each with a single study.

Figure H11 Network for hip fracture surgery, intervention class comparisons of total PE

A topology map of the network meta-analysis of different classes of thromboprophylaxis interventions for total pulmonary embolism after hip fracture surgery. Fourteen classes or combinations of classes are displayed, of which 7 are compared to each other. These include antiplatelet drugs, factor 10-a inhibitors, low molecular weight heparin, mechanical devices, unfractionated heparin, vitamin K antagonists, and placebo. Among the possible pairwise comparisons, 6 are covered by direct study comparisons, each with a single study.

Figure H12 Network for hip fracture surgery, specific intervention comparisons of total PE

A topology map of the network meta-analysis of different specific thromboprophylaxis interventions for total pulmonary embolism after hip fracture surgery. Thirty-three interventions or combinations of interventions are displayed, of which 8 are compared to each other. These include aspirin, dalteparin, enoxaparin, fondaparinux, heparin, venous foot pumps, warfarin, and placebo. Among the possible pairwise comparisons, 7 are covered by direct study comparisons, each with a single study.