# Appendix G Pairwise Results of Network Meta-Analyses With Informative Priors

Table G1 Network meta-analysis pairwise results: Total hip replacement, intervention class comparisons of total DVT

| LMWH+Mechanical | FXaI | DTI | FEI | Mechanical | Antiplatelet | LMWH | VKA | UFH | Placebo
LMWH+Mechanical | LMWH+Mechanical | 2.96 ( 1, 9.7) | 3.35 ( 1.1, 11.2) | 3.29 (0.618, 19.1) | 4.07 (1.28, 13.9) | 4.08 (1.05, 16.2) | 4.94 (1.79, 15.3) | 7.41 (2.41, 24.7) | 7.61 (2.62, 25) | 11.4 (3.97, 36.4)
FXaI | 0.338 (0.103, 0.997) | FXaI | 1.14 (0.621, 2.02) | 1.11 (0.305, 4.03) | 1.38 (0.719, 2.51) | 1.37 (0.524, 3.33) | 1.68 (1.15, 2.39) | 2.51 (1.37, 4.42) | 2.58 (1.55, 4.22) | 3.85 (2.43, 6.05)
DTI | 0.298 (0.0889, 0.91) | 0.881 (0.496, 1.61) | DTI | 0.975 (0.243, 4.1) | 1.21 (0.607, 2.37) | 1.21 (0.444, 3.12) | 1.48 (0.925, 2.35) | 2.21 (1.15, 4.24) | 2.27 (1.39, 3.79) | 3.38 (1.95, 6.05)
FEI | 0.304 (0.0524, 1.62) | 0.904 (0.248, 3.27) | 1.03 (0.244, 4.12) | FEI | 1.24 (0.296, 5.07) | 1.24 (0.251, 5.85) | 1.52 (0.391, 5.75) | 2.26 (0.539, 9.19) | 2.32 (0.581, 9.11) | 3.48 (0.885, 13.5)
Mechanical | 0.246 (0.072, 0.78) | 0.727 (0.398, 1.39) | 0.825 (0.423, 1.65) | 0.805 (0.197, 3.37) | Mechanical | 1 (0.383, 2.52) | 1.22 (0.739, 2.06) | 1.82 (1.07, 3.15) | 1.87 (1.06, 3.45) | 2.79 (1.59, 5.1)
Antiplatelet | 0.245 (0.0616, 0.95) | 0.728 (0.301, 1.91) | 0.827 (0.32, 2.25) | 0.808 (0.171, 3.98) | 0.999 (0.397, 2.61) | Antiplatelet | 1.22 (0.535, 2.97) | 1.82 ( 0.8, 4.34) | 1.88 (0.778, 4.89) | 2.8 (1.24, 6.76)
LMWH | 0.203 (0.0655, 0.559) | 0.596 (0.419, 0.869) | 0.677 (0.426, 1.08) | 0.66 (0.174, 2.56) | 0.821 (0.486, 1.35) | 0.82 (0.337, 1.87) | LMWH | 1.49 (0.932, 2.37) | 1.54 (1.09, 2.2) | 2.3 (1.66, 3.22)
VKA | 0.135 (0.0405, 0.415) | 0.398 (0.226, 0.732) | 0.453 (0.236, 0.871) | 0.443 (0.109, 1.85) | 0.55 (0.317, 0.934) | 0.549 (0.23, 1.25) | 0.67 (0.421, 1.07) | VKA | 1.03 (0.585, 1.84) | 1.54 (0.901, 2.69)
UFH | 0.131 (0.04, 0.381) | 0.387 (0.237, 0.644) | 0.44 (0.264, 0.721) | 0.431 (0.11, 1.72) | 0.534 (0.29, 0.942) | 0.532 (0.204, 1.28) | 0.651 (0.454, 0.92) | 0.972 (0.544, 1.71) | UFH | 1.49 (0.936, 2.4)
Placebo | 0.0878 (0.0275, 0.252) | 0.26 (0.165, 0.412) | 0.295 (0.165, 0.514) | 0.287 (0.0743, 1.13) | 0.358 (0.196, 0.628) | 0.357 (0.148, 0.807) | 0.435 (0.31, 0.603) | 0.651 (0.372, 1.11) | 0.67 (0.417, 1.07) | Placebo

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all classes. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.

Abbreviations: DTI = direct thrombin inhibitor, DVT = deep vein thrombosis, FEI=factor XIII inhibitor, FXaI = factor Xa inhibitor, FXIi = factor XI inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin, VKA = vitamin K antagonist

Table G2 Network meta-analysis pairwise results: Total hip replacement, specific intervention comparisons of total DVT

| Enoxaparin+IPC | Apixaban | Edoxaban | Enoxaparin+GCS | Semuloparin | Desirudin | Fondaparinux | Darexaban | VFP | Dabigatran | Aspirin | Dalteparin | Enoxaparin | IPC | Rivaroxaban | TB402 | Tinzaparin | Heparin | Warfarin | Placebo
Enoxaparin+IPC | Enoxaparin+IPC | 5.75 (0.509, 197) | 7.05 (0.588, 256) | 7.64 (0.882, 238) | 10.1 (0.91, 336) | 10.4 (1.02, 342) | 11.7 (1.15, 378) | 12.5 (1.17, 416) | 13.2 (1.25, 435) | 16.1 (1.56, 537) | 17.1 (1.58, 563) | 17.1 (1.66, 550) | 18.5 (1.95, 593) | 19.6 (1.83, 640) | 24.1 (2.26, 808) | 27.5 (1.88, >100) | 26.9 (2.68, 851) | 26.3 (2.68, 845) | 31.7 ( 3.1, >100) | 44.2 (4.61, >100)
Apixaban | 0.174 (0.00506, 1.96) | Apixaban | 1.23 (0.331, 4.53) | 1.36 (0.32, 5.48) | 1.76 (0.57, 5.36) | 1.84 (0.694, 4.83) | 2.02 (0.801, 5.68) | 2.19 (0.731, 6.73) | 2.32 (0.805, 6.56) | 2.84 (1.03, 7.72) | 2.99 (0.942, 9.39) | 2.97 (1.15, 8.5) | 3.26 (1.44, 7.56) | 3.44 (1.17, 10.1) | 4.21 (1.39, 12.8) | 4.7 (0.938, 23.6) | 4.66 (1.85, 12.9) | 4.59 (1.93, 11.6) | 5.51 (2.11, 15.5) | 7.71 (3.25, 19.5)
Edoxaban | 0.142 (0.0039, 1.7) | 0.816 (0.221, 3.02) | Edoxaban | 1.11 (0.235, 5.06) | 1.43 (0.407, 5.05) | 1.49 (0.494, 4.66) | 1.65 (0.554, 5.34) | 1.78 (0.521, 6.38) | 1.89 (0.571, 6.29) | 2.3 (0.726, 7.47) | 2.43 (0.677, 8.83) | 2.44 (0.802, 7.92) | 2.65 (0.995, 7.49) | 2.79 (0.838, 9.52) | 3.42 ( 1, 12) | 3.83 (0.695, 21.3) | 3.8 (1.28, 12.1) | 3.73 (1.34, 11.2) | 4.5 (1.47, 14.5) | 6.28 (2.25, 18.7)
Enoxaparin+GCS | 0.131 (0.00421, 1.13) | 0.735 (0.183, 3.12) | 0.904 (0.198, 4.26) | Enoxaparin+GCS | 1.29 (0.33, 5.19) | 1.35 (0.398, 4.88) | 1.5 (0.455, 5.53) | 1.61 (0.432, 6.36) | 1.71 (0.476, 6.46) | 2.08 (0.591, 7.64) | 2.2 (0.564, 9) | 2.2 (0.655, 8.21) | 2.4 (0.79, 7.82) | 2.53 (0.685, 9.76) | 3.11 (0.834, 12) | 3.48 (0.592, 20.9) | 3.44 (1.05, 12.4) | 3.39 (1.08, 11.7) | 4.08 (1.21, 15) | 5.67 (1.88, 19.2)
Semuloparin | 0.0994 (0.00298, 1.1) | 0.57 (0.186, 1.75) | 0.701 (0.198, 2.46) | 0.773 (0.193, 3.03) | Semuloparin | 1.05 (0.421, 2.6) | 1.15 (0.489, 3.08) | 1.24 (0.446, 3.6) | 1.33 (0.484, 3.55) | 1.61 (0.628, 4.22) | 1.71 (0.57, 5.06) | 1.69 (0.702, 4.61) | 1.86 (0.882, 4.01) | 1.96 (0.716, 5.39) | 2.4 (0.839, 6.96) | 2.67 (0.55, 13.1) | 2.65 (1.12, 6.92) | 2.61 (1.19, 6.19) | 3.15 (1.29, 8.4) | 4.38 (1.99, 10.3)
Desirudin | 0.0957 (0.00293, 0.985) | 0.543 (0.207, 1.44) | 0.67 (0.215, 2.03) | 0.74 (0.205, 2.51) | 0.951 (0.385, 2.38) | Desirudin | 1.09 (0.562, 2.42) | 1.19 (0.494, 2.94) | 1.26 (0.574, 2.74) | 1.53 (0.723, 3.35) | 1.63 (0.638, 4.1) | 1.62 (0.843, 3.44) | 1.77 (1.08, 2.97) | 1.87 (0.817, 4.31) | 2.28 (0.956, 5.55) | 2.54 (0.594, 11.2) | 2.52 (1.31, 5.31) | 2.49 (1.59, 4.22) | 3 (1.52, 6.38) | 4.18 (2.42, 7.79)
Fondaparinux | 0.0856 (0.00265, 0.869) | 0.496 (0.176, 1.25) | 0.605 (0.187, 1.81) | 0.669 (0.181, 2.2) | 0.87 (0.325, 2.04) | 0.914 (0.414, 1.78) | Fondaparinux | 1.08 (0.427, 2.55) | 1.14 (0.475, 2.48) | 1.4 (0.609, 2.89) | 1.47 (0.545, 3.64) | 1.47 (0.697, 3.09) | 1.62 (0.913, 2.59) | 1.69 (0.688, 3.83) | 2.07 (0.823, 4.9) | 2.3 (0.513, 9.9) | 2.31 (1.13, 4.62) | 2.27 (1.21, 4.1) | 2.72 (1.28, 5.67) | 3.8 (2.07, 6.78)
Darexaban | 0.0801 (0.0024, 0.855) | 0.457 (0.149, 1.37) | 0.563 (0.157, 1.92) | 0.621 (0.157, 2.32) | 0.803 (0.278, 2.24) | 0.842 (0.341, 2.02) | 0.927 (0.392, 2.34) | Darexaban | 1.06 (0.393, 2.73) | 1.29 (0.506, 3.24) | 1.37 (0.462, 3.92) | 1.36 (0.568, 3.47) | 1.49 (0.711, 3.1) | 1.57 (0.579, 4.22) | 1.91 (0.693, 5.28) | 2.15 (0.449, 10.1) | 2.13 (0.919, 5.17) | 2.1 (0.952, 4.75) | 2.53 (1.04, 6.31) | 3.53 (1.67, 7.65)
VFP | 0.0759 (0.0023, 0.802) | 0.43 (0.152, 1.24) | 0.528 (0.159, 1.75) | 0.585 (0.155, 2.1) | 0.754 (0.282, 2.07) | 0.791 (0.366, 1.74) | 0.875 (0.403, 2.11) | 0.942 (0.366, 2.55) | VFP | 1.21 (0.525, 2.92) | 1.29 (0.479, 3.5) | 1.29 (0.598, 3.02) | 1.41 (0.756, 2.69) | 1.49 (0.599, 3.74) | 1.8 (0.708, 4.8) | 2.02 (0.452, 9.19) | 2.01 (0.954, 4.6) | 1.98 (1.05, 3.98) | 2.38 (1.09, 5.59) | 3.33 (1.74, 6.76)
Dabigatran | 0.0623 (0.00186, 0.642) | 0.352 (0.13, 0.973) | 0.434 (0.134, 1.38) | 0.48 (0.131, 1.69) | 0.62 (0.237, 1.59) | 0.652 (0.298, 1.38) | 0.716 (0.346, 1.64) | 0.774 (0.309, 1.98) | 0.825 (0.342, 1.91) | Dabigatran | 1.06 (0.394, 2.83) | 1.05 (0.49, 2.45) | 1.16 (0.65, 2.05) | 1.22 (0.496, 2.95) | 1.49 (0.588, 3.75) | 1.66 (0.379, 7.54) | 1.65 (0.795, 3.71) | 1.62 (0.857, 3.25) | 1.95 (0.901, 4.47) | 2.73 (1.45, 5.39)
Aspirin | 0.0583 (0.00178, 0.634) | 0.335 (0.106, 1.06) | 0.411 (0.113, 1.48) | 0.455 (0.111, 1.77) | 0.586 (0.198, 1.75) | 0.614 (0.244, 1.57) | 0.678 (0.275, 1.84) | 0.73 (0.255, 2.17) | 0.774 (0.286, 2.09) | 0.939 (0.353, 2.54) | Aspirin | 0.996 (0.444, 2.43) | 1.09 (0.498, 2.46) | 1.15 (0.459, 2.91) | 1.4 (0.491, 4.02) | 1.57 (0.328, 7.7) | 1.56 (0.695, 3.79) | 1.54 (0.683, 3.64) | 1.85 (0.88, 4.1) | 2.58 (1.23, 5.77)
Dalteparin | 0.0585 (0.00182, 0.603) | 0.336 (0.118, 0.867) | 0.411 (0.126, 1.25) | 0.454 (0.122, 1.53) | 0.592 (0.217, 1.43) | 0.619 (0.29, 1.19) | 0.681 (0.324, 1.43) | 0.733 (0.288, 1.76) | 0.777 (0.332, 1.67) | 0.95 (0.408, 2.04) | 1 (0.412, 2.25) | Dalteparin | 1.1 (0.605, 1.85) | 1.15 (0.542, 2.27) | 1.4 (0.554, 3.35) | 1.56 (0.346, 6.76) | 1.57 (0.825, 2.91) | 1.54 (0.875, 2.62) | 1.86 (1.12, 2.98) | 2.59 (1.44, 4.48)
Enoxaparin | 0.0539 (0.00169, 0.513) | 0.306 (0.132, 0.696) | 0.377 (0.134, 1.01) | 0.417 (0.128, 1.27) | 0.537 (0.25, 1.13) | 0.565 (0.336, 0.925) | 0.619 (0.386, 1.1) | 0.67 (0.322, 1.41) | 0.711 (0.372, 1.32) | 0.865 (0.487, 1.54) | 0.919 (0.406, 2.01) | 0.913 (0.541, 1.65) | Enoxaparin | 1.05 (0.526, 2.08) | 1.28 (0.622, 2.67) | 1.44 (0.361, 5.75) | 1.43 (0.893, 2.45) | 1.41 (1.03, 2.01) | 1.69 (0.994, 3.01) | 2.36 (1.73, 3.34)
IPC | 0.0509 (0.00156, 0.546) | 0.291 (0.0993, 0.853) | 0.358 (0.105, 1.19) | 0.396 (0.102, 1.46) | 0.51 (0.185, 1.4) | 0.535 (0.232, 1.22) | 0.591 (0.261, 1.45) | 0.637 (0.237, 1.73) | 0.673 (0.268, 1.67) | 0.823 (0.34, 2.02) | 0.871 (0.344, 2.18) | 0.868 (0.441, 1.85) | 0.951 (0.481, 1.9) | IPC | 1.22 (0.462, 3.27) | 1.36 (0.297, 6.36) | 1.36 (0.671, 2.94) | 1.34 (0.66, 2.82) | 1.61 (0.936, 2.9) | 2.25 (1.13, 4.68)
Rivaroxaban | 0.0414 (0.00124, 0.442) | 0.237 (0.0783, 0.719) | 0.292 (0.0835, 0.997) | 0.322 (0.0831, 1.2) | 0.417 (0.144, 1.19) | 0.438 (0.18, 1.05) | 0.483 (0.204, 1.21) | 0.523 (0.19, 1.44) | 0.555 (0.209, 1.41) | 0.671 (0.267, 1.7) | 0.713 (0.248, 2.04) | 0.712 (0.298, 1.8) | 0.779 (0.375, 1.61) | 0.819 (0.306, 2.17) | Rivaroxaban | 1.11 (0.346, 3.63) | 1.11 (0.481, 2.7) | 1.1 (0.502, 2.46) | 1.32 (0.548, 3.28) | 1.84 (0.876, 3.95)
TB402 | 0.0364 (0.000924, 0.532) | 0.213 (0.0424, 1.07) | 0.261 (0.0469, 1.44) | 0.287 (0.048, 1.69) | 0.374 (0.0764, 1.82) | 0.393 (0.0894, 1.68) | 0.434 (0.101, 1.95) | 0.464 (0.0995, 2.23) | 0.495 (0.109, 2.21) | 0.604 (0.133, 2.64) | 0.639 (0.13, 3.05) | 0.64 (0.148, 2.89) | 0.696 (0.174, 2.77) | 0.734 (0.157, 3.37) | 0.898 (0.276, 2.89) | TB402 | 1 (0.238, 4.43) | 0.981 (0.24, 4.09) | 1.18 (0.273, 5.21) | 1.65 (0.414, 6.67)
Tinzaparin | 0.0372 (0.00118, 0.373) | 0.215 (0.0772, 0.54) | 0.263 (0.0828, 0.781) | 0.291 (0.0804, 0.951) | 0.377 (0.144, 0.892) | 0.396 (0.188, 0.761) | 0.434 (0.216, 0.885) | 0.468 (0.193, 1.09) | 0.497 (0.218, 1.05) | 0.606 (0.27, 1.26) | 0.643 (0.264, 1.44) | 0.638 (0.343, 1.21) | 0.701 (0.408, 1.12) | 0.736 (0.34, 1.49) | 0.898 (0.37, 2.08) | 1 (0.226, 4.21) | Tinzaparin | 0.986 (0.551, 1.72) | 1.18 (0.666, 2.07) | 1.65 ( 1, 2.68)
Heparin | 0.038 (0.00118, 0.373) | 0.218 (0.0861, 0.517) | 0.268 (0.0893, 0.745) | 0.295 (0.0855, 0.927) | 0.384 (0.162, 0.843) | 0.402 (0.237, 0.629) | 0.441 (0.244, 0.826) | 0.476 (0.21, 1.05) | 0.505 (0.251, 0.953) | 0.616 (0.308, 1.17) | 0.651 (0.275, 1.46) | 0.649 (0.382, 1.14) | 0.711 (0.497, 0.972) | 0.749 (0.355, 1.52) | 0.913 (0.406, 1.99) | 1.02 (0.245, 4.17) | 1.01 (0.581, 1.82) | Heparin | 1.2 (0.678, 2.17) | 1.68 (1.09, 2.58)
Warfarin | 0.0315 (0.000977, 0.322) | 0.182 (0.0647, 0.475) | 0.222 (0.0688, 0.68) | 0.245 (0.0665, 0.825) | 0.318 (0.119, 0.777) | 0.333 (0.157, 0.658) | 0.367 (0.176, 0.783) | 0.395 (0.159, 0.961) | 0.42 (0.179, 0.916) | 0.512 (0.224, 1.11) | 0.54 (0.244, 1.14) | 0.538 (0.336, 0.895) | 0.592 (0.332, 1.01) | 0.621 (0.345, 1.07) | 0.757 (0.305, 1.83) | 0.845 (0.192, 3.67) | 0.845 (0.483, 1.5) | 0.832 (0.462, 1.48) | Warfarin | 1.4 (0.793, 2.42)
Placebo | 0.0226 (0.000707, 0.217) | 0.13 (0.0514, 0.308) | 0.159 (0.0533, 0.445) | 0.176 (0.0521, 0.533) | 0.228 (0.0971, 0.502) | 0.239 (0.128, 0.414) | 0.263 (0.147, 0.483) | 0.284 (0.131, 0.598) | 0.3 (0.148, 0.575) | 0.366 (0.185, 0.688) | 0.388 (0.173, 0.814) | 0.386 (0.223, 0.694) | 0.423 (0.299, 0.577) | 0.445 (0.214, 0.886) | 0.543 (0.253, 1.14) | 0.605 (0.15, 2.42) | 0.605 (0.374, 1) | 0.596 (0.387, 0.92) | 0.717 (0.414, 1.26) | Placebo

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all interventions. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.

Abbreviations: DVT = deep vein thrombosis, GCS = graduated compression stocking, IPC = intermittent pneumatic compression, VFP = venous foot pump.

Table G3 Network meta-analysis pairwise results: Total hip replacement, intervention class comparisons of major bleeding

| Mechanical | VKA | Placebo | LMWH | DTI | FXaI | Antiplatelet | UFH | FEI
Mechanical | Mechanical | >100 (12.1, >100) | >100 (18.2, >100) | >100 (25.6, >100) | >100 (32.7, >100) | >100 (33.2, >100) | >100 (<0.01, >100) | >100 ( 52, >100) | >100 (>100, >100)
VKA | <0.01 (<0.01, 0.0828) | VKA | 1.54 (0.494, 4.95) | 1.97 (1.15, 3.49) | 2.53 ( 1.3, 5.05) | 2.64 (1.41, 5.07) | >100 (<0.01, >100) | 4.32 (1.99, 9.59) | >100 (>100, >100)
Placebo | <0.01 (<0.01, 0.0548) | 0.651 (0.202, 2.02) | Placebo | 1.28 (0.46, 3.58) | 1.65 (0.546, 4.87) | 1.72 (0.603, 4.87) | >100 (<0.01, >100) | 2.82 (0.884, 8.59) | >100 (>100, >100)
LMWH | <0.01 (<0.01, 0.039) | 0.508 (0.287, 0.872) | 0.781 (0.279, 2.17) | LMWH | 1.28 (0.868, 1.91) | 1.34 (0.967, 1.87) | >100 (<0.01, >100) | 2.18 (1.29, 3.86) | >100 (>100, >100)
DTI | <0.01 (<0.01, 0.0306) | 0.396 (0.198, 0.768) | 0.608 (0.206, 1.83) | 0.779 (0.523, 1.15) | DTI | 1.04 (0.623, 1.74) | >100 (<0.01, >100) | 1.71 (0.871, 3.39) | >100 (>100, >100)
FXaI | <0.01 (<0.01, 0.0301) | 0.378 (0.197, 0.711) | 0.581 (0.205, 1.66) | 0.745 (0.535, 1.03) | 0.957 (0.574, 1.6) | FXaI | >100 (<0.01, >100) | 1.63 (0.874, 3.11) | >100 (>100, >100)
Antiplatelet | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | Antiplatelet | <0.01 (<0.01, >100) | >100 (<0.01, >100)
UFH | <0.01 (<0.01, 0.0192) | 0.232 (0.104, 0.503) | 0.355 (0.116, 1.13) | 0.459 (0.259, 0.778) | 0.586 (0.295, 1.15) | 0.614 (0.322, 1.14) | >100 (<0.01, >100) | UFH | >100 (72.4, >100)
FEI | <0.01 (<0.01, <0.01) | <0.01 (<0.01, 0.00329) | <0.01 (<0.01, 0.00513) | <0.01 (<0.01, 0.00628) | <0.01 (<0.01, 0.00791) | <0.01 (<0.01, 0.0084) | <0.01 (<0.01, >100) | <0.01 (<0.01, 0.0138) | FEI

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all classes. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.

Abbreviations: DTI = direct thrombin inhibitor, FEI=factor XIII inhibitor, FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin, VKA = vitamin K antagonist

Table G4 Network meta-analysis pairwise results: Total hip replacement, specific intervention comparisons of major bleeding

| IPC | Semuloparin | Warfarin | Dalteparin | Edoxaban | Tinzaparin | Placebo | Darexaban | Enoxaparin | Desirudin | Aspirin | Rivaroxaban | Apixaban | Dabigatran | Fondaparinux | Heparin | TB402
IPC | IPC | >100 (4.95, >100) | >100 ( 7, >100) | >100 (9.62, >100) | >100 (11.9, >100) | >100 (11.7, >100) | >100 ( 14, >100) | >100 (11.4, >100) | >100 (19.7, >100) | >100 (19.1, >100) | >100 (<0.01, >100) | >100 (20.7, >100) | >100 (23.3, >100) | >100 ( 29, >100) | >100 (30.9, >100) | >100 (44.5, >100) | >100 (>100, >100)
Semuloparin | <0.01 (<0.01, 0.202) | Semuloparin | 1.38 (0.342, 6.58) | 2.13 (0.384, 13.9) | 2.27 (0.372, 14.6) | 2.38 (0.493, 13.6) | 2.86 (0.602, 15.2) | 3.75 (0.0593, 113) | 3.73 (1.23, 14.6) | 3.73 (0.98, 17.4) | >100 (<0.01, >100) | 4.21 (0.953, 21.5) | 4.57 (1.22, 21.2) | 5.47 (1.61, 23) | 5.97 (1.79, 25.5) | 8.28 (2.34, 35.8) | >100 ( 48, >100)
Warfarin | <0.01 (<0.01, 0.143) | 0.724 (0.152, 2.93) | Warfarin | 1.53 (0.546, 4.57) | 1.65 (0.328, 7.68) | 1.72 (0.673, 4.42) | 2.05 (0.514, 8.17) | 2.66 (0.0466, 68.6) | 2.7 (1.25, 6.45) | 2.7 (0.931, 8.35) | >100 (<0.01, >100) | 3.02 (0.877, 11.2) | 3.28 (1.16, 10.1) | 3.93 (1.56, 10.8) | 4.3 (1.74, 11.6) | 5.95 ( 2.3, 16.8) | >100 ( 39, >100)
Dalteparin | <0.01 (<0.01, 0.104) | 0.469 (0.0717, 2.61) | 0.653 (0.219, 1.83) | Dalteparin | 1.07 (0.173, 6.34) | 1.13 (0.269, 4.38) | 1.35 (0.236, 7.13) | 1.68 (0.0313, 54) | 1.77 (0.491, 6.34) | 1.76 (0.402, 7.7) | >100 (<0.01, >100) | 1.98 (0.388, 9.92) | 2.16 (0.503, 9.44) | 2.58 (0.657, 10.3) | 2.82 (0.71, 11.2) | 3.89 (0.965, 16.1) | >100 (23.4, >100)
Edoxaban | <0.01 (<0.01, 0.0843) | 0.44 (0.0686, 2.68) | 0.607 (0.13, 3.04) | 0.937 (0.158, 5.78) | Edoxaban | 1.06 (0.193, 6.09) | 1.25 (0.223, 7.8) | 1.59 (0.0261, 52.5) | 1.67 (0.429, 7.09) | 1.66 (0.35, 8.4) | >100 (<0.01, >100) | 1.86 (0.364, 10.1) | 2.03 (0.44, 10) | 2.41 (0.574, 11.1) | 2.65 (0.627, 12.2) | 3.7 (0.853, 17) | >100 (18.7, >100)
Tinzaparin | <0.01 (<0.01, 0.0851) | 0.419 (0.0737, 2.03) | 0.58 (0.226, 1.49) | 0.889 (0.228, 3.71) | 0.943 (0.164, 5.18) | Tinzaparin | 1.18 (0.254, 5.63) | 1.49 (0.0236, 44) | 1.58 (0.549, 4.75) | 1.57 (0.435, 5.72) | >100 (<0.01, >100) | 1.75 (0.416, 7.75) | 1.92 (0.547, 7.13) | 2.3 (0.719, 7.72) | 2.51 (0.797, 8.28) | 3.46 (1.05, 12.1) | >100 (22.9, >100)
Placebo | <0.01 (<0.01, 0.0715) | 0.35 (0.0659, 1.66) | 0.487 (0.122, 1.95) | 0.742 (0.14, 4.23) | 0.8 (0.128, 4.48) | 0.849 (0.178, 3.94) | Placebo | 1.29 (0.0203, 35.6) | 1.32 (0.453, 4) | 1.33 (0.365, 4.86) | >100 (<0.01, >100) | 1.46 (0.429, 5.47) | 1.61 (0.449, 5.93) | 1.92 (0.597, 6.54) | 2.1 (0.665, 7.09) | 2.9 (0.891, 9.91) | >100 (18.4, >100)
Darexaban | <0.01 (<0.01, 0.0877) | 0.267 (0.00888, 16.9) | 0.376 (0.0146, 21.5) | 0.596 (0.0185, 32) | 0.629 (0.0191, 38.3) | 0.672 (0.0227, 42.4) | 0.773 (0.0281, 49.2) | Darexaban | 1.02 (0.0451, 55) | 1.02 (0.0419, 58.4) | >100 (<0.01, >100) | 1.15 (0.0448, 68.8) | 1.24 (0.0514, 72.8) | 1.49 (0.0642, 80.4) | 1.64 (0.0684, 88.4) | 2.27 (0.094, 112) | >100 (9.66, >100)
Enoxaparin | <0.01 (<0.01, 0.0509) | 0.268 (0.0686, 0.812) | 0.371 (0.155, 0.799) | 0.565 (0.158, 2.04) | 0.599 (0.141, 2.33) | 0.632 (0.211, 1.82) | 0.757 (0.25, 2.21) | 0.979 (0.0182, 22.2) | Enoxaparin | 0.994 (0.482, 2.03) | >100 (<0.01, >100) | 1.11 (0.429, 2.9) | 1.22 ( 0.6, 2.51) | 1.46 (0.888, 2.4) | 1.59 (1.02, 2.55) | 2.19 (1.25, 3.89) | >100 (13.9, >100)
Desirudin | <0.01 (<0.01, 0.0522) | 0.268 (0.0575, 1.02) | 0.37 (0.12, 1.07) | 0.567 (0.13, 2.49) | 0.603 (0.119, 2.86) | 0.635 (0.175, 2.3) | 0.754 (0.206, 2.74) | 0.981 (0.0171, 23.9) | 1.01 (0.493, 2.07) | Desirudin | >100 (<0.01, >100) | 1.12 (0.344, 3.69) | 1.23 (0.451, 3.42) | 1.46 (0.612, 3.55) | 1.6 (0.692, 3.82) | 2.22 (0.898, 5.54) | >100 (14.2, >100)
Aspirin | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | Aspirin | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | 0.0112 (<0.01, >100) | >100 (<0.01, >100)
Rivaroxaban | <0.01 (<0.01, 0.0484) | 0.237 (0.0466, 1.05) | 0.331 (0.0897, 1.14) | 0.506 (0.101, 2.58) | 0.539 (0.0989, 2.75) | 0.572 (0.129, 2.4) | 0.683 (0.183, 2.33) | 0.871 (0.0145, 22.3) | 0.901 (0.345, 2.33) | 0.894 (0.271, 2.91) | >100 (<0.01, >100) | Rivaroxaban | 1.1 (0.332, 3.62) | 1.31 (0.443, 3.89) | 1.43 (0.506, 4.12) | 1.98 (0.667, 5.89) | >100 (12.5, >100)
Apixaban | <0.01 (<0.01, 0.0428) | 0.219 (0.0472, 0.822) | 0.305 (0.0993, 0.859) | 0.464 (0.106, 1.99) | 0.493 (0.0996, 2.27) | 0.52 (0.14, 1.83) | 0.621 (0.169, 2.22) | 0.804 (0.0137, 19.4) | 0.822 (0.398, 1.67) | 0.813 (0.292, 2.22) | >100 (<0.01, >100) | 0.909 (0.276, 3.02) | Apixaban | 1.2 (0.499, 2.84) | 1.31 (0.559, 3.07) | 1.81 (0.718, 4.45) | >100 (11.2, >100)
Dabigatran | <0.01 (<0.01, 0.0345) | 0.183 (0.0435, 0.62) | 0.254 (0.0928, 0.641) | 0.387 (0.0967, 1.52) | 0.414 (0.09, 1.74) | 0.434 (0.13, 1.39) | 0.52 (0.153, 1.67) | 0.673 (0.0124, 15.6) | 0.687 (0.417, 1.13) | 0.685 (0.282, 1.64) | >100 (<0.01, >100) | 0.764 (0.257, 2.26) | 0.834 (0.352, 2) | Dabigatran | 1.1 (0.559, 2.15) | 1.51 (0.708, 3.23) | >100 (9.33, >100)
Fondaparinux | <0.01 (<0.01, 0.0323) | 0.167 (0.0392, 0.558) | 0.232 (0.0862, 0.575) | 0.354 (0.0896, 1.41) | 0.377 (0.0823, 1.6) | 0.398 (0.121, 1.26) | 0.476 (0.141, 1.5) | 0.612 (0.0113, 14.6) | 0.629 (0.392, 0.982) | 0.625 (0.262, 1.45) | >100 (<0.01, >100) | 0.697 (0.242, 1.98) | 0.762 (0.326, 1.79) | 0.913 (0.466, 1.79) | Fondaparinux | 1.38 (0.666, 2.88) | >100 (8.57, >100)
Heparin | <0.01 (<0.01, 0.0225) | 0.121 (0.0279, 0.428) | 0.168 (0.0595, 0.436) | 0.257 (0.0621, 1.04) | 0.27 (0.0588, 1.17) | 0.289 (0.0823, 0.955) | 0.345 (0.101, 1.12) | 0.44 (0.00889, 10.6) | 0.456 (0.257, 0.798) | 0.451 (0.18, 1.11) | 89.2 (<0.01, >100) | 0.505 (0.17, 1.5) | 0.551 (0.225, 1.39) | 0.663 (0.31, 1.41) | 0.724 (0.347, 1.5) | Heparin | >100 (6.15, >100)
TB402 | <0.01 (<0.01, <0.01) | <0.01 (<0.01, 0.0208) | <0.01 (<0.01, 0.0256) | <0.01 (<0.01, 0.0428) | <0.01 (<0.01, 0.0534) | <0.01 (<0.01, 0.0437) | <0.01 (<0.01, 0.0544) | <0.01 (<0.01, 0.103) | <0.01 (<0.01, 0.072) | <0.01 (<0.01, 0.0704) | <0.01 (<0.01, >100) | <0.01 (<0.01, 0.0803) | <0.01 (<0.01, 0.0894) | <0.01 (<0.01, 0.107) | <0.01 (<0.01, 0.117) | <0.01 (<0.01, 0.162) | TB402

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all interventions. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.

Abbreviations: IPC = intermittent pneumatic compression.

Table G5 Network meta-analysis pairwise results: Total knee replacement, intervention class comparisons of total DVT

| LMWH+Mechanical | FXaI | Antiplatelet+Mechanical | DTI | FXIi | LMWH | FXaI+Mechanical | Mechanical | UFH | VKA | Antiplatelet | Placebo
LMWH+Mechanical | LMWH+Mechanical | 1.12 (0.498, 2.59) | 1.16 (0.601, 2.21) | 1.34 (0.528, 3.53) | 1.86 (0.66, 5.51) | 2.37 (1.08, 5.41) | 2.38 (0.713, 8.45) | 2.5 (1.03, 6.37) | 3.52 (1.45, 8.74) | 4.28 (1.91, 9.96) | 4.85 (2.15, 11.4) | 7.12 (3.04, 17.1)
FXaI | 0.895 (0.386, 2.01) | FXaI | 1.04 (0.446, 2.31) | 1.2 (0.692, 2.06) | 1.66 (0.823, 3.41) | 2.12 (1.71, 2.66) | 2.13 (0.88, 5.36) | 2.24 (1.34, 3.74) | 3.14 (2.01, 4.93) | 3.82 (2.79, 5.4) | 4.34 (2.74, 6.97) | 6.34 ( 4.5, 9.06)
Antiplatelet+Mechanical | 0.864 (0.453, 1.67) | 0.963 (0.432, 2.24) | Antiplatelet+Mechanical | 1.15 (0.455, 3.02) | 1.61 (0.567, 4.66) | 2.04 (0.937, 4.65) | 2.06 (0.616, 7.17) | 2.16 (0.902, 5.32) | 3.04 (1.26, 7.53) | 3.69 (1.67, 8.57) | 4.18 (1.96, 9.42) | 6.13 (2.66, 14.6)
DTI | 0.746 (0.284, 1.89) | 0.835 (0.485, 1.45) | 0.866 (0.331, 2.2) | DTI | 1.39 (0.596, 3.26) | 1.77 (1.06, 2.98) | 1.78 (0.624, 5.13) | 1.87 (0.943, 3.74) | 2.63 (1.37, 5.04) | 3.19 (1.82, 5.71) | 3.63 (1.87, 7.04) | 5.29 (3.19, 8.9)
FXIi | 0.539 (0.182, 1.52) | 0.602 (0.294, 1.22) | 0.622 (0.215, 1.77) | 0.72 (0.307, 1.68) | FXIi | 1.27 (0.65, 2.5) | 1.28 (0.404, 4.08) | 1.35 (0.59, 3.08) | 1.9 (0.873, 4.11) | 2.3 (1.12, 4.73) | 2.61 (1.17, 5.84) | 3.83 (1.79, 8.06)
LMWH | 0.421 (0.185, 0.927) | 0.472 (0.376, 0.584) | 0.49 (0.215, 1.07) | 0.566 (0.336, 0.941) | 0.784 (0.399, 1.54) | LMWH | 1 (0.401, 2.58) | 1.05 (0.654, 1.71) | 1.49 (0.995, 2.2) | 1.8 (1.42, 2.33) | 2.05 (1.34, 3.15) | 3 (2.16, 4.15)
FXaI+Mechanical | 0.42 (0.118, 1.4) | 0.469 (0.187, 1.14) | 0.486 (0.139, 1.62) | 0.561 (0.195, 1.6) | 0.78 (0.245, 2.47) | 0.996 (0.387, 2.49) | FXaI+Mechanical | 1.05 (0.367, 2.92) | 1.48 (0.531, 4.03) | 1.8 (0.677, 4.68) | 2.04 (0.728, 5.58) | 2.97 (1.12, 7.76)
Mechanical | 0.4 (0.157, 0.976) | 0.447 (0.267, 0.744) | 0.463 (0.188, 1.11) | 0.535 (0.268, 1.06) | 0.743 (0.325, 1.69) | 0.948 (0.586, 1.53) | 0.951 (0.342, 2.72) | Mechanical | 1.41 (0.754, 2.59) | 1.71 (1.01, 2.89) | 1.95 (1.14, 3.32) | 2.84 (1.67, 4.85)
UFH | 0.284 (0.114, 0.688) | 0.318 (0.203, 0.498) | 0.329 (0.133, 0.796) | 0.38 (0.198, 0.73) | 0.528 (0.244, 1.15) | 0.673 (0.454, 1) | 0.675 (0.248, 1.88) | 0.711 (0.386, 1.33) | UFH | 1.22 (0.77, 1.96) | 1.38 (0.772, 2.47) | 2.02 ( 1.2, 3.38)
VKA | 0.234 ( 0.1, 0.524) | 0.262 (0.185, 0.359) | 0.271 (0.117, 0.6) | 0.313 (0.175, 0.55) | 0.435 (0.211, 0.895) | 0.554 (0.429, 0.707) | 0.557 (0.214, 1.48) | 0.584 (0.346, 0.988) | 0.823 (0.51, 1.3) | VKA | 1.14 (0.728, 1.75) | 1.66 ( 1.1, 2.49)
Antiplatelet | 0.206 (0.0874, 0.465) | 0.231 (0.143, 0.365) | 0.239 (0.106, 0.51) | 0.275 (0.142, 0.535) | 0.383 (0.171, 0.856) | 0.488 (0.318, 0.747) | 0.49 (0.179, 1.37) | 0.514 (0.301, 0.88) | 0.725 (0.405, 1.29) | 0.879 (0.571, 1.37) | Antiplatelet | 1.46 (0.871, 2.46)
Placebo | 0.141 (0.0586, 0.329) | 0.158 (0.11, 0.222) | 0.163 (0.0684, 0.376) | 0.189 (0.112, 0.313) | 0.261 (0.124, 0.56) | 0.334 (0.241, 0.462) | 0.336 (0.129, 0.892) | 0.353 (0.206, 0.6) | 0.495 (0.296, 0.834) | 0.603 (0.402, 0.909) | 0.684 (0.406, 1.15) | Placebo

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all classes. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.

Abbreviations: DTI = direct thrombin inhibitor, DVT = deep vein thrombosis, FXaI = factor Xa inhibitor, FXIi = factor XI inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin, VKA = vitamin K antagonist

Table G6 Network meta-analysis pairwise results: Total knee replacement, specific intervention comparisons of total DVT

| Rivaroxaban | Aspirin+VFP | Fondaparinux | Edoxaban | Apixaban | Darexaban | Dabigatran | Enoxaparin+IPC | IPC | FXIASO | Aspirin+IPC | Semuloparin | Enoxaparin+VFP | Edoxaban+VFP | Enoxaparin | VFP | Flexion | Tinzaparin | Heparin | Aspirin | Warfarin | Placebo | Enoxaparin+GCS
Rivaroxaban | Rivaroxaban | 1.33 (0.313, 6.64) | 1.9 (0.648, 7.07) | 2.24 (0.732, 8.59) | 2.5 (0.866, 9.16) | 2.63 (0.708, 11.2) | 2.69 (0.858, 10.3) | 2.78 (0.525, 16.4) | 2.94 (0.807, 13.4) | 3.65 (1.07, 15) | 3.69 (0.592, 25) | 3.91 (1.33, 14.3) | >100 (<0.01, >100) | 4.84 (1.12, 23.8) | 4.69 (1.74, 16.5) | 5.73 ( 1.8, 22.1) | >100 (<0.01, >100) | 6.05 (1.94, 22.8) | 7 (2.36, 26) | 7.57 (2.72, 27.4) | 8.99 (3.21, 32.2) | 14.4 ( 5, 52.8) | >100 (>100, >100)
Aspirin+VFP | 0.751 (0.15, 3.19) | Aspirin+VFP | 1.44 (0.435, 4.94) | 1.69 (0.501, 5.95) | 1.89 (0.592, 6.34) | 1.96 (0.486, 8) | 2.01 (0.599, 7.1) | 2.07 (0.383, 11.1) | 2.22 (0.626, 8.01) | 2.74 (0.76, 10.6) | 2.76 (0.443, 17.3) | 2.95 (0.901, 10) | >100 (<0.01, >100) | 3.61 (0.803, 16.8) | 3.55 (1.17, 11.3) | 4.32 (1.24, 15.6) | >100 (<0.01, >100) | 4.54 (1.37, 15.6) | 5.28 (1.62, 17.9) | 5.75 (2.16, 15.8) | 6.77 (2.25, 21.6) | 10.8 ( 3.4, 36.5) | >100 (>100, >100)
Fondaparinux | 0.527 (0.142, 1.54) | 0.695 (0.202, 2.3) | Fondaparinux | 1.18 ( 0.6, 2.25) | 1.31 (0.736, 2.28) | 1.36 (0.535, 3.28) | 1.4 (0.721, 2.69) | 1.44 (0.368, 5.14) | 1.54 (0.529, 4.44) | 1.91 (0.846, 4.32) | 1.91 (0.417, 8.44) | 2.05 (1.11, 3.72) | >100 (<0.01, >100) | 2.5 (0.821, 7.55) | 2.47 (1.58, 3.8) | 3 (1.48, 5.93) | >100 (<0.01, >100) | 3.16 (1.57, 6.29) | 3.68 (1.99, 6.62) | 3.99 (2.01, 7.86) | 4.71 (2.74, 8.07) | 7.54 (4.42, 12.8) | >100 (>100, >100)
Edoxaban | 0.446 (0.116, 1.37) | 0.591 (0.168, 2) | 0.85 (0.444, 1.67) | Edoxaban | 1.11 (0.607, 2.07) | 1.16 (0.448, 2.85) | 1.19 (0.597, 2.36) | 1.22 (0.309, 4.55) | 1.31 (0.438, 3.92) | 1.62 (0.701, 3.87) | 1.62 (0.348, 7.22) | 1.74 (0.926, 3.33) | >100 (<0.01, >100) | 2.13 (0.869, 5.26) | 2.09 (1.28, 3.48) | 2.54 (1.22, 5.24) | >100 (<0.01, >100) | 2.68 ( 1.3, 5.65) | 3.13 (1.64, 5.99) | 3.39 (1.66, 7.02) | 4 (2.23, 7.32) | 6.39 (3.77, 11) | >100 (>100, >100)
Apixaban | 0.4 (0.109, 1.15) | 0.53 (0.158, 1.69) | 0.762 (0.438, 1.36) | 0.899 (0.484, 1.65) | Apixaban | 1.05 (0.415, 2.44) | 1.07 (0.573, 1.99) | 1.1 (0.286, 3.87) | 1.17 (0.425, 3.3) | 1.46 (0.677, 3.16) | 1.45 (0.323, 6.3) | 1.56 (0.916, 2.7) | >100 (<0.01, >100) | 1.91 (0.645, 5.68) | 1.88 (1.33, 2.68) | 2.28 (1.19, 4.39) | >100 (<0.01, >100) | 2.41 (1.27, 4.62) | 2.8 (1.62, 4.77) | 3.04 (1.62, 5.8) | 3.59 (2.26, 5.82) | 5.75 (3.52, 9.5) | >100 (>100, >100)
Darexaban | 0.381 (0.0893, 1.41) | 0.511 (0.125, 2.06) | 0.733 (0.305, 1.87) | 0.861 (0.351, 2.23) | 0.957 (0.41, 2.41) | Darexaban | 1.03 (0.417, 2.68) | 1.06 (0.233, 4.57) | 1.14 (0.329, 3.98) | 1.4 (0.494, 4.14) | 1.4 (0.269, 7.23) | 1.49 (0.63, 3.78) | >100 (<0.01, >100) | 1.82 (0.52, 6.85) | 1.8 (0.83, 4.2) | 2.18 (0.857, 5.86) | >100 (<0.01, >100) | 2.32 (0.897, 6.27) | 2.68 (1.12, 6.94) | 2.93 (1.14, 7.79) | 3.44 (1.49, 8.55) | 5.49 (2.58, 12.7) | >100 (>100, >100)
Dabigatran | 0.372 (0.0974, 1.17) | 0.497 (0.141, 1.67) | 0.713 (0.371, 1.39) | 0.839 (0.423, 1.67) | 0.935 (0.503, 1.74) | 0.975 (0.374, 2.4) | Dabigatran | 1.02 (0.256, 3.81) | 1.1 (0.371, 3.27) | 1.36 (0.581, 3.22) | 1.37 (0.289, 6.21) | 1.46 (0.761, 2.81) | >100 (<0.01, >100) | 1.78 (0.573, 5.57) | 1.76 (1.06, 2.95) | 2.13 (1.02, 4.43) | >100 (<0.01, >100) | 2.25 (1.08, 4.74) | 2.62 (1.37, 5.02) | 2.84 (1.38, 5.98) | 3.36 (1.85, 6.22) | 5.38 (3.21, 9.03) | >100 (>100, >100)
Enoxaparin+IPC | 0.36 (0.0609, 1.9) | 0.482 (0.0903, 2.61) | 0.696 (0.195, 2.72) | 0.819 (0.22, 3.24) | 0.912 (0.258, 3.49) | 0.944 (0.219, 4.29) | 0.977 (0.263, 3.9) | Enoxaparin+IPC | 1.08 (0.223, 5.3) | 1.34 (0.324, 5.58) | 1.34 (0.652, 2.75) | 1.42 (0.398, 5.51) | >100 (<0.01, >100) | 1.74 (0.356, 9.06) | 1.72 (0.512, 6.23) | 2.09 (0.546, 8.35) | >100 (<0.01, >100) | 2.18 (0.586, 8.9) | 2.56 (0.713, 9.79) | 2.77 (0.739, 11.2) | 3.27 (0.934, 12.5) | 5.23 ( 1.5, 20) | >100 (>100, >100)
IPC | 0.34 (0.0749, 1.24) | 0.45 (0.125, 1.6) | 0.648 (0.225, 1.89) | 0.763 (0.255, 2.28) | 0.852 (0.303, 2.35) | 0.876 (0.251, 3.04) | 0.908 (0.306, 2.69) | 0.925 (0.189, 4.49) | IPC | 1.24 (0.381, 4.02) | 1.24 (0.216, 6.91) | 1.33 (0.465, 3.79) | >100 (<0.01, >100) | 1.63 (0.392, 6.67) | 1.6 (0.605, 4.22) | 1.94 (0.633, 5.86) | >100 (<0.01, >100) | 2.05 (0.71, 5.85) | 2.39 (0.834, 6.74) | 2.58 (1.17, 5.8) | 3.05 (1.16, 7.96) | 4.88 (1.75, 13.5) | >100 (>100, >100)
FXIASO | 0.274 (0.0666, 0.935) | 0.366 (0.0947, 1.32) | 0.522 (0.231, 1.18) | 0.618 (0.259, 1.43) | 0.686 (0.316, 1.48) | 0.715 (0.242, 2.02) | 0.735 (0.31, 1.72) | 0.748 (0.179, 3.09) | 0.806 (0.249, 2.62) | FXIASO | 0.995 ( 0.2, 4.93) | 1.07 (0.482, 2.39) | >100 (<0.01, >100) | 1.31 (0.376, 4.45) | 1.3 (0.65, 2.57) | 1.57 (0.641, 3.75) | >100 (<0.01, >100) | 1.65 (0.695, 3.98) | 1.92 (0.866, 4.3) | 2.09 (0.873, 4.96) | 2.47 (1.15, 5.31) | 3.95 (1.81, 8.58) | >100 (>100, >100)
Aspirin+IPC | 0.271 (0.0401, 1.69) | 0.362 (0.0579, 2.26) | 0.523 (0.118, 2.4) | 0.616 (0.139, 2.87) | 0.688 (0.159, 3.1) | 0.712 (0.138, 3.71) | 0.728 (0.161, 3.46) | 0.748 (0.363, 1.53) | 0.805 (0.145, 4.63) | 1.01 (0.203, 5) | Aspirin+IPC | 1.07 (0.243, 4.92) | >100 (<0.01, >100) | 1.31 (0.227, 7.83) | 1.29 (0.312, 5.63) | 1.57 (0.339, 7.41) | >100 (<0.01, >100) | 1.65 (0.358, 7.91) | 1.91 (0.436, 8.72) | 2.08 (0.459, 9.94) | 2.46 (0.578, 11.1) | 3.95 (0.925, 18) | >100 (>100, >100)
Semuloparin | 0.256 (0.0697, 0.754) | 0.339 (0.0999, 1.11) | 0.488 (0.269, 0.899) | 0.575 ( 0.3, 1.08) | 0.64 (0.371, 1.09) | 0.67 (0.265, 1.59) | 0.685 (0.356, 1.31) | 0.703 (0.181, 2.51) | 0.751 (0.264, 2.15) | 0.932 (0.418, 2.08) | 0.934 (0.203, 4.12) | Semuloparin | >100 (<0.01, >100) | 1.22 (0.408, 3.69) | 1.21 (0.803, 1.81) | 1.46 (0.734, 2.89) | >100 (<0.01, >100) | 1.54 (0.784, 3.02) | 1.79 (1.01, 3.16) | 1.95 ( 1, 3.8) | 2.3 (1.38, 3.87) | 3.68 (2.16, 6.3) | >100 (>100, >100)
Enoxaparin+VFP | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | Enoxaparin+VFP | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | 0.0123 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | 0.0103 (<0.01, >100) | 0.0168 (<0.01, >100) | >100 (<0.01, >100)
Edoxaban+VFP | 0.207 (0.0419, 0.895) | 0.277 (0.0596, 1.25) | 0.4 (0.132, 1.22) | 0.471 (0.19, 1.15) | 0.524 (0.176, 1.55) | 0.549 (0.146, 1.92) | 0.56 (0.179, 1.75) | 0.576 (0.11, 2.81) | 0.614 (0.15, 2.55) | 0.765 (0.224, 2.66) | 0.765 (0.128, 4.41) | 0.822 (0.271, 2.45) | >100 (<0.01, >100) | Edoxaban+VFP | 0.99 (0.352, 2.75) | 1.2 (0.374, 3.79) | >100 (<0.01, >100) | 1.26 (0.396, 4.02) | 1.47 (0.481, 4.43) | 1.59 (0.512, 5.05) | 1.89 (0.645, 5.54) | 3.01 (1.06, 8.59) | >100 (87.4, >100)
Enoxaparin | 0.213 (0.0605, 0.575) | 0.282 (0.0881, 0.854) | 0.405 (0.263, 0.632) | 0.478 (0.288, 0.784) | 0.531 (0.373, 0.753) | 0.555 (0.238, 1.2) | 0.568 (0.339, 0.946) | 0.581 (0.16, 1.95) | 0.626 (0.237, 1.65) | 0.772 (0.39, 1.54) | 0.774 (0.178, 3.21) | 0.829 (0.552, 1.24) | >100 (<0.01, >100) | 1.01 (0.363, 2.84) | Enoxaparin | 1.21 (0.694, 2.1) | >100 (<0.01, >100) | 1.28 (0.75, 2.2) | 1.49 (0.989, 2.22) | 1.61 (0.958, 2.75) | 1.9 (1.39, 2.64) | 3.05 (2.15, 4.31) | >100 ( 89, >100)
VFP | 0.175 (0.0453, 0.555) | 0.232 (0.0642, 0.808) | 0.334 (0.169, 0.674) | 0.394 (0.191, 0.82) | 0.439 (0.228, 0.843) | 0.458 (0.171, 1.17) | 0.469 (0.225, 0.976) | 0.479 (0.12, 1.83) | 0.516 (0.171, 1.58) | 0.638 (0.266, 1.56) | 0.637 (0.135, 2.95) | 0.685 (0.346, 1.36) | >100 (<0.01, >100) | 0.836 (0.264, 2.68) | 0.825 (0.476, 1.44) | VFP | >100 (<0.01, >100) | 1.06 (0.485, 2.32) | 1.23 (0.614, 2.42) | 1.33 (0.626, 2.87) | 1.58 (0.834, 3.01) | 2.53 (1.38, 4.6) | >100 (73.3, >100)
Flexion | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | 81.4 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | Flexion | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | >100 (<0.01, >100)
Tinzaparin | 0.165 (0.0438, 0.517) | 0.22 (0.064, 0.728) | 0.316 (0.159, 0.637) | 0.374 (0.177, 0.77) | 0.415 (0.216, 0.786) | 0.431 (0.16, 1.12) | 0.445 (0.211, 0.927) | 0.458 (0.112, 1.71) | 0.488 (0.171, 1.41) | 0.605 (0.251, 1.44) | 0.606 (0.126, 2.79) | 0.648 (0.331, 1.28) | >100 (<0.01, >100) | 0.792 (0.249, 2.52) | 0.783 (0.455, 1.33) | 0.948 (0.431, 2.06) | >100 (<0.01, >100) | Tinzaparin | 1.16 (0.59, 2.26) | 1.26 (0.638, 2.52) | 1.49 (0.97, 2.31) | 2.39 (1.26, 4.55) | >100 (74.1, >100)
Heparin | 0.143 (0.0384, 0.424) | 0.189 (0.0559, 0.616) | 0.271 (0.151, 0.503) | 0.32 (0.167, 0.611) | 0.357 (0.21, 0.616) | 0.374 (0.144, 0.89) | 0.381 (0.199, 0.731) | 0.391 (0.102, 1.4) | 0.419 (0.148, 1.2) | 0.52 (0.232, 1.15) | 0.523 (0.115, 2.3) | 0.558 (0.317, 0.99) | >100 (<0.01, >100) | 0.681 (0.226, 2.08) | 0.672 (0.45, 1.01) | 0.813 (0.414, 1.63) | >100 (<0.01, >100) | 0.859 (0.442, 1.7) | Heparin | 1.08 (0.561, 2.13) | 1.28 (0.771, 2.15) | 2.05 (1.21, 3.51) | >100 (60.2, >100)
Aspirin | 0.132 (0.0364, 0.368) | 0.174 (0.0632, 0.463) | 0.251 (0.127, 0.497) | 0.295 (0.143, 0.603) | 0.329 (0.172, 0.616) | 0.341 (0.128, 0.874) | 0.352 (0.167, 0.723) | 0.361 (0.0896, 1.35) | 0.387 (0.172, 0.855) | 0.479 (0.202, 1.15) | 0.48 (0.101, 2.18) | 0.514 (0.263, 0.997) | >100 (<0.01, >100) | 0.629 (0.198, 1.95) | 0.62 (0.364, 1.04) | 0.749 (0.348, 1.6) | >100 (<0.01, >100) | 0.792 (0.398, 1.57) | 0.922 (0.469, 1.78) | Aspirin | 1.18 ( 0.7, 1.99) | 1.89 (1.01, 3.49) | >100 (58.8, >100)
Warfarin | 0.111 (0.0311, 0.312) | 0.148 (0.0464, 0.444) | 0.212 (0.124, 0.365) | 0.25 (0.137, 0.448) | 0.278 (0.172, 0.443) | 0.29 (0.117, 0.67) | 0.298 (0.161, 0.541) | 0.306 (0.08, 1.07) | 0.328 (0.126, 0.861) | 0.406 (0.188, 0.866) | 0.407 (0.0902, 1.73) | 0.435 (0.259, 0.725) | 97.4 (<0.01, >100) | 0.53 (0.18, 1.55) | 0.525 (0.379, 0.717) | 0.635 (0.333, 1.2) | >100 (<0.01, >100) | 0.671 (0.433, 1.03) | 0.781 (0.464, 1.3) | 0.846 (0.503, 1.43) | Warfarin | 1.6 (0.998, 2.56) | >100 (47.8, >100)
Placebo | 0.0696 (0.019, 0.2) | 0.0925 (0.0274, 0.295) | 0.133 (0.0783, 0.226) | 0.156 (0.0913, 0.265) | 0.174 (0.105, 0.284) | 0.182 (0.079, 0.388) | 0.186 (0.111, 0.311) | 0.191 (0.0499, 0.666) | 0.205 (0.0743, 0.57) | 0.253 (0.117, 0.551) | 0.253 (0.0556, 1.08) | 0.272 (0.159, 0.463) | 59.6 (<0.01, >100) | 0.332 (0.116, 0.944) | 0.328 (0.232, 0.465) | 0.396 (0.217, 0.725) | >100 (<0.01, >100) | 0.418 (0.22, 0.796) | 0.488 (0.285, 0.827) | 0.529 (0.286, 0.986) | 0.625 (0.39, 1) | Placebo | >100 ( 30, >100)
Enoxaparin+GCS | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, >100) | <0.01 (<0.01, 0.0114) | <0.01 (<0.01, 0.0112) | <0.01 (<0.01, 0.0136) | <0.01 (<0.01, >100) | <0.01 (<0.01, 0.0135) | <0.01 (<0.01, 0.0166) | <0.01 (<0.01, 0.017) | <0.01 (<0.01, 0.0209) | <0.01 (<0.01, 0.0333) | Enoxaparin+GCS

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all interventions. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.

Abbreviations: DVT = deep vein thrombosis, GCS = graduated compression stocking, IPC = intermittent pneumatic compression, VFP = venous foot pump.

Table G7 Network meta-analysis pairwise results: Total knee replacement, intervention class comparisons of major bleeding

| VKA | LMWH | UFH | Placebo | DTI | FXIi | FXaI+Mechanical | FXaI
VKA | VKA | 2.05 (0.861, 5.28) | 2.07 (0.233, 19.4) | 2.31 (0.411, 13.4) | 2.32 (0.779, 8.5) | 642 (<0.01, >100) | 3.37 (0.33, 38.6) | 3.1 (1.04, 11.3)
LMWH | 0.488 (0.189, 1.16) | LMWH | 1 (0.136, 7.81) | 1.11 (0.251, 5.2) | 1.13 (0.56, 2.67) | 322 (<0.01, >100) | 1.62 (0.189, 15.4) | 1.51 (0.748, 3.62)
UFH | 0.482 (0.0515, 4.3) | 0.997 (0.128, 7.35) | UFH | 1.11 (0.087, 14.1) | 1.13 (0.135, 10.2) | 320 (<0.01, >100) | 1.62 (0.0834, 33.5) | 1.52 (0.178, 13.7)
Placebo | 0.432 (0.0749, 2.44) | 0.9 (0.192, 3.99) | 0.903 (0.071, 11.5) | Placebo | 1.02 (0.222, 5.02) | 303 (<0.01, >100) | 1.45 (0.107, 21.2) | 1.36 (0.259, 7.64)
DTI | 0.431 (0.118, 1.28) | 0.884 (0.374, 1.78) | 0.883 (0.0979, 7.42) | 0.982 (0.199, 4.5) | DTI | 288 (<0.01, >100) | 1.43 (0.14, 14.5) | 1.33 (0.464, 3.97)
FXIi | 0.00156 (<0.01, >100) | 0.00311 (<0.01, >100) | 0.00313(<0.01, >100) | 0.0033 (<0.01, >100) | 0.00347 (<0.01, >100) | FXIi | 0.00498 (<0.01, >100) | 0.00473 (<0.01, >100)
FXaI+Mechanical | 0.297 (0.0259, 3.03) | 0.617 (0.0649, 5.3) | 0.618 (0.0299, 12) | 0.687 (0.0473, 9.36) | 0.699 (0.0688, 7.13) | 201(<0.01, >100) | FXaI+Mechanical | 0.937 (0.12, 7.35)
FXaI | 0.322 (0.0886, 0.965) | 0.664 (0.276, 1.34) | 0.658 (0.0732, 5.63) | 0.735 (0.131, 3.86) | 0.751 (0.252, 2.16) | 211 (<0.01, >100) | 1.07 (0.136, 8.36) | FXaI

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all classes. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.

Abbreviations: DTI = direct thrombin inhibitor, FXaI = factor Xa inhibitor, FXIi = factor XI inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin, VKA = vitamin K antagonist

Table G8 Network meta-analysis pairwise results: Total knee replacement, specific intervention comparisons of major bleeding

| FXIASO | Warfarin | Eribaxaban | Apixaban | TAK442 | Semuloparin | Heparin | Enoxaparin | Dabigatran | Placebo | Tinzaparin | Edoxaban+VFP | Edoxaban | Fondaparinux | Darexaban
FXIASO | FXIASO | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100)
Warfarin | <0.01 (<0.01, >100) | Warfarin | 0.81 (0.0198, 10.4) | 1.06 (0.258, 4.41) | 1.03 (0.088, 9.09) | 1.19 (0.164, 8.13) | 1.71 (0.212, 13) | 1.66 (0.681, 4.55) | 1.84 (0.619, 6.37) | 2.32 (0.393, 14.5) | 3.35 (0.821, 17.3) | 10.4 (0.488, 485) | 9.58 (0.864, 283) | 24.7 (3.13, 543) | >100 ( 8.4, >100)
Eribaxaban | <0.01 (<0.01, >100) | 1.23 (0.0963, 50.6) | Eribaxaban | 1.33 (0.0951, 55.6) | 1.3 (0.0494, 73.7) | 1.49 (0.0777, 76.7) | 2.2 (0.0963, 110) | 2.02 (0.194, 74.5) | 2.29 (0.195, 92.3) | 2.96 (0.167, 145) | 4.41 (0.21, 232) | 14 (0.297, 2.03e+03) | 13.2 (0.468, 1.37e+03) | 34.5 (1.34, 3.13e+03) | >100 (7.39, >100)
Apixaban | <0.01 (<0.01, >100) | 0.945 (0.227, 3.88) | 0.753 (0.018, 10.5) | Apixaban | 0.965 (0.0811, 9.05) | 1.12 (0.146, 8.24) | 1.61 (0.189, 13.5) | 1.57 (0.563, 4.64) | 1.75 (0.524, 6.47) | 2.19 (0.346, 14.2) | 3.2 (0.434, 27.6) | 9.71 (0.434, 459) | 8.94 (0.776, 274) | 23.6 ( 2.6, 530) | >100 (7.66, >100)
TAK442 | <0.01 (<0.01, >100) | 0.972 (0.11, 11.4) | 0.77 (0.0136, 20.3) | 1.04 (0.111, 12.3) | TAK442 | 1.17 (0.0811, 19.2) | 1.67 (0.109, 29.2) | 1.62 (0.232, 15.7) | 1.8 (0.235, 19.4) | 2.29 (0.184, 35) | 3.35 (0.249, 58.4) | 10.4 (0.286, 797) | 9.77 (0.46, 444) | 26.2 (1.57, 839) | >100 (7.01, >100)
Semuloparin | <0.01 (<0.01, >100) | 0.841 (0.123, 6.08) | 0.673 (0.013, 12.9) | 0.889 (0.121, 6.83) | 0.853 (0.052, 12.3) | Semuloparin | 1.43 (0.118, 17.3) | 1.4 (0.264, 8.17) | 1.56 (0.266, 10.5) | 1.93 (0.206, 20.9) | 2.9 (0.252, 36.9) | 8.84 (0.302, 517) | 8.09 (0.484, 331) | 21.3 ( 1.7, 669) | >100 (6.35, >100)
Heparin | <0.01 (<0.01, >100) | 0.584 (0.0767, 4.71) | 0.454 (0.00907, 10.4) | 0.622 (0.0743, 5.29) | 0.6 (0.0342, 9.13) | 0.697 (0.0578, 8.51) | Heparin | 0.987 (0.161, 6.49) | 1.09 (0.16, 8.1) | 1.37 (0.133, 15.2) | 2 (0.164, 28.6) | 6.13 (0.183, 390) | 5.65 (0.308, 234) | 15 (1.02, 493) | >100 (4.16, >100)
Enoxaparin | <0.01 (<0.01, >100) | 0.604 (0.22, 1.47) | 0.494 (0.0134, 5.16) | 0.637 (0.216, 1.78) | 0.616 (0.0638, 4.31) | 0.714 (0.122, 3.78) | 1.01 (0.154, 6.21) | Enoxaparin | 1.11 (0.586, 2.24) | 1.37 (0.313, 6.56) | 2.03 (0.357, 13.3) | 6.05 (0.336, 254) | 5.52 (0.634, 150) | 14.6 (2.28, 268) | >100 (5.24, >100)
Dabigatran | <0.01 (<0.01, >100) | 0.543 (0.157, 1.62) | 0.438 (0.0108, 5.14) | 0.572 (0.155, 1.91) | 0.554 (0.0515, 4.26) | 0.64 (0.0956, 3.76) | 0.918 (0.123, 6.25) | 0.904 (0.447, 1.71) | Dabigatran | 1.24 (0.268, 5.85) | 1.83 (0.273, 13.3) | 5.45 (0.278, 239) | 5.03 (0.501, 140) | 13.3 (1.77, 261) | >100 (4.83, >100)
Placebo | <0.01 (<0.01, >100) | 0.431 (0.0691, 2.54) | 0.338 (0.0069, 5.98) | 0.457 (0.0704, 2.89) | 0.437 (0.0286, 5.43) | 0.518 (0.0479, 4.86) | 0.729 (0.0657, 7.5) | 0.731 (0.153, 3.19) | 0.809 (0.171, 3.73) | Placebo | 1.47 (0.14, 15.9) | 4.53 (0.164, 231) | 4.15 (0.27, 130) | 11.1 (0.859, 263) | >100 (3.33, >100)
Tinzaparin | <0.01 (<0.01, >100) | 0.299 (0.0579, 1.22) | 0.227 (0.00431, 4.77) | 0.312 (0.0362, 2.31) | 0.298 (0.0171, 4.01) | 0.345 (0.0271, 3.96) | 0.499 (0.0349, 6.11) | 0.492 (0.0752, 2.8) | 0.547 (0.075, 3.66) | 0.682 (0.063, 7.16) | Tinzaparin | 3.06 (0.091, 182) | 2.89 (0.146, 106) | 7.39 (0.533, 224) | >100 (2.03, >100)
Edoxaban+VFP | <0.01 (<0.01, >100) | 0.0964 (0.00206, 2.05) | 0.0712 (0.000493, 3.37) | 0.103 (0.00218, 2.3) | 0.0963 (0.00125, 3.5) | 0.113 (0.00193, 3.31) | 0.163 (0.00257, 5.48) | 0.165 (0.00393, 2.97) | 0.183 (0.00419, 3.59) | 0.221 (0.00433, 6.09) | 0.327 (0.00551, 11) | Edoxaban+VFP | 0.953 (0.148, 6.02) | 2.56 (0.0383, 147) | >100 (0.639, >100)
Edoxaban | <0.01 (<0.01, >100) | 0.104 (0.00354, 1.16) | 0.0758 (0.000732, 2.14) | 0.112 (0.00365, 1.29) | 0.102 (0.00225, 2.18) | 0.124 (0.00303, 2.07) | 0.177 (0.00427, 3.24) | 0.181 (0.00665, 1.58) | 0.199 (0.00713, 2) | 0.241 (0.0077, 3.71) | 0.347 (0.00947, 6.84) | 1.05 (0.166, 6.77) | Edoxaban | 2.67 (0.0651, 97.4) | >100 (0.801, >100)
Fondaparinux | <0.01 (<0.01, >100) | 0.0405 (0.00184, 0.32) | 0.029 (0.000319, 0.745) | 0.0424 (0.00189, 0.385) | 0.0381 (0.00119, 0.638) | 0.047 (0.00149, 0.589) | 0.0665 (0.00203, 0.981) | 0.0685 (0.00373, 0.438) | 0.0751 (0.00383, 0.566) | 0.0901 (0.0038, 1.16) | 0.135 (0.00446, 1.88) | 0.391 (0.00679, 26.1) | 0.375 (0.0103, 15.4) | Fondaparinux | >100 (0.248, >100)
Darexaban | <0.01 (<0.01, >100) | <0.01 (<0.01, 0.119) | <0.01 (<0.01, 0.135) | <0.01 (<0.01, 0.13) | <0.01 (<0.01, 0.143) | <0.01 (<0.01, 0.157) | <0.01 (<0.01, 0.24) | <0.01 (<0.01, 0.191) | <0.01 (<0.01, 0.207) | <0.01 (<0.01, 0.301) | <0.01 (<0.01, 0.492) | <0.01 (<0.01, 1.57) | <0.01 (<0.01, 1.25) | <0.01 (<0.01, 4.04) | Darexaban

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all interventions. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.

Abbreviations: GCS = graduated compression stocking, IPC = intermittent pneumatic compression, VFP = venous foot pump.

Table G9 Network meta-analysis pairwise results: Hip fracture surgery, intervention class comparisons of total DVT

| UFH | FXaI | LMWH | Placebo
UFH | UFH | 1.28 (0.35, 5.3) | 3.28 (0.967, 12.4) | 8.78 (2.04, 41.2)
FXaI | 0.783 (0.189, 2.85) | FXaI | 2.57 (1.51, 4.09) | 6.84 (2.86, 16.7)
LMWH | 0.305 (0.0809, 1.03) | 0.389 (0.245, 0.66) | LMWH | 2.67 (1.22, 6.13)
Placebo | 0.114 (0.0243, 0.49) | 0.146 (0.06, 0.349) | 0.375 (0.163, 0.817) | Placebo

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all classes. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.

Abbreviations: DVT = deep vein thrombosis, FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin

Table G10 Network meta-analysis pairwise results: Hip fracture surgery, specific intervention comparisons of total DVT

| Heparin | Fondaparinux | Dalteparin | Semuloparin | Enoxaparin | Edoxaban | Placebo
Heparin | Heparin | 2.58 (0.494, 14.2) | 3.26 (0.96, 11.9) | 5.35 (0.987, 31) | 7.36 (1.51, 38.8) | 19.1 (0.97, 829) | 13.6 (2.77, 70.2)
Fondaparinux | 0.388 (0.0705, 2.02) | Fondaparinux | 1.27 (0.422, 3.72) | 2.06 (1.02, 4.44) | 2.84 (1.78, 4.71) | 7.08 (0.591, 240) | 5.19 (2.07, 13.8)
Dalteparin | 0.306 (0.0837, 1.04) | 0.789 (0.269, 2.37) | Dalteparin | 1.63 (0.525, 5.29) | 2.25 (0.834, 6.36) | 5.7 (0.404, 198) | 4.12 (1.55, 11.3)
Semuloparin | 0.187 (0.0322, 1.01) | 0.486 (0.225, 0.981) | 0.612 (0.189, 1.91) | Semuloparin | 1.38 (0.79, 2.38) | 3.4 (0.285, 117) | 2.52 (0.888, 7.3)
Enoxaparin | 0.136 (0.0258, 0.662) | 0.352 (0.212, 0.561) | 0.444 (0.157, 1.2) | 0.725 (0.42, 1.27) | Enoxaparin | 2.45 (0.219, 80.7) | 1.82 (0.748, 4.57)
Edoxaban | 0.0523 (0.00121, 1.03) | 0.141 (0.00417, 1.69) | 0.176 (0.00504, 2.48) | 0.294 (0.00854, 3.51) | 0.408 (0.0124, 4.57) | Edoxaban | 0.74 (0.0204, 9.79)
Placebo | 0.0738 (0.0142, 0.362) | 0.193 (0.0726, 0.484) | 0.242 (0.0885, 0.645) | 0.397 (0.137, 1.13) | 0.548 (0.219, 1.34) | 1.35 (0.102, 48.9) | Placebo

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all interventions. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.

Abbreviations: DVT = deep vein thrombosis.

Table G11 Network meta-analysis pairwise results: Hip fracture surgery, intervention class comparisons of major bleeding

| Antiplatelet | VKA | Placebo | LMWH | FXaI
Antiplatelet | Antiplatelet | 7.27 (0.932, 279) | 7.63 (0.912, 280) | >100 ( 4.1, >100) | >100 (4.48, >100)
VKA | 0.138 (0.00359, 1.07) | VKA | 1.04 (0.242, 4.43) | >100 (0.722, >100) | >100 (0.827, >100)
Placebo | 0.131 (0.00357, 1.1) | 0.959 (0.226, 4.13) | Placebo | >100 (0.802, >100) | >100 (0.904,> 100)
LMWH | <0.01 (<0.01, 0.244) | <0.01 (<0.01, 1.39) | <0.01 (<0.01, 1.25) | LMWH | 1.06 (0.512, 2.39)
FXaI | <0.01 (<0.01, 0.223) | <0.01 (<0.01, 1.21) | <0.01 (<0.01, 1.11) | 0.946 (0.419, 1.95) | FXaI

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all classes. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.

Abbreviations: FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, VKA = vitamin K antagonist

Table G12 Network meta-analysis pairwise results: Hip fracture surgery, specific intervention comparisons of major bleeding

| Aspirin | Warfarin | Placebo | Dalteparin | Edoxaban | Enoxaparin | Fondaparinux | Semuloparin
Aspirin | Aspirin | 7.35 (0.864, >100) | 7.62 (0.87, >100) | >100 (2.05, >100) | >100 (2.27, >100) | >100 (9.87, >100) | >100 (11.3, >100) | >100 (14.5, >100)
Warfarin | 0.136 (<0.01, 1.16) | Warfarin | 1.04 (0.233, 4.43) | >100 (0.331, >100) | >100 (0.329, >100) | >100 (1.56, >100) | >100 (1.79, >100) | >100 (2.44, >100)
Placebo | 0.131 (<0.01, 1.15) | 0.962 (0.226, 4.29) | Placebo | >100 (0.358, >100) | >100 (0.383, >100) | >100 (1.71, >100) | >100 (1.99, >100) | >100 (2.71, >100)
Dalteparin | <0.01 (<0.01, 0.489) | <0.01 (<0.01, 3.02) | <0.01 (<0.01, 2.79) | Dalteparin | 1.3 (0.0135, 173) | 2.47 (0.182, 79.9) | 2.86 (0.189, 98.4) | 4.6 (0.214, 209)
Edoxaban | <0.01 (<0.01, 0.44) | <0.01 (<0.01, 3.04) | <0.01 (<0.01, 2.61) | 0.772 (0.00579, 74.3) | Edoxaban | 2.06 (0.0525, 85.7) | 2.32 (0.056, 108) | 3.78 (0.0676, 220)
Enoxaparin | <0.01 (<0.01, 0.101) | <0.01 (<0.01, 0.643) | <0.01 (<0.01, 0.586) | 0.405 (0.0125, 5.49) | 0.486 (0.0117, 19) | Enoxaparin | 1.13 (0.516, 2.89) | 1.8 (0.374, 10.2)
Fondaparinux | <0.01 (<0.01, 0.0889) | <0.01 (<0.01, 0.559) | <0.01 (<0.01, 0.502) | 0.35 (0.0102, 5.3) | 0.431 (0.00927, 17.8) | 0.888 (0.346, 1.94) | Fondaparinux | 1.61 (0.251, 10.6)
Semuloparin | <0.01 (<0.01, 0.0688) | <0.01 (<0.01, 0.41) | <0.01 (<0.01, 0.368) | 0.217 (0.00479, 4.68) | 0.264 (0.00455, 14.8) | 0.554 (0.0985, 2.67) | 0.621 (0.0948, 3.98) | Semuloparin

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all interventions. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.