# Appendix F Study Results

Table F1 RCT total hip replacement

Study | Arm | Timepoint | n/N (%)
Adherent/Compliant
Fuji 2014A 25047458 | Edoxaban 30 mg (NA) | 11–14 days | 85/85 (100%)
| Edoxaban 15 mg (NA) | | 89/89 (100%)
| Enoxaparin 20 mg BID (NA) | | 83/87 (95%)
Lassen 2010A 21175312 | Apixaban (NA) | ~34 days | 2595/2626 (99%)
| Enoxaparin (NA) | | 2647/2659 (100%)
Bleeding, Fatal
Bailey 1991 1774568 | IPC (Mechanical) | Post-operative days | 0/50 (0%)
| Warfarin (VKA) | | 0/45 (0%)
Barre 1987 2834500 | Dalteparin (LMWH) | 60 days | 0/40 (0%)
| Heparin (UFH) | | 0/40 (0%)
Comp 2001 11263636 THR | Enoxaparin 7–10 days (NA) | 30 days | 0/211 (0%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | | 0/224 (0%)
Dahl 1997 9031444 | Dalteparin 35 days (NA) | 35 days | 0/134 (0%)
| Dalteparin 7 days (NA) | | 0/131 (0%)
Edwards 2008 18534421 THA | Enoxaparin + IPC (LMWH_Mechanical) | post-operative days | 0/65 (0%)
| Enoxaparin (LMWH) | | 0/59 (0%)
Eriksson 1991 2013587 | Dalteparin (LMWH) | Post-operative days | 0/67 (0%)
| Heparin (UFH) | | 0/69 (0%)
Eriksson 1996 8596376 | Desirudin (DTI) | post-operative days | 0/202 (0%)
| Heparin (UFH) | | 0/229 (0%)
Eriksson 1997A 9070519 | Desirudin (DTI) | 42 days | 0/180 (0%)
| Heparin (UFH) | | 0/180 (0%)
Eriksson 2007B 17869635 | Dabigatran 150mg (NA) | Post-operative days | 1/1163 (0.1%)
| Dabigatran 220mg (DTI) | | 1/1146 (0.1%)
| Enoxaparin (LMWH) | | 0/1154 (0%)
Eriksson 2011 21225098 | Dabigatran 220 mg (DTI) | 28–35 (during treatment period) days | 0/1010 (0%)
| Enoxaparin (LMWH) | | 0/1003 (0%)
Francis 1992 1583760 | IPC (Mechanical) | Post-operative days | 0/98 (0%)
| Warfarin (VKA) | | 0/103 (0%)
Hull 1993 8413432 THA | Tinzaparin (LMWH) | Post-operative days | 0/398 (0%)
| Warfarin (VKA) | | 0/397 (0%)
Hull 2000 10904464 | Warfarin (VKA) | Post-operative days | 0/489 (0%)
| Dalteparin preoperative (NA) | | 0/496 (0%)
| Dalteparin postoperative (LMWH) | | 0/487 (0%)
Lassen 2002 12049858 | Fondaparinux (FXaI) | 11 days | 0/1140 (0%)
| Enoxaparin (LMWH) | | 0/1133 (0%)
Lassen 2010A 21175312 | Apixaban (FXaI) | ~34 (on treatment) days | 0/2673 (0%)
| Enoxaparin (LMWH) | | 0/2659 (0%)
Lassen 2012 22429800 THA | Semuloparin (NA) | period from the first injection given during the study up to the last injection plus 3 calendar days days | 0/1153 (0%)
| Enoxaparin (NA) | | 0/1155 (0%)
Levine 1991 1848054 | Heparin (UFH) | Post-operative days | 0/332 (0%)
| Enoxaparin (LMWH) | | 0/333 (0%)
Lieberman 1994 8126039 | Aspirin (Antiplatelet) | Post-operative days | 0/118 (0%)
| Aspirin+IPC (Antiplatelet_Mechanical) | | 0/113 (0%)
Nilsson 1997 9048404 | Enoxaparin 9 days (NA) | 90 days | 0/131 (0%)
| Enoxaparin 30 days (NA) | | 0/131 (0%)
Planes 1988 2853459 | Heparin (UFH) | Post-operative days | 0/108 (0%)
| Enoxaparin (LMWH) | | 0/120 (0%)
Planes 1997 9048403 | Enoxaparin 21 days post-discharge (NA) | 35 days | 0/85 (0%)
| Enoxaparin to discharge (NA) | | 0/88 (0%)
Planès 1999 10348714 | Tinzaparin (NA) | Post-operative days | 0/251 (0%)
| Enoxaparin (NA) | | 0/248 (0%)
Prandoni 2002 12230419 | Warfarin 28 days (NA) | 90 days | 0/184 (0%)
| Warfarin until hospital discharge (NA) | | 0/176 (0%)
Sakai 2016 26735531 | Edoxaban | 28 days | 0/62 (0)
| Edoxaban + foot pump | | 0/58 (0)
Samama 1997 9215015 | Placebo (Placebo) | 10 +/− 2 days | 0/84 (0%)
| Enoxaparin (LMWH) | | 0/85 (0%)
Santori 1994 8027144 | VFP (Mechanical) | 42 days | 0/67 (0%)
| Heparin (UFH) | | 0/65 (0%)
Schwartsmann 1996 Embase 1996366023 | Heparin (UFH) | Post-operative days | 0/47 (0%)
| Enoxaparin (LMWH) | | 0/52 (0%)
Senaran 2006 16333632 | Heparin (UFH) | 42 days | 0/50 (0%)
| Enoxaparin (LMWH) | | 0/50 (0%)
Sørensen 1990 1966794 | Placebo (Placebo) | Post-operative days | 0/33 (0%)
| Tinzaparin (LMWH) | | 0/31 (0%)
Stannard 1996 8640382 | VFP (PlexiPulse) (NA) | Post-operative days | 0/25 (0%)
| VFP (PlexiPulse)+ Heparin then Aspirin (NA) | | 0/25 (0%)
| Heparin then Aspirin (NA) | | 0/25 (0%)
Tørholm 1991 1670445 | Placebo (Placebo) | Post-operative days | 0/54 (0%)
| Dalteparin (LMWH) | | 0/58 (0%)
Turpie 1986 3531851 | Placebo (Placebo) | Post-operative days | 1/50 (2.0%)
| Enoxaparin (LMWH) | | 0/50 (0%)
Turpie 2002 12049860 | Fondaparinux (FXaI) | 11 days | 0/1126 (0%)
| Enoxaparin (LMWH) | | 0/1128 (0%)
Warwick 1998 9730125 | VFP (AV Impulse system) (Mechanical) | post-operative days | 0/147 (0%)
| Enoxaparin (LMWH) | | 0/143 (0%)
Bleeding, Leading to infection
Verhamme 2013 23615791 | TB-402 50 mg (NA) | 35 days | 1/208 (0.5%)
Verhamme 2013 23615791 | TB-402 25 mg (NA) | 35 days | 2/207 (1.0%)
Verhamme 2013 23615791 | Rivaroxaban 10 mg (NA) | 35 days | 0/207 (0%)
Bleeding, Leading to reoperation
Borgen 2012 22476844 | Dalteparin (postop) (NA) | ~8 days | 0/40 (0%)
| Dalteparin (preop) (NA) | | 1/40 (2.5%)
Bramlage 2012 22713698 | Certoparin 3000 IU (NA) | 8–16 days | 5/247 (2.0%)
| Certoparin 5000 IU (NA) | | 4/232 (1.7%)
Eriksson 1991 2013587 | Dalteparin (LMWH) | Post-operative days | 0/67 (0%)
| Heparin (UFH) | | 0/69 (0%)
Eriksson 1996 8596376 | Desirudin (DTI) | Post-operative days | 4/277 (1.4%)
| Heparin (UFH) | | 2/277 (0.7%)
Eriksson 1997A 9070519 | Desirudin (DTI) | 42 days | 0/225 (0%)
| Heparin (UFH) | | 0/220 (0%)
Eriksson 2007B 17869635 | Dabigatran 150mg (NA) | Post-operative days | 3/1163 (0.3%)
| Dabigatran 220mg (DTI) | | 2/1146 (0.2%)
| Enoxaparin (LMWH) | | 3/1154 (0.3%)
Francis 1992 1583760 | IPC (Mechanical) | Post-operative days | 0/98 (0%)
| Warfarin (VKA) | | 0/103 (0%)
Francis 1997 9314399 | Dalteparin (LMWH) | Post-operative days | 1/271 (0.4%)
| Warfarin (VKA) | | 0/279 (0%)
Lassen 2002 12049858 | Fondaparinux (FXaI) | 11 days | 5/1140 (0.4%)
| Enoxaparin (LMWH) | | 3/1133 (0.3%)
Lassen 2010A 21175312 | Apixaban (FXaI) | ~34 (on treatment) days | 1/2673 (0.04%)
| Enoxaparin (LMWH) | | 1/2659 (0.04%)
Samama 1997 9215015 | Placebo (Placebo) | 10 +/− 2 days | 0/75 (0%)
| Enoxaparin (LMWH) | | 0/78 (0%)
Turpie 2002 12049860 | Fondaparinux (FXaI) | 11 days | 2/1128 (0.2%)
| Enoxaparin (LMWH) | | 2/1129 (0.2%)
Bleeding, Major
2014 NCT00246025 | Dabigatran Etexilate 110 mg | 2 weeks (treatment period) | 1/133 (0.8)
| Dabigatran Etexilate 150 mg | | 0/126 (0)
| Dabigatran Etexilate 220 mg | | 3/129 (2.3)
Anderson 2013 23732713 | Dalteparin (NA) | ~100 days | 1/400 (0.3%)
| Dalteparin then Aspirin (NA) | | 0/385 (0%)
Bramlage 2012 22713698 | Certoparin 3000 IU (NA) | 8–16 days | 3/252 (1.2%)
| Certoparin 5000 IU (NA) | | 9/248 (3.6%)
Colwell 1994 8288662 | Enoxaparin 40 mg (LMWH) | Post-operative days | 3/203 (1.5%)
| Enoxaparin 30 mg (NA) | | 8/195 (4.1%)
| Heparin (UFH) | | 13/209 (6.2%)
Colwell 1999 10428124 | Warfarin (VKA) | post-operative days | 8/1495 (0.5%)
| Enoxaparin (LMWH) | | 18/1516 (1.2%)
Colwell 2010 20194309 | Continuous Enhanced Circulation Therapy + Synchronized Flow Technology (Mechanical) | 30 days | 0/198 (0%)
| Enoxaparin (LMWH) | | 11/194 (5.7%)
Comp 2001 11263636 THR | Enoxaparin 7–10 days (NA) | 30 days | 0/211 (0%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | | 0/224 (0%)
Eriksson 1991 2013587 | Dalteparin (LMWH) | Post-operative days | 0/67 (0%)
| Heparin (UFH) | | 0/69 (0%)
Eriksson 1997B 9358126 | Enoxaparin (NA) | Post-operative days | 1/365 (0.3%)
| Desirudin (NA) | | 2/349 (0.6%)
| Enoxaparin (NA) | | 0/351 (0%)
| Desirudin (NA) | | 8/1032 (0.8%)
| Enoxaparin (NA) | | 2/1026 (0.2%)
| Desirudin (DTI) | | 20/1028 (1.9%)
| Enoxaparin (LMWH) | | 20/1023 (2.0%)
| Desirudin (NA) | | 5/275 (1.8%)
| Enoxaparin (NA) | | 1/294 (0.3%)
Eriksson 2005 15634273 THA | Dabigatran 150 mg (DTI) | post-operative years | 10/266 (3.8%)
| Dabigatran 300 mg (NA) | | 12/258 (4.7%)
| Enoxaprin (LMWH) | | 6/270 (2.2%)
| Dabigatran 50 mg (NA) | | 0/265 (0%)
| Dabigatran 225 mg (NA) | | 12/270 (4.4%)
Eriksson 2007B 17869635 | Dabigatran 150mg (NA) | Post-operative days | 15/1163 (1.3%)
| Dabigatran 220 mg (DTI) | | 23/1146 (2.0%)
| Enoxaparin (LMWH) | | 18/1154 (1.6%)
Eriksson 2010 20088935 | Darexaban 60 mg qD (NA) | 9 days | 1/163 (0.6%)
| Darexaban 5 mg (NA) | | 0/158 (0%)
| Enoxaparin 40 mg (NA) | | 1/166 (0.6%)
| Darexaban 120 mg (NA) | | 0/156 (0%)
| Darexaban 30 mg qD (NA) | | 0/156 (0%)
| Darexaban 10 mg (NA) | | 0/161 (0%)
| Darexaban 60 mg qD (FXaI) | 6 weeks | 1/163 (0.6%)
| Darexaban 5 mg (NA) | | 0/158 (0%)
| Enoxaparin 40 mg (LMWH) | | 1/166 (0.6%)
| Darexaban 120 mg (NA) | | 0/156 (0%)
| Darexaban 30 mg qD (NA) | | 0/156 (0%)
| Darexaban 10 mg (NA) | | 0/161 (0%)
Eriksson 2011 21225098 | Dabigatran 220 mg (DTI) | 28–35 (during treatment period) days | 14/1010 (1.4%)
| Enoxaparin (LMWH) | | 9/1003 (0.9%)
Francis 1997 9314399 | Dalteparin (LMWH) | Post-operative days | 6/271 (2.2%)
| Warfarin (VKA) | | 4/279 (1.4%)
Fuji 2008 18843459 THA | Placebo (Placebo) | post-operative years | 0/101 (0%)
| Enoxaparin 40 mg (LMWH) | | 2/102 (2.0%)
| Enoxaparin 20 mg (NA) | | 3/104 (2.9%)
Fuji 2014A 25047458 | Edoxaban 30 mg (FXaI) | 11–14 days | 1/85 (1.2%)
| Edoxaban 15 mg (NA) | | 0/89 (0%)
| Enoxaparin 20 mg BID (LMWH) | | 0/87 (0%)
Fuji 2014D 22952213 THA | Placebo (NA) | 10–14 (during treatment period) days | 0/163 (0%)
| Darexaban 15 mg BID (NA) | | 0/169 (0%)
| Darexaban 30 mg BID (NA) | | 0/174 (0%)
| Enoxaparin (NA) | | 0/103 (0%)
| Placebo (Placebo) | 3–5 weeks after the last dose (till study ended) weeks | 0/163 (0%)
| Darexaban 15 mg BID (NA) | | 0/169 (0%)
| Darexaban 30 mg BID (FXaI) | | 0/174 (0%)
| Enoxaparin (LMWH) | | 0/103 (0%)
Fuji 2015 26269694 | Edoxaban (FXaI) | 11–14 days | 2/303 (0.7%)
| Enoxaparin (LMWH) | | 6/301 (2.0%)
Hull 1993 8413432 THA | Tinzaparin (LMWH) | Post-operative days | 11/398 (2.8%)
| Warfarin (VKA) | | 6/397 (1.5%)
Hull 2000 10904464 | Warfarin (VKA) | 0–1 days | 20/489 (4.1%)
| Dalteparin preoperative (NA) | | 33/496 (6.7%)
| Dalteparin postoperative (LMWH) | | 28/487 (5.7%)
| Warfarin (NA) | 2–8 days | 2/489 (0.4%)
| Dalteparin preoperative (NA) | | 11/496 (2.2%)
| Dalteparin postoperative (NA) | | 4/487 (0.8%)
Kim 1998 9549575 | Control (undefined) (Placebo) | post-operative days | 0/50 (0%)
| Aspirin (Antiplatelet) | | 0/50 (0%)
Lassen 1998 9669750 | Dalteparin (NA) | 35 days | 1/141 (0.7%)
| Extended Dalteparin (NA) | | 0/140 (0%)
Lassen 2002 12049858 | Fondaparinux (FXaI) | 11 days | 47/1140 (4.1%)
| Enoxaparin (LMWH) | | 32/1133 (2.8%)
Lassen 2010A 21175312 | Apixaban (FXaI) | ~34 (on treatment) days | 22/2673 (0.8%)
| Enoxaparin (LMWH) | | 18/2659 (0.7%)
Lassen 2012 22429800 THA | Semuloparin (NA) | period from the first injection given during the study up to the last injection plus 3 calendar days days | 4/1153 (0.3%)
| Enoxaparin (NA) | | 14/1155 (1.2%)
Levine 1991 1848054 | Heparin (UFH) | Post-operative days | 19/332 (5.7%)
| Enoxaparin (LMWH) | | 11/333 (3.3%)
Menzin 1994 8173149 | Enoxaparin 40 mg (LMWH) | Post-operative days | 3/202 (1.5%)
| Enoxaparin 30 mg (NA) | | 8/192 (4.2%)
| Heparin (UFH) | | 13/209 (6.2%)
Paiement 1987 3572408 | IPC (Mechanical) | Post-operative days | 0/66 (0%)
| Warfarin (VKA) | | 0/72 (0%)
Planes 1988 2853459 | Heparin (UFH) | Post-operative days | 0/112 (0%)
| Enoxaparin (LMWH) | | 2/124 (1.6%)
Planes 1997 9048403 | Enoxaparin 21 days post-discharge (NA) | 35 days | 0/90 (0%)
| Enoxaparin to discharge (NA) | | 0/89 (0%)
Planès 1999 10348714 | Tinzaparin (NA) | Post-operative days | 2/251 (0.8%)
| Enoxaparin (NA) | | 4/248 (1.6%)
Prandoni 2002 12230419 | Warfarin 28 days (NA) | 60 days | 1/184 (0.5%)
| Warfarin until hospital discharge (NA) | | 0/176 (0%)
Raskob 2010 20589317 | Edoxaban 90 mg (NA) | 10 days | 2/171 (1.2%)
| Edoxaban 60 mg (NA) | | 1/185 (0.5%)
| Edoxaban 30 mg (FXaI) | | 1/170 (0.6%)
| Edoxaban 15 mg (NA) | | 1/192 (0.5%)
| Dalteparin 5000 IU (LMWH) | | 0/172 (0%)
Sakai 2016 26735531 | Edoxaban | 28 days | 3/62 (4.8)
| Edoxaban + foot pump | | 3/58 (5.2)
Samama 1997 9215015 | Placebo (Placebo) | 10 +/− 2 days | 1/75 (1.3%)
| Enoxaparin (LMWH) | | 1/78 (1.3%)
Senaran 2006 16333632 | Heparin (UFH) | 42 days | 0/50 (0%)
| Enoxaparin (LMWH) | | 2/50 (4.0%)
Turpie 1986 3531851 | Placebo (Placebo) | Post-operative days | 2/50 (4.0%)
| Enoxaparin (LMWH) | | 1/50 (2.0%)
Turpie 2002 12049860 | Fondaparinux (FXaI) | 11 days | 20/1128 (1.8%)
| Enoxaparin (LMWH) | | 11/1129 (1.0%)
Verhamme 2013 23615791 | TB-402 50 mg (FViiiI) | 35 days | 5/208 (2.4%)
| TB-402 25 mg (NA) | | 4/207 (1.9%)
| Rivaroxaban 10 mg (FXaI) | | 0/207 (0%)
Yokote 2011 21282767 | Placebo (Placebo) | 11 days | 0/85 (0%)
| Fondaparinux (FXaI) | | 0/85 (0%)
| Enoxaparin (LMWH) | | 0/85 (0%)
Major Bleeding: Complicated wound bleeding requiring Transfusion >=6 units of packed RBC
Kim 2016 26790579a | Placebo | 2 days after treatment | 3/185 (1.6)
| Rivaroxaban | | 4/184 (2.2)
| Enoxaparin | | 4/184 (2.2)
Kim 2016 26790579b | Rivaroxaban | 2 days after treatment | 3/166 (1.8)
| Enoxaparin | | 3/167 (1.8)
Major Bleeding: Complicated wound bleeding requiring Prolonged hospitalisation >= 1 week
Kim 2016 26790579a | Placebo | 2 days after treatment | 4/185 (2.2)
| Rivaroxaban | | 6/184 (3.3)
| Enoxaparin | | 5/184 (2.7)
Kim 2016 26790579b | Rivaroxaban | 2 days after treatment | 6/166 (3.6)
| Enoxaparin | | 5/167 (3)
Major Bleeding: Complicated wound bleeding requiring Medical intervention to manage hypotension
Kim 2016 26790579a | Placebo | 2 days after treatment | 1/185 (0.5)
| Rivaroxaban | | 1/184 (0.5)
| Enoxaparin | | 1/184 (0.5)
Kim 2016 26790579b | Rivaroxaban | 2 days after treatment | 1/166 (0.6)
| Enoxaparin | | 1/167 (0.6)
Bleeding, Surgical site/joint
2014 NCT00246025 | Dabigatran Etexilate 110 mg | 2 weeks (treatment period) | 0/133 (0)
| Dabigatran Etexilate 150 mg | | 0/126 (0)
| Dabigatran Etexilate 220 mg | | 1/129 (0.8)
Anderson 2013 23732713 | Dalteparin (NA) | ~100 days | 5/400 (1.3%)
| Dalteparin then Aspirin (NA) | | 4/385 (1.0%)
Borgen 2012 22476844 | Dalteparin (postop) (NA) | ~8 days | 4/40 (10%)
| Dalteparin (preop) (NA) | | 3/40 (7.5%)
Bramlage 2012 22713698 | Certoparin 3000 IU (NA) | 8–16 days | 7/247 (2.8%)
| Certoparin 5000 IU (NA) | | 4/232 (1.7%)
Colwell 1994 8288662 | Enoxaparin 40 mg (LMWH) | Post-operative days | 1/203 (0.5%)
| Enoxaparin 30 mg (NA) | | 6/195 (3.1%)
| Heparin (UFH) | | 7/209 (3.3%)
Colwell 1999 10428124 | Warfarin (VKA) | post-operative days | 5/1495 (0.3%)
| Enoxaparin (LMWH) | | 14/1516 (0.9%)
| Warfarin (VKA) | | 45/1495 (3.0%)
| Enoxaparin (LMWH) | | 62/1516 (4.1%)
Eriksson 1996 8596376 | Desirudin (DTI) | Post-operative days | 8/277 (2.9%)
| Heparin (UFH) | | 7/277 (2.5%)
Eriksson 1997B 9358126 | Desirudin (DTI) | Post-operative days | 336/1042 (32%)
| Enoxaparin (LMWH) | | 341/1036 (33%)
Francis 1997 9314399 | Dalteparin (LMWH) | Post-operative days | 12/271 (4.4%)
| Warfarin (VKA) | | 3/279 (1.1%)
Fuji 2015 26269694 | Edoxaban (FXaI) | 11–14 days | 2/303 (0.7%)
| Enoxaparin (LMWH) | | 1/301 (0.3%)
Hull 2000 10904464 | Warfarin (NA) | 0–1 days | 0/489 (0%)
| Dalteparin preoperative (NA) | | 0/496 (0%)
| Dalteparin postoperative (NA) | | 1/487 (0.2%)
| Warfarin (NA) | 2–8 days | 0/489 (0%)
| Dalteparin preoperative (NA) | | 0/496 (0%)
| Dalteparin postoperative (NA) | | 2/487 (0.4%)
| Warfarin (VKA) | 0–1 days | 17/489 (3.5%)
| Dalteparin preoperative (NA) | | 32/496 (6.5%)
| Dalteparin postoperative (LMWH) | | 27/487 (5.5%)
| Warfarin (NA) | 2–8 days | 2/489 (0.4%)
| Dalteparin preoperative (NA) | | 9/496 (1.8%)
| Dalteparin postoperative (NA) | | 3/487 (0.6%)
Lassen 2002 12049858 | Fondaparinux (FXaI) | 11 days | 40/1140 (3.5%)
| Enoxaparin (LMWH) | | 29/1133 (2.6%)
Lassen 2010A 21175312 | Apixaban (FXaI) | ~34 (on treatment) days | 2/2673 (0.1%)
| Enoxaparin (LMWH) | | 4/2659 (0.2%)
| Apixaban (FXaI) | | 18/2673 (0.7%)
| Enoxaparin (LMWH) | | 16/2659 (0.6%)
Planès 1999 10348714 | Tinzaparin (NA) | Post-operative days | 2/251 (0.8%)
| Enoxaparin (NA) | | 4/248 (1.6%)
Sakai 2016 26735531 | Edoxaban | 28 days | 2/62 (3.2)
| Edoxaban + foot pump | | 2/58 (3.4)
Senaran 2006 16333632 | Heparin (UFH) | 42 days | 4/50 (8.0%)
| Enoxaparin (LMWH) | | 3/50 (6.0%)
Verhamme 2013 23615791 | TB-402 50 mg (FViiiI) | 35 days | 24/208 (12%)
| TB-402 25 mg (NA) | | 19/207 (9.2%)
| Rivaroxaban 10 mg (FXaI) | | 9/207 (4.3%)
DVT, Proximal
2014 NCT00246025 | Dabigatran Etexilate 110 mg | 2 weeks (treatment period) | 2/115 (1.7)
| Dabigatran Etexilate 150 mg | | 2/113 (1.8)
| Dabigatran Etexilate 220 mg | | 0/102 (0)
Anderson 2013 23732713 | Dalteparin (NA) | ~100 days | 2/398 (0.5%)
| Dalteparin then Aspirin (NA) | | 1/380 (0.3%)
Avikainen 1995 7645915 | Heparin (UFH) | Post-operative days | 4/84 (4.8%)
| Enoxaparin (LMWH) | | 1/83 (1.2%)
Bailey 1991 1774568 | IPC (Mechanical) | Post-operative days | 2/50 (4.0%)
| Warfarin (VKA) | | 0/45 (0%)
Bramlage 2012 22713698 | Certoparin 3000 IU (NA) | 8–16 days | 9/193 (4.7%)
| Certoparin 5000 IU (NA) | | 9/205 (4.4%)
Colwell 1994 8288662 | Enoxaparin 40 mg (LMWH) | Post-operative days | 8/203 (3.9%)
| Enoxaparin 30 mg (NA) | | 4/194 (2.1%)
| Heparin (UFH) | | 10/207 (4.8%)
Colwell 2010 20194309 | Continuous Enhanced Circulation Therapy + Synchronized Flow Technology (Mechanical) | 10 days | 3/196 (1.5%)
| Enoxaparin (LMWH) | | 2/190 (1.1%)
Comp 2001 11263636 THR | Enoxaparin 7–10 days (NA) | 30 days | 27/211 (13%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | | 6/224 (2.7%)
Dahl 1997 9031444 | Dalteparin 35 days (NA) | 35 days | 10/114 (8.8%)
| Dalteparin 7 days (NA) | | 14/104 (13%)
Dechavanne 1989 2537787 | Dalteparin 2500 U q12h (NA) | Post-operative days | 1/41 (2.4%)
| Dalteparin 5000 U qD (LMWH) | | 1/41 (2.4%)
| Heparin (UFH) | | 3/40 (7.5%)
Edwards 2008 18534421 THA | Enoxaparin + IPC (LMWH_Mechanical) | post-operative days | 0/65 (0%)
| Enoxaparin (LMWH) | | 0/59 (0%)
Eriksson 1996 8596376 | Desirudin (DTI) | Post-operative days | 6/195 (3.1%)
| Heparin (UFH) | | 43/219 (20%)
Eriksson 1997A 9070519 | Desirudin (DTI) | 42 days | 3/174 (1.7%)
| Heparin (UFH) | | 16/177 (9.0%)
Eriksson 1997B 9358126 | Desirudin (DTI) | Post-operative days | 36/802 (4.5%)
| Enoxaparin (LMWH) | | 59/785 (7.5%)
Eriksson 2005 15634273 THA | Dabigatran 150 mg (DTI) | post-operative years | 8/201 (4.0%)
| Dabigatran 300 mg (NA) | | 3/191 (1.6%)
| Enoxaprin (LMWH) | | 11/208 (5.3%)
| Dabigatran 50 mg (NA) | | 12/208 (5.8%)
| Dabigatran 225 mg (NA) | | 4/204 (2.0%)
Eriksson 2010 20088935 | Darexaban 60 mg qD (FXaI) | 9 days | 2/120 (1.7%)
| Darexaban 5 mg (NA) | | 6/117 (5.1%)
| Enoxaparin 40 mg (LMWH) | | 5/127 (3.9%)
| Darexaban 120 mg (NA) | | 1/110 (0.9%)
| Darexaban 30 mg qD (NA) | | 5/114 (4.4%)
| Darexaban 10 mg (NA) | | 7/120 (5.8%)
Eriksson 2011 21225098 | Dabigatran 220 mg (DTI) | 28–35 (during treatment period) days | 17/804 (2.1%)
| Enoxaparin (LMWH) | | 31/792 (3.9%)
Fordyce 1992 1732264 | Venous foot pump (A-V Impulse System) (Mechanical) | Post-operative days | 2/39 (5.1%)
| Control (Placebo) | | 5/40 (13%)
Francis 1992 1583760 | IPC (Mechanical) | Post-operative days | 12/98 (12%)
| Warfarin (VKA) | | 3/103 (2.9%)
Francis 1997 9314399 | Dalteparin (LMWH) | Post-operative days | 10/192 (5.2%)
| Warfarin (VKA) | | 16/190 (8.4%)
Fuji 2008 18843459 THA | Placebo (Placebo) | post-operative years | 9/86 (10%)
| Enoxaparin 40 mg (LMWH) | | 6/80 (7.5%)
| Enoxaparin 20 mg (NA) | | 3/90 (3.3%)
Fuji 2014A 25047458 | Edoxaban 30 mg (FXaI) | 11–14 days | 0/72 (0%)
| Edoxaban 15 mg (NA) | | 0/78 (0%)
| Enoxaparin 20 mg BID (LMWH) | | 0/74 (0%)
Fuji 2014D 22952213 THA | Placebo (Placebo) | 10–14 (during treatment period) days | 5/137 (3.6%)
| Darexaban 15 mg BID (NA) | | 1/144 (0.7%)
| Darexaban 30 mg BID (FXaI) | | 0/174 (0%)
| Enoxaparin (LMWH) | | 0/103 (0%)
Fuji 2015 26269694 | Edoxaban (FXaI) | 11–14 days | 1/255 (0.4%)
| Enoxaparin (LMWH) | | 2/248 (0.8%)
Hull 1993 8413432 THA | Tinzaparin (LMWH) | Post-operative days | 16/332 (4.8%)
| Warfarin (VKA) | | 13/340 (3.8%)
Hull 2000 10904464 | Warfarin (VKA) | post-operative days | 11/363 (3.0%)
| Dalteparin preoperative (NA) | | 3/354 (0.8%)
| Dalteparin postoperative (LMWH) | | 3/358 (0.8%)
Kalodiki 1996 8803642 | Placebo (Placebo) | Post-operative days | 8/14 (57%)
| GCS+ Enoxaparin (LMWH_Mechanical) | | 4/32 (13%)
| Enoxaparin (LMWH) | | 9/32 (28%)
Lassen 1991 1848385 | Placebo (Placebo) | Post-operative days | 35/97 (36%)
| Tinzaparin (LMWH) | | 24/93 (26%)
Lassen 1998 9669750 | Dalteparin (NA) | 35 days | 5/101 (5.0%)
| Extended Dalteparin (NA) | | 1/111 (0.9%)
Lassen 2002 12049858 | Fondaparinux (FXaI) | 11 days | 6/922 (0.7%)
| Enoxaparin (LMWH) | | 23/927 (2.5%)
Lassen 2010A 21175312 | Apixaban (FXaI) | ~34 (on treatment) days | 7/2196 (0.3%)
| Enoxaparin (LMWH) | | 20/2190 (0.9%)
Lassen 2012 22429800 THA | Semuloparin (NA) | 7–11 days | 13/1002 (1.3%)
| Enoxaparin (NA) | | 15/1011 (1.5%)
Levine 1991 1848054 | Heparin (UFH) | Post-operative days | 17/263 (6.5%)
| Enoxaparin (LMWH) | | 14/258 (5.4%)
Lieberman 1994 8126039 | Aspirin (Antiplatelet) | Post-operative days | 7/124 (5.6%)
| Aspirin+IPC (Antiplatelet_Mechanical) | | 0/124 (0%)
Lotke 1996 8595765 THA | Aspirin (Antiplatelet) | Post-operative days | 3/62 (4.8%)
| Warfarin (VKA) | | 10/71 (14%)
Nilsson 1997 9048404 | Enoxaparin 9 days (NA) | 30 days | 28/131 (21%)
| Enoxaparin 30 days (NA) | | 8/131 (6.1%)
Paiement 1987 3572408 | IPC (Mechanical) | Post-operative days | 10/66 (15%)
| Warfarin (VKA) | | 5/72 (6.9%)
Planes 1988 2853459 | Heparin (UFH) | Post-operative days | 20/108 (19%)
| Enoxaparin (LMWH) | | 9/120 (7.5%)
Planes 1997 9048403 | Enoxaparin 21 days post-discharge (NA) | 35 days | 5/85 (5.9%)
| Enoxaparin to discharge (NA) | | 7/88 (8.0%)
Planès 1999 10348714 | Tinzaparin (NA) | Post-operative days | 21/221 (10%)
| Enoxaparin (NA) | | 23/219 (11%)
Prandoni 2002 12230419 | Warfarin 28 days (NA) | 60 days | 1/184 (0.5%)
| Warfarin until hospital discharge (NA) | | 3/176 (1.7%)
Raskob 2010 20589317 | Edoxaban 90 mg (NA) | 7–10 days | 2/151 (1.3%)
| Edoxaban 60 mg (NA) | | 2/158 (1.3%)
| Edoxaban 30 mg (FXaI) | | 5/151 (3.3%)
| Edoxaban 15 mg (NA) | | 11/170 (6.5%)
| Dalteparin 5000 IU (LMWH) | | 20/144 (14%)
Ryan 2002 12429761 | IPC (Venaflow) (NA) | post-operative days | 4/50 (8.0%)
| GCS (T.E.D.) (NA) | | 11/50 (22%)
Sakai 2016 26735531 | Edoxaban | 28 days | 0/62 (0)
| Edoxaban + foot pump | | 0/58 (0)
Samama 1997 9215015 | Placebo (Placebo) | 10 +/− 2 days | 12/75 (16%)
| Enoxaparin (LMWH) | | 2/78 (2.6%)
Schwartsmann 1996 Embase 1996366023 | Heparin (UFH) | Post-operative days | 5/47 (11%)
| Enoxaparin (LMWH) | | 4/52 (7.7%)
Silbersack 2004 15330019 THA | Enoxaparin + GCS (Comprinet Pro) (NA) | 6–12th post-operative days | 1/28 (3.6%)
| Enoxaparin + IPC (Venaflow) (NA) | | 0/33 (0%)
Stannard 1996 8640382 | VFP (PlexiPulse) (NA) | Post-operative days | 0/25 (0%)
| VFP (PlexiPulse)+ Heparin then Aspirin (NA) | | 0/25 (0%)
| Heparin then Aspirin (NA) | | 5/25 (20%)
Stone 1996 9049766 | IPC (Mechanical) | Post-operative days | 1/25 (4.0%)
| Enoxaparin (LMWH) | | 1/25 (4.0%)
Tørholm 1991 1670445 | Placebo (Placebo) | Post-operative days | 4/54 (7.4%)
| Dalteparin (LMWH) | | 0/58 (0%)
Turpie 1986 3531851 | Placebo (Placebo) | Post-operative days | 9/39 (23%)
| Enoxaparin (LMWH) | | 2/37 (5.4%)
Turpie 2002 12049860 | Fondaparinux (FXaI) | 11 days | 14/816 (1.7%)
| Enoxaparin (LMWH) | | 10/830 (1.2%)
Verhamme 2013 23615791 | TB-402 50 mg (FViiiI) | 35 days | 4/193 (2.1%)
| TB-402 25 mg (NA) | | 1/187 (0.5%)
| Rivaroxaban 10 mg (FXaI) | | 1/191 (0.5%)
Warwick 1995 7559695 | Control (Placebo) | Post-operative days | 14/78 (18%)
| Enoxaparin (LMWH) | | 12/78 (15%)
Warwick 1998 9730125 | VFP (AV Impulse system) (Mechanical) | post-operative days | 17/136 (13%)
| Enoxaparin (LMWH) | | 12/138 (8.7%)
Woolson 1991 2013589 | IPC+ Aspirin (Antiplatelet_Mechanical) | Post-operative days | 7/72 (10%)
| IPC (Mechanical) | | 9/76 (12%)
| IPC+ wafarin (VKA_Mechanical) | | 6/69 (8.7%)
Yokote 2011 21282767 | Placebo (Placebo) | 11 days | 0/83 (0%)
| Fondaparinux (FXaI) | | 1/84 (1.2%)
| Enoxaparin (LMWH) | | 0/83 (0%)
Zhang 2013 EMBASE 2014592535 | Rivaroxaban (FXaI) | 6 months | 0/53 (0%)
| LMWH (LMWH) | | 7/53 (13%)
DVT, Symptomatic
2014 NCT00246025 | Dabigatran Etexilate 110 mg | 2 weeks (treatment period) | 1/133 (0.8)
| Dabigatran Etexilate 150 mg | | 2/126 (1.6)
| Dabigatran Etexilate 220 mg | | 1/129 (0.8)
Andersen 1997 9690480 | Dalteparin 35 days (NA) | 35 days | 1/20 (5.0%)
| Dalteparin 5–7 days (NA) | | 1/21 (4.8%)
Anderson 2013 23732713 | Dalteparin (NA) | ~100 days | 3/398 (0.8%)
| Dalteparin then Aspirin (NA) | | 1/380 (0.3%)
Avikainen 1995 7645915 | Heparin (UFH) | Post-operative days | 4/84 (4.8%)
| Enoxaparin (LMWH) | | 1/83 (1.2%)
Borgen 2012 22476844 | Dalteparin (postop) (NA) | ~8 days | 0/40 (0%)
| Dalteparin (preop) (NA) | | 0/40 (0%)
Colwell 1999 10428124 | Warfarin (VKA) | 90 days | 47/1495 (3.1%)
| Enoxaparin (LMWH) | | 49/1516 (3.2%)
Dahl 1997 9031444 | Dalteparin 35 days (NA) | 35 days | 8/114 (7.0%)
| Dalteparin 7 days (NA) | | 4/104 (3.8%)
Eriksson 1991 2013587 | Dalteparin (LMWH) | Post-operative days | 2/63 (3.2%)
| Heparin (UFH) | | 2/59 (3.4%)
Eriksson 2007B 17869635 | Dabigatran 150mg (NA) | Post-operative days | 9/1156 (0.8%)
| Dabigatran 220mg (DTI) | | 6/1137 (0.5%)
| Enoxaparin (LMWH) | | 1/1142 (0.1%)
Eriksson 2010 20088935 | Darexaban 60 mg qD (FXaI) | 9 days | 1/120 (0.8%)
| Darexaban 5 mg (NA) | | 1/117 (0.9%)
| Enoxaparin 40 mg (LMWH) | | 0/127 (0%)
| Darexaban 120 mg (NA) | | 1/110 (0.9%)
| Darexaban 30 mg qD (NA) | | 0/114 (0%)
| Darexaban 10 mg (NA) | | 1/120 (0.8%)
Eriksson 2011 21225098 | Dabigatran 220 mg (DTI) | 28–35 (during treatment period) days | 0/1001 (0%)
| Enoxaparin (LMWH) | | 4/992 (0.4%)
Fuji 2014A 25047458 | Edoxaban 30 mg (FXaI) | 11–14 days | 0/72 (0%)
| Edoxaban 15 mg (NA) | | 0/78 (0%)
| Enoxaparin 20 mg BID (LMWH) | | 0/74 (0%)
Fuji 2014D 22952213 THA | Placebo (Placebo) | 10–14 (during treatment period) days | 0/163 (0%)
| Darexaban 15 mg BID (NA) | | 0/169 (0%)
| Darexaban 30 mg BID (FXaI) | | 0/174 (0%)
| Enoxaparin (LMWH) | | 0/103 (0%)
Fuji 2015 26269694 | Edoxaban (FXaI) | 11–14 days | 0/255 (0%)
| Enoxaparin (LMWH) | | 0/248 (0%)
Hull 2000 10904464 | Warfarin (VKA) | post-operative days | 15/338 (4.4%)
| Dalteparin preoperative (NA) | | 5/337 (1.5%)
| Dalteparin postoperative (LMWH) | | 10/336 (3.0%)
Kim 2016 26790579a | Placebo | 2 days after treatment | 4/185 (2.2)
| Rivaroxaban | | 3/184 (1.6)
| Enoxaparin | | 4/184 (2.2)
Kim 2016 26790579a | Placebo | 4 weeks post-treatment | 4/185 (2.2)
| Rivaroxaban | | 3/184 (1.6)
| Enoxaparin | | 4/184 (2.2)
Kim 2016 26790579b | Rivaroxaban | 2 days after treatment | 3/166 (1.8)
| Enoxaparin | | 3/167 (1.8)
Kim 2016 26790579b | Rivaroxaban | 4 weeks post-treatment | 3/166 (1.8)
| Enoxaparin | | 3/167 (1.8)
Lassen 1991 1848385 | Placebo (Placebo) | Post-operative days | 0/97 (0%)
| Tinzaparin (LMWH) | | 0/93 (0%)
Lassen 2002 12049858 | Fondaparinux (FXaI) | 11 days | 3/1129 (0.3%)
| Enoxaparin (LMWH) | | 1/1123 (0.1%)
Lassen 2010A 21175312 | Apixaban (NA) | On treatment, ~34 days | 1/2708 (0.04%)
| Enoxaparin (NA) | | 5/2699 (0.2%)
| Apixaban (FXaI) | Post-treatment, ~94 days | 1/2708 (0.04%)
| Enoxaparin (LMWH) | | 8/2699 (0.3%)
Nilsson 1997 9048404 | Enoxaparin 9 days (NA) | 30 days | 8/131 (6.1%)
| Enoxaparin 30 days (NA) | | 2/131 (1.5%)
Planès 1999 10348714 | Tinzaparin (NA) | Post-operative days | 2/221 (0.9%)
| Enoxaparin (NA) | | 3/219 (1.4%)
Prandoni 2002 12230419 | Warfarin 28 days (NA) | 60 days | 2/184 (1.1%)
| Warfarin until hospital discharge (NA) | | 3/176 (1.7%)
Ryan 2002 12429761 | IPC (Venaflow) (NA) | post-operative days | 0/50 (0%)
| GCS (T.E.D.) (NA) | | 0/50 (0%)
Sakai 2016 26735531 | Edoxaban | 28 days | 1/62 (1.6)
| Edoxaban + foot pump | | 3/58 (5.2)
Samama 1997 9215015 | Placebo (Placebo) | 10 +/− 2 days | 1/75 (1.3%)
| Enoxaparin (LMWH) | | 1/78 (1.3%)
Schwartsmann 1996 Embase 1996366023 | Heparin (UFH) | Post-operative days | 3/47 (6.4%)
| Enoxaparin (LMWH) | | 3/52 (5.8%)
Senaran 2006 16333632 | Heparin (UFH) | 42 days | 0/50 (0%)
| Enoxaparin (LMWH) | | 2/50 (4.0%)
Stannard 1996 8640382 | VFP (PlexiPulse) (NA) | Post-operative days | 0/25 (0%)
| VFP (PlexiPulse)+ Heparin then Aspirin (NA) | | 0/25 (0%)
| Heparin then Aspirin (NA) | | 3/25 (12%)
Stone 1996 9049766 | IPC (Mechanical) | Post-operative days | 0/25 (0%)
| Enoxaparin (LMWH) | | 0/25 (0%)
Turpie 2002 12049860 | Fondaparinux (FXaI) | 11 days | 5/1126 (0.4%)
| Enoxaparin (LMWH) | | 0/1128 (0%)
Verhamme 2013 23615791 | TB-402 50 mg (FViiiI) | 35 days | 0/193 (0%)
| TB-402 25 mg (NA) | | 0/187 (0%)
| Rivaroxaban 10 mg (FXaI) | | 0/191 (0%)
Warwick 1998 9730125 | VFP (AV Impulse system) (Mechanical) | post-operative days | 0/136 (0%)
| Enoxaparin (LMWH) | | 1/138 (0.7%)
Yokote 2011 21282767 | Placebo (Placebo) | 11 days | 0/83 (0%)
| Fondaparinux (FXaI) | | 1/84 (1.2%)
| Enoxaparin (LMWH) | | 0/83 (0%)
DVT, Total
2014 NCT00246025 | Dabigatran Etexilate 110 mg | 2 weeks (treatment period) | 42/106 (39.6)
| Dabigatran Etexilate 150 mg | | 34/104 (32.7)
| Dabigatran Etexilate 220 mg | | 23/96 (24)
Alfaro 1986 3535158 | Aspirin 125 mg (Antiplatelet) | Post-operative | 1/30 (3.3%)
| Control (Placebo) | | 9/30 (30%)
| Aspirin 500 mg (NA) | | 1/30 (3.3%)
Andersen 1997 9690480 | Dalteparin 35 days (NA) | 35 days | 2/20 (10%)
| Dalteparin 5–7 days (NA) | | 3/21 (14%)
Avikainen 1995 7645915 | Heparin (UFH) | Post-operative | 4/84 (4.8%)
| Enoxaparin (LMWH) | | 1/83 (1.2%)
Bailey 1991 1774568 | IPC (Mechanical) | Post-operative | 3/50 (6.0%)
| Warfarin (VKA) | | 12/45 (27%)
Barre 1987 2834500 | Dalteparin (LMWH) | Post-operative | 7/40 (18%)
| Heparin (UFH) | | 4/40 (10%)
Bramlage 2012 22713698 | Certoparin 3000 IU (NA) | 8–16 days | 28/193 (15%)
| Certoparin 5000 IU (NA) | | 35/205 (17%)
Colwell 1994 8288662 | Enoxaparin 40 mg (LMWH) | Post-operative | 30/203 (15%)
| Enoxaparin 30 mg (NA) | | 9/194 (4.6%)
| Heparin (UFH) | | 24/207 (12%)
Colwell 2010 20194309 | Continuous Enhanced Circulation Therapy + Synchronized Flow Technology (Mechanical) | 10 days | 8/196 (4.1%)
| Enoxaparin (LMWH) | | 8/190 (4.2%)
Comp 2001 11263636 THR | Enoxaparin 7–10 days (NA) | 30 days | 49/211 (23%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | | 18/224 (8.0%)
Dahl 1997 9031444 | Dalteparin 35 days (NA) | 7–35 days | 11/93 (12%)
| Dalteparin 7 days (NA) | | 23/89 (26%)
Dechavanne 1989 2537787 | Dalteparin 2500 U q12h (NA) | Post-operative | 2/41 (4.9%)
| Dalteparin 5000 U qD (LMWH) | | 3/41 (7.3%)
| Heparin (UFH) | | 4/40 (10%)
Edwards 2008 18534421 THA | Enoxaparin + IPC (LMWH_Mechanical) | Post-operative | 1/65 (1.5%)
| Enoxaparin (LMWH) | | 2/59 (3.4%)
Eisele 2007 17473143 THR | Certoparin + IPC | discharge | 0/191 (0)
| Certoparin | | 6/115 (5.2)
Eisele 2007 17473143 TKR | Certoparin + IPC | discharge | 3/79 (3.8)
| Certoparin | | 4/54 (7.4)
Eriksson 1991 2013587 | Dalteparin (LMWH) | Post-operative | 19/63 (30%)
| Heparin (UFH) | | 25/59 (42%)
Eriksson 1996 8596376 | Desirudin (DTI) | Post-operative | 37/202 (18%)
| Heparin (UFH) | | 77/229 (34%)
Eriksson 1997A 9070519 | Desirudin (DTI) | 42 days | 13/180 (7.2%)
| Heparin (UFH) | | 42/180 (23%)
Eriksson 1997B 9358126 | Desirudin (DTI) | Post-operative | 142/773 (18%)
| Enoxaparin (LMWH) | | 196/768 (26%)
Eriksson 2005 15634273 THA | Dabigatran 150 mg (DTI) | post-operative | 26/201 (13%)
| Dabigatran 300 mg (NA) | | 25/191 (13%)
| Enoxaprin (LMWH) | | 31/208 (15%)
| Dabigatran 50 mg (NA) | | 49/208 (24%)
| Dabigatran 225 mg (NA) | | 17/204 (8.3%)
Eriksson 2010 20088935 | Darexaban 60 mg qD (FXaI) | 9 days | 16/120 (13%)
| Darexaban 5 mg (NA) | | 32/117 (27%)
| Enoxaparin 40 mg (LMWH) | | 24/127 (19%)
| Darexaban 120 mg (NA) | | 15/110 (14%)
| Darexaban 30 mg qD (NA) | | 22/114 (19%)
| Darexaban 10 mg (NA) | | 38/120 (32%)
Eriksson 2011 21225098 | Dabigatran 220 mg (DTI) | 28–35 (during treatment period) days | 60/791 (7.6%)
| Enoxaparin (LMWH) | | 67/783 (8.6%)
Fordyce 1992 1732264 | Venous foot pump (A-V Impulse System) (Mechanical) | Post-operative | 4/39 (10%)
| Control (Placebo) | | 16/40 (40%)
Francis 1992 1583760 | IPC (Mechanical) | Post-operative | 26/98 (27%)
| Warfarin (VKA) | | 32/103 (31%)
Francis 1997 9314399 | Dalteparin (LMWH) | Post-operative | 28/192 (15%)
| Warfarin (VKA) | | 49/190 (26%)
Fuji 2008 18843459 THA | Placebo (Placebo) | Post-operative | 36/86 (42%)
| Enoxaparin 40 mg (LMWH) | | 27/80 (34%)
| Enoxaparin 20 mg (NA) | | 18/90 (20%)
Fuji 2014A 25047458 | Edoxaban 30 mg (FXaI) | 11–14 days | 2/72 (2.8%)
| Edoxaban 15 mg (NA) | | 3/78 (3.8%)
| Enoxaparin 20 mg BID (LMWH) | | 3/74 (4.1%)
Fuji 2014D 22952213 THA | Placebo (Placebo) | 10–14 (during treatment period) days | 22/129 (17%)
| Darexaban 15 mg BID (NA) | | 4/136 (2.9%)
| Darexaban 30 mg BID (FXaI) | | 6/133 (4.5%)
| Enoxaparin (LMWH) | | 2/82 (2.4%)
Fuji 2015 26269694 | Edoxaban (FXaI) | 11–14 days | 6/255 (2.4%)
| Enoxaparin (LMWH) | | 17/248 (6.9%)
Hull 1993 8413432 THA | Tinzaparin (LMWH) | Post-operative | 69/332 (21%)
| Warfarin (VKA) | | 79/340 (23%)
Hull 2000 10904464 | Warfarin (VKA) | post-operative days | 81/338 (24%)
| Dalteparin preoperative (NA) | | 36/337 (11%)
| Dalteparin postoperative (LMWH) | | 44/336 (13%)
Kalodiki 1996 8803642 | Placebo (Placebo) | Post-operative | 13/14 (93%)
| GCS+ Enoxaparin (LMWH_Mechanical) | | 8/32 (25%)
| Enoxaparin (LMWH) | | 12/32 (38%)
Kim 1998 9549575 | Control (undefined) (Placebo) | post-operative days | 10/50 (20%)
| Aspirin (Antiplatelet) | | 6/50 (12%)
Kim 2016 26790579a | Placebo | 2 days after treatment | 12/185 (6.5)
| Rivaroxaban | | 10/184 (5.4)
| Enoxaparin | | 11/184 (6)
Kim 2016 26790579a | Placebo | 4 weeks post-treatment | 12/185 (6.5)
| Rivaroxaban | | 10/184 (5.4)
| Enoxaparin | | 11/184 (6)
Kim 2016 26790579b | Rivaroxaban | 2 days after treatment | 14/166 (8.4)
| Enoxaparin | | 12/167 (7.2)
Kim 2016 26790579b | Rivaroxaban | 4 weeks post-treatment | 14/166 (8.4)
| Enoxaparin | | 12/167 (7.2)
Lassen 1991 1848385 | Placebo (Placebo) | Post-operative days | 44/97 (45%)
| Tinzaparin (LMWH) | | 29/93 (31%)
Lassen 1998 9669750 | Dalteparin (NA) | 35 days | 12/102 (12%)
| Extended Dalteparin (NA) | | 5/113 (4.4%)
Lassen 2002 12049858 | Fondaparinux (FXaI) | 11 days | 36/908 (4.0%)
Lass | Enoxaparin (LMWH) | | 83/918 (9.0%)
Lassen 2010A 21175312 | Apixaban (FXaI) | ~34 (on treatment) days | 22/1944 (1.1%)
| Enoxaparin (LMWH) | | 68/1911 (3.6%)
Lassen 2012 22429800 THA | Semuloparin (NA) | 7–11 days | 57/915 (6.2%)
| Enoxaparin (NA) | | 102/931 (11%)
Levine 1991 1848054 | Heparin (UFH) | Post-operative days | 61/263 (23%)
| Enoxaparin (LMWH) | | 50/258 (19%)
Lotke 1996 8595765 THA | Aspirin (Antiplatelet) | Post-operative | 18/62 (29%)
| Warfarin (VKA) | | 26/71 (37%)
Lou 2010 20646562 | LMWH (LMWH) | 7 days | 3/38 (7.9%)
| Control (Placebo) | | 15/35 (43%)
Menzin 1994 8173149 | Enoxaparin 40 mg (LMWH) | Post-operative | 30/202 (15%)
| Enoxaparin 30 mg (NA) | | 9/192 (4.7%)
| Heparin (UFH) | | 24/209 (11%)
Nilsson 1997 9048404 | Enoxaparin 9 days (NA) | 30 days | 43/131 (33%)
| Enoxaparin 30 days (NA) | | 21/131 (16%)
Paiement 1987 3572408 | IPC (Mechanical) | Post-operative | 11/66 (17%)
| Warfarin (VKA) | | 12/72 (17%)
Planes 1988 2853459 | Heparin (UFH) | Post-operative | 27/108 (25%)
| Enoxaparin (LMWH) | | 15/120 (13%)
Planes 1997 9048403 | Enoxaparin 21 days post-discharge (NA) | 35 days | 6/85 (7.1%)
| Enoxaparin to discharge (NA) | | 17/88 (19%)
Planès 1999 10348714 | Tinzaparin (NA) | Post-operative | 48/221 (22%)
| Enoxaparin (NA) | | 44/219 (20%)
Prandoni 2002 12230419 | Warfarin 28 days (NA) | 60 days | 3/184 (1.6%)
| Warfarin until hospital discharge (NA) | | 8/176 (4.5%)
Rader 1998 9526211 THA | Heparin + Heparin (NA) | Post-operative | 1/56 (1.8%)
| Heparin + Enoxaparin (NA) | | 2/70 (2.9%)
Sakai 2016 26735531 | Edoxaban | 28 days | 11/62 (17.7)
| Edoxaban + foot pump | | 18/58 (31)
Samama 1997 9215015 | Placebo (Placebo) | 10 +/− 2 days | 28/75 (37%)
| Enoxaparin (LMWH) | | 11/78 (14%)
Santori 1994 8027144 | VFP (Mechanical) | 42 days | 9/67 (13%)
| Heparin (UFH) | | 23/65 (35%)
Schwartsmann 1996 Embase 1996366023 | Heparin (UFH) | Post-operative | 5/47 (11%)
| Enoxaparin (LMWH) | | 5/52 (10%)
Senaran 2006 16333632 | Heparin (UFH) | discharge days | 2/50 (4.0%)
| Enoxaparin (LMWH) | | 0/50 (0%)
Silbersack 2004 15330019 THA | Enoxaparin + GCS (Comprinet Pro) (NA) | 6–12th post-operative days | 4/28 (14%)
| Enoxaparin + IPC (Venaflow) (NA) | | 0/33 (0%)
Sørensen 1990 1966794 | Placebo (Placebo) | Post-operative | 16/33 (48%)
| Tinzaparin (LMWH) | | 17/31 (55%)
Stannard 1996 8640382 | VFP (PlexiPulse) (NA) | Post-operative | 0/25 (0%)
| VFP (PlexiPulse)+ Heparin then Aspirin (NA) | | 0/25 (0%)
| Heparin then Aspirin (NA) | | 5/25 (20%)
Stone 1996 9049766 | IPC (Mechanical) | Post-operative | 1/25 (4.0%)
| Enoxaparin (LMWH) | | 1/25 (4.0%)
Tørholm 1991 1670445 | Placebo (Placebo) | Post-operative | 16/54 (30%)
| Dalteparin (LMWH) | | 8/58 (14%)
Turpie 1986 3531851 | Placebo (Placebo) | Post-operative | 20/39 (51%)
| Enoxaparin (LMWH) | | 4/37 (11%)
Turpie 2002 12049860 | Fondaparinux (FXaI) | 11 days | 44/784 (5.6%)
| Enoxaparin (LMWH) | | 65/796 (8.2%)
Verhamme 2013 23615791 | TB-402 50 mg (FViiiI) | 35 days | 10/193 (5.2%)
| TB-402 25 mg (NA) | | 10/187 (5.3%)
| Rivaroxaban 10 mg (FXaI) | | 9/191 (4.7%)
Warwick 1995 7559695 | Control (Placebo) | Post-operative | 33/78 (42%)
| Enoxaparin (LMWH) | | 22/78 (28%)
Warwick 1998 9730125 | VFP (AV Impulse system) (Mechanical) | Post-operative | 24/136 (18%)
| Enoxaparin (LMWH) | | 18/138 (13%)
Welin-Berger 1982 6184938 | Heparin (UFH) | Post-operative | 8/20 (40%)
| Control (Placebo) | | 5/20 (25%)
Yokote 2011 21282767 | Placebo (Placebo) | 11 days | 6/83 (7.2%)
| Fondaparinux (FXaI) | | 6/84 (7.1%)
| Enoxaparin (LMWH) | | 5/83 (6.0%)
Zhang 2013 EMBASE 2014592535 | Rivaroxaban (FXaI) | 6 months | 0/53 (0%)
| LMWH (LMWH) | | 7/53 (13%)
Zhang 2014 24767296 | Rivaroxaban 35 days (NA) | 35 days | 0/20 (0%)
| Rivaroxaban 7 days (NA) | | 0/20 (0%)
Zhirova 2014 25831700 | enoxaparin + rivaroxaban (NA) | in hospital N/A | 5/40 (13%)
| enoxaparin + dabigatran (NA) | | 3/42 (7.1%)
| enoxaparin (NA) | | 6/39 (15%)
Heparin-induced thrombocytopenia
Colwell 1994 8288662 | Enoxaparin 40 mg (NA) | Post-operative days | 0/203 (0%)
| Enoxaparin 30 mg (NA) | | 0/195 (0%)
| Heparin (NA) | | 1/209 (0.5%)
Colwell 1999 10428124 | Warfarin (NA) | post-operative days | 0/1495 (0%)
| Enoxaparin (NA) | | 0/1516 (0%)
Levine 1991 1848054 | Heparin (NA) | Post-operative days | 9/332 (2.7%)
| Enoxaparin (NA) | | 0/333 (0%)
Planès 1999 10348714 | Tinzaparin (NA) | Post-operative days | 0/251 (0%)
| Enoxaparin (NA) | | 1/248 (0.4%)
Senaran 2006 16333632 | Heparin (NA) | 42 days | 0/50 (0%)
| Enoxaparin (NA) | | 0/50 (0%)
Infection, Joint
Kim 2016 26790579a | Placebo | 2 days after treatment | 0/184 (0)
| Rivaroxaban | | 0/184 (0)
| Enoxaparin | | 0/184 (0)
Kim 2016 26790579b | Rivaroxaban | 2 days after treatment | 0/166 (0)
| Enoxaparin | | 0/167 (0)
Infection, Wound
2014 NCT00246025 | Dabigatran Etexilate 110 mg | 2 weeks (treatment period) | 0/133 (0)
| Dabigatran Etexilate 150 mg | | 1/126 (0.8)
| Dabigatran Etexilate 220 mg | | 0/129 (0)
Anderson 2013 23732713 | Dalteparin (NA) | ~100 days | 10/400 (2.5%)
| Dalteparin then Aspirin (NA) | | 12/385 (3.1%)
Bramlage 2012 22713698 | Certoparin 3000 IU (NA) | 8–16 days | 0/252 (0%)
| Certoparin 5000 IU (NA) | | 0/248 (0%)
| Certoparin 3000 IU (NA) | | 2/252 (0.8%)
| Certoparin 5000 IU (NA) | | 5/248 (2.0%)
Kim 2016 26790579a | Placebo | 2 days after treatment | 0/185 (0)
| Rivaroxaban | | 0/184 (0)
| Enoxaparin | | 0/184 (0)
Kim 2016 26790579b | Rivaroxaban | 2 days after treatment | 0/166 (0)
| Enoxaparin | | 0/167 (0)
Major adverse event, other
Colwell 2010 20194309 | Continuous Enhanced Circulation Therapy + Synchronized Flow Technology (Mechanical) | 3 months | 3/198 (1.5%)
| Enoxaparin (LMWH) | | 10/194 (5.2%)
Fuji 2014A 25047458 | Edoxaban 30 mg (FXaI) | 11–14 days | 0/85 (0%)
| Edoxaban 15 mg (NA) | | 0/89 (0%)
| Enoxaparin 20 mg BID (LMWH) | | 1/87 (1.1%)
Fuji 2014D 22952213 THA | Placebo (Placebo) | 10–14 (during treatment period) days | 4/163 (2.5%)
| Darexaban 15 mg BID (NA) | | 2/169 (1.2%)
| Darexaban 30 mg BID (FXaI) | | 1/174 (0.6%)
| Enoxaparin (LMWH) | | 3/103 (2.9%)
Fuji 2015 26269694 | Edoxaban (FXaI) | 11–14 days | 9/303 (3.0%)
| Enoxaparin (LMWH) | | 10/301 (3.3%)
Lassen 2010A 21175312 | Apixaban (FXaI) | ~34 (on treatment) days | 184/2673 (6.9%)
| Enoxaparin (LMWH) | | 172/2659 (6.5%)
Lassen 2012 22429800 THA | Semuloparin (NA) | period from the first injection given during the study up to the last injection plus 3 calendar days days | 32/1153 (2.8%)
| Enoxaparin (NA) | | 43/1155 (3.7%)
Raskob 2010 20589317 | Edoxaban 90 mg (NA) | 10 days | 10/177 (5.6%)
| Edoxaban 60 mg (NA) | | 8/185 (4.3%)
| Edoxaban 30 mg (FXaI) | | 5/170 (2.9%)
| Edoxaban 15 mg (NA) | | 8/192 (4.2%)
| Dalteparin 5000 IU (LMWH) | | 3/172 (1.7%)
Mortality, 30 day or in-hospital (AE)
2013 NCT00595426 | Wafarin | nd | 2/133 (1.5)
| Darexaban 60 mg QD | | 0/137 (0)
| Darexaban 30 mg BID | | 0/137 (0)
| Darexaban 60 mg BID | | 0/138 (0)
| Darexaban 120 mg QD | | 0/141 (0)
Bailey 1991 1774568 | IPC (Mechanical) | Post-operative days | 0/50 (0%)
| Warfarin (VKA) | | 0/45 (0%)
Colwell 1994 8288662 | Enoxaparin 40 mg (LMWH) | Post-operative days | 0/203 (0%)
| Enoxaparin 30 mg (NA) | | 1/195 (0.5%)
| Heparin (UFH) | | 2/209 (1.0%)
Comp 2001 11263636 THR | Enoxaparin 7–10 days (NA) | 30 days | 0/211 (0%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | | 0/224 (0%)
Dahl 1997 9031444 | Dalteparin 35 days (NA) | 35 days | 1/134 (0.7%)
| Dalteparin 7 days (NA) | | 1/131 (0.8%)
Edwards 2008 18534421 THA | Enoxaparin + IPC (LMWH_Mechanical) | post-operative days | 0/65 (0%)
| Enoxaparin (LMWH) | | 0/59 (0%)
Eriksson 1991 2013587 | Dalteparin (LMWH) | Post-operative days | 0/67 (0%)
| Heparin (UFH) | | 1/69 (1.4%)
Eriksson 1996 8596376 | Desirudin (DTI) | 42 days | 0/202 (0%)
| Heparin (UFH) | | 1/229 (0.4%)
Eriksson 1997A 9070519 | Desirudin (DTI) | 42 days | 0/180 (0%)
| Heparin (UFH) | | 2/180 (1.1%)
Eriksson 1997B 9358126 | Desirudin (DTI) | 42 days | 4/802 (0.5%)
| Enoxaparin (LMWH) | | 1/785 (0.1%)
Eriksson 2007B 17869635 | Dabigatran 150mg (NA) | Post-operative days | 3/1156 (0.3%)
| Dabigatran 220mg (DTI) | | 3/1137 (0.3%)
| Enoxaparin (LMWH) | | 0/1142 (0%)
Eriksson 2011 21225098 | Dabigatran 220 mg (DTI) | 28–35 (during treatment period) days | 0/1001 (0%)
| Enoxaparin (LMWH) | | 1/992 (0.1%)
Francis 1992 1583760 | IPC (Mechanical) | Post-operative days | 1/98 (1.0%)
| Warfarin (VKA) | | 1/103 (1.0%)
Fuji 2014D 22952213 THA | Placebo (Placebo) | 10–14 (during treatment period) days | 0/163 (0%)
| Darexaban 15 mg BID (NA) | | 0/169 (0%)
| Darexaban 30 mg BID (FXaI) | | 0/174 (0%)
| Enoxaparin (LMWH) | | 0/103 (0%)
Hull 2000 10904464 | Warfarin (VKA) | Post-operative days | 0/489 (0%)
| Dalteparin preoperative (NA) | | 2/496 (0.4%)
| Dalteparin postoperative (LMWH) | | 0/487 (0%)
Kim 2016 26790579a | Placebo | 4 weeks post-treatment | 0/185 (0)
| Rivaroxaban | | 0/184 (0)
| Enoxaparin | | 0/184 (0)
Kim 2016 26790579b | Rivaroxaban | 4 weeks post-treatment | 0/166 (0)
| Enoxaparin | | 0/167 (0)
Lassen 1991 1848385 | Placebo (Placebo) | In-hospital days | 1/97 (1.0%)
| Tinzaparin (LMWH) | | 1/93 (1.1%)
Lassen 2002 12049858 | Fondaparinux (FXaI) | NR | 2/1140 (0.2%)
| Enoxaparin (LMWH) | | 4/1133 (0.4%)
Lassen 2012 22429800 THA | Semuloparin (NA) | 7–11 days | 1/1150 (0.1%)
| Enoxaparin (NA) | | 2/1152 (0.2%)
Levine 1991 1848054 | Heparin (UFH) | Post-operative days | 0/332 (0%)
| Enoxaparin (LMWH) | | 0/333 (0%)
Lieberman 1994 8126039 | Aspirin (Antiplatelet) | Post-operative days | 0/118 (0%)
| Aspirin+IPC (Antiplatelet_Mechanical) | | 1/113 (0.9%)
Planes 1988 2853459 | Heparin (UFH) | Post-operative days | 0/108 (0%)
| Enoxaparin (LMWH) | | 0/120 (0%)
Planes 1997 9048403 | Enoxaparin 21 days post-discharge (NA) | 35 days | 0/85 (0%)
| Enoxaparin to discharge (NA) | | 0/88 (0%)
Planès 1999 10348714 | Tinzaparin (NA) | Post-operative days | 0/251 (0%)
| Enoxaparin (NA) | | 1/248 (0.4%)
Samama 1997 9215015 | Placebo (Placebo) | 10 +/− 2 days | 0/84 (0%)
| Enoxaparin (LMWH) | | 0/85 (0%)
Santori 1994 8027144 | VFP (Mechanical) | 42 days | 0/67 (0%)
| Heparin (UFH) | | 1/65 (1.5%)
Schwartsmann 1996 Embase 1996366023 | Heparin (UFH) | Post-operative days | 0/47 (0%)
| Enoxaparin (LMWH) | | 0/52 (0%)
Senaran 2006 16333632 | Heparin (UFH) | 42 days | 0/50 (0%)
| Enoxaparin (LMWH) | | 0/50 (0%)
Sørensen 1990 1966794 | Placebo (Placebo) | Post-operative days | 1/33 (3.0%)
| Tinzaparin (LMWH) | | 1/31 (3.2%)
Stannard 1996 8640382 | VFP (PlexiPulse) (NA) | Post-operative days | 0/25 (0%)
| VFP (PlexiPulse)+ Heparin then Aspirin (NA) | | 0/25 (0%)
| Heparin then Aspirin (NA) | | 0/25 (0%)
Tørholm 1991 1670445 | Placebo (Placebo) | Post-operative days | 0/54 (0%)
| Dalteparin (LMWH) | | 1/58 (1.7%)
Turpie 1986 3531851 | Placebo (Placebo) | Post-operative days | 1/50 (2.0%)
| Enoxaparin (LMWH) | | 0/50 (0%)
Turpie 2002 12049860 | Fondaparinux (FXaI) | 49 days | 6/1128 (0.5%)
| Enoxaparin (LMWH) | | 3/1129 (0.3%)
Verhamme 2013 23615791 | TB-402 50 mg (FViiiI) | 35 days | 0/208 (0%)
| TB-402 25 mg (NA) | | 1/207 (0.5%)
| Rivaroxaban 10 mg (FXaI) | | 1/207 (0.5%)
Warwick 1998 9730125 | VFP (AV Impulse system) (Mechanical) | post-operative days | 0/147 (0%)
| Enoxaparin (LMWH) | | 0/143 (0%)
PE, Fatal
Anderson 2013 23732713 | Dalteparin (NA) | ~100 days | 0/398 (0%)
| Dalteparin then Aspirin (NA) | | 0/380 (0%)
Barre 1987 2834500 | Dalteparin (LMWH) | 60 days | 0/40 (0%)
| Heparin (UFH) | | 0/40 (0%)
Colwell 1994 8288662 | Enoxaparin 40 mg (LMWH) | Post-operative days | 0/203 (0%)
| Enoxaparin 30 mg (NA) | | 0/195 (0%)
| Heparin (UFH) | | 0/209 (0%)
Colwell 1999 10428124 | Warfarin (VKA) | 90 days | 0/1495 (0%)
| Enoxaparin (LMWH) | | 1/1516 (0.1%)
Colwell 2010 20194309 | Continuous Enhanced Circulation Therapy + Synchronized Flow Technology (Mechanical) | 10 days | 0/196 (0%)
| Enoxaparin (LMWH) | | 0/190 (0%)
Comp 2001 11263636 THR | Enoxaparin 7–10 days (NA) | 30 days | 0/211 (0%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | | 0/224 (0%)
Dahl 1997 9031444 | Dalteparin 35 days (NA) | 7–35 days | 0/111 (0%)
| Dalteparin 7 days (NA) | | 1/106 (0.9%)
Edwards 2008 18534421 THA | Enoxaparin + IPC (LMWH_Mechanical) | 90 days | 0/65 (0%)
| Enoxaparin (LMWH) | | 0/59 (0%)
Eriksson 1991 2013587 | Dalteparin (LMWH) | Post-operative days | 0/65 (0%)
| Heparin (UFH) | | 0/62 (0%)
Eriksson 1996 8596376 | Desirudin (DTI) | post-operative days | 0/202 (0%)
| Heparin (UFH) | | 0/229 (0%)
Eriksson 1997A 9070519 | Desirudin (DTI) | 42 days | 0/180 (0%)
| Heparin (UFH) | | 0/180 (0%)
Eriksson 1997B 9358126 | Desirudin (DTI) | Post-operative to 42 days | 1/802 (0.1%)
| Enoxaparin (LMWH) | | 0/785 (0%)
Eriksson 2007B 17869635 | Dabigatran 150mg (NA) | Post-operative days | 1/1156 (0.1%)
| Dabigatran 220mg (DTI) | | 0/1137 (0%)
| Enoxaparin (LMWH) | | 0/1142 (0%)
Eriksson 2010 20088935 | Darexaban 60 mg qD (FXaI) | 9 days | 0/120 (0%)
| Darexaban 5 mg (NA) | | 0/117 (0%)
| Enoxaparin 40 mg (LMWH) | | 0/127 (0%)
| Darexaban 120 mg (NA) | | 0/110 (0%)
| Darexaban 30 mg qD (NA) | | 0/114 (0%)
| Darexaban 10 mg (NA) | | 0/120 (0%)
Eriksson 2014 24136153 | Enoxaparin 40 mg qD (LMWH) | 12 days | 0/314 (0%)
| Darexaban 30 mg qD (NA) | | 0/293 (0%)
| Darexaban 60 mg qD (FXaI) | | 0/274 (0%)
| Darexaban 30 mg BID (NA) | | 0/296 (0%)
| Darexaban 15 mg BID (NA) | | 0/269 (0%)
Fuji 2014A 25047458 | Edoxaban 30 mg (FXaI) | 11–14 days | 0/72 (0%)
| Edoxaban 15 mg (NA) | | 0/78 (0%)
| Enoxaparin 20 mg BID (LMWH) | | 0/74 (0%)
Fuji 2015 26269694 | Edoxaban (FXaI) | 11–14 days | 0/255 (0%)
| Enoxaparin (LMWH) | | 0/248 (0%)
Hull 1993 8413432 THA | Tinzaparin (LMWH) | 90 days | 0/398 (0%)
| Warfarin (VKA) | | 0/397 (0%)
Hull 2000 10904464 | Warfarin (VKA) | post-operative days | 0/489 (0%)
| Dalteparin preoperative (NA) | | 0/496 (0%)
| Dalteparin postoperative (LMWH) | | 0/487 (0%)
Kim 2016 26790579a | Placebo | 2 days after treatment | 0/185 (0)
| Rivaroxaban | | 0/184 (0)
| Enoxaparin | | 0/184 (0)
Kim 2016 26790579a | Placebo | 4 weeks post-treatment | 0/185 (0)
| Rivaroxaban | | 0/184 (0)
| Enoxaparin | | 0/184 (0)
Kim 2016 26790579b | Rivaroxaban | 2 days after treatment | 0/166 (0)
| Enoxaparin | | 0/167 (0)
Kim 2016 26790579b | Rivaroxaban | 4 weeks post-treatment | 0/166 (0)
| Enoxaparin | | 0/167 (0)
Lassen 1991 1848385 | Placebo (Placebo) | Post-operative days | 0/97 (0%)
| Tinzaparin (LMWH) | | 0/93 (0%)
Lassen 2002 12049858 | Fondaparinux (FXaI) | 49 days | 0/1129 (0%)
| Enoxaparin (LMWH) | | 0/1123 (0%)
Lassen 2010A 21175312 | Apixaban (NA) | ~34 (on treatment) days | 1/2708 (0.04%)
| Enoxaparin (NA) | | 0/2699 (0%)
| Apixaban (FXaI) | ~94 (post-treatment) days | 1/2708 (0.04%)
| Enoxaparin (LMWH) | | 0/2699 (0%)
Levine 1991 1848054 | Heparin (UFH) | Post-operative days | 0/332 (0%)
| Enoxaparin (LMWH) | | 0/333 (0%)
Lieberman 1994 8126039 | Aspirin (Antiplatelet) | 90 days | 0/118 (0%)
| Aspirin+IPC (Antiplatelet_Mechanical) | | 0/113 (0%)
Nilsson 1997 9048404 | Enoxaparin 9 days (NA) | 30 days | 0/131 (0%)
| Enoxaparin 30 days (NA) | | 0/131 (0%)
Paiement 1987 3572408 | IPC (Mechanical) | Post-operative days | 0/66 (0%)
| Warfarin (VKA) | | 0/72 (0%)
Planes 1988 2853459 | Heparin (UFH) | Post-operative days | 0/108 (0%)
| Enoxaparin (LMWH) | | 0/120 (0%)
Planes 1997 9048403 | Enoxaparin 21 days post-discharge (NA) | 35 days | 0/85 (0%)
| Enoxaparin to discharge (NA) | | 0/88 (0%)
Planès 1999 10348714 | Tinzaparin (NA) | Post-operative days | 0/251 (0%)
| Enoxaparin (NA) | | 1/248 (0.4%)
Prandoni 2002 12230419 | Warfarin 28 days (NA) | 28 days | 0/184 (0%)
| Warfarin until hospital discharge (NA) | | 0/176 (0%)
Ryan 2002 12429761 | IPC (Venaflow) (NA) | post-operative days | 0/50 (0%)
| GCS (T.E.D.) (NA) | | 0/50 (0%)
Sakai 2016 26735531 | Edoxaban | 28 days | 0/62 (0)
| Edoxaban + foot pump | | 0/58 (0)
Samama 1997 9215015 | Placebo (Placebo) | 10 +/− 2 days | 0/84 (0%)
| Enoxaparin (LMWH) | | 0/85 (0%)
Schwartsmann 1996 Embase 1996366023 | Heparin (UFH) | Post-operative days | 0/47 (0%)
| Enoxaparin (LMWH) | | 0/52 (0%)
Senaran 2006 16333632 | Heparin (UFH) | 42 days | 0/50 (0%)
| Enoxaparin (LMWH) | | 0/50 (0%)
Turpie 1986 3531851 | Placebo (Placebo) | Post-operative days | 0/50 (0%)
| Enoxaparin (LMWH) | | 0/50 (0%)
Turpie 2002 12049860 | Fondaparinux (FXaI) | 49 days | 1/1126 (0.1%)
| Enoxaparin (LMWH) | | 2/1128 (0.2%)
Verhamme 2013 23615791 | TB-402 50 mg (FViiiI) | 35 days | 0/193 (0%)
| TB-402 25 mg (NA) | | 0/187 (0%)
| Rivaroxaban 10 mg (FXaI) | | 0/191 (0%)
Warwick 1998 9730125 | VFP (AV Impulse system) (Mechanical) | post-operative days | 0/136 (0%)
| Enoxaparin (LMWH) | | 0/138 (0%)
Yokote 2011 21282767 | Placebo (Placebo) | 11 days | 0/83 (0%)
| Fondaparinux (FXaI) | | 0/84 (0%)
| Enoxaparin (LMWH) | | 0/83 (0%)
PE, Symptomatic
Anderson 2013 23732713 | Dalteparin (NA) | ~100 days | 3/398 (0.8%)
| Dalteparin then Aspirin (NA) | | 0/380 (0%)
Borgen 2012 22476844 | Dalteparin (postop) (NA) | ~8 days | 1/40 (2.5%)
| Dalteparin (preop) (NA) | | 0/40 (0%)
Bramlage 2012 22713698 | Certoparin 3000 IU (NA) | 8–16 days | 2/193 (1.0%)
| Certoparin 5000 IU (NA) | | 0/205 (0%)
Colwell 2010 20194309 | Continuous Enhanced Circulation Therapy + Synchronized Flow Technology (NA) | 10 days | 2/196 (1.0%)
| Enoxaparin (NA) | | 2/190 (1.1%)
| Continuous Enhanced Circulation Therapy + Synchronized Flow Technology (Mechanical) | 3 months | 3/196 (1.5%)
| Enoxaparin (LMWH) | | 2/190 (1.1%)
Eriksson 2010 20088935 | Darexaban 60 mg qD (FXaI) | 9 days | 0/120 (0%)
| Darexaban 5 mg (NA) | | 0/117 (0%)
| Enoxaparin 40 mg (LMWH) | | 0/127 (0%)
| Darexaban 120 mg (NA) | | 0/110 (0%)
| Darexaban 30 mg qD (NA) | | 0/114 (0%)
| Darexaban 10 mg (NA) | | 0/120 (0%)
Fuji 2014A 25047458 | Edoxaban 30 mg (FXaI) | 11–14 days | 0/72 (0%)
| Edoxaban 15 mg (NA) | | 0/78 (0%)
| Enoxaparin 20 mg BID (LMWH) | | 0/74 (0%)
Fuji 2014D 22952213 THA | Placebo (Placebo) | 10–14 (during treatment period) days | 0/163 (0%)
| Darexaban 15 mg BID (NA) | | 0/169 (0%)
| Darexaban 30 mg BID (FXaI) | | 1/174 (0.6%)
| Enoxaparin (LMWH) | | 0/103 (0%)
Fuji 2015 26269694 | Edoxaban (FXaI) | 11–14 days | 0/255 (0%)
| Enoxaparin (LMWH) | | 0/248 (0%)
Kim 2016 26790579a | Placebo | 2 days after treatment | 1/185 (0.5)
| Rivaroxaban | | 1/184 (0.5)
| Enoxaparin | | 0/184 (0)
Kim 2016 26790579a | Placebo | 4 weeks post-treatment | 1/185 (0.5)
| Rivaroxaban | | 1/184 (0.5)
| Enoxaparin | | 0/184 (0)
Kim 2016 26790579b | Rivaroxaban | 2 days after treatment days | 1/166 (0.6)
| Enoxaparin | | 1/167 (0.6)
Kim 2016 26790579b | Rivaroxaban | 4 weeks post-treatment | 1/166 (0.6)
| Enoxaparin | | 1/167 (0.6)
Raskob 2010 20589317 | Edoxaban 90 mg (NA) | 7–10 days | 0/151 (0%)
| Edoxaban 60 mg (NA) | | 1/158 (0.6%)
| Edoxaban 30 mg (FXaI) | | 0/151 (0%)
| Edoxaban 15 mg (NA) | | 0/170 (0%)
| Dalteparin 5000 IU (LMWH) | | 0/144 (0%)
Sakai 2016 26735531 | Edoxaban | 28 days | 0/62 (0)
| Edoxaban + foot pump | | 0/58 (0)
Verhamme 2013 23615791 | TB-402 50 mg (FViiiI) | 35 days | 0/193 (0%)
| TB-402 25 mg (NA) | | 0/187 (0%)
| Rivaroxaban 10 mg (FXaI) | | 0/191 (0%)
PE, Total
2014 NCT00246025 | Dabigatran Etexilate 110 mg | 2 weeks (treatment period) | 0/133 (0)
| Dabigatran Etexilate 150 mg | | 0/126 (0)
| Dabigatran Etexilate 220 mg | | 0/129 (0)
Alfaro 1986 3535158 | Aspirin 125 mg (Antiplatelet) | Post-operative days | 0/30 (0%)
| Control (Placebo) | | 1/30 (3.3%)
| Aspirin 500 mg (NA) | | 0/30 (0%)
Andersen 1997 9690480 | Dalteparin 35 days (NA) | 35 days | 0/20 (0%)
| Dalteparin 5–7 days (NA) | | 1/21 (4.8%)
Avikainen 1995 7645915 | Heparin (UFH) | Post-operative days | 1/84 (1.2%)
| Enoxaparin (LMWH) | | 0/83 (0%)
Barre 1987 2834500 | Dalteparin (LMWH) | 60 days | 0/40 (0%)
| Heparin (UFH) | | 0/40 (0%)
Colwell 1994 8288662 | Enoxaparin 40 mg (NA) | Post-operative days | 0/203 (0%)
| Enoxaparin 30 mg (NA) | | 0/195 (0%)
| Heparin (NA) | | 1/209 (0.5%)
| Enoxaparin 40 mg (LMWH) | 42 days | 0/203 (0%)
| Enoxaparin 30 mg (NA) | | 0/195 (0%)
| Heparin (UFH) | | 4/209 (1.9%)
Colwell 1999 10428124 | Warfarin (VKA) | 90 days | 12/1495 (0.8%)
| Enoxaparin (LMWH) | | 15/1516 (1.0%)
Comp 2001 11263636 THR | Enoxaparin 7–10 days (NA) | 30 days | 1/211 (0.5%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | | 0/224 (0%)
Dahl 1997 9031444 | Dalteparin 35 days (NA) | 7–35 days | 4/111 (3.6%)
| Dalteparin 7 days (NA) | | 7/106 (6.6%)
Edwards 2008 18534421 THA | Enoxaparin + IPC (LMWH_Mechanical) | 90 days | 0/65 (0%)
| Enoxaparin (LMWH) | | 0/59 (0%)
Eriksson 1991 2013587 | Dalteparin (LMWH) | Post-operative days | 8/65 (12%)
| Heparin (UFH) | | 19/62 (31%)
Eriksson 1996 8596376 | Desirudin (DTI) | post-operative days | 1/202 (0.5%)
| Heparin (UFH) | | 0/229 (0%)
Eriksson 1997A 9070519 | Desirudin (DTI) | 42 days | 0/180 (0%)
| Heparin (UFH) | | 4/180 (2.2%)
Eriksson 1997B 9358126 | Desirudin (NA) | Post-operative days | 2/802 (0.2%)
| Enoxaparin (NA) | | 2/785 (0.3%)
| Desirudin (DTI) | 42 days | 3/802 (0.4%)
| Enoxaparin (LMWH) | | 7/785 (0.9%)
Eriksson 2007B 17869635 | Dabigatran 150mg (NA) | Post-operative days | 1/1156 (0.1%)
| Dabigatran 220mg (DTI) | | 5/1137 (0.4%)
| Enoxaparin (LMWH) | | 3/1142 (0.3%)
Fuji 2008 18843459 THA | Placebo (Placebo) | post-operative years | 0/86 (0%)
| Enoxaparin 40 mg (LMWH) | | 1/80 (1.3%)
| Enoxaparin 20 mg (NA) | | 0/90 (0%)
Hull 1993 8413432 THA | Tinzaparin (LMWH) | 90 days | 1/398 (0.3%)
| Warfarin (VKA) | | 0/397 (0%)
Hull 2000 10904464 | Warfarin (VKA) | post-operative days | 0/489 (0%)
| Dalteparin preoperative (NA) | | 0/496 (0%)
| Dalteparin postoperative (LMWH) | | 0/487 (0%)
Lassen 1991 1848385 | Placebo (Placebo) | Post-operative days | 1/97 (1.0%)
| Tinzaparin (LMWH) | | 1/93 (1.1%)
Lassen 2002 12049858 | Fondaparinux (FXaI) | 49 days | 2/1129 (0.2%)
| Enoxaparin (LMWH) | | 2/1123 (0.2%)
Lassen 2010A 21175312 | Apixaban (NA) | ~34 (on treatment) days | 3/2708 (0.1%)
| Enoxaparin (NA) | | 5/2699 (0.2%)
| Apixaban (FXaI) | ~94 (post-treatment) days | 3/2708 (0.1%)
| Enoxaparin (LMWH) | | 9/2699 (0.3%)
Levine 1991 1848054 | Heparin (UFH) | Post-operative days | 2/332 (0.6%)
| Enoxaparin (LMWH) | | 0/333 (0%)
Lieberman 1994 8126039 | Aspirin (Antiplatelet) | 90 days | 1/118 (0.8%)
| Aspirin+IPC (Antiplatelet_Mechanical) | | 1/113 (0.9%)
Nilsson 1997 9048404 | Enoxaparin 9 days (NA) | 30 days | 2/131 (1.5%)
| Enoxaparin 30 days (NA) | | 0/131 (0%)
Paiement 1987 3572408 | IPC (Mechanical) | Post-operative days | 0/66 (0%)
| Warfarin (VKA) | | 0/72 (0%)
Planes 1988 2853459 | Heparin (UFH) | Post-operative days | 1/108 (0.9%)
| Enoxaparin (LMWH) | | 0/120 (0%)
Planes 1997 9048403 | Enoxaparin 21 days post-discharge (NA) | 35 days | 0/85 (0%)
| Enoxaparin to discharge (NA) | | 0/88 (0%)
Planès 1999 10348714 | Tinzaparin (NA) | Post-operative days | 1/251 (0.4%)
| Enoxaparin (NA) | | 2/248 (0.8%)
Prandoni 2002 12230419 | Warfarin 28 days (NA) | 28 days | 0/184 (0%)
| Warfarin until hospital discharge (NA) | | 1/176 (0.6%)
Ryan 2002 12429761 | IPC (Venaflow) (NA) | post-operative days | 0/50 (0%)
| GCS (T.E.D.) (NA) | | 0/50 (0%)
Sakai 2016 26735531 | Edoxaban | 28 days | 0/62 (0)
| Edoxaban + foot pump | | 0/58 (0)
Samama 1997 9215015 | Placebo (Placebo) | 10 +/− 2 days | 0/84 (0%)
| Enoxaparin (LMWH) | | 0/85 (0%)
Schwartsmann 1996 Embase 1996366023 | Heparin (UFH) | Post-operative days | 0/47 (0%)
| Enoxaparin (LMWH) | | 0/52 (0%)
Senaran 2006 16333632 | Heparin (UFH) | 42 days | 0/50 (0%)
| Enoxaparin (LMWH) | | 0/50 (0%)
Turpie 1986 3531851 | Placebo (Placebo) | Post-operative days | 1/50 (2.0%)
| Enoxaparin (LMWH) | | 0/50 (0%)
Turpie 2002 12049860 | Fondaparinux (FXaI) | 49 days | 12/1126 (1.1%)
| Enoxaparin (LMWH) | | 4/1128 (0.4%)
Warwick 1995 7559695 | Control (Placebo) | Post-operative days | 2/78 (2.6%)
| Enoxaparin (LMWH) | | 1/78 (1.3%)
Warwick 1998 9730125 | VFP (AV Impulse system) (Mechanical) | post-operative days | 1/136 (0.7%)
| Enoxaparin (LMWH) | | 0/138 (0%)
Welin-Berger 1982 6184938 | Heparin (UFH) | Post-operative days | 0/20 (0%)
| Control (Placebo) | | 1/20 (5.0%)
Woolson 1991 2013589 | IPC+ Aspirin (Antiplatelet_Mechanical) | Post-operative days | 1/70 (1.4%)
| IPC (Mechanical) | | 0/73 (0%)
| IPC+ wafarin (VKA_Mechanical) | | 0/69 (0%)
Yokote 2011 21282767 | Placebo (Placebo) | 11 days | 0/83 (0%)
| Fondaparinux (FXaI) | | 0/84 (0%)
| Enoxaparin (LMWH) | | 0/83 (0%)
Return to OR, bleeding or infection (combined)
Andersen 1997 9690480 | Dalteparin 35 days (NA) | 35 days | 0/20 (0%)
| Dalteparin 5–7 days (NA) | | 2/21 (10%)
VTE, Symptomatic
Anderson 2013 23732713 | Dalteparin (NA) | ~100 days | 6/398 (1.5%)
| Dalteparin then Aspirin (NA) | | 1/380 (0.3%)
Colwell 1999 10428124 | Warfarin (VKA) | 90 days | 56/1495 (3.7%)
| Enoxaparin (LMWH) | | 55/1516 (3.6%)
Comp 2001 11263636 THR | Enoxaparin 7–10 days (NA) | 30 days | 49/211 (23%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | | 18/224 (8.0%)
Eriksson 2010 20088935 | Darexaban 60 mg qD (FXaI) | 9 days | 1/120 (0.8%)
| Darexaban 5 mg (NA) | | 1/117 (0.9%)
| Enoxaparin 40 mg (LMWH) | | 0/127 (0%)
| Darexaban 120 mg (NA) | | 1/110 (0.9%)
| Darexaban 30 mg qD (NA) | | 0/114 (0%)
| Darexaban 10 mg (NA) | | 1/120 (0.8%)
Eriksson 2011 21225098 | Dabigatran 220 mg (NA) | 28–35 (during treatment period) days | 1/1001 (0.1%)
| Enoxaparin (NA) | | 6/992 (0.6%)
| Dabigatran 220 mg (DTI) | 3 (treatment + follow-up) months | 3/1001 (0.3%)
| Enoxaparin (LMWH) | | 8/992 (0.8%)
Fuji 2014A 25047458 | Edoxaban 30 mg (FXaI) | 11–14 days | 0/72 (0%)
| Edoxaban 15 mg (NA) | | 0/78 (0%)
| Enoxaparin 20 mg BID (LMWH) | | 0/74 (0%)
Fuji 2015 26269694 | Edoxaban (FXaI) | 11–14 days | 0/255 (0%)
| Enoxaparin (LMWH) | | 0/248 (0%)
Hull 1993 8413432 THA | Tinzaparin (LMWH) | 90 days | 6/398 (1.5%)
| Warfarin (VKA) | | 2/397 (0.5%)
Lassen 2002 12049858 | Fondaparinux (FXaI) | 49 days | 12/1129 (1.1%)
| Enoxaparin (LMWH) | | 9/1123 (0.8%)
Nilsson 1997 9048404 | Enoxaparin 9 days (NA) | 30 days | 10/131 (7.6%)
| Enoxaparin 30 days (NA) | | 2/131 (1.5%)
Prandoni 2002 12230419 | Warfarin 28 days (NA) | 90 days | 3/184 (1.6%)
| Warfarin until hospital discharge (NA) | | 9/176 (5.1%)
Sakai 2016 26735531 | Edoxaban | 28 days | 1/62 (1.6)
| Edoxaban + foot pump | | 3/58 (5.2)
Senaran 2006 16333632 | Heparin (UFH) | 42 days | 2/50 (4.0%)
| Enoxaparin (LMWH) | | 2/50 (4.0%)
| Heparin (NA) | post-operative until discharge days | 2/50 (4.0%)
| Enoxaparin (NA) | | 0/50 (0%)
Turpie 2002 12049860 | Fondaparinux (FXaI) | 49 days | 29/1126 (2.6%)
| Enoxaparin (LMWH) | | 13/1128 (1.2%)
Verhamme 2013 23615791 | TB-402 50 mg (FViiiI) | 35 days | 0/193 (0%)
| TB-402 25 mg (NA) | | 0/187 (0%)
| Rivaroxaban 10 mg (FXaI) | | 0/191 (0%)
Yokote 2011 21282767 | Placebo (Placebo) | 11 days | 0/83 (0%)
| Fondaparinux (FXaI) | | 1/84 (1.2%)
| Enoxaparin (LMWH) | | 0/83 (0%)
VTE, Total
2013 NCT00595426 | Wafarin | 14 days (treatment duration) | 24/133 (18)
| Darexaban 60 mg QD | | 12/137 (8.8)
| Darexaban 30 mg BID | | 21/137 (15.3)
| Darexaban 60 mg BID | | 9/138 (6.5)
| Darexaban 120 mg QD | | 9/141 (6.4)
Colwell 2010 20194309 | Continuous Enhanced Circulation Therapy + Synchronized Flow Technology (Mechanical) | 3 months | 10/196 (5.1%)
| Enoxaparin (LMWH) | | 10/190 (5.3%)
Eriksson 2010 20088935 | Darexaban 60 mg qD (FXaI) | 9 days | 16/120 (13%)
| Darexaban 5 mg (NA) | | 32/117 (27%)
| Enoxaparin 40 mg (LMWH) | | 24/127 (19%)
| Darexaban 120 mg (NA) | | 15/110 (14%)
| Darexaban 30 mg qD (NA) | | 22/114 (19%)
| Darexaban 10 mg (NA) | | 38/120 (32%)
Eriksson 2014 24136153 | Enoxaparin 40 mg qD (LMWH) | 12 days | 48/314 (15%)
| Darexaban 30 mg qD (NA) | | 39/293 (13%)
| Darexaban 60 mg qD (FXaI) | | 36/274 (13%)
| Darexaban 30 mg BID (NA) | | 33/296 (11%)
| Darexaban 15 mg BID (NA) | | 42/269 (16%)
Fuji 2014A 25047458 | Edoxaban 30 mg (FXaI) | 11–14 days | 2/72 (2.8%)
| Edoxaban 15 mg (NA) | | 3/78 (3.8%)
| Enoxaparin 20 mg BID (LMWH) | | 3/74 (4.1%)
Fuji 2014D 22952213 THA | Placebo (Placebo) | 10–14 (during treatment period) days | 22/129 (17%)
| Darexaban 15 mg BID (NA) | | 4/136 (2.9%)
| Darexaban 30 mg BID (FXaI) | | 7/134 (5.2%)
| Enoxaparin (LMWH) | | 2/82 (2.4%)
Fuji 2015 26269694 | Edoxaban (FXaI) | 11–14 days | 6/255 (2.4%)
| Enoxaparin (LMWH) | | 17/248 (6.9%)
Lassen 2010A 21175312 | Apixaban (FXaI) | ~34 (on treatment) days | 10/2199 (0.5%)
| Enoxaparin (LMWH) | | 25/2195 (1.1%)
Raskob 2010 20589317 | Edoxaban 90 mg (NA) | 7–10 days | 16/151 (11%)
| Edoxaban 60 mg (NA) | | 24/158 (15%)
| Edoxaban 30 mg (FXaI) | | 32/151 (21%)
| Edoxaban 15 mg (NA) | | 48/170 (28%)
| Dalteparin 5000 IU (LMWH) | | 63/144 (44%)
Sakai 2016 26735531 | Edoxaban | 28 days | 11/62 (17.7)
| Edoxaban + foot pump | | 18/58 (31)
Verhamme 2013 23615791 | TB-402 50 mg (FViiiI) | 35 days | 10/193 (5.2%)
| TB-402 25 mg (NA) | | 10/187 (5.3%)
| Rivaroxaban 10 mg (FXaI) | | 9/191 (4.7%)

Table F2 RCT total knee replacement

Study | Arm | Timepoint | n/N (%)
Adherent/Compliant
Choi 2015 24408881 | Pneumatic compression with adjusted cycling rate (NA) | 16.4 (full hospitalization) days | 27/27 (100%)
| Pneumatic compression with fixed cycling rate (NA) | | 27/27 (100%)
Bleeding, Fatal
Bauer 2001 11794149 | Fondaparinux (FXaI) | 11 days | 0/517 (0%)
| Enoxaparin (LMWH) | | 0/517 (0%)
Cho 2013 23381297 | Placebo (Placebo) | 90 days | 0/74 (0%)
| Fondaparinux (FXaI) | | 0/74 (0%)
Comp 2001 11263636 TKR | Enoxaparin 7–10 days (NA) | 30 days | 0/221 (0%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | | 0/217 (0%)
Edwards 2008 18534421 TKA | Enoxaparin + IPC (LMWH_Mechanical) | post-operative days | 0/76 (0%)
| Enoxaparin (LMWH) | | 0/77 (0%)
Eriksson 2007A 17764540 | Dabigatran 150 mg (NA) | 90 days | 0/703 (0%)
| Enoxaparin (LMWH) | | 0/694 (0%)
| Dabigatran 220 mg (DTI) | | 0/679 (0%)
Fitzgerald 2001 11407799 | Warfarin (VKA) | post-operative days | 1/176 (0.6%)
| Enoxaparin (LMWH) | | 0/173 (0%)
Fuji 2010A 19854610 | Dabigatran 150 mg (NA) | post-operative days | 0/126 (0%)
| Placebo (Placebo) | | 0/124 (0%)
| Dabigatran 220 mg (DTI) | | 0/129 (0%)
Ginsberg 2009 18534438 | Dabigatran 150 mg (NA) | post-operative years | 0/871 (0%)
| Enoxaparin (LMWH) | | 0/868 (0%)
| Dabigatran 220 mg (DTI) | | 0/857 (0%)
Hull 1993 8413432 TKA | Tinzaparin (LMWH) | Post-operative days | 0/317 (0%)
| Warfarin (VKA) | | 0/324 (0%)
Lachiewicz 2004 15568526 | IPC (Venaflow) (NA) | post-operative days | 0/206 (0%)
| IPC (Kendal) (NA) | | 0/217 (0%)
Lassen 2012 22429800 TKA | Semuloparin (NA) | period from the first injection given during the study up to the last injection plus 3 calendar days days days | 0/573 (0%)
| Enoxaparin (NA) | | 0/568 (0%)
Leclerc 1996 8607589 | Warfarin (VKA) | Post-operative days | 0/334 (0%)
| Enoxaparin (LMWH) | | 0/336 (0%)
McKenna 1980 6989432 | Placebo (Placebo) | Post-operative days | 0/12 (0%)
| Aspirin (Antiplatelet) | | 0/9 (0%)
Warwick 2002 12002490 | VFP (AV Impulse system) (Mechanical) | post-operative days | 0/117 (0%)
| Enoxaparin (LMWH) | | 0/112 (0%)
Bleeding, Leading to reoperation
Bauer 2001 11794149 | Fondaparinux (FXaI) | 11 days | 2/517 (0.4%)
| Enoxaparin (LMWH) | | 1/517 (0.2%)
Cho 2013 23381297 | Placebo (Placebo) | 90 days | 0/74 (0%)
| Fondaparinux (FXaI) | | 0/74 (0%)
Eriksson 2007A 17764540 | Dabigatran 150 mg (NA) | 90 days | 1/703 (0.1%)
| Enoxaparin (LMWH) | | 1/694 (0.1%)
| Dabigatran 220 mg (DTI) | | 3/679 (0.4%)
Fitzgerald 2001 11407799 | Warfarin (VKA) | post-operative days | 0/176 (0%)
| Enoxaparin (LMWH) | | 0/173 (0%)
Fuji 2010A 19854610 | Dabigatran 150 mg (NA) | post-operative days | 0/126 (0%)
| Placebo (Placebo) | | 0/124 (0%)
| Dabigatran 220 mg (DTI) | | 1/129 (0.8%)
Ginsberg 2009 18534438 | Dabigatran 150 mg (NA) | post-operative years | 0/871 (0%)
| Enoxaparin (NA) | | 1/868 (0.1%)
| Dabigatran 220 mg (NA) | | 0/857 (0%)
Bleeding, Major
Barrellier 2010 20797774 | Anticoagulation (mixed) 35+−5 days (NA) | ~35 days | 3/422 (0.7%)
| Anticoagulation (mixed) 10+−2 days (NA) | | 2/420 (0.5%)
| Anticoagulation (mixed) 35+−5 days (NA) | 3 months | 3/422 (0.7%)
| Anticoagulation (mixed) 10+−2 days (NA) | | 3/420 (0.7%)
Bauer 2001 11794149 | Fondaparinux (FXaI) | 11 days | 11/517 (2.1%)
| Enoxaparin (LMWH) | | 1/517 (0.2%)
Büller 2015 25482425 | FXI-ASO 300 (NA) | ~3 months | 1/77 (1.3%)
| Enoxaparin (LMWH) | | 0/72 (0%)
| FXI-ASO 200 (FXiI) | | 0/144 (0%)
Cho 2013 23381297 | Placebo (Placebo) | 90 days | 0/74 (0%)
| Fondaparinux (FXaI) | | 0/74 (0%)
Cohen 2013 23782955 | Eribaxaban 1 mg (FXaI) | ~10 days | 1/202 (0.5%)
| Enoxaparin 30 mg BID (LMWH) | | 3/397 (0.8%)
| Eribaxaban 2.5 mg (NA) | | 1/200 (0.5%)
| Eribaxaban 10 mg (NA) | | 1/65 (1.5%)
| Eribaxaban 0.1 mg (NA) | | 0/61 (0%)
| Eribaxaban 4 mg (NA) | | 0/140 (0%)
| Eribaxaban 0.5 mg (NA) | | 2/183 (1.1%)
| Eribaxaban 0.3 mg (NA) | | 0/141 (0%)
Colwell 1995 7497668 | Heparin (UFH) | Post-operative days | 3/225 (1.3%)
| Enoxaparin (LMWH) | | 3/228 (1.3%)
Comp 2001 11263636 TKR | Enoxaparin 7–10 days (NA) | 30 days | 1/221 (0.5%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | | 0/217 (0%)
Eriksson 2005 15634273 TKA | Dabigatran 150 mg (DTI) | post-operative years | 6/124 (4.8%)
| Dabigatran 300 mg (NA) | | 6/127 (4.7%)
| Enoxaprin (LMWH) | | 2/122 (1.6%)
| Dabigatran 50 mg (NA) | | 1/124 (0.8%)
| Dabigatran 225 mg (NA) | | 3/123 (2.4%)
Eriksson 2007A 17764540 | Dabigatran 150 mg (NA) | 90 days | 9/703 (1.3%)
| Enoxaparin (LMWH) | | 9/694 (1.3%)
| Dabigatran 220 mg (DTI) | | 10/679 (1.5%)
Fitzgerald 2001 11407799 | Warfarin (VKA) | post-operative days | 4/176 (2.3%)
| Enoxaparin (LMWH) | | 9/173 (5.2%)
Fuji 2008 18843459 TKA | Placebo (Placebo) | post-operative years | 4/89 (4.5%)
| Enoxaparin 40 mg (LMWH) | | 1/91 (1.1%)
| Enoxaparin 20 mg (NA) | | 3/95 (3.2%)
Fuji 2010A 19854610 | Dabigatran 150 mg (NA) | post-operative days | 0/126 (0%)
| Placebo (Placebo) | | 1/124 (0.8%)
| Dabigatran 220 mg (DTI) | | 3/129 (2.3%)
Fuji 2010B 20723033 | Placebo (Placebo) | 11–14 days | 0/102 (0%)
| Edoxaban 60 mg (NA) | | 1/106 (0.9%)
| Edoxaban 30 mg (FXaI) | | 0/103 (0%)
| Edoxaban 15 mg (NA) | | 0/106 (0%)
| Edoxaban 5 mg (NA) | | 0/103 (0%)
Fuji 2014C 25294589 | Edoxaban (FXaI) | 11–14 days | 4/354 (1.1%)
| Enoxaparin (LMWH) | | 1/349 (0.3%)
Fuji 2014D 22952213 TKA | Placebo (NA) | 10–14 (during treatment period) days | 0/96 (0%)
| Darexaban 15 mg BID (NA) | | 0/92 (0%)
| Darexaban 30 mg BID (NA) | | 1/88 (1.1%)
| Enoxaparin (NA) | | 0/90 (0%)
| Placebo (Placebo) | 3–5 weeks after the last dose (till study ended) weeks | 0/96 (0%)
| Darexaban 15 mg BID (NA) | | 0/92 (0%)
| Darexaban 30 mg BID (FXaI) | | 1/88 (1.1%)
| Enoxaparin (LMWH) | | 0/90 (0%)
Ginsberg 2009 18534438 | Dabigatran 150 mg (NA) | post study period to 90 days | 2/871 (0.2%)
| Enoxaparin (NA) | | 0/868 (0%)
| Dabigatran 220 mg (NA) | | 1/857 (0.1%)
| Dabigatran 150 mg (NA) | post-operative (in study period) days | 5/871 (0.6%)
| Enoxaparin (LMWH) | | 12/868 (1.4%)
| Dabigatran 220 mg (DTI) | | 5/857 (0.6%)
Hull 1993 8413432 TKA | Tinzaparin (LMWH) | Post-operative days | 9/317 (2.8%)
| Warfarin (VKA) | | 3/324 (0.9%)
Iliopoulos 2011 Abstract P104 | Dabigatran 110 mg (DTI) | 5 days | 0/40 (0%)
| Tinzaparin (NA) | | 0/40 (0%)
| Fondaparinux (FXaI) | | 0/40 (0%)
| Enoxaparin (LMWH) | | 0/40 (0%)
Lassen 2007 17868430 | Warfarin (VKA) | Post-operative years | 0/151 (0%)
| Enoxaparin (LMWH) | | 0/149 (0%)
Lassen 2010B 20206776 | Apixaban (FXaI) | NR | 9/1501 (0.6%)
| Enoxaparin (LMWH) | | 14/1508 (0.9%)
Lassen 2012 22429800 TKA | Semuloparin (NA) | period from the first injection given during the study up to the last injection plus 3 calendar days days days | 3/573 (0.5%)
| Enoxaparin (NA) | | 4/568 (0.7%)
Leclerc 1996 8607589 | Warfarin (VKA) | Post-operative days | 6/334 (1.8%)
| Enoxaparin (LMWH) | | 7/336 (2.1%)
Mirdamadi 2014 25815018 | Dabigatran 225 mg (DTI) | 15 days | 3/45 (6.7%)
| Enoxaparin (LMWH) | | 2/45 (4.4%)
Verhamme 2011 21284801 | Enoxaparin then TB-402 0.3 mg/kg (NA) | 90 days | 0/75 (0%)
| Enoxaparin then TB-402 0.6 mg/kg (NA) | | 1/74 (1.4%)
| Enoxaparin then TB-402 1.2 mg/kg (NA) | | 4/87 (4.6%)
| Enoxaparin (NA) | | 0/79 (0%)
Weitz 2010 20886185 | TAK-442 40 qD (NA) | 10 days | 0/162 (0%)
| TAK-442 40 BID (FXaI) | | 2/162 (1.2%)
| TAK-442 80 BID (NA) | | 0/161 (0%)
| TAK-442 10 (NA) | | 0/104 (0%)
| TAK-442 20 (NA) | | 1/128 (0.8%)
| TAK-442 80 qD (NA) | | 1/160 (0.6%)
| Enoxaparin (LMWH) | | 3/161 (1.9%)
Westrich 1996 8666599 | Aspirin (NA) | Post-operative days | 0/61 (0%)
| Aspirin+ VFP (NA) | | 0/61 (0%)
Bleeding, Surgical site/joint
Colwell 1995 7497668 | Heparin (UFH) | Post-operative days | 5/225 (2.2%)
| Enoxaparin (LMWH) | | 9/228 (3.9%)
Fitzgerald 2001 11407799 | Warfarin (VKA) | Post-operative days | 6/176 (3.4%)
| Enoxaparin (LMWH) | | 12/173 (6.9%)
Fuji 2014C 25294589 | Edoxaban (FXaI) | 11–14 days | 6/354 (1.7%)
| Enoxaparin (LMWH) | | 2/349 (0.6%)
Ginsberg 2009 18534438 | Dabigatran 150 mg (NA) | post-operative years | 3/871 (0.3%)
| Enoxaparin (LMWH) | | 11/868 (1.3%)
| Dabigatran 220 mg (DTI) | | 2/857 (0.2%)
Lassen 2010B 20206776 | Apixaban (FXaI) | nd days | 8/1501 (0.5%)
| Enoxaparin (LMWH) | | 11/1508 (0.7%)
DVT, Proximal
Barrellier 2010 20797774 | Anticoagulation (mixed) 35+−5 days (NA) | ~35 days | 4/422 (0.9%)
| Anticoagulation (mixed) 10+−2 days (NA) | | 6/420 (1.4%)
| Anticoagulation (mixed) 35+−5 days (NA) | 3 months | 4/422 (0.9%)
| Anticoagulation (mixed) 10+−2 days (NA) | | 6/420 (1.4%)
Bauer 2001 11794149 | Fondaparinux (FXaI) | 11 days | 9/368 (2.4%)
| Enoxaparin (LMWH) | | 20/372 (5.4%)
Büller 2015 25482425 | FXI-ASO 300 (NA) | ~12 days | 1/71 (1.4%)
| Enoxaparin (LMWH) | | 5/71 (7.0%)
| FXI-ASO 200 (FXiI) | | 7/139 (5.0%)
Chin 2009 19398783 | Control (Placebo) | Post-operative days | 3/110 (2.7%)
| Enoxaparin (LMWH) | | 1/110 (0.9%)
Cho 2013 23381297 | Placebo (NA) | 7 days | 4/74 (5.4%)
| Fondaparinux (NA) | | 1/74 (1.4%)
| Placebo (Placebo) | 90 days | 4/74 (5.4%)
| Fondaparinux (FXaI) | | 1/74 (1.4%)
Choi 2015 24408881 | Pneumatic compression with adjusted cycling rate (NA) | 5 days | 1/27 (3.7%)
| Pneumatic compression with fixed cycling rate (NA) | | 1/27 (3.7%)
Cohen 2013 23782955 | Eribaxaban 1 mg (FXaI) | ~10 days | 4/120 (3.3%)
| Enoxaparin 30 mg BID (LMWH) | | 4/188 (2.1%)
| Eribaxaban 2.5 mg (NA) | | 2/112 (1.8%)
| Eribaxaban 10 mg (NA) | | 1/27 (3.7%)
| Eribaxaban 0.1 mg (NA) | | 2/35 (5.7%)
| Eribaxaban 4 mg (NA) | | 0/74 (0%)
| Eribaxaban 0.5 mg (NA) | | 4/104 (3.8%)
| Eribaxaban 0.3 mg (NA) | | 3/89 (3.4%)
| Eribaxaban 1 mg (FXaI) | ~40 days | 4/120 (3.3%)
| Enoxaparin 30 mg BID (LMWH) | | 5/188 (2.7%)
| Eribaxaban 2.5 mg (NA) | | 2/112 (1.8%)
| Eribaxaban 10 mg (NA) | | 1/27 (3.7%)
| Eribaxaban 0.1 mg (NA) | | 2/35 (5.7%)
| Eribaxaban 4 mg (NA) | | 0/74 (0%)
| Eribaxaban 0.5 mg (NA) | | 4/104 (3.8%)
| Eribaxaban 0.3 mg (NA) | | 3/89 (3.4%)
Colwell 1995 7497668 | Heparin (UFH) | Post-operative days | 22/225 (10%)
| Enoxaparin (LMWH) | | 5/228 (2.2%)
Comp 2001 11263636 TKR | Enoxaparin 7–10 days (NA) | 30 days | 17/221 (7.7%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | | 9/217 (4.1%)
Edwards 2008 18534421 TKA | Enoxaparin + IPC (LMWH_Mechanical) | post-operative days | 0/76 (0%)
| Enoxaparin (LMWH) | | 0/77 (0%)
Eriksson 2005 15634273 TKA | Dabigatran 150 mg (DTI) | post-operative years | 1/81 (1.2%)
| Dabigatran 300 mg (NA) | | 3/92 (3.3%)
| Enoxaprin (LMWH) | | 6/92 (6.5%)
| Dabigatran 50 mg (NA) | | 3/94 (3.2%)
| Dabigatran 225 mg (NA) | | 1/93 (1.1%)
Faunø 1994 7989386 | Heparin (UFH) | Post-operative days | 5/93 (5.4%)
| Enoxaparin (LMWH) | | 3/92 (3.3%)
Fitzgerald 2001 11407799 | Warfarin (VKA) | post-operative days | 20/176 (11%)
| Enoxaparin (LMWH) | | 3/173 (1.7%)
Fuji 2008 18843459 TKA | Placebo (Placebo) | post-operative years | 6/79 (7.6%)
| Enoxaparin 40 mg (LMWH) | | 3/74 (4.1%)
| Enoxaparin 20 mg (NA) | | 0/84 (0%)
Fuji 2010A 19854610 | Dabigatran 150 mg (NA) | post-operative days | 2/113 (1.8%)
| Placebo (Placebo) | | 6/104 (5.8%)
| Dabigatran 220 mg (DTI) | | 0/102 (0%)
Fuji 2010B 20723033 | Edoxaban 60 mg (NA) | 11–14 days | 1/88 (1.1%)
| Edoxaban 30 mg (NA) | | 1/88 (1.1%)
| Edoxaban 15 mg (NA) | | 0/92 (0%)
| Edoxaban 5 mg (NA) | | 0/87 (0%)
Fuji 2014C 25294589 | Edoxaban (FXaI) | 11–14 days | 0/299 (0%)
| Enoxaparin (LMWH) | | 1/295 (0.3%)
Fuji 2014D 22952213 TKA | Placebo (Placebo) | 10–14 (during treatment period) days | 3/70 (4.3%)
| Darexaban 15 mg BID (NA) | | 5/83 (6.0%)
| Darexaban 30 mg BID (FXaI) | | 1/74 (1.4%)
| Enoxaparin (LMWH) | | 1/74 (1.4%)
Ginsberg 2009 18534438 | Dabigatran 150 mg (NA) | post-operative years | 20/649 (3.1%)
| Enoxaparin (LMWH) | | 10/643 (1.6%)
| Dabigatran 220 mg (DTI) | | 14/604 (2.3%)
Haas 1990 2404020 | Aspirin (Antiplatelet) | Post-operative days | 1/58 (1.7%)
| IPC (Mechanical) | | 2/61 (3.3%)
Hull 1993 8413432 TKA | Tinzaparin (LMWH) | Post-operative days | 20/258 (7.8%)
| Warfarin (VKA) | | 34/277 (12%)
Jiang 2014 24931228 | Aspirin (NA) | 5 days | 1/60 (1.7%)
| LMWH then rivaroxaban (NA) | | 1/60 (1.7%)
Koo 2014 25436073 | alternate sequential compression device (SCD Express) (NA) | 4 days | 0/13 (0%)
| simultaneous sequential compression device (DVT-3000) (NA) | | 0/11 (0%)
Lachiewicz 2004 15568526 | IPC (Venaflow) (NA) | post-operative days | 1/232 (0.4%)
| IPC (Kendal) (NA) | | 6/240 (2.5%)
Lassen 2007 17868430 | Warfarin (VKA) | Post-operative years | 2/109 (1.8%)
| Enoxaparin (LMWH) | | 1/109 (0.9%)
Lassen 2012 22429800 TKA | Semuloparin (NA) | 7–11 days | 17/483 (3.5%)
| Enoxaparin (NA) | | 10/487 (2.1%)
Leclerc 1996 8607589 | Warfarin (VKA) | Post-operative days | 22/334 (6.6%)
| Enoxaparin (LMWH) | | 24/336 (7.1%)
Lotke 1996 8595765 TKA | Aspirin (Antiplatelet) | Post-operative days days | 13/114 (11%)
| Warfarin (VKA) | | 8/75 (11%)
McKenna 1980 6989432 | Placebo (Placebo) | Post-operative days | 5/12 (42%)
| Aspirin (Antiplatelet) | | 3/9 (33%)
Silbersack 2004 15330019 TKA | Enoxaparin + GCS (Comprinet Pro) (NA) | 6th−12th post-operative days | 1/35 (2.9%)
| Enoxaparin + IPC (Venaflow) (NA) | | 0/35 (0%)
Verhamme 2011 21284801 | Enoxaparin then TB-402 0.3 mg/kg (NA) | 7–11 days | 1/72 (1.4%)
| Enoxaparin then TB-402 0.6 mg/kg (NA) | | 0/67 (0%)
| Enoxaparin then TB-402 1.2 mg/kg (NA) | | 0/79 (0%)
| Enoxaparin (NA) | | 3/77 (3.9%)
| Enoxaparin then TB-402 0.3 mg/kg (NA) | 90 days | 1/72 (1.4%)
| Enoxaparin then TB-402 0.6 mg/kg (NA) | | 0/67 (0%)
| Enoxaparin then TB-402 1.2 mg/kg (NA) | | 0/79 (0%)
| Enoxaparin (NA) | | 4/77 (5.2%)
Warwick 2002 12002490 | VFP (AV Impulse system) (Mechanical) | post-operative days | 4/99 (4.0%)
| Enoxaparin (LMWH) | | 0/89 (0%)
Weitz 2010 20886185 | TAK-442 40 qD (NA) | 10 days | 4/115 (3.5%)
| TAK-442 40 BID (FXaI) | | 4/112 (3.6%)
| TAK-442 80 BID (NA) | | 1/119 (0.8%)
| TAK-442 10 (NA) | | 2/77 (2.6%)
| TAK-442 20 (NA) | | 4/86 (4.7%)
| TAK-442 80 qD (NA) | | 3/112 (2.7%)
| Enoxaparin (LMWH) | | 3/109 (2.8%)
Westrich 1996 8666599 | Aspirin (Antiplatelet) | Post-operative days | 5/39 (13%)
| Aspirin+ VFP (Antiplatelet_Mechanical) | | 0/41 (0%)
Wilson 1992 1732265 | Venous foot pump (A-V Impulse System) (Mechanical) | Post-operative days | 0/28 (0%)
| Control (Placebo) | | 6/32 (19%)
DVT, Symptomatic
Barrellier 2010 20797774 | Anticoagulation (mixed) 35+−5 days (NA) | ~35 days | 2/422 (0.5%)
| Anticoagulation (mixed) 10+−2 days (NA) | | 7/420 (1.7%)
| Anticoagulation (mixed) 35+−5 days (NA) | 3 months | 2/422 (0.5%)
| Anticoagulation (mixed) 10+−2 days (NA) | | 7/420 (1.7%)
Bauer 2001 11794149 | Fondaparinux (FXaI) | 11 days | 3/517 (0.6%)
| Enoxaparin (LMWH) | | 4/517 (0.8%)
Bonneux 2006 16387501 | Fondaparinux (FXaI) | Post-operative days | 2/55 (3.6%)
| Enoxaparin (LMWH) | | 1/54 (1.9%)
Büller 2015 25482425 | FXI-ASO 300 (NA) | ~12 days | 0/71 (0%)
| Enoxaparin (NA) | | 1/71 (1.4%)
| FXI-ASO 200 (NA) | | 2/139 (1.4%)
| FXI-ASO 300 (NA) | ~3 months | 0/71 (0%)
| Enoxaparin (LMWH) | | 1/71 (1.4%)
| FXI-ASO 200 (FXiI) | | 2/139 (1.4%)
Cho 2013 23381297 | Placebo (NA) | 7 days | 0/74 (0%)
| Fondaparinux (NA) | | 0/74 (0%)
| Placebo (Placebo) | 90 days | 0/74 (0%)
| Fondaparinux (FXaI) | | 0/74 (0%)
Cohen 2013 23782955 | Eribaxaban 1 mg (FXaI) | ~10 days | 0/120 (0%)
| Enoxaparin 30 mg BID (LMWH) | | 1/188 (0.5%)
| Eribaxaban 2.5 mg (NA) | | 0/112 (0%)
| Eribaxaban 10 mg (NA) | | 0/27 (0%)
| Eribaxaban 0.1 mg (NA) | | 0/35 (0%)
| Eribaxaban 4 mg (NA) | | 0/74 (0%)
| Eribaxaban 0.5 mg (NA) | | 1/104 (1.0%)
| Eribaxaban 0.3 mg (NA) | | 0/89 (0%)
Eriksson 2007A 17764540 | Dabigatran 150 mg (NA) | 90 days | 3/696 (0.4%)
| Enoxaparin (LMWH) | | 8/685 (1.2%)
| Dabigatran 220 mg (DTI) | | 1/675 (0.1%)
Faunø 1994 7989386 | Heparin (UFH) | 60 days | 1/93 (1.1%)
| Enoxaparin (LMWH) | | 0/92 (0%)
Fuji 2010A 19854610 | Dabigatran 150 mg (NA) | post-operative days | 2/126 (1.6%)
| Placebo (Placebo) | | 2/124 (1.6%)
| Dabigatran 220 mg (DTI) | | 1/129 (0.8%)
Fuji 2010B 20723033 | Edoxaban 60 mg (NA) | 11–14 days | 0/88 (0%)
| Edoxaban 30 mg (NA) | | 0/88 (0%)
| Edoxaban 15 mg (NA) | | 0/92 (0%)
| Edoxaban 5 mg (NA) | | 1/88 (1.1%)
Fuji 2014C 25294589 | Edoxaban (FXaI) | 11–14 days | 4/299 (1.3%)
| Enoxaparin (LMWH) | | 1/295 (0.3%)
Fuji 2014D 22952213 TKA | Placebo (Placebo) | 10–14 (during treatment period) days | 0/96 (0%)
| Darexaban 15 mg BID (NA) | | 1/91 (1.1%)
| Darexaban 30 mg BID (FXaI) | | 0/88 (0%)
| Enoxaparin (LMWH) | | 1/90 (1.1%)
Ginsberg 2009 18534438 | Dabigatran 150 mg (NA) | post-operative years | 6/649 (0.9%)
| Enoxaparin (LMWH) | | 5/643 (0.8%)
| Dabigatran 220 mg (DTI) | | 7/604 (1.2%)
Jiang 2014 24931228 | Aspirin (NA) | 5 days | 0/60 (0%)
| LMWH then rivaroxaban (NA) | | 0/60 (0%)
| Aspirin (NA) | 6 weeks | 0/60 (0%)
| LMWH then rivaroxaban (NA) | | 0/60 (0%)
Koo 2014 25436073 | alternate sequential compression device (SCD Express) (NA) | 4 days | 0/13 (0%)
| simultaneous sequential compression device (DVT-3000) (NA) | | 0/11 (0%)
Lachiewicz 2004 15568526 | IPC (Venaflow) (NA) | discharge-180 days | 0/206 (0%)
| IPC (Kendal) (NA) | | 0/217 (0%)
Lassen 2007 17868430 | Warfarin (VKA) | Post-operative years | 1/109 (0.9%)
| Enoxaparin (LMWH) | | 1/109 (0.9%)
Lassen 2010B 20206776 | Apixaban (NA) | 10–14 (during intended treatment) days | 3/1528 (0.2%)
| Enoxaparin (NA) | | 7/1529 (0.5%)
| Apixaban (FXaI) | 30–60 after completion of treatment (during intended treatment and follow-up) days | 5/1528 (0.3%)
| Enoxaparin (LMWH) | | 7/1529 (0.5%)
Mirdamadi 2014 25815018 | Dabigatran 225 mg (DTI) | 15 days | 1/45 (2.2%)
| Enoxaparin (LMWH) | | 1/45 (2.2%)
Verhamme 2011 21284801 | Enoxaparin then TB-402 0.3 mg/kg (NA) | 7–11 days | 0/72 (0%)
| Enoxaparin then TB-402 0.6 mg/kg (NA) | | 0/67 (0%)
| Enoxaparin then TB-402 1.2 mg/kg (NA) | | 1/79 (1.3%)
| Enoxaparin (NA) | | 0/77 (0%)
Weitz 2010 20886185 | TAK-442 40 qD (NA) | 10 days | 1/115 (0.9%)
| TAK-442 40 BID (FXaI) | | 4/112 (3.6%)
| TAK-442 80 BID (NA) | | 1/119 (0.8%)
| TAK-442 10 (NA) | | 1/77 (1.3%)
| TAK-442 20 (NA) | | 1/86 (1.2%)
| TAK-442 80 qD (NA) | | 1/112 (0.9%)
| Enoxaparin (LMWH) | | 2/109 (1.8%)
Windisch 2011 20652250 | Enoxaparin + A-V Impulse (AVI) (LMWH_Mechanical) | 8 days | 0/40 (0%)
| Enoxaparin (LMWH) | | 0/40 (0%)
| Enoxaparin + A-V Impulse (AVI) (LMWH_Mechanical) | 3 months | 0/40 (0%)
| Enoxaparin (LMWH) | | 0/40 (0%)
Zou 2014 24695091 | Aspirin (Antiplatelet) | 4 weeks | 2/110 (1.8%)
| Rivaroxaban (FXaI) | | 0/102 (0%)
| Enoxaparin (LMWH) | | 1/112 (0.9%)
DVT, Total
Alkire 2010 20142693 | Placebo (no device) (Placebo) | 3 months | 0/32 (0%)
| Continuous passive motion (Danniflex 480) (Mechanical) | 3 months | 0/32 (0%)
Bauer 2001 11794149 | Fondaparinux (FXaI) | 11 days | 45/361 (12%)
| Enoxaparin (LMWH) | 11 days | 98/361 (27%)
Büller 2015 25482425 | FXI-ASO 300 (NA) | ~12 days | 3/71 (4.2%)
| Enoxaparin (LMWH) | ~12 days | 22/71 (31%)
| FXI-ASO 200 (FXiI) | ~12 days | 36/139 (26%)
Chin 2009 19398783 | Control (Placebo) | Post-operative days | 24/110 (22%)
| Enoxaparin (LMWH) | Post-operative days | 6/110 (5.5%)
Cho 2013 23381297 | Placebo (Placebo) | 7 days | 19/74 (26%)
| Fondaparinux (FXaI) | 7 days | 5/74 (6.8%)
| Placebo (NA) | 90 days | 19/74 (26%)
| Fondaparinux (NA) | 90 days | 5/74 (6.8%)
Choi 2015 24408881 | Pneumatic compression with adjusted cycling rate (NA) | 5 days | 15/27 (56%)
| Pneumatic compression with fixed cycling rate (NA) | 5 days | 14/27 (52%)
Colwell 1995 7497668 | Heparin (UFH) | Post-operative days | 77/225 (34%)
| Enoxaparin (LMWH) | Post-operative days | 56/228 (25%)
Comp 2001 11263636 TKR | Enoxaparin 7–10 days (NA) | 30 days | 46/221 (21%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | 30 days | 38/217 (18%)
Edwards 2008 18534421 TKA | Enoxaparin + IPC (LMWH_Mechanical) | post-operative days | 5/76 (6.6%)
| Enoxaparin (LMWH) | | 8/77 (10%)
Eriksson 2005 15634273 TKA | Dabigatran 150 mg (DTI) | post-operative years | 21/81 (26%)
| Dabigatran 300 mg (NA) | | 22/92 (24%)
| Enoxaprin (LMWH) | | 41/92 (45%)
| Dabigatran 50 mg (NA) | | 37/94 (39%)
| Dabigatran 225 mg (NA) | | 22/93 (24%)
Faunø 1994 7989386 | Heparin (UFH) | Post-operative days | 25/93 (27%)
| Enoxaparin (LMWH) | | 21/92 (23%)
Fitzgerald 2001 11407799 | Warfarin (VKA) | post-operative days | 79/176 (45%)
| Enoxaparin (LMWH) | | 44/173 (25%)
Fuji 2008 18843459 TKA | Placebo (Placebo) | post-operative years | 48/79 (61%)
| Enoxaparin 40 mg (LMWH) | | 25/74 (34%)
| Enoxaparin 20 mg (NA) | | 25/84 (30%)
Fuji 2010A 19854610 | Dabigatran 150 mg (NA) | post-operative days | 34/104 (33%)
| Placebo (Placebo) | | 57/101 (56%)
| Dabigatran 220 mg (DTI) | | 23/96 (24%)
Fuji 2010B 20723033 | Placebo (Placebo) | 11–14 days | 43/89 (48%)
| Edoxaban 60 mg (NA) | | 8/88 (9.1%)
| Edoxaban 30 mg (FXaI) | | 11/88 (13%)
| Edoxaban 15 mg (NA) | | 24/92 (26%)
| Edoxaban 5 mg (NA) | | 25/87 (29%)
Fuji 2014C 25294589 | Edoxaban (FXaI) | 11–14 days | 22/299 (7.4%)
| Enoxaparin (LMWH) | | 41/295 (14%)
Fuji 2014D 22952213 TKA | Placebo (Placebo) | 10–14 (during treatment period) days | 38/72 (53%)
| Darexaban 15 mg BID (NA) | | 22/81 (27%)
| Darexaban 30 mg BID (FXaI) | | 11/71 (15%)
| Enoxaparin (LMWH) | | 14/66 (21%)
Haas 1990 2404020 | Aspirin (Antiplatelet) | Post-operative days | 32/58 (55%)
| IPC (Mechanical) | | 20/61 (33%)
Hu 2015 No PMID | Rivaroxaban (FXaI) | 2 weeks | 1/45 (2.2%)
| Enoxaparin (LMWH) | | 4/45 (8.9%)
Hull 1993 8413432 TKA | Tinzaparin (LMWH) | Post-operative days | 116/258 (45%)
| Warfarin (VKA) | | 152/277 (55%)
Iliopoulos 2011 Abstract P104 | Dabigatran 110 mg (DTI) | 5 days | 0/40 (0%)
| Tinzaparin (NA) | | 0/40 (0%)
| Fondaparinux (FXaI) | | 0/40 (0%)
| Enoxaparin (LMWH) | | 0/40 (0%)
Jiang 2014 24931228 | Aspirin (NA) | 5 days | 10/60 (17%)
| LMWH then rivaroxaban (NA) | | 11/60 (18%)
Koo 2014 25436073 | alternate sequential compression device (SCD Express) (NA) | 4 days | 1/13 (7.7%)
| simultaneous sequential compression device (DVT-3000) (NA) | | 4/11 (36%)
Lachiewicz 2004 15568526 | IPC (Venaflow) (NA) | post-operative days | 16/232 (6.9%)
| IPC (Kendal) (NA) | | 36/240 (15%)
Lassen 2010B 20206776 | Apixaban (FXaI) | 10–14 (during intended treatment) days | 142/971 (15%)
| Enoxaparin (LMWH) | | 243/997 (24%)
Lassen 2012 22429800 TKA | Semuloparin (NA) | 7–11 days | 105/428 (25%)
| Enoxaparin (NA) | | 120/427 (28%)
Leclerc 1996 8607589 | Warfarin (VKA) | Post-operative days | 109/334 (33%)
| Enoxaparin (LMWH) | | 76/336 (23%)
Lotke 1996 8595765 TKA | Aspirin (Antiplatelet) | Post-operative days days | 76/114 (67%)
| Warfarin (VKA) | | 52/75 (69%)
McKenna 1980 6989432 | Placebo (Placebo) | Post-operative days | 9/12 (75%)
| Aspirin (Antiplatelet) | | 7/9 (78%)
Rader 1998 9526211 TKA | Heparin+ Enoxaparin (NA) | post-operative days | 6/60 (10%)
| Heparin+ Heparin (NA) | | 1/60 (1.7%)
Silbersack 2004 15330019 TKA | Enoxaparin + GCS (Comprinet Pro) (NA) | 6th−12th post-operative days | 14/35 (40%)
| Enoxaparin + IPC (Venaflow) (NA) | | 0/35 (0%)
Verhamme 2011 21284801 | Enoxaparin then TB-402 0.3 mg/kg (NA) | 7–11 days | 12/72 (17%)
| Enoxaparin then TB-402 0.6 mg/kg (NA) | | 16/67 (24%)
| Enoxaparin then TB-402 1.2 mg/kg (NA) | | 19/79 (24%)
| Enoxaparin (NA) | | 30/77 (39%)
| Enoxaparin then TB-402 0.3 mg/kg (NA) | 90 days | 12/72 (17%)
| Enoxaparin then TB-402 0.6 mg/kg (NA) | | 16/67 (24%)
| Enoxaparin then TB-402 1.2 mg/kg (NA) | | 19/79 (24%)
| Enoxaparin (NA) | | 31/77 (40%)
Warwick 2002 12002490 | VFP (AV Impulse system) (Mechanical) | post-operative days | 57/99 (58%)
| Enoxaparin (LMWH) | | 48/89 (54%)
Westrich 1996 8666599 | Aspirin (Antiplatelet) | Post-operative days | 26/39 (67%)
| Aspirin+ VFP (Antiplatelet_Mechanical) | | 11/41 (27%)
Wilson 1992 1732265 | Venous foot pump (A-V Impulse System) (Mechanical) | Post-operative days | 14/28 (50%)
| Control (Placebo) | | 22/32 (69%)
Windisch 2011 20652250 | Enoxaparin + A-V Impulse (AVI) (LMWH_Mechanical) | 8 days | 0/40 (0%)
| Enoxaparin (LMWH) | | 0/40 (0%)
Zou 2014 24695091 | Aspirin (Antiplatelet) | 4 weeks | 18/110 (16%)
| Rivaroxaban (FXaI) | | 3/102 (2.9%)
| Enoxaparin (LMWH) | | 14/112 (13%)
Heparin-induced thrombocytopenia
Barrellier 2010 20797774 | Anticoagulation (mixed) 35+−5 days (NA) | ~35 days | 0/422 (0%)
| Anticoagulation (mixed) 10+−2 days (NA) | | 0/420 (0%)
Infection, Leading to reoperation
Fitzgerald 2001 11407799 | Warfarin (NA) | post-operative days | 0/176 (0%)
| Enoxaparin (NA) | | 0/173 (0%)
Major adverse event, other
Büller 2015 25482425 | FXI-ASO 300 (NA) | ~3 months | 1/77 (1.3%)
| Enoxaparin (LMWH) | | 0/72 (0%)
| FXI-ASO 200 (FXiI) | | 3/144 (2.1%)
Cho 2013 23381297 | Placebo (Placebo) | 90 days | 0/74 (0%)
| Fondaparinux (FXaI) | | 0/74 (0%)
Cohen 2013 23782955 | Eribaxaban 1 mg (FXaI) | ~10 days | 0/202 (0%)
| Enoxaparin 30 mg BID (LMWH) | | 3/397 (0.8%)
| Eribaxaban 2.5 mg (NA) | | 0/200 (0%)
| Eribaxaban 10 mg (NA) | | 2/65 (3.1%)
| Eribaxaban 0.1 mg (NA) | | 0/61 (0%)
| Eribaxaban 4 mg (NA) | | 0/140 (0%)
| Eribaxaban 0.5 mg (NA) | | 2/183 (1.1%)
| Eribaxaban 0.3 mg (NA) | | 2/141 (1.4%)
Fuji 2014C 25294589 | Edoxaban (FXaI) | 11–14 days | 10/354 (2.8%)
| Enoxaparin (LMWH) | | 11/349 (3.2%)
Fuji 2014D 22952213 TKA | Placebo (Placebo) | 10–14 (during treatment period) days | 1/96 (1.0%)
| Darexaban 15 mg BID (NA) | | 1/92 (1.1%)
| Darexaban 30 mg BID (FXaI) | | 3/88 (3.4%)
| Enoxaparin (LMWH) | | 2/90 (2.2%)
Lassen 2012 22429800 TKA | Semuloparin (NA) | period from the first injection given during the study up to the last injection plus 3 calendar days days days | 13/573 (2.3%)
| Enoxaparin (NA) | | 17/568 (3.0%)
Weitz 2010 20886185 | TAK-442 40 qD (NA) | 10 days | 12/162 (7.4%)
| TAK-442 40 BID (FXaI) | | 7/162 (4.3%)
| TAK-442 80 BID (NA) | | 14/161 (8.7%)
| TAK-442 10 (NA) | | 9/104 (8.7%)
| TAK-442 20 (NA) | | 12/128 (9.4%)
| TAK-442 80 qD (NA) | | 12/160 (7.5%)
| Enoxaparin (LMWH) | | 16/161 (10%)
Mortality, 30 day or in-hospital (AE)
Barrellier 2010 20797774 | Anticoagulation (mixed) 35+−5 days (NA) | ~35 days | 0/422 (0%)
| Anticoagulation (mixed) 10+−2 days (NA) | | 0/420 (0%)
Bauer 2001 11794149 | Fondaparinux (FXaI) | 49 days | 2/517 (0.4%)
| Enoxaparin (LMWH) | | 3/517 (0.6%)
Comp 2001 11263636 TKR | Enoxaparin 7–10 days (NA) | 30 days | 0/221 (0%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | | 0/217 (0%)
Edwards 2008 18534421 TKA | Enoxaparin + IPC (LMWH_Mechanical) | post-operative days | 0/76 (0%)
| Enoxaparin (LMWH) | | 0/77 (0%)
Eriksson 2007A 17764540 | Dabigatran 150 mg (NA) | 90 days | 1/696 (0.1%)
| Enoxaparin (LMWH) | | 1/685 (0.1%)
| Dabigatran 220 mg (DTI) | | 1/675 (0.1%)
Fitzgerald 2001 11407799 | Warfarin (VKA) | post-operative days | 3/176 (1.7%)
| Enoxaparin (LMWH) | | 1/173 (0.6%)
Fuji 2010A 19854610 | Dabigatran 150 mg (NA) | post-operative days | 0/126 (0%)
| Placebo (Placebo) | | 0/124 (0%)
| Dabigatran 220 mg (DTI) | | 0/129 (0%)
Fuji 2014D 22952213 TKA | Placebo (Placebo) | 10–14 (during treatment period) days | 0/96 (0%)
| Darexaban 15 mg BID (NA) | | 0/92 (0%)
| Darexaban 30 mg BID (FXaI) | | 0/88 (0%)
| Enoxaparin (LMWH) | | 0/90 (0%)
Ginsberg 2009 18534438 | Dabigatran 150 mg (NA) | post-operative years | 1/871 (0.1%)
| Enoxaparin (NA) | | 0/868 (0%)
| Dabigatran 220 mg (NA) | | 1/857 (0.1%)
Lachiewicz 2004 15568526 | IPC (Venaflow) (NA) | post-operative days | 0/206 (0%)
| IPC (Kendal) (NA) | | 1/217 (0.5%)
Lassen 2010B 20206776 | Apixaban (FXaI) | 10–14 (during intended treatment) days | 2/1528 (0.1%)
| Enoxaparin (LMWH) | | 0/1529 (0%)
Lassen 2012 22429800 TKA | Semuloparin (NA) | 7–11 days | 0/573 (0%)
| Enoxaparin (NA) | | 0/568 (0%)
McKenna 1980 6989432 | Placebo (Placebo) | Post-operative days | 0/12 (0%)
| Aspirin (Antiplatelet) | | 0/9 (0%)
Warwick 2002 12002490 | VFP (AV Impulse system) (Mechanical) | post-operative days | 3/117 (2.6%)
| Enoxaparin (LMWH) | | 1/112 (0.9%)
PE, Fatal
Barrellier 2010 20797774 | Anticoagulation (mixed) 35+−5 days (NA) | ~35 days | 0/422 (0%)
| Anticoagulation (mixed) 10+−2 days (NA) | | 0/420 (0%)
| Anticoagulation (mixed) 35+−5 days (NA) | 3 months | 0/422 (0%)
| Anticoagulation (mixed) 10+−2 days (NA) | | 0/420 (0%)
Bauer 2001 11794149 | Fondaparinux (FXaI) | 49 days | 1/517 (0.2%)
| Enoxaparin (LMWH) | | 1/517 (0.2%)
Büller 2015 25482425 | FXI-ASO 300 (NA) | ~12 days | 0/71 (0%)
| Enoxaparin (LMWH) | | 0/71 (0%)
| FXI-ASO 200 (FXiI) | | 0/139 (0%)
Cohen 2013 23782955 | Eribaxaban 1 mg (FXaI) | ~10 days | 0/120 (0%)
| Enoxaparin 30 mg BID (LMWH) | | 0/188 (0%)
| Eribaxaban 2.5 mg (NA) | | 0/112 (0%)
| Eribaxaban 10 mg (NA) | | 0/27 (0%)
| Eribaxaban 0.1 mg (NA) | | 0/35 (0%)
| Eribaxaban 4 mg (NA) | | 0/74 (0%)
| Eribaxaban 0.5 mg (NA) | | 0/104 (0%)
| Eribaxaban 0.3 mg (NA) | | 0/89 (0%)
Colwell 1995 7497668 | Heparin (UFH) | Post-operative days | 1/225 (0.4%)
| Enoxaparin (LMWH) | | 0/228 (0%)
Comp 2001 11263636 TKR | Enoxaparin 7–10 days (NA) | 30 days | 0/221 (0%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | | 0/217 (0%)
Edwards 2008 18534421 TKA | Enoxaparin + IPC (LMWH_Mechanical) | 90 days | 0/76 (0%)
| Enoxaparin (LMWH) | | 0/77 (0%)
Eriksson 2007A 17764540 | Dabigatran 150 mg (NA) | Post-operative days | 0/696 (0%)
| Enoxaparin (LMWH) | | 1/685 (0.1%)
| Dabigatran 220 mg (DTI) | | 0/675 (0%)
Faunø 1994 7989386 | Heparin (UFH) | Post-operative days | 0/93 (0%)
| Enoxaparin (LMWH) | | 0/92 (0%)
Fuji 2010A 19854610 | Dabigatran 150 mg (NA) | post-operative days | 0/126 (0%)
| Placebo (Placebo) | | 0/124 (0%)
| Dabigatran 220 mg (DTI) | | 0/129 (0%)
Fuji 2010B 20723033 | Edoxaban 60 mg (NA) | 11–14 days | 0/88 (0%)
| Edoxaban 30 mg (NA) | | 0/88 (0%)
| Edoxaban 15 mg (NA) | | 0/92 (0%)
| Edoxaban 5 mg (NA) | | 0/88 (0%)
Fuji 2014C 25294589 | Edoxaban (FXaI) | 11–14 days | 0/299 (0%)
| Enoxaparin (LMWH) | | 0/295 (0%)
Hull 1993 8413432 TKA | Tinzaparin (LMWH) | 90 days | 0/317 (0%)
| Warfarin (VKA) | | 0/324 (0%)
Jiang 2014 24931228 | Aspirin (NA) | 5 days | 0/60 (0%)
| LMWH then rivaroxaban (NA) | | 0/60 (0%)
| Aspirin (NA) | 6 weeks | 0/60 (0%)
| LMWH then rivaroxaban (NA) | | 0/60 (0%)
Lachiewicz 2004 15568526 | IPC (Venaflow) (NA) | post-operative days | 0/206 (0%)
| IPC (Kendal) (NA) | | 0/217 (0%)
Lassen 2007 17868430 | Warfarin (VKA) | Post-operative years | 0/109 (0%)
| Enoxaparin (LMWH) | | 0/109 (0%)
Lassen 2010B 20206776 | Apixaban (NA) | 10–14 (during intended treatment) days | 1/1528 (0.1%)
| Enoxaparin (NA) | | 0/1529 (0%)
Lassen 2010B 20206776 | Apixaban (FXaI) | 30–60 after completion of treatment (during intended treatment and follow-up) years | 2/1528 (0.1%)
| Enoxaparin (LMWH) | | 0/1529 (0%)
Leclerc 1996 8607589 | Warfarin (VKA) | Post-operative days | 0/334 (0%)
| Enoxaparin (LMWH) | | 0/336 (0%)
Mirdamadi 2014 25815018 | Dabigatran 225 mg (DTI) | 15 days | 0/45 (0%)
| Enoxaparin (LMWH) | | 0/45 (0%)
Verhamme 2011 21284801 | Enoxaparin then TB-402 0.3 mg/kg (NA) | 7–11 days | 0/72 (0%)
| Enoxaparin then TB-402 0.6 mg/kg (NA) | | 0/67 (0%)
| Enoxaparin then TB-402 1.2 mg/kg (NA) | | 0/79 (0%)
| Enoxaparin (NA) | | 0/77 (0%)
Warwick 2002 12002490 | VFP (AV Impulse system) (Mechanical) | post-operative days | 2/117 (1.7%)
| Enoxaparin (LMWH) | | 0/112 (0%)
Weitz 2010 20886185 | TAK-442 40 qD (NA) | 10 days | 0/115 (0%)
| TAK-442 40 BID (FXaI) | | 0/112 (0%)
| TAK-442 80 BID (NA) | | 0/119 (0%)
| TAK-442 10 (NA) | | 0/77 (0%)
| TAK-442 20 (NA) | | 0/86 (0%)
| TAK-442 80 qD (NA) | | 0/112 (0%)
| Enoxaparin (LMWH) | | 0/109 (0%)
Wilson 1992 1732265 | Venous foot pump (A-V Impulse System) (Mechanical) | Post-operative days | 0/28 (0%)
| Control (Placebo) | | 0/32 (0%)
PE, Symptomatic
Barrellier 2010 20797774 | Anticoagulation (mixed) 35+−5 days (NA) | ~35 days | 1/422 (0.2%)
| Anticoagulation (mixed) 10+−2 days (NA) | | 2/420 (0.5%)
| Anticoagulation (mixed) 35+−5 days (NA) | 3 months | 1/422 (0.2%)
| Anticoagulation (mixed) 10+−2 days (NA) | | 2/420 (0.5%)
Büller 2015 25482425 | FXI-ASO 300 (NA) | ~12 days | 0/71 (0%)
| Enoxaparin (NA) | | 0/71 (0%)
| FXI-ASO 200 (NA) | | 0/139 (0%)
| FXI-ASO 300 (NA) | ~3 months | 0/71 (0%)
| Enoxaparin (LMWH) | | 0/71 (0%)
| FXI-ASO 200 (FXiI) | | 0/139 (0%)
Cho 2013 23381297 | Placebo (NA) | 7 days | 0/74 (0%)
| Fondaparinux (NA) | | 0/74 (0%)
Cho 2013 23381297 | Placebo (Placebo) | 90 days | 0/74 (0%)
| Fondaparinux (FXaI) | | 0/74 (0%)
Fuji 2010B 20723033 | Edoxaban 60 mg (NA) | 11–14 days | 0/88 (0%)
| Edoxaban 30 mg (NA) | | 0/88 (0%)
| Edoxaban 15 mg (NA) | | 0/92 (0%)
| Edoxaban 5 mg (NA) | | 0/88 (0%)
Fuji 2014C 25294589 | Edoxaban (FXaI) | 11–14 days | 0/299 (0%)
Fuji 2014C 25294589 | Enoxaparin (LMWH) | | 0/295 (0%)
Fuji 2014D 22952213 TKA | Placebo (Placebo) | 10–14 (during treatment period) days | 0/96 (0%)
| Darexaban 15 mg BID (NA) | | 0/92 (0%)
| Darexaban 30 mg BID (FXaI) | | 0/88 (0%)
| Enoxaparin (LMWH) | | 1/90 (1.1%)
Jiang 2014 24931228 | Aspirin (NA) | 5 days | 0/60 (0%)
| LMWH then rivaroxaban (NA) | | 0/60 (0%)
| Aspirin (NA) | 6 weeks | 0/60 (0%)
| LMWH then rivaroxaban (NA) | | 0/60 (0%)
Mirdamadi 2014 25815018 | Dabigatran 225 mg (DTI) | 15 days | 0/45 (0%)
| Enoxaparin (LMWH) | | 0/45 (0%)
Verhamme 2011 21284801 | Enoxaparin then TB-402 0.3 mg/kg (NA) | 7–11 days | 0/72 (0%)
| Enoxaparin then TB-402 0.6 mg/kg (NA) | | 0/67 (0%)
| Enoxaparin then TB-402 1.2 mg/kg (NA) | | 0/79 (0%)
| Enoxaparin (NA) | | 0/77 (0%)
Weitz 2010 20886185 | TAK-442 40 qD (NA) | 10 days | 0/115 (0%)
| TAK-442 40 BID (FXaI) | 10 days | 1/112 (0.9%)
| TAK-442 80 BID (NA) | | 2/119 (1.7%)
| TAK-442 10 (NA) | | 1/77 (1.3%)
| TAK-442 20 (NA) | | 1/86 (1.2%)
| TAK-442 80 qD (NA) | | 0/112 (0%)
| Enoxaparin (LMWH) | | 2/109 (1.8%)
Windisch 2011 20652250 | Enoxaparin + A-V Impulse (AVI) (LMWH_Mechanical) | 8 days | 0/40 (0%)
| Enoxaparin (LMWH) | | 0/40 (0%)
PE, Total
Bauer 2001 11794149 | Fondaparinux (FXaI) | 49 days | 3/517 (0.6%)
| Enoxaparin (LMWH) | | 5/517 (1.0%)
| Fondaparinux (NA) | 11 days | 1/517 (0.2%)
| Enoxaparin (NA) | | 4/517 (0.8%)
Chin 2009 19398783 | Control (Placebo) | Post-operative days | 1/110 (0.9%)
| Enoxaparin (LMWH) | | 0/110 (0%)
Cohen 2013 23782955 | Eribaxaban 1 mg (FXaI) | ~10 days | 1/120 (0.8%)
| Enoxaparin 30 mg BID (LMWH) | | 3/188 (1.6%)
| Eribaxaban 2.5 mg (NA) | | 1/112 (0.9%)
| Eribaxaban 10 mg (NA) | | 0/27 (0%)
| Eribaxaban 0.1 mg (NA) | | 0/35 (0%)
| Eribaxaban 4 mg (NA) | | 0/74 (0%)
| Eribaxaban 0.5 mg (NA) | | 0/104 (0%)
| Eribaxaban 0.3 mg (NA) | | 0/89 (0%)
| Eribaxaban 1 mg (FXaI) | ~40 days | 1/120 (0.8%)
| Enoxaparin 30 mg BID (LMWH) | | 4/188 (2.1%)
| Eribaxaban 2.5 mg (NA) | | 1/112 (0.9%)
| Eribaxaban 10 mg (NA) | | 0/27 (0%)
| Eribaxaban 0.1 mg (NA) | | 0/35 (0%)
| Eribaxaban 4 mg (NA) | | 0/74 (0%)
| Eribaxaban 0.5 mg (NA) | | 0/104 (0%)
| Eribaxaban 0.3 mg (NA) | | 0/89 (0%)
Colwell 1995 7497668 | Heparin (UFH) | Post-operative days | 2/225 (0.9%)
| Enoxaparin (LMWH) | | 0/228 (0%)
Comp 2001 11263636 TKR | Enoxaparin 7–10 days (NA) | 30 days | 2/221 (0.9%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | | 0/217 (0%)
Edwards 2008 18534421 TKA | Enoxaparin + IPC (LMWH_Mechanical) | 90 days | 1/76 (1.3%)
| Enoxaparin (LMWH) | | 1/77 (1.3%)
Eriksson 2007A 17764540 | Dabigatran 150 mg (NA) | Post-operative days | 1/696 (0.1%)
| Enoxaparin (LMWH) | | 1/685 (0.1%)
| Dabigatran 220 mg (DTI) | | 0/675 (0%)
Faunø 1994 7989386 | Heparin (UFH) | Post-operative days | 0/93 (0%)
| Enoxaparin (LMWH) | | 0/92 (0%)
Fitzgerald 2001 11407799 | Warfarin (VKA) | post-operative days | 1/176 (0.6%)
| Enoxaparin (LMWH) | | 0/173 (0%)
Fuji 2008 18843459 TKA | Placebo (Placebo) | post-operative years | 1/79 (1.3%)
| Enoxaparin 40 mg (LMWH) | | 1/74 (1.4%)
| Enoxaparin 20 mg (NA) | | 0/84 (0%)
Fuji 2010A 19854610 | Dabigatran 150 mg (NA) | post-operative days | 0/126 (0%)
| Placebo (Placebo) | | 0/124 (0%)
| Dabigatran 220 mg (DTI) | | 0/129 (0%)
Hull 1993 8413432 TKA | Tinzaparin (LMWH) | 90 days | 0/317 (0%)
| Warfarin (VKA) | | 1/324 (0.3%)
Iliopoulos 2011 Abstract P104 | Dabigatran 110 mg (DTI) | 5 days | 0/40 (0%)
| Tinzaparin (NA) | | 0/40 (0%)
| Fondaparinux (FXaI) | | 0/40 (0%)
| Enoxaparin (LMWH) | | 0/40 (0%)
Lachiewicz 2004 15568526 | IPC (Venaflow) (NA) | post-operative days | 0/206 (0%)
| IPC (Kendal) (NA) | | 1/217 (0.5%)
Lassen 2007 17868430 | Warfarin (VKA) | Post-operative years | 0/109 (0%)
| Enoxaparin (LMWH) | | 2/109 (1.8%)
Lassen 2010B 20206776 | Apixaban (NA) | 10–14 (during intended treatment) days | 4/1528 (0.3%)
| Enoxaparin (NA) | | 0/1529 (0%)
| Apixaban (FXaI) | 30–60 after completion of treatment (during intended treatment and follow-up) days | 7/1528 (0.5%)
| Enoxaparin (LMWH) | | 1/1529 (0.1%)
Leclerc 1996 8607589 | Warfarin (VKA) | Post-operative days | 3/334 (0.9%)
| Enoxaparin (LMWH) | | 1/336 (0.3%)
Wilson 1992 1732265 | Venous foot pump (A-V Impulse System) (Mechanical) | Post-operative days | 0/28 (0%)
| Control (Placebo) | | 0/32 (0%)
Zou 2014 24695091 | Aspirin (Antiplatelet) | 4 weeks | 0/110 (0%)
| Rivaroxaban (FXaI) | | 0/102 (0%)
| Enoxaparin (LMWH) | | 0/112 (0%)
Readmission, bleeding or infection (combined)
Bonneux 2006 16387501 | Fondaparinux (NA) | Post-operative days | 4/55 (7.3%)
| Enoxaparin (NA) | | 1/55 (1.8%)
Fitzgerald 2001 11407799 | Warfarin (NA) | post-operative days | 0/176 (0%)
| Enoxaparin (NA) | | 0/173 (0%)
VTE, Symptomatic
Bauer 2001 11794149 | Fondaparinux (FXaI) | 49 days | 5/517 (1.0%)
| Enoxaparin (LMWH) | | 10/517 (1.9%)
Büller 2015 25482425 | FXI-ASO 300 (NA) | ~12 days | 0/71 (0%)
| Enoxaparin (LMWH) | | 1/71 (1.4%)
| FXI-ASO 200 (FXiI) | | 2/139 (1.4%)
Comp 2001 11263636 TKR | Enoxaparin 7–10 days (NA) | 30 days | 46/221 (21%)
| Enoxaparin 7–10 days+ 3 weeks (NA) | | 38/217 (18%)
Fuji 2010B 20723033 | Edoxaban 60 mg (NA) | 11–14 days | 0/88 (0%)
| Edoxaban 30 mg (NA) | | 0/88 (0%)
| Edoxaban 15 mg (NA) | | 0/92 (0%)
| Edoxaban 5 mg (NA) | | 1/88 (1.1%)
Fuji 2014C 25294589 | Edoxaban (FXaI) | 11–14 days | 4/299 (1.3%)
| Enoxaparin (LMWH) | | 1/295 (0.3%)
Hull 1993 8413432 TKA | Tinzaparin (LMWH) | 90 days | 1/317 (0.3%)
| Warfarin (VKA) | | 1/324 (0.3%)
Jiang 2014 24931228 | Aspirin (NA) | 5 days | 0/60 (0%)
| LMWH then rivaroxaban (NA) | | 0/60 (0%)
| Aspirin (NA) | 6 weeks | 0/60 (0%)
| LMWH then rivaroxaban (NA) | | 0/60 (0%)
Leclerc 1996 8607589 | Warfarin (VKA) | 180 days | 1/334 (0.3%)
| Enoxaparin (LMWH) | | 3/336 (0.9%)
Verhamme 2011 21284801 | Enoxaparin then TB-402 0.3 mg/kg (NA) | 7–11 days | 0/72 (0%)
| Enoxaparin then TB-402 0.6 mg/kg (NA) | | 0/67 (0%)
| Enoxaparin then TB-402 1.2 mg/kg (NA) | | 1/79 (1.3%)
| Enoxaparin (NA) | | 0/77 (0%)
Weitz 2010 20886185 | TAK-442 40 qD (NA) | 10 days | 1/115 (0.9%)
| TAK-442 40 BID (FXaI) | | 5/112 (4.5%)
| TAK-442 80 BID (NA) | | 3/119 (2.5%)
| TAK-442 10 (NA) | | 2/77 (2.6%)
| TAK-442 20 (NA) | | 2/86 (2.3%)
| TAK-442 80 qD (NA) | | 1/112 (0.9%)
| Enoxaparin (LMWH) | | 4/109 (3.7%)
Yilmaz 2015 25852131 | Enoxaparin + electrostimulation device (The Geko) (LMWH_Mechanical) | 6 days | 0/15 (0%)
| Enoxaparin (LMWH) | | 0/15 (0%)
VTE, Total
Büller 2015 25482425 | FXI-ASO 300 (NA) | ~12 days | 3/71 (4.2%)
| Enoxaparin (LMWH) | | 22/71 (31%)
| FXI-ASO 200 (FXiI) | | 36/139 (26%)
Cohen 2013 23782955 | Eribaxaban 1 mg (FXaI) | ~10 days | 23/120 (19%)
| Enoxaparin 30 mg BID (LMWH) | | 34/188 (18%)
| Eribaxaban 2.5 mg (NA) | | 16/112 (14%)
| Eribaxaban 10 mg (NA) | | 3/27 (11%)
| Eribaxaban 0.1 mg (NA) | | 13/35 (37%)
| Eribaxaban 4 mg (NA) | | 1/74 (1.4%)
| Eribaxaban 0.5 mg (NA) | | 30/104 (29%)
| Eribaxaban 0.3 mg (NA) | | 33/89 (37%)
Fuji 2010B 20723033 | Edoxaban 60 mg (NA) | 11–14 days | 8/88 (9.1%)
| Edoxaban 30 mg (NA) | | 11/88 (13%)
| Edoxaban 15 mg (NA) | | 24/92 (26%)
| Edoxaban 5 mg (NA) | | 26/88 (30%)
Fuji 2014C 25294589 | Edoxaban (FXaI) | 11–14 days | 22/299 (7.4%)
| Enoxaparin (LMWH) | | 41/295 (14%)
Fuji 2014D 22952213 TKA | Placebo (Placebo) | 10–14 (during treatment period) days | 38/72 (53%)
| Darexaban 15 mg BID (NA) | | 22/81 (27%)
| Darexaban 30 mg BID (FXaI) | | 11/71 (15%)
| Enoxaparin (LMWH) | | 15/66 (23%)
Verhamme 2011 21284801 | Enoxaparin then TB-402 0.3 mg/kg (NA) | 7–11 days | 12/72 (17%)
| Enoxaparin then TB-402 0.6 mg/kg (NA) | | 16/67 (24%)
| Enoxaparin then TB-402 1.2 mg/kg (NA) | | 19/79 (24%)
| Enoxaparin (NA) | | 30/77 (39%)
Weitz 2010 20886185 | TAK-442 40 qD (NA) | 10 days | 27/115 (23%)
| TAK-442 40 BID (FXaI) | | 24/112 (21%)
| TAK-442 80 BID (NA) | | 17/119 (14%)
| TAK-442 10 (NA) | | 30/77 (39%)
| TAK-442 20 (NA) | | 33/86 (38%)
| TAK-442 80 qD (NA) | | 29/112 (26%)
| Enoxaparin (LMWH) | | 24/109 (22%)
Yilmaz 2015 25852131 | Enoxaparin + electrostimulation device (The Geko) (LMWH_Mechanical) | 6 days | 0/15 (0%)
| Enoxaparin (LMWH) | | 0/15 (0%)
Wound complication
Jiang 2014 24931228 | Aspirin (NA) | 5 days | 1/60 (1.7%)
| LMWH then rivaroxaban (NA) | | 2/60 (3.3%)
Zou 2014 24695091 | Aspirin (NA) | 4 weeks | 2/110 (1.8%)
| Rivaroxaban (NA) | | 5/102 (4.9%)
| Enoxaparin (NA) | | 3/112 (2.7%)

Table F3 RCT hip fracture surgery

Study | Arm | Timepoint | n/N (%)
Bleeding, Fatal
Eriksson 2001 11794148 | Fondaparinux (FXaI) | 11 days | 0/831 (0%)
| Enoxaparin (LMWH) | | 1/842 (0.1%)
Eriksson 2003 12796070 | Fondaparinux 6–8 days (NA) | 32 days | 8/329 (2.4%)
| Fondaparinux 25–31 days (NA) | | 6/327 (1.8%)
Jørgensen 1992 1314147 | Placebo (Placebo) | Post-operative days | 0/38 (0%)
| Dalteparin (LMWH) | | 0/30 (0%)
Lassen 2012 22429800 HFx | Semuloparin (NA) | period from the first injection given during the study up to the last injection plus 3 calendar | 0/488 (0%)
| Enoxaparin (NA) | | 0/499 (0%)
Monreal 1989 2544742 | Dalteparin (LMWH) | Post-operative days | 0/46 (0%)
| Heparin (UFH) | | 1/44 (2.3%)
Powers 1989 2650646 | Placebo (Placebo) | 21 days | 0/63 (0%)
| Aspirin (Antiplatelet) | | 0/66 (0%)
| Warfarin (VKA) | | 0/65 (0%)
Sasaki 2011 21293896 | Placebo (Placebo) | 14 days | 0/29 (0%)
- | Fondaparinux (FXaI) | | 0/27 (0%)
| Enoxaparin (LMWH) | | 0/28 (0%)
Bleeding, Leading to infection
Eriksson 2003 12796070 | Fondaparinux 6–8 days (NA) | 32 days | 0/329 (0%)
| Fondaparinux 25–31 days (NA) | | 0/327 (0%)
Bleeding, Leading to reoperation
Eriksson 2001 11794148 | Fondaparinux (FXaI) | 11 days | 3/831 (0.4%)
| Enoxaparin (LMWH) | | 2/842 (0.2%)
Eriksson 2003 12796070 | Fondaparinux 6–8 days (NA) | 32 days | 2/329 (0.6%)
| Fondaparinux 25–31 days (NA) | | 2/327 (0.6%)
Bleeding, Major
Eriksson 2001 11794148 | Fondaparinux (FXaI) | 11 days | 18/831 (2.2%)
| Enoxaparin (LMWH) | | 19/842 (2.3%)
| Fondaparinux 6–8 days (NA) | 32 days | 2/329 (0.6%)
| Fondaparinux 25–31 days (NA) | | 8/327 (2.4%)
Fisher 2013 23539696 | Semuloparin 28 days (NA) | 28 days | 1/312 (0.3%)
| Semuloparin 8 days (NA) | | 0/157 (0%)
Fuji 2014B 24680549 | Edoxaban (FXaI) | 25–35 days | 1/59 (1.7%)
| Enoxaparin (LMWH) | | 1/29 (3.4%)
Lassen 2012 22429800 HFx | Semuloparin (NA) | period from the first injection given during the study up to the last injection plus 3 calendar days days days | 5/488 (1.0%)
| Enoxaparin (NA) | | 3/499 (0.6%)
Powers 1989 2650646 | Placebo (Placebo) | 21 days | 5/63 (7.9%)
| Aspirin (Antiplatelet) | | 1/66 (1.5%)
| Warfarin (VKA) | | 5/65 (7.7%)
Sasaki 2011 21293896 | Placebo (Placebo) | 14 days | 0/29 (0%)
| Fondaparinux (FXaI) | | 2/27 (7.4%)
| Enoxaparin (LMWH) | | 0/28 (0%)
The TIFDED Study Group 1999 10844404 | Dalteparin (NA) | Post-operative days | 1/66 (1.5%)
| Enoxaparin (NA) | | 2/66 (3.0%)
Bleeding, Surgical site/joint
Eriksson 2003 12796070 | Fondaparinux 6–8 days (NA) | 32 days | 0/329 (0%)
- | Fondaparinux 25–31 days (NA) | | 6/327 (1.8%)
The TIFDED Study Group 1999 10844404 | Dalteparin (NA) | Post-operative days | 1/66 (1.5%)
| Enoxaparin (NA) | | 0/66 (0%)
DVT, Proximal
Eriksson 2001 11794148 | Fondaparinux (FXaI) | 11 days | 6/650 (0.9%)
| Enoxaparin (LMWH) | | 28/646 (4.3%)
Eriksson 2003 12796070 | Fondaparinux 6–8 days (NA) | 32 days | 35/222 (16%)
| Fondaparinux 25–31 days (NA) | | 2/221 (0.9%)
Fisher 2013 23539696 | Semuloparin 28 days (NA) | 28 days | 4/267 (1.5%)
| Semuloparin 8 days (NA) | | 11/127 (8.7%)
Fuji 2014B 24680549 | Edoxaban (FXaI) | 11–14 days | 0/46 (0%)
-- | Enoxaparin (LMWH) | | 0/27 (0%)
Lassen 2012 22429800 HFx | Semuloparin (NA) | 7–11 days | 13/426 (3.1%)
| Enoxaparin (NA) | | 26/420 (6.2%)
Monreal 1989 2544742 | Dalteparin (LMWH) | Post-operative days | 12/32 (38%)
| Heparin (UFH) | | 5/30 (17%)
Sasaki 2011 21293896 | Placebo (Placebo) | 14 days | 4/29 (14%)
| Fondaparinux (FXaI) | | 1/27 (3.7%)
| Enoxaparin (LMWH) | | 2/28 (7.1%)
The TIFDED Study Group 1999 10844404 | Dalteparin (NA) | Post-operative days | 3/57 (5.3%)
| Enoxaparin (NA) | | 2/52 (3.8%)
DVT, Symptomatic
Eriksson 2001 11794148 | Fondaparinux (FXaI) | 11 days | 1/831 (0.1%)
| Enoxaparin (LMWH) | | 1/840 (0.1%)
Eriksson 2003 12796070 | Fondaparinux 6–8 days (NA) | 32 days | 6/330 (1.8%)
| Fondaparinux 25–31 days (NA) | | 1/326 (0.3%)
Fuji 2014B 24680549 | Edoxaban (FXaI) | 11–14 days | 0/46 (0%)
| Enoxaparin (LMWH) | | 0/27 (0%)
Kennedy 2000 10697085 | Aspirin (Antiplatelet) | post-operative days | 4/73 (5.5%)
| VFP (AV impulse system) (Mechanical) | | 2/70 (2.9%)
The TIFDED Study Group 1999 10844404 | Dalteparin (NA) | Post-operative days | 0/57 (0%)
| Enoxaparin (NA) | | 0/52 (0%)
DVT, Total
Eriksson 2001 11794148 | Fondaparinux (FXaI) | 11 days | 49/624 (7.9%)
| Enoxaparin (LMWH) | | 117/623 (19%)
Eriksson 2003 12796070 | Fondaparinux 6–8 days (NA) | 32 days | 74/218 (34%)
| Fondaparinux 25–31 days (NA) | | 3/208 (1.4%)
Fisher 2013 23539696 | Semuloparin 28 days (NA) | 28 days | 9/230 (3.9%)
| Semuloparin 8 days (NA) | | 17/100 (17%)
Fuji 2014B 24680549 | Edoxaban (FXaI) | 11–14 days | 3/46 (6.5%)
| Enoxaparin (LMWH) | | 1/27 (3.7%)
Jørgensen 1992 1314147 | Placebo (Placebo) | Post-operative days | 18/38 (47%)
| Dalteparin (LMWH) | | 5/30 (17%)
Kennedy 2000 10697085 | Aspirin (NA) | post-operative days | 7/73 (9.6%)
- | VFP (AV impulse system) (NA) | | 4/70 (5.7%)
Lassen 2012 22429800 HFx | Semuloparin (NA) | 7–11 days | 63/379 (17%)
| Enoxaparin (NA) | | 79/367 (22%)
Monreal 1989 2544742 | Dalteparin (LMWH) | Post-operative days | 14/32 (44%)
| Heparin (UFH) | | 6/30 (20%)
Sasaki 2011 21293896 | Placebo (Placebo) | 14 days | 19/29 (66%)
| Fondaparinux (FXaI) | | 7/27 (26%)
| Enoxaparin (LMWH) | | 16/28 (57%)
The TIFDED Study Group 1999 10844404 | Dalteparin (NA) | Post-operative days | 5/57 (8.8%)
| Enoxaparin (NA) | | 8/52 (15%)
Major adverse event, other
Fisher 2013 23539696 | Semuloparin 28 days (NA) | 28 days | 6/312 (1.9%)
| Semuloparin 8 days (NA) | | 7/157 (4.5%)
Fuji 2014B 24680549 | Edoxaban (FXaI) | 25–35 days | 3/59 (5.1%)
| Enoxaparin (LMWH) | | 3/29 (10%)
Lassen 2012 22429800 HFx | Semuloparin (NA) | period from the first injection given during the study up to the last injection plus 3 calendar days days days | 28/488 (5.7%)
| Enoxaparin (NA) | | 27/499 (5.4%)
Mortality, 30 day or in-hospital (AE)
Eriksson 2001 11794148 | Fondaparinux (FXaI) | 49 days | 38/831 (4.6%)
| Enoxaparin (LMWH) | | 42/842 (5.0%)
Fisher 2013 23539696 | Semuloparin 28 days (NA) | 28 days | 0/312 (0%)
- | Semuloparin 8 days (NA) | | 2/157 (1.3%)
Jørgensen 1992 1314147 | Placebo (Placebo) | Post-operative days | 4/38 (11%)
| Dalteparin (LMWH) | | 3/30 (10%)
Lassen 2012 22429800 HFx | Semuloparin (NA) | 7–11 days | 4/488 (0.8%)
| Enoxaparin (NA) | | 2/499 (0.4%)
Monreal 1989 2544742 | Dalteparin (LMWH) | Post-operative days | 2/46 (4.3%)
| Heparin (UFH) | | 3/44 (6.8%)
PE, Fatal
Eriksson 2001 11794148 | Fondaparinux (FXaI) | 49 days | 8/831 (1.0%)
| Enoxaparin (LMWH) | | 7/840 (0.8%)
Eriksson 2003 12796070 | Fondaparinux 6–8 days (NA) | 32 days | 1/330 (0.3%)
| Fondaparinux 25–31 days (NA) | | 0/326 (0%)
Fisher 2013 23539696 | Semuloparin 28 days (NA) | 28 days | 0/312 (0%)
| Semuloparin 8 days (NA) | | 1/157 (0.6%)
F--uji 2014B 24680549 | Edoxaban (FXaI) | 11–14 days | 0/46 (0%)
| Enoxaparin (LMWH) | | 0/27 (0%)
Monreal 1989 2544742 | Dalteparin (LMWH) | Post-operative days | 0/46 (0%)
| Heparin (UFH) | | 0/44 (0%)
Powers 1989 2650646 | Placebo (Placebo) | 21 days | 0/63 (0%)
| Aspirin (Antiplatelet) | | 1/66 (1.5%)
| Warfarin (VKA) | | 0/65 (0%)
The TIFDED Study Group 1999 10844404 | Dalteparin (NA) | Post-operative days | 0/66 (0%)
| Enoxaparin (NA) | | 0/66 (0%)
PE, Symptomatic
Fuji 2014B 24680549 | Edoxaban (FXaI) | 11–14 days | 0/46 (0%)
| Enoxaparin (LMWH) | | 0/27 (0%)
Sasaki 2011 21293896 | Placebo (Placebo) | 14 days | 1/29 (3.4%)
| Fondaparinux (FXaI) | | 0/27 (0%)
| Enoxaparin (LMWH) | | 0/28 (0%)
PE, Total
Eriksson 2001 11794148 | Fondaparinux (FXaI) | 49 days | 11/831 (1.3%)
| Enoxaparin (LMWH) | | 11/840 (1.3%)
Eriksson 2003 12796070 | Fondaparinux 6–8 days (NA) | 32 days | 3/330 (0.9%)
| Fondaparinux 25–31 days (NA) | | 0/326 (0%)
Kennedy 2000 10697085 | Aspirin (Antiplatelet) | post-operative days | 1/73 (1.4%)
| VFP (AV impulse system) (Mechanical) | | 0/70 (0%)
Monreal 1989 2544742 | Dalteparin (LMWH) | Post-operative days | 6/46 (13%)
| Heparin (UFH) | | 0/44 (0%)
Powers 1989 2650646 | Placebo (Placebo) | 21 days | 2/63 (3.2%)
| Aspirin (Antiplatelet) | | 1/66 (1.5%)
| Warfarin (VKA) | | 0/65 (0%)
The TIFDED Study Group 1999 10844404 | Dalteparin (NA) | Post-operative days | 0/66 (0%)
| Enoxaparin (NA) | | 0/66 (0%)
VTE, Symptomatic
Eriksson 2001 11794148 | Fondaparinux (FXaI) | 49 days | 17/831 (2.0%)
| Enoxaparin (LMWH) | | 13/840 (1.5%)
Eriksson 2003 12796070 | Fondaparinux 6–8 days (NA) | 32 days | 9/330 (2.7%)
| Fondaparinux 25–31 days (NA) | | 1/326 (0.3%)
Fuji 2014B 24680549 | Edoxaban (FXaI) | 11–14 days | 0/46 (0%)
| Enoxaparin (LMWH) | | 0/27 (0%)
-VTE, Total
Fuji 2014B 24680549 | Edoxaban (FXaI) | 11–14 days | 3/46 (6.5%)
| Enoxaparin (LMWH) | | 1/27 (3.7%)

Table F4 NRCS total hip replacement

Study Year PMID Region | Timepoint | Arm | n/N (%) | Between Arms Comparison | Adjusted Hazard Ratio (95% CI) | Adjusted P-Value
Total Venous Thromboembolism
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >14 days | 7/376 (1.9) | Anticoagulation (mixed) >14 days vs. Anticoagulation (mixed) 1–14 days | | 0.33
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >21 days | 6/299 (2.0) | Anticoagulation (mixed) >21 days vs. Anticoagulation (mixed) 1–21 days | | 0.53
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >28 days | 3/229 (1.3) | Anticoagulation (mixed) >28 days vs Anticoagulation (mixed) 1–28 days | | 0.18
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–14 days | 23/747 (3.1)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–21 days | 24/824 (2.9)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–28 days | 27/894 (3.0)
Pedersen 2015 25511580 Denmark | 90 days | Anticoagulation (mixed) Short duration (0–6 days) | 54/4804 (1.1) | Anticoagulation (mixed) Short duration (0–6 days) vs. Anticoagulation (mixed) Extended duration (>=28 days) | 0.83 (0.52, 1.31)
Pedersen 2015 25511580 Denmark | 90 days | Anticoagulation (mixed) Standard duration (7–27 days) | 86/6362 (1.4) | Anticoagulation (mixed) Standard duration (7–27 days) vs. Anticoagulation (mixed) Extended duration (>=28 days) | 0.82 (0.50, 1.33)
Pedersen 2015 25511580 Denmark | 90 days | Anticoagulation (mixed) Extended duration (>=28 days) | 57/5699 (1.0)
Total Pulmonary Embolism
Bloch 2014 24395322 UK | 90 days | Dabigatran (DTI) | 2/415 (0.5)
Bloch 2014 24395322 UK | 90 days | LMWH + aspirin (antiplatelet) | 1/164 (0.6)
Bloch 2014 24395322 UK | 90 days | LMWH | 2/185 (1.1)
Ishibe 2011 22101618 Japan | 7 days | Fondaparinux (FXaI) | 0/547 (0)
Ishibe 2011 22101618 Japan | 7 days | Enoxaparin (LMWH) | 0/509 (0)
Jameson 2011 22058295 UK | 90 days | LMWH | 583/85642 (0.7) | LMWH vs Aspirin | 0.97 (0.81, 1.17) [propensity score matched: 0.94 (0.75, 1.17)] | 0.78 [0.56]
Jameson 2011 22058295 UK | 90 days | Aspirin (antiplatelet) | 156/22942 (0.7)
Khatod 2011 22005861 U.S. | 90 days | Coumadin (warfarin) + mechanical (SCD or VFP or TED hose) | 20/4602 (0.4)
Khatod 2011 22005861 U.S. | 90 days | Coumadin (warfarin) +/− mechanical (SCD or VFP or TED hose) | 26/6063 (0.4)
Khatod 2011 22005861 U.S. | 90 days | Coumadin (warfarin) | 6/1461 (0.41)
Khatod 2011 22005861 U.S. | 90 days | LMWH + mechanical (SCD or VFP or TED hose) | 27/6265 (0.43)
Khatod 2011 22005861 U.S. | 90 days | LMWH +/− mechanical (SCD or VFP or TED hose) | 29/7202 (0.43)
Khatod 2011 22005861 U.S. | 90 days | LMWH | 2/937 (0.21)
Khatod 2011 22005861 U.S. | 90 days | Aspirin (antiplatelet) + mechanical (SCD or VFP or TED hose) | 3/874 (0.34)
Khatod 2011 22005861 U.S. | 90 days | Aspirin (antiplatelet) +/− mechanical (SCD or VFP or TED hose) | 4/934 (0.43)
Khatod 2011 22005861 U.S. | 90 days | Aspirin (antiplatelet) | 1/60 (1.67)
Khatod 2011 22005861 U.S. | 90 days | SCD or VFP (mechanical) | 5/1341 (0.37)
Khatod 2011 22005861 U.S. | 90 days | Compression stockings (mechanical) | 0/192 (0)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >14 days | 1/376 (0.27) | Anticoagulation (mixed) >14 days vs, Anticoagulation (mixed) 1–14 days | | 0.28
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >21 days | 1/299 (0.33) | Anticoagulation (mixed) >21 days vs. Anticoagulation (mixed) 1–21 days | | 0.69
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >28 days | 1/229 (0.44) | Anticoagulation (mixed) >28 days vs. Anticoagulation (mixed) 1–28 days | | 1
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–14 days | 7/747 (0.94)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–21 days | 7/824 (0.85)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–28 days | 7/894 (0.78)
Fatal Pulmonary Embolism
Khatod 2011 22005861 U.S. | 90 days | Coumadin (warfarin) + mechanical (SCD or VFP or TED hose) | 0/4602 (0)
Khatod 2011 22005861 U.S. | 90 days | Coumadin (warfarin) +/− mechanical (SCD or VFP or TED hose) | 0/6063 (0)
Khatod 2011 22005861 U.S. | 90 days | Coumadin (warfarin) | | 0/1461 (0)
Khatod 2011 22005861 U.S. | 90 days | LMWH + mechanical (SCD or VFP or TED hose) | 1/6265 (0.02)
Khatod 2011 22005861 U.S. | 90 days | LMWH +/− mechanical (SCD or VFP or TED hose) | 1/7202 (0.01)
Khatod 2011 22005861 U.S. | 90 days | LMWH | 0/937 (0)
Khatod 2011 22005861 U.S. | 90 days | Aspirin (antiplatelet) + mechanical (SCD or VFP or TED hose) | 0/874 (0)
Khatod 2011 22005861 U.S. | 90 days | Aspirin (antiplatelet) +/− mechanical (SCD or VFP or TED hose) | 0/934 (0)
Khatod 2011 22005861 U.S. | 90 days | Aspirin (antiplatelet) | 0/60 (0)
Khatod 2011 22005861 U.S. | 90 days | SCD or VFP (mechanical) | 0/1341 (0)
Khatod 2011 22005861 U.S. | 90 days | Compression stockings (mechanical) | 0/192 (0)
Total Deep Vein Thrombosis
Bloch 2014 24395322 UK | 90 days | Dabigatran (DTI) | 1/415 (0.2)
Bloch 2014 24395322 UK | 90 days | LMWH + aspirin (antiplatelet) | 0/164 (0)
Bloch 2014 24395322 UK | 90 days | LMWH | 3/185 (1.6)
Ishibe 2011 22101618 Japan | 1 week | Fondaparinux (FXaI) | 4/547 (0.7) | Fondaparinux vs Enoxaparin | | NS (adjustment NR)
Ishibe 2011 22101618 Japan | 1 week | Enoxaparin (LMWH) | 0/509 (0)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >14 days | 6/376 (1.60) | Anticoagulation (mixed) >14 days vs, Anticoagulation (mixed) 1–14 days | | 0.65
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >21 days | 5/299 (1.67) | Anticoagulation (mixed) >21 days vs. Anticoagulation (mixed) 1–21 days | | 0.81
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >28 days | 2/229 (0.87) | Anticoagulation (mixed) >28 days vs. Anticoagulation (mixed) 1–28 days | | 0.28
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–14 days | 16/747 (2.14)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–21 days | 17/824 (2.06)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–28 days | 20/894 (2.24)
Symptomatic (diagnosed) DVT
Jameson 2011 22058295 UK | 90 days | LMWH | 806/85642 (0.94) | LMWH vs Aspirin | 0.91 (0.79, 1.06) [propensity score matched: 0.84 (0.70, 1.03)] | 0.23 [0.10]
Jameson 2011 22058295 UK | 90 days | Aspirin (antiplatelet) | 227/22942 (0.99)
Major Bleeding
Jameson 2011 22058295 UK | 30 days | LMWH | 620/85642 (0.72) | LMWH vs Aspirin | 0.92 (0.77, 1.09) [propensity score matched: 0.95 (0.77, 1.17)] | 0.34 [0.63]
Jameson 2011 22058295 UK | 30 days | Aspirin (antiplatelet) | 176/22942 (0.77)
Pedersen 2015 25511580 Denmark | 90 days | Anticoagulation (mixed) short duration (0–6 days) | 51/4804 (1.1) | Anticoagulation (mixed) Short duration (0–6 days) vs Anticoagulation (mixed) Extended duration (>=28 days) | HR 1.64 (0.83, 3.21)
Pedersen 2015 25511580 Denmark | 90 days | Anticoagulation (mixed) standard duration (7–27 days) | 66/6362 (1.0) | Anticoagulation (mixed) Standard duration (7–27 days) vs Anticoagulation (mixed) Extended duration (>=28 days) | HR 1.24 (0.61, 2.51)
Pedersen 2015 25511580 Denmark | 90 days | Anticoagulation (mixed) extended duration (>=28 days) | 37/5699 (0.7)
Vulcano 2012 22684546 U.S. | 90 days | Warfarin | 3/172 (1.74)
Vulcano 2012 22684546 U.S. | 90 days | Aspirin (antiplatelet) | 2/705 (0.28)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >14 days | 1/376 (0.27) | Anticoagulation (mixed) >14 days vs, Anticoagulation (mixed) 1–14 days | | 0.03
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >21 days | 0/299 (0) | Anticoagulation (mixed) >21 days vs. Anticoagulation (mixed) 1–21 days | | 0.02
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >28 days | 0/229 (0) | Anticoagulation (mixed) >28 days vs. Anticoagulation (mixed) 1–28 days | | 0.05
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–14 days | 14/747 (1.87)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–21 days | 15/824 (1.82)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–28 days | 15/894 (1.68)
Mortality, 30 day or in-hospital (AE) | Timepoint | Arm (Class) | n/N (%) | Between Arms Comparison | Adjusted Odds Ratio (95% CI) | Adjusted P-Value
Vulcano 2012 22684546 U.S. | 30 days | Warfarin | 0/172 (0)
Vulcano 2012 22684546 U.S. | 30 days | Aspirin (antiplatelet) | 1/705 (0.14)
Infection, Leading to reoperation
Jameson 2011 22058295 UK | 30 days | LMWH | 312/85642 (0.36) | LMWH vs Aspirin | 1.15 (0.88, 1.50) | 0.29
Jameson 2011 22058295 UK | 30 days | Aspirin (antiplatelet) | 71/22942 (0.31)

Abbreviations: DVT = deep vein thrombosis; PE = pulmonary embolism; LMWH = low molecular weight heparin; PMID = PubMed identifier, SCD = Sequential Compression Device; TED = Thromboembolic Deterrent; VFP = venous foot pump; PMID = PubMed identifier; DTI = direct thrombin inhibitor; FXaI = factor Xa inhibitor, NR = not reported;

Table F5 NRCS total knee replacement

Study Year PMID Region | Timepoint | Arm (Class) | n/N (%) | Between Arms Comparison | Adjusted Odds Ratio (95% CI) | Adjusted P-Value
Total Venous Thromboembolism
Bozic 2010 19679434 US | 30 days | Warfarin | 2009/51923 (3.87) | Warfarin vs Aspirin | 1.36 (1.02, 1.82)
Bozic 2010 19679434 US | 30 days | Aspirin (antiplatelet) | 110/4719 (2.33)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >14 days | 8/671 (1.19) | Anticoagulation (mixed) >14 days vs, Anticoagulation (mixed) 1–14 days | | <0.01
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >21 days | 5/532 (0.94) | Anticoagulation (mixed) >21 days vs. Anticoagulation (mixed) 1–21 days | | <0.01
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >28 days | 3/390 (0.77) | Anticoagulation (mixed) >28 days vs. Anticoagulation (mixed) 1–28 days | | <0.01
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–14 days | 62/1401 (4.43)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–21 days | 65/1540 (4.22)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–28 days | 67/1682 (3.98)
Llau 2011 Abstract 6AP3-2 Spain | 90 days | Enoxaparin (LMWH) (start before surgery) | 0/834 (0)
Llau 2011 Abstract 6AP3-2 Spain | 90 days | Enoxaparin (LMWH) (start after surgery) | 2/688 (0.29)
Total Pulmonary Embolism
Bloch 2014 24395322 UK | 90 days | Dabigatran (DTI) | 2/457 (0.4)
Bloch 2014 24395322 UK | 90 days | LMWH + aspirin (antiplatelet) | 0/141 (0)
Bloch 2014 24395322 UK | 90 days | LMWH | 1/366 (0.3)
Jameson 2012 22733945 UK | 90 days | LMWH | 539/120639 (0.45) | LMWH vs Aspirin | 0.88 (0.74, 1.05) | 0.16
Jameson 2012 22733945 UK | 90 days | Aspirin (antiplatelet) | 178/36159 (0.49)
Khatod 2012 21641758 U.S. | 90 days | Coumadin (warfarin) + mechanical | 23/7708 (0.30)
Khatod 2012 21641758 U.S. | 90 days | Coumadin (warfarin) +/− mechanical | 31/9634 (0.32)
Khatod 2012 21641758 U.S. | 90 days | Coumadin (warfarin) | 8/1926 (0.42)
Khatod 2012 21641758 U.S. | 90 days | LMWH + mechanical | 47/9128 (0.51)
Khatod 2012 21641758 U.S. | 90 days | LMWH +/− mechanical | 55/10662 (0.52)
Khatod 2012 21641758 U.S. | 90 days | LMWH | 8/1534 (0.52)
Khatod 2012 21641758 U.S. | 90 days | Aspirin (antiplatelet) + mechanical | 15/3479 (0.43)
Khatod 2012 21641758 U.S. | 90 days | Aspirin (antiplatelet) +/− mechanical | 16/3777 (0.42)
Khatod 2012 21641758 U.S. | 90 days | Aspirin (antiplatelet) | 1/298 (0.34)
Khatod 2012 21641758 U.S. | 90 days | SCD or VFP (mechanical) | 20/2779 (0.72)
Khatod 2012 21641758 U.S. | 90 days | Compression stockings (mechanical) | 1/280 (0.36)
Llau 2011 Abstract 6AP3-2 Spain | 90 days | Enoxaparin (LMWH) (start before surgery) | 4/834 (0.49)
Llau 2011 Abstract 6AP3-2 Spain | 90 days | Enoxaparin (LMWH) (start after syrgert) | 5/688 (0.74)
Rath 2013 23566737 UK | 90 days | Rivaroxaban (FXaI) | 24/266 (4)
Rath 2013 23566737 UK | 90 days | Aspirin (antiplatelet) +/− enoxaparin (LMWH) | 2/596 (0.7)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >14 days | 1/671 (0.15) | Anticoagulation (mixed) >14 days vs, Anticoagulation (mixed) 1–14 days | | 0.01
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >21 days | 0/532 (0) | Anticoagulation (mixed) >21 days vs. Anticoagulation (mixed) 1–21 days | | 0.01
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >28 days | 0/390 (0) | Anticoagulation (mixed) >28 days vs. Anticoagulation (mixed) 1–28 days | | 0.03
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–14 days | 17/1401 (1.21)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–21 days | 18/1540 (1.17)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–28 days | 18/1682 (1.07)
Fatal Pulmonary Embolism
Khatod 2012 21641758 U.S. | 90 days | LMWH + mechanical | 1/9128 (0.01)
Khatod 2012 21641758 U.S. | 90 days | LMWH +/− mechanical | 1/10662 (0.01)
Khatod 2012 21641758 U.S. | 90 days | LMWH | 0/1534 (0)
Khatod 2012 21641758 U.S. | 90 days | Coumadin (warfarin) + mechanical | 1/7708 (0.01)
Khatod 2012 21641758 U.S. | 90 days | Coumadin (warfarin) +/− mechanical | 1/9634 (0.01)
Khatod 2012 21641758 U.S. | 90 days | Coumadin (warfarin) | 0/1926 (0)
Khatod 2012 21641758 U.S. | 90 days | Aspirin (antiplatelet) + mechanical | 0/3479 (0)
Khatod 2012 21641758 U.S. | 90 days | Aspirin (antiplatelet) +/− mechanical | 0/3777 (0)
Khatod 2012 21641758 U.S. | 90 days | Aspirin (antiplatelet) | 0/298 (0)
Khatod 2012 21641758 U.S. | 90 days | SCD or VFP (mechanical) | 1/2779 (0.04)
Khatod 2012 21641758 U.S. | 90 days | Compression stockings (mechanical) | 0/280 (0)
Rath 2013 23566737 UK | 90 days | Rvaroxaban | 0/266 (0)
Rath 2013 23566737 UK | 90 days | Aspirin (antiplatelet) +/− enoxaparin (LMWH) | 0/596 (0)
Total Deep Vein Thrombosis
Bloch 2014 24395322 UK | 90 days | Dabigatran (DTI) | 5/457 (1.1)
Bloch 2014 24395322 UK | 90 days | LMWH + aspirin (antiplatelet) | 0/141 (0)
Bloch 2014 24395322 UK | 90 days | LMWH | 7/366 (1.9)
Jameson 2012 22733945 UK | 90 days | LMWH | 762/120639 (0.63) | LMWH vs Aspirin | 0.93 (0.81, 1.08) | 0.37
Jameson 2012 22733945 UK | 90 days | Aspirin (antiplatelet) | 239/36159 (0.66)
Kang 2015 25963358 China | 7 days | Foot pump (mechanical) + LMWH | 34/332 (10.24) | foot pump + LMWH vs LMWH | 0.91 (0.84, 1.01) | 0.09
Kang 2015 25963358 China | 7 days | LMWH | 141/693 (20.35)
Llau 2011 Abstract 6AP3-2 Spain | 90 days | Enoxaparin (LMWH) (start before surgery) | 8/834 (0.98)
Llau 2011 Abstract 6AP3-2 Spain | 90 days | Enoxaparin (LMWH) (start after surgery) | 8/688 (1.19)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >14 days | 7/671 (1.07) | Anticoagulation (mixed) >14 days vs, Anticoagulation (mixed) 1–14 days | | <0.01
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >21 days | 5/532 (0.94) | Anticoagulation (mixed) >21 days vs. Anticoagulation (mixed) 1–21 days | | 0.01
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >28 days | 3/390 (0.77) | Anticoagulation (mixed) >28 days vs. Anticoagulation (mixed) 1–28 days | | 0.01
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–14 days | 45/1401 (3.21)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–21 days | 47/1540 (3.05)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–28 days | 49/1682 (2.91)
Symptomatic Deep Vein Thrombosis
Rath 2013 23566737 UK | 90 days | Rivaroxaban (FXaI) | 2/266 (0.75) | rivaroxaban vs aspirin +/− enoxaparin | | 0.23 (adjustment NR)
Rath 2013 23566737 UK | 90 days | Aspirin (antiplatelet) +/− enoxaparin (LMWH) | 1/596 (0.17)
Major Bleeding
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >14 days | 3/671 (0.45) | Anticoagulation (mixed) >14 days vs, Anticoagulation (mixed) 1–14 days | | 0.03
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >21 days | 2/532 (0.38) | Anticoagulation (mixed) >21 days vs. Anticoagulation (mixed) 1–21 days | | 0.04
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) >28 days | 1/390 (0.26) | Anticoagulation (mixed) >28 days vs. Anticoagulation (mixed) 1–28 days | | 0.07
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–14 days | 22/1401 (1.57)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–21 days | 23/1540 (1.49)
Wells 2010 21348557 U.S. | 90 days | Anticoagulation (mixed) 1–28 days | 24/1682 (1.43)
Jameson 2012 22733945 UK | 30 days | LMWH | 465/120639 (0.39) | LMWH vs Aspirin | 1.01 (0.83, 1.22) | 0.94
| | Aspirin (antiplatelet) | 134/36159 (0.37)
Surgical Site Bleeding
Bozic 2010 19679434 US | 30 days | Warfarin | 548/51923 (1.06) | Warfarin vs Aspirin | 0.97 (0.65, 1.47)
Bozic 2010 19679434 US | 30 days | Aspirin (antiplatelet) | 30/4719 (0.64) | | | .
Mortality, 30 day or in-hospital
Bozic 2010 19679434 US | 30 days | Warfarin | 54/51923 (0.1) | Warfarin vs Aspirin | 0.54 (0.25, 1.15)
Bozic 2010 19679434 US | 30 days | Aspirin (antiplatelet) | 9/4719 (0.19)
Infection, Wound
Bozic 2010 19679434 US | 30 days | Warfarin | 6349/51923 (12.23) | Warfarin vs Aspirin | 1.10 (0.96, 1.26)
Bozic 2010 19679434 US | 30 days | Aspirin (antiplatelet) | 559/4719 (11.85)
Infection, Leading to reoperation
Jameson 2012 22733945 UK | 30 days | LMWH | 224/120639 (0.19) | LMWH vs Aspirin | 0.73 (0.58, 0.94)
Jameson 2012 22733945 UK | 30 days | Aspirin (antiplatelet) | 94/36159 (0.26)
Return to OR, bleeding or infection
Rath 2013 23566737 UK | 90 days | Rivaroxaban (FXaI) | 7/266 (2.6) | Rivaroxaban vs aspirin +/− enoxaparin | | 0.01 (adjustment NR)
Rath 2013 23566737 UK | 90 days | Aspirin (antiplatelet) +/− enoxaparin (LMWH) | 2/596 (0.3)

Abbreviations: DVT = deep vein thrombosis; VTE = venous thromboembolism; PE = pulmonary embolism; LMWH = low molecular weight heparin; SCD = Sequential Compression Device; TED = Thromboembolic Deterrent; VFP = venous foot pump; PMID = PubMed identifier; DTI = direct thrombin inhibitor; FXaI = factor Xa inhibitor; NR = not reported; OR = operating room

Table F6 NRCS hip fracture surgery

Study Year PMID Region | Timepoint | Arm (Class) | n/N (%) | Between Arms Comparator | Adjusted Odds Ratio (95% CI) | Adjusted P-Value
PE, Total
Tsuda 2014 25034972 Japan | Post-operative | Mechanical + Fondaparinux (FXaI) | 29/4792 (0.61) | Mechanical + fondaparinux vs Mechanical | 0.67 (0.44, 0.99) | 0.05
Tsuda 2014 25034972 Japan | Post-operative | Mechanical | 160/17984 (0.89)
PE, Fatal
Tsuda 2014 25034972 Japan | in hospital | Mechanical + Fondaparinux (FXaI) | 4/4792 (0.083) | Mechanical + fondaparinux vs Mechanical | | 0.53
Tsuda 2014 25034972 Japan | in hospital | Mechanical | 21/17984 (0.11)

Abbreviations: PE = pulmonary embolism; PMID = PubMed identifier; FXaI = factor Xa inhibitor

Table F7.1 Network meta-analysis pairwise results: Total hip replacement, intervention class comparisons of DVT

| LMWH +Mechanical | FXaI | DTI | FEI | Mechanical | Antiplatelet | LMWH | VKA | UFH | Placebo
LMWH +Mechanical | LMWH +Mechanical | 3.06 ( 1, 10.7) | 3.45 (1.08, 12.5) | 3.43 (0.582, 21.8) | 4.15 (1.25, 14.6) | 4.13 (1.04, 17.8) | 5.09 (1.77, 16.5) | 7.59 (2.37, 27.1) | 7.92 (2.59, 27.4) | 11.9 (3.98, 39.9)
FXaI | 0.327 (0.0938, 0.999) | FXaI | 1.13 (0.583, 2.14) | 1.11 (0.281, 4.38) | 1.35 (0.672, 2.61) | 1.34 (0.49, 3.53) | 1.66 (1.11, 2.44) | 2.48 (1.28, 4.64) | 2.58 ( 1.5, 4.47) | 3.86 (2.37, 6.32)
DTI | 0.289 (0.0801, 0.927) | 0.888 (0.466, 1.72) | DTI | 0.989 (0.216, 4.64) | 1.2 (0.563, 2.47) | 1.19 (0.418, 3.37) | 1.48 (0.879, 2.48) | 2.2 (1.06, 4.51) | 2.29 (1.33, 4.03) | 3.42 (1.86, 6.45)
FEI | 0.291 (0.0458, 1.72) | 0.899 (0.228, 3.55) | 1.01 (0.216, 4.62) | FEI | 1.21 (0.259, 5.49) | 1.21 (0.217, 6.45) | 1.49 (0.353, 6.26) | 2.23 (0.477, 10.1) | 2.32 (0.527, 10.2) | 3.47 (0.808, 15.1)
Mechanical | 0.241 (0.0685, 0.802) | 0.743 (0.384, 1.49) | 0.835 (0.405, 1.78) | 0.826 (0.182, 3.86) | Mechanical | 1 (0.367, 2.72) | 1.23 (0.72, 2.17) | 1.84 (1.03, 3.35) | 1.92 (1.04, 3.71) | 2.87 (1.56, 5.46)
Antiplatelet | 0.242 (0.0561, 0.965) | 0.744 (0.283, 2.04) | 0.838 (0.297, 2.39) | 0.826 (0.155, 4.6) | 1 (0.368, 2.73) | Antiplatelet | 1.24 (0.501, 3.11) | 1.84 (0.752, 4.63) | 1.92 (0.729, 5.23) | 2.87 (1.19, 7.3)
LMWH | 0.196 (0.0608, 0.566) | 0.601 (0.409, 0.9) | 0.677 (0.403, 1.14) | 0.671 (0.16, 2.83) | 0.81 (0.461, 1.39) | 0.808 (0.321, 2) | LMWH | 1.49 (0.883, 2.5) | 1.55 (1.07, 2.31) | 2.32 (1.65, 3.35)
VKA | 0.132 (0.0369, 0.422) | 0.404 (0.215, 0.78) | 0.455 (0.222, 0.941) | 0.448 (0.099, 2.1) | 0.544 (0.299, 0.968) | 0.542 (0.216, 1.33) | 0.67 ( 0.4, 1.13) | VKA | 1.04 (0.565, 1.98) | 1.56 (0.864, 2.91)
UFH | 0.126 (0.0365, 0.386) | 0.387 (0.224, 0.669) | 0.437 (0.248, 0.75) | 0.431 (0.098, 1.9) | 0.522 (0.27, 0.962) | 0.521 (0.191, 1.37) | 0.644 (0.434, 0.934) | 0.961 (0.504, 1.77) | UFH | 1.5 (0.905, 2.48)
Placebo | 0.0843 (0.0251, 0.251) | 0.259 (0.158, 0.423) | 0.292 (0.155, 0.538) | 0.288 (0.0664, 1.24) | 0.349 (0.183, 0.642) | 0.348 (0.137, 0.843) | 0.431 (0.298, 0.608) | 0.641 (0.344, 1.16) | 0.669 (0.404, 1.11) | Placebo

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all classes. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class. Statistically significant differences are bold.

Abbreviations: DTI = direct thrombin inhibitor, DVT = deep vein thrombosis, FEI = factor VIII inhibitor, FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, UFH = unfractionated heparin, VKA = vitamin K antagonist.

Table F7.2 Network meta-analysis pairwise results: Total hip replacement, specific intervention comparisons of DVT

| Enoxaparin+IPC | Apixaban | Edoxaban | Enoxaparin+GCS | Desirudin | Semuloparin | Fondaparinux | Darexaban | VFP | Dabigatran | Aspirin | Dalteparin | Enoxaparin | IPC | Rivaroxaban | TB402 | Heparin | Tinzaparin | Warfarin | Placebo
Enoxaparin+IPC | Enoxaparin+IPC | 5.88 (0.467, 231) | 7.4 (0.553, 296) | 7.77 (0.892, 261) | 10.7 (0.996, 394) | 10.3 (0.857, 411) | 12.5 (1.18, 473) | 13.1 (1.14, 509) | 13.4 ( 1.2, 500) | 16.6 (1.49, 618) | 17.4 (1.49, 672) | 18.4 (1.74, 687) | 19 (1.93, 674) | 20 (1.78, 790) | 24.9 ( 2.2, 935) | 28.2 (1.79, 1.3e+03) | 27.5 (2.78, 1e+03) | 28.2 (2.71, 1.05e+03) | 33.3 (3.11, 1.27e+03) | 46.1 (4.64, 1.66e+03)
Apixaban | 0.17 (0.004, 2.14) | Apixaban | 1.24 (0.282, 5.37) | 1.35 (0.281, 6.45) | 1.83 (0.584, 5.91) | 1.77 (0.464, 6.79) | 2.12 (0.709, 7.13) | 2.23 (0.629, 8.24) | 2.28 (0.673, 7.68) | 2.82 (0.847, 9.43) | 2.99 (0.801, 11.2) | 3.11 ( 1, 10.6) | 3.27 (1.23, 8.76) | 3.42 (0.989, 11.9) | 4.21 ( 1.2, 15) | 4.73 (0.785, 28.4) | 4.7 (1.69, 14.1) | 4.82 ( 1.6, 16) | 5.66 (1.81, 18.7) | 7.89 (2.83, 23.1)
Edoxaban | 0.135 (0.003, 1.81) | 0.806 (0.186, 3.54) | Edoxaban | 1.09 (0.206, 5.61) | 1.48 (0.43, 5.27) | 1.41 (0.336, 6.01) | 1.72 (0.507, 6.28) | 1.8 (0.459, 7.29) | 1.83 (0.493, 6.83) | 2.27 (0.63, 8.46) | 2.4 (0.588, 9.87) | 2.51 (0.742, 9.2) | 2.63 (0.898, 8.06) | 2.74 (0.727, 10.7) | 3.4 (0.877, 13.1) | 3.81 (0.597, 24.5) | 3.79 (1.23, 12.6) | 3.91 (1.17, 14) | 4.57 (1.32, 16.7) | 6.39 (2.07, 20.9)
Enoxaparin+GCS | 0.129 (0.004, 1.12) | 0.741 (0.155, 3.56) | 0.916 (0.178, 4.84) | Enoxaparin+GCS | 1.35 (0.355, 5.4) | 1.3 (0.287, 6.05) | 1.58 (0.421, 6.43) | 1.66 (0.388, 7.37) | 1.68 (0.414, 6.97) | 2.09 (0.519, 8.7) | 2.2 (0.498, 9.87) | 2.31 (0.617, 9.42) | 2.41 (0.724, 8.43) | 2.53 (0.61, 10.9) | 3.12 (0.742, 13.5) | 3.51 (0.519, 24) | 3.48 (1.01, 12.9) | 3.59 (0.965, 14.1) | 4.19 (1.12, 16.9) | 5.84 (1.73, 20.9)
Desirudin | 0.0936 (0.00254, 1) | 0.546 (0.169, 1.71) | 0.675 (0.19, 2.32) | 0.741 (0.185, 2.81) | Desirudin | 0.959 (0.314, 2.87) | 1.15 (0.513, 2.84) | 1.22 (0.443, 3.41) | 1.24 (0.501, 3.03) | 1.54 (0.613, 3.88) | 1.63 (0.566, 4.54) | 1.69 (0.782, 3.97) | 1.78 (0.963, 3.25) | 1.87 (0.713, 4.83) | 2.29 (0.853, 6.25) | 2.57 (0.516, 12.8) | 2.56 (1.48, 4.71) | 2.63 (1.18, 6.21) | 3.09 (1.36, 7.31) | 4.3 ( 2.2, 8.76)
Semuloparin | 0.0972 (0.002, 1.17) | 0.566 (0.147, 2.15) | 0.707 (0.166, 2.98) | 0.772 (0.165, 3.49) | 1.04 (0.348, 3.19) | Semuloparin | 1.2 (0.422, 3.91) | 1.27 (0.376, 4.45) | 1.3 (0.396, 4.1) | 1.61 (0.502, 5.13) | 1.7 (0.47, 6.01) | 1.77 (0.602, 5.69) | 1.86 (0.738, 4.74) | 1.94 (0.58, 6.5) | 2.39 (0.713, 8.27) | 2.68 (0.463, 15.8) | 2.67 (1.01, 7.57) | 2.74 (0.952, 8.6) | 3.21 (1.08, 10.2) | 4.48 ( 1.7, 12.6)
Fondaparinux | 0.0799 (0.002, 0.847) | 0.471 (0.14, 1.41) | 0.582 (0.159, 1.97) | 0.634 (0.155, 2.37) | 0.867 (0.352, 1.95) | 0.832 (0.256, 2.37) | Fondaparinux | 1.05 (0.372, 2.82) | 1.07 (0.402, 2.58) | 1.34 (0.502, 3.22) | 1.4 (0.458, 3.82) | 1.46 (0.621, 3.48) | 1.54 (0.804, 2.7) | 1.6 (0.58, 4.13) | 1.98 (0.711, 5.21) | 2.21 (0.424, 10.8) | 2.22 (1.07, 4.4) | 2.27 (0.981, 5.13) | 2.66 ( 1.1, 6.27) | 3.72 (1.85, 7.17)
Darexaban | 0.0764 (0.002, 0.873) | 0.448 (0.121, 1.59) | 0.556 (0.137, 2.18) | 0.603 (0.136, 2.58) | 0.821 (0.293, 2.26) | 0.789 (0.225, 2.66) | 0.957 (0.354, 2.69) | Darexaban | 1.02 (0.336, 2.96) | 1.27 (0.423, 3.67) | 1.33 (0.395, 4.3) | 1.4 (0.518, 3.94) | 1.46 (0.638, 3.31) | 1.53 (0.496, 4.62) | 1.88 (0.602, 5.82) | 2.11 (0.387, 11.3) | 2.11 (0.865, 5.26) | 2.17 (0.823, 5.9) | 2.54 (0.926, 7.07) | 3.54 (1.51, 8.38)
VFP | 0.0745 (0.002, 0.833) | 0.439 (0.13, 1.49) | 0.545 (0.146, 2.03) | 0.594 (0.143, 2.42) | 0.806 (0.331, 2) | 0.77 (0.244, 2.52) | 0.934 (0.387, 2.49) | 0.98 (0.338, 2.98) | VFP | 1.24 (0.468, 3.36) | 1.31 (0.434, 3.99) | 1.37 (0.574, 3.51) | 1.44 (0.707, 2.95) | 1.51 (0.547, 4.19) | 1.85 (0.652, 5.42) | 2.07 (0.406, 11) | 2.07 (1.02, 4.49) | 2.12 (0.895, 5.43) | 2.5 (1.02, 6.38) | 3.48 (1.68, 7.59)
Dabigatran | 0.0601 (0.002, 0.67) | 0.355 (0.106, 1.18) | 0.44 (0.118, 1.59) | 0.479 (0.115, 1.93) | 0.65 (0.258, 1.63) | 0.623 (0.195, 1.99) | 0.748 (0.311, 1.99) | 0.789 (0.272, 2.37) | 0.806 (0.297, 2.14) | Dabigatran | 1.06 (0.339, 3.2) | 1.1 (0.448, 2.92) | 1.16 (0.58, 2.32) | 1.21 (0.429, 3.35) | 1.49 (0.514, 4.32) | 1.68 (0.318, 8.85) | 1.67 (0.777, 3.76) | 1.71 (0.713, 4.38) | 2.01 (0.803, 5.23) | 2.8 ( 1.3, 6.27)
Aspirin | 0.0574 (0.001, 0.67) | 0.334 (0.0892, 1.25) | 0.417 (0.101, 1.7) | 0.455 (0.101, 2.01) | 0.615 (0.22, 1.77) | 0.589 (0.166, 2.13) | 0.714 (0.262, 2.18) | 0.751 (0.233, 2.53) | 0.765 (0.251, 2.31) | 0.946 (0.312, 2.95) | Aspirin | 1.05 (0.422, 2.84) | 1.09 (0.458, 2.69) | 1.15 (0.415, 3.16) | 1.41 (0.449, 4.61) | 1.59 (0.29, 8.91) | 1.58 (0.644, 4.14) | 1.62 (0.646, 4.35) | 1.9 (0.828, 4.54) | 2.65 (1.17, 6.43)
Dalteparin | 0.0544 (0.001, 0.574) | 0.322 (0.0947, 1) | 0.399 (0.109, 1.35) | 0.433 (0.106, 1.62) | 0.59 (0.252, 1.28) | 0.566 (0.176, 1.66) | 0.684 (0.288, 1.61) | 0.713 (0.254, 1.93) | 0.729 (0.285, 1.74) | 0.908 (0.343, 2.23) | 0.957 (0.353, 2.37) | Dalteparin | 1.05 (0.543, 1.91) | 1.1 (0.467, 2.37) | 1.35 (0.482, 3.53) | 1.52 (0.291, 7.38) | 1.51 (0.813, 2.74) | 1.55 (0.745, 3.23) | 1.82 (0.998, 3.2) | 2.53 (1.33, 4.71)
Enoxaparin | 0.0526 (0.001, 0.519) | 0.306 (0.114, 0.813) | 0.38 (0.124, 1.11) | 0.416 (0.119, 1.38) | 0.56 (0.307, 1.04) | 0.538 (0.211, 1.36) | 0.648 (0.371, 1.24) | 0.684 (0.302, 1.57) | 0.696 (0.339, 1.42) | 0.864 (0.432, 1.72) | 0.913 (0.372, 2.18) | 0.952 (0.525, 1.84) | Enoxaparin | 1.04 (0.482, 2.25) | 1.29 (0.581, 2.85) | 1.45 (0.32, 6.42) | 1.44 (0.998, 2.17) | 1.48 (0.844, 2.76) | 1.73 (0.94, 3.33) | 2.42 ( 1.7, 3.56)
IPC | 0.05 (0.001, 0.563) | 0.292 (0.0838, 1.01) | 0.364 (0.0931, 1.38) | 0.396 (0.0915, 1.64) | 0.535 (0.207, 1.4) | 0.514 (0.154, 1.72) | 0.624 (0.242, 1.72) | 0.654 (0.217, 2.01) | 0.664 (0.238, 1.83) | 0.824 (0.298, 2.33) | 0.873 (0.316, 2.41) | 0.911 (0.422, 2.14) | 0.958 (0.445, 2.07) | IPC | 1.23 (0.418, 3.72) | 1.38 (0.26, 7.46) | 1.38 (0.62, 3.19) | 1.41 (0.627, 3.38) | 1.66 (0.902, 3.19) | 2.31 (1.06, 5.21)
Rivaroxaban | 0.0402 (0.001, 0.454) | 0.238 (0.0665, 0.836) | 0.294 (0.0762, 1.14) | 0.321 (0.0739, 1.35) | 0.436 (0.16, 1.17) | 0.418 (0.121, 1.4) | 0.504 (0.192, 1.41) | 0.531 (0.172, 1.66) | 0.54 (0.184, 1.53) | 0.67 (0.232, 1.95) | 0.709 (0.217, 2.23) | 0.739 (0.283, 2.07) | 0.775 (0.35, 1.72) | 0.812 (0.269, 2.39) | Rivaroxaban | 1.12 (0.316, 3.98) | 1.12 (0.473, 2.74) | 1.15 (0.448, 3.07) | 1.35 (0.499, 3.75) | 1.87 (0.838, 4.37)
TB402 | 0.0355 (0.001, 0.559) | 0.211 (0.0352, 1.27) | 0.262 (0.0409, 1.68) | 0.285 (0.0417, 1.93) | 0.389 (0.0783, 1.94) | 0.373 (0.0634, 2.16) | 0.452 (0.0924, 2.36) | 0.473 (0.0883, 2.59) | 0.482 (0.091, 2.46) | 0.597 (0.113, 3.15) | 0.631 (0.112, 3.45) | 0.66 (0.136, 3.44) | 0.692 (0.156, 3.13) | 0.726 (0.134, 3.85) | 0.893 (0.252, 3.17) | TB402 | 0.999 (0.219, 4.76) | 1.03 (0.213, 5.14) | 1.2 (0.243, 6.2) | 1.68 (0.377, 7.79)
Heparin | 0.0364 (0.001, 0.36) | 0.213 (0.0708, 0.593) | 0.264 (0.0794, 0.815) | 0.288 (0.0775, 0.991) | 0.39 (0.212, 0.678) | 0.375 (0.132, 0.989) | 0.451 (0.227, 0.932) | 0.474 (0.19, 1.16) | 0.483 (0.223, 0.984) | 0.6 (0.266, 1.29) | 0.634 (0.242, 1.55) | 0.661 (0.365, 1.23) | 0.694 (0.461, 1) | 0.726 (0.314, 1.61) | 0.894 (0.366, 2.12) | 1 (0.21, 4.57) | Heparin | 1.03 (0.531, 2.01) | 1.21 (0.615, 2.35) | 1.68 (1.03, 2.72)
Tinzaparin | 0.0355 (0.001, 0.369) | 0.208 (0.0627, 0.625) | 0.256 (0.0714, 0.854) | 0.279 (0.0711, 1.04) | 0.38 (0.161, 0.844) | 0.365 (0.116, 1.05) | 0.44 (0.195, 1.02) | 0.461 (0.169, 1.22) | 0.472 (0.184, 1.12) | 0.585 (0.228, 1.4) | 0.617 (0.23, 1.55) | 0.644 (0.31, 1.34) | 0.677 (0.363, 1.18) | 0.708 (0.296, 1.59) | 0.872 (0.325, 2.23) | 0.975 (0.195, 4.69) | 0.974 (0.498, 1.88) | Tinzaparin | 1.17 (0.603, 2.25) | 1.64 (0.918, 2.87)
Warfarin | 0.03 (0.001, 0.322) | 0.177 (0.0534, 0.552) | 0.219 (0.06, 0.758) | 0.239 (0.0593, 0.89) | 0.324 (0.137, 0.738) | 0.311 (0.0979, 0.923) | 0.376 (0.16, 0.907) | 0.394 (0.141, 1.08) | 0.401 (0.157, 0.976) | 0.498 (0.191, 1.24) | 0.525 (0.22, 1.21) | 0.55 (0.312, 1) | 0.578 ( 0.3, 1.06) | 0.603 (0.313, 1.11) | 0.742 (0.267, 2) | 0.831 (0.161, 4.11) | 0.829 (0.426, 1.63) | 0.853 (0.444, 1.66) | Warfarin | 1.4 (0.741, 2.63)
Placebo | 0.0217 (0.001, 0.216) | 0.127 (0.0434, 0.353) | 0.157 (0.0478, 0.484) | 0.171 (0.0478, 0.579) | 0.232 (0.114, 0.455) | 0.223 (0.0795, 0.589) | 0.269 (0.139, 0.542) | 0.282 (0.119, 0.66) | 0.287 (0.132, 0.596) | 0.358 (0.159, 0.77) | 0.378 (0.155, 0.854) | 0.395 (0.212, 0.755) | 0.413 (0.281, 0.59) | 0.432 (0.192, 0.946) | 0.534 (0.229, 1.19) | 0.597 (0.128, 2.65) | 0.596 (0.367, 0.972) | 0.611 (0.349, 1.09) | 0.717 (0.381, 1.35) | Placebo

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all interventions. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class. Statistically significant differences are bold.

Abbreviations: DVT = deep vein thrombosis, GCS = graduated compression stocking, IPC = intermittent pneumatic compression, THR = total hip replacement, VFP = venous foot pump.

Table F7.3 Network meta-analysis pairwise results: Total hip replacement, intervention class comparisons of major bleeding

| Mechanical | Antiplatelet | VKA | Placebo | LMWH | DTI | FXaI | UFH | FEI
Mechanical | Mechanical | <0.01 (<0.01, >100) | >100 ( 11, >100) | >100 (14.5, >100) | >100 (21.6, >100) | >100 (27.4, >100) | >100 (29.5, >100) | >100 ( 48, >100) | >100 (>100, >100)
Antiplatelet | >100 (<0.01, >100) | Antiplatelet | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (>100, >100)
VKA | <0.01 (<0.01, 0.091) | <0.01 (<0.01, >100) | VKA | 1.57 (0.43, 5.21) | 1.96 ( 1.1, 3.68) | 2.54 (1.25, 5.44) | 2.65 (1.31, 5.4) | 4.27 (1.92, 10.1) | >100 (>100, >100)
Placebo | <0.01 (<0.01, 0.0688) | <0.01 (<0.01, >100) | 0.637 (0.192, 2.32) | Placebo | 1.26 (0.451, 4.09) | 1.63 (0.538, 5.63) | 1.7 (0.576, 5.48) | 2.77 (0.832, 9.79) | >100 (>100, >100)
LMWH | <0.01 (<0.01, 0.0463) | <0.01 (<0.01, >100) | 0.509 (0.272, 0.906) | 0.793 (0.244, 2.22) | LMWH | 1.29 (0.841, 2.01) | 1.34 (0.93, 1.91) | 2.18 (1.22, 3.91) | >100 (>100, >100)
DTI | <0.01 (<0.01, 0.0365) | <0.01 (<0.01, >100) | 0.393 (0.184, 0.799) | 0.613 (0.178, 1.86) | 0.775 (0.498, 1.19) | DTI | 1.04 (0.585, 1.8) | 1.69 (0.808, 3.42) | >100 ( 91, >100)
FXaI | <0.01 (<0.01, 0.0339) | <0.01 (<0.01, >100) | 0.377 (0.185, 0.761) | 0.589 (0.182, 1.74) | 0.744 (0.524, 1.08) | 0.96 (0.555, 1.71) | FXaI | 1.63 (0.815, 3.24) | >100 (>100, >100)
UFH | <0.01 (<0.01, 0.0208) | <0.01 (<0.01, >100) | 0.234 (0.0991, 0.522) | 0.361 (0.102, 1.2) | 0.459 (0.256, 0.82) | 0.593 (0.292, 1.24) | 0.615 (0.309, 1.23) | UFH | >100 ( 49, >100)
FEI | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, 0.011) | <0.01 (<0.01, 0.0117) | <0.01 (<0.01, 0.0204) | FEI

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all classes. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class. Statistically significant differences are bold.

Abbreviations: DTI = direct thrombin inhibitor, FEI = factor VIII inhibitor, FXaI = factor Xa inhibitor, LMWH = low molecular weight heparin, THR = total hip replacement, UFH = unfractionated heparin, VKA = vitamin K antagonist.

Table F7.4 Network meta-analysis pairwise results: Total hip replacement, specific intervention comparisons of major bleeding

| IPC | Semuloparin | Warfarin | Dalteparin | Tinzaparin | Edoxaban | Placebo | Enoxaparin | Darexaban | Desirudin | Rivaroxaban | Apixaban | Dabigatran | Fondaparinux | Heparin | Aspirin | TB402
IPC | IPC | >100 (11.2, >100) | >100 ( 15, >100) | >100 ( 21, >100) | >100 (26.5, >100) | >100 (27.9, >100) | >100 (31.4, >100) | >100 (47.1, >100) | >100 (19.9, >100) | >100 (44.5, >100) | >100 ( 48, >100) | >100 (55.3, >100) | >100 (66.6, >100) | >100 (73.3, >100) | >100 (90.6, >100) | >100 (<0.01, >100) | >100 (>100, >100)
Semuloparin | <0.01 (<0.01, 0.0892) | Semuloparin | 1.33 (0.26, 7.41) | 2.07 (0.288, 14.8) | 2.32 (0.39, 14.8) | 2.47 (0.342, 20.2) | 2.85 (0.504, 18) | 3.79 (1.07, 16.1) | 3.93 (0.0826, 224) | 3.76 (0.77, 21.1) | 4.27 (0.816, 25.1) | 4.65 (0.96, 26.8) | 5.59 (1.37, 27.2) | 6.09 (1.47, 30.4) | 7.99 (1.89, 38.9) | >100 (<0.01, >100) | >100 (85.7, >100)
Warfarin | <0.01 (<0.01, 0.0667) | 0.754 (0.135, 3.84) | Warfarin | 1.53 (0.519, 4.69) | 1.74 ( 0.6, 5.04) | 1.83 (0.326, 11.1) | 2.15 (0.462, 9.82) | 2.81 (1.13, 8.15) | 2.85 (0.0721, 154) | 2.78 (0.774, 11.7) | 3.13 (0.805, 13.9) | 3.46 (0.955, 14.4) | 4.13 (1.39, 14.5) | 4.52 ( 1.5, 15.8) | 5.99 (1.91, 20.5) | >100 (<0.01, >100) | >100 (65.4, >100)
Dalteparin | <0.01 (<0.01, 0.0475) | 0.483 (0.0677, 3.47) | 0.654 (0.213, 1.93) | Dalteparin | 1.11 (0.247, 5.24) | 1.19 (0.172, 9.14) | 1.38 (0.217, 8.85) | 1.85 (0.451, 8.35) | 1.86 (0.0404, 110) | 1.8 (0.348, 11) | 2.05 (0.368, 12.6) | 2.25 (0.43, 13.5) | 2.7 (0.594, 14) | 2.97 (0.644, 15.2) | 3.93 (0.811, 19.3) | >100 (<0.01, >100) | >100 (38.6, >100)
Tinzaparin | <0.01 (<0.01, 0.0377) | 0.43 (0.0677, 2.57) | 0.576 (0.198, 1.67) | 0.898 (0.191, 4.06) | Tinzaparin | 1.06 (0.16, 7.9) | 1.24 (0.226, 6.71) | 1.64 (0.499, 5.94) | 1.63 (0.0387, 88.7) | 1.62 (0.366, 8.07) | 1.8 (0.383, 9.55) | 2 (0.445, 10.1) | 2.41 (0.644, 10.1) | 2.62 (0.698, 11.2) | 3.48 (0.873, 14.4) | >100 (<0.01, >100) | >100 (37.1, >100)
Edoxaban | <0.01 (<0.01, 0.0358) | 0.404 (0.0495, 2.92) | 0.546 (0.0901, 3.07) | 0.841 (0.109, 5.82) | 0.947 (0.127, 6.24) | Edoxaban | 1.19 (0.17, 7.65) | 1.52 (0.347, 7.08) | 1.57 (0.0327, 79.8) | 1.52 (0.259, 9.08) | 1.7 (0.281, 10.6) | 1.9 (0.319, 10.9) | 2.24 (0.454, 11.5) | 2.45 (0.483, 12.7) | 3.25 (0.607, 17.3) | >100 (<0.01, >100) | >100 (32.5, >100)
Placebo | <0.01 (<0.01, 0.0319) | 0.35 (0.0556, 1.98) | 0.466 (0.102, 2.16) | 0.722 (0.113, 4.62) | 0.806 (0.149, 4.43) | 0.843 (0.131, 5.88) | Placebo | 1.33 (0.436, 4.4) | 1.33 (0.0358, 68.7) | 1.32 (0.306, 5.96) | 1.48 (0.394, 5.8) | 1.63 (0.381, 7.58) | 1.96 (0.542, 7.69) | 2.13 (0.581, 8.56) | 2.82 (0.753, 10.8) | >100 (<0.01, >100) | >100 (30.5, >100)
Enoxaparin | <0.01 (<0.01, 0.0212) | 0.264 (0.062, 0.932) | 0.356 (0.123, 0.884) | 0.541 (0.12, 2.22) | 0.609 (0.168, 2) | 0.656 (0.141, 2.88) | 0.75 (0.227, 2.29) | Enoxaparin | 0.987 (0.0277, 44) | 0.99 (0.387, 2.52) | 1.11 (0.395, 3.11) | 1.22 (0.476, 3.17) | 1.46 (0.806, 2.75) | 1.6 (0.849, 3.11) | 2.12 (1.04, 4.04) | >100 (<0.01, >100) | >100 (25.6, >100)
Darexaban | <0.01 (<0.01, 0.0503) | 0.254 (0.00447, 12.1) | 0.35 (0.00651, 13.9) | 0.538 (0.00906, 24.8) | 0.615 (0.0113, 25.8) | 0.638 (0.0125, 30.6) | 0.749 (0.0146, 28) | 1.01 (0.0227, 36.1) | Darexaban | 0.996 (0.0199, 40.5) | 1.13 (0.0218, 44) | 1.22 (0.0247, 46.1) | 1.43 (0.0308, 55) | 1.6 (0.0336, 61.2) | 2.12 (0.0439, 81.7) | >100 (<0.01, >100) | >100 (14.5, >100)
Desirudin | <0.01 (<0.01, 0.0225) | 0.266 (0.0475, 1.3) | 0.359 (0.0853, 1.29) | 0.554 (0.091, 2.87) | 0.619 (0.124, 2.73) | 0.66 (0.11, 3.87) | 0.758 (0.168, 3.27) | 1.01 (0.396, 2.58) | 1 (0.0247, 50.2) | Desirudin | 1.13 (0.273, 4.51) | 1.23 (0.327, 4.68) | 1.48 (0.484, 4.59) | 1.61 (0.519, 5.1) | 2.15 (0.64, 6.5) | >100 (<0.01, >100) | >100 (24.6, >100)
Rivaroxaban | <0.01 (<0.01, 0.0208) | 0.234 (0.0399, 1.22) | 0.319 (0.0721, 1.24) | 0.487 (0.0795, 2.72) | 0.557 (0.105, 2.61) | 0.587 (0.0947, 3.55) | 0.674 (0.172, 2.54) | 0.901 (0.321, 2.53) | 0.888 (0.0227, 45.8) | 0.888 (0.221, 3.67) | Rivaroxaban | 1.1 (0.268, 4.5) | 1.32 (0.396, 4.41) | 1.44 (0.429, 4.97) | 1.91 (0.543, 6.41) | >100 (<0.01, >100) | >100 (21.9, >100)
Apixaban | <0.01 (<0.01, 0.0181) | 0.215 (0.0374, 1.04) | 0.289 (0.0692, 1.05) | 0.444 (0.0741, 2.33) | 0.501 (0.0988, 2.25) | 0.525 (0.0919, 3.14) | 0.614 (0.132, 2.62) | 0.82 (0.316, 2.1) | 0.82 (0.0217, 40.5) | 0.81 (0.214, 3.06) | 0.905 (0.222, 3.73) | Apixaban | 1.19 (0.394, 3.76) | 1.31 (0.421, 4.08) | 1.74 (0.518, 5.22) | >100 (<0.01, >100) | >100 (19.1, >100)
Dabigatran | <0.01 (<0.01, 0.015) | 0.179 (0.0368, 0.731) | 0.242 (0.0691, 0.718) | 0.371 (0.0712, 1.68) | 0.416 (0.0991, 1.55) | 0.446 (0.0869, 2.2) | 0.511 (0.13, 1.85) | 0.685 (0.364, 1.24) | 0.698 (0.0182, 32.5) | 0.676 (0.218, 2.07) | 0.757 (0.227, 2.53) | 0.838 (0.266, 2.54) | Dabigatran | 1.1 (0.444, 2.65) | 1.45 (0.551, 3.44) | >100 (<0.01, >100) | >100 (16.8, >100)
Fondaparinux | <0.01 (<0.01, 0.0136) | 0.164 (0.0329, 0.682) | 0.221 (0.0633, 0.666) | 0.337 (0.0656, 1.55) | 0.382 (0.0893, 1.43) | 0.408 (0.0789, 2.07) | 0.468 (0.117, 1.72) | 0.623 (0.321, 1.18) | 0.624 (0.0163, 29.7) | 0.62 (0.196, 1.93) | 0.693 (0.201, 2.33) | 0.765 (0.245, 2.38) | 0.911 (0.378, 2.25) | Fondaparinux | 1.33 (0.492, 3.13) | >100 (<0.01, >100) | >100 (15.5, >100)
Heparin | <0.01 (<0.01, 0.011) | 0.125 (0.0257, 0.529) | 0.167 (0.0488, 0.524) | 0.254 (0.0519, 1.23) | 0.287 (0.0693, 1.15) | 0.307 (0.0579, 1.65) | 0.355 (0.0926, 1.33) | 0.471 (0.247, 0.965) | 0.472 (0.0122, 22.8) | 0.465 (0.154, 1.56) | 0.524 (0.156, 1.84) | 0.574 (0.191, 1.93) | 0.688 (0.291, 1.82) | 0.752 (0.319, 2.03) | Heparin | >100 (<0.01, >100) | >100 (12.1, >100)
Aspirin | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | Aspirin | <0.01 (<0.01, >100)
TB402 | <0.01 (<0.01, <0.01) | <0.01 (<0.01, 0.0117) | <0.01 (<0.01, 0.0153) | <0.01 (<0.01, 0.0259) | <0.01 (<0.01, 0.0269) | <0.01 (<0.01, 0.0307) | <0.01 (<0.01, 0.0327) | <0.01 (<0.01, 0.0391) | <0.01 (<0.01, 0.0689) | <0.01 (<0.01, 0.0407) | <0.01 (<0.01, 0.0456) | <0.01 (<0.01, 0.0522) | <0.01 (<0.01, 0.0596) | <0.01 (<0.01, 0.0647) | <0.01 (<0.01, 0.0828) | >100 (<0.01, >100) | TB402

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all interventions. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class. Statistically significant differences are bold.

Abbreviations: IPC = intermittent pneumatic compression, THR = total hip replacement.

Table F7.5 Network meta-analysis pairwise results: Total knee replacement, intervention class comparisons of DVT

| LMWH+Mechanical | FXaI | Antiplatelet+Mechanical | DTI | FXIi | LMWH | FXaI+Mechanical | Mechanical | UFH | VKA | Antiplatelet | Placebo
LMWH+Mechanical | LMWH+Mechanical | 1.14 (0.495, 2.54) | 1.15 (0.598, 2.27) | 1.37 (0.514, 3.47) | 1.88 (0.661, 5.45) | 2.4 (1.09, 5.32) | 2.4 (0.686, 8.15) | 2.55 (1.02, 6.22) | 3.56 (1.46, 8.5) | 4.36 (1.89, 9.94) | 4.94 (2.16, 11.1) | 7.17 (3.09, 17.2)
FXaI | 0.88 (0.393, 2.02) | FXaI | 1.02 (0.439, 2.34) | 1.21 (0.684, 2.07) | 1.68 (0.804, 3.51) | 2.12 ( 1.7, 2.71) | 2.1 (0.874, 5.31) | 2.24 (1.34, 3.83) | 3.13 (1.98, 5.06) | 3.83 (2.77, 5.55) | 4.34 (2.71, 7.13) | 6.37 (4.47, 9.15)
Antiplatelet+Mechanical | 0.872 (0.441, 1.67) | 0.981 (0.428, 2.28) | Antiplatelet+Mechanical | 1.18 (0.447, 3.12) | 1.64 (0.559, 5) | 2.08 (0.925, 4.8) | 2.09 (0.594, 7.3) | 2.2 (0.892, 5.55) | 3.07 (1.25, 7.79) | 3.8 (1.63, 8.89) | 4.27 (1.98, 9.51) | 6.22 (2.62, 15.4)
DTI | 0.732 (0.288, 1.95) | 0.829 (0.483, 1.46) | 0.845 (0.321, 2.24) | DTI | 1.39 (0.586, 3.36) | 1.76 (1.07, 3.03) | 1.77 (0.611, 5.11) | 1.87 (0.923, 3.72) | 2.59 (1.37, 5.16) | 3.2 (1.82, 5.87) | 3.62 (1.87, 7.24) | 5.27 (3.23, 8.93)
FXIi | 0.533 (0.184, 1.51) | 0.597 (0.285, 1.24) | 0.61 ( 0.2, 1.79) | 0.721 (0.298, 1.71) | FXIi | 1.27 (0.63, 2.55) | 1.26 (0.393, 4.18) | 1.35 (0.568, 3.12) | 1.88 (0.837, 4.17) | 2.3 ( 1.1, 4.86) | 2.61 (1.14, 5.98) | 3.81 (1.74, 8.12)
LMWH | 0.417 (0.188, 0.92) | 0.473 (0.37, 0.587) | 0.48 (0.208, 1.08) | 0.568 (0.33, 0.938) | 0.788 (0.393, 1.59) | LMWH | 0.989 (0.396, 2.53) | 1.06 (0.652, 1.71) | 1.48 (0.984, 2.23) | 1.81 (1.41, 2.38) | 2.05 (1.33, 3.2) | 3 (2.15, 4.15)
FXaI+Mechanical | 0.417 (0.123, 1.46) | 0.476 (0.188, 1.14) | 0.479 (0.137, 1.68) | 0.566 (0.196, 1.64) | 0.792 (0.239, 2.55) | 1.01 (0.394, 2.53) | FXaI+Mechanical | 1.06 (0.369, 3.05) | 1.49 (0.529, 4.08) | 1.83 (0.691, 4.76) | 2.08 (0.727, 5.73) | 3.03 (1.13, 7.79)
Mechanical | 0.393 (0.161, 0.977) | 0.446 (0.261, 0.747) | 0.456 (0.18, 1.12) | 0.534 (0.269, 1.08) | 0.742 (0.321, 1.76) | 0.945 (0.584, 1.53) | 0.942 (0.328, 2.71) | Mechanical | 1.4 (0.75, 2.62) | 1.71 (1.01, 2.93) | 1.95 (1.12, 3.36) | 2.83 (1.64, 4.94)
UFH | 0.281 (0.118, 0.686) | 0.32 (0.197, 0.504) | 0.326 (0.128, 0.8) | 0.386 (0.194, 0.728) | 0.531 (0.24, 1.2) | 0.677 (0.448, 1.02) | 0.671 (0.245, 1.89) | 0.714 (0.382, 1.33) | UFH | 1.22 (0.762, 2.02) | 1.39 (0.762, 2.54) | 2.03 (1.19, 3.42)
VKA | 0.229 (0.101, 0.53) | 0.261 (0.18, 0.361) | 0.263 (0.112, 0.612) | 0.312 (0.17, 0.549) | 0.435 (0.206, 0.909) | 0.553 (0.421, 0.709) | 0.547 (0.21, 1.45) | 0.584 (0.341, 0.987) | 0.817 (0.495, 1.31) | VKA | 1.13 (0.715, 1.79) | 1.66 (1.07, 2.49)
Antiplatelet | 0.203 (0.0898, 0.463) | 0.231 (0.14, 0.37) | 0.234 (0.105, 0.506) | 0.276 (0.138, 0.534) | 0.383 (0.167, 0.877) | 0.488 (0.313, 0.752) | 0.48 (0.175, 1.38) | 0.513 (0.298, 0.89) | 0.719 (0.394, 1.31) | 0.888 (0.559, 1.4) | Antiplatelet | 1.46 (0.857, 2.47)
Placebo | 0.14 (0.0583, 0.324) | 0.157 (0.109, 0.224) | 0.161 (0.065, 0.382) | 0.19 (0.112, 0.31) | 0.262 (0.123, 0.573) | 0.334 (0.241, 0.464) | 0.331 (0.128, 0.883) | 0.353 (0.202, 0.609) | 0.492 (0.292, 0.843) | 0.603 (0.401, 0.931) | 0.686 (0.404, 1.17) | Placebo

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all classes. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class. Statistically significant differences are bold.

Abbreviations: DTI = direct thrombin inhibitor, DVT = deep vein thrombosis, FXaI = factor Xa inhibitor, FXIi = factor XI inhibitor, LMWH = low molecular weight heparin, TKR = total knee replacement, UFH = unfractionated heparin, VKA = vitamin K antagonist.

Table F7.6 Network meta-analysis pairwise results: Total knee replacement, specific intervention comparisons of DVT

| Rivaroxaban | Aspirin+VFP | Fondaparinux | Edoxaban | Apixaban | Darexaban | Flexion | Dabigatran | Enoxaparin+VFP | Enoxaparin+IPC | IPC | FXIASO | Aspirin+IPC | Semuloparin | Edoxaban+VFP | Enoxaparin | VFP | Tinzaparin | Heparin | Aspirin | Warfarin | Placebo | Enoxaparin+GCS
Rivaroxaban | Rivaroxaban | 1.31 (0.292, 6.75) | 1.86 (0.594, 7.51) | 2.2 (0.689, 8.66) | 2.41 (0.78, 9.51) | 2.52 (0.638, 11.7) | <0.01 (<0.01, >100) | 2.61 ( 0.8, 10.4) | <0.01 (<0.01, >100) | 2.75 (0.494, 16.5) | 2.89 (0.754, 13.9) | 3.62 (0.97, 15.5) | 3.63 (0.56, 25.3) | 3.75 (1.21, 15) | 4.64 (1.04, 24.8) | 4.53 (1.61, 16.7) | 5.54 (1.65, 22.8) | 5.79 ( 1.8, 24) | 6.73 (2.16, 26.5) | 7.48 (2.54, 27.5) | 8.65 (2.99, 32.7) | 13.8 (4.58, 52.7) | >100 (>100, >100)
Aspirin+VFP | 0.764 (0.148, 3.43) | Aspirin+VFP | 1.43 (0.417, 5.32) | 1.67 (0.468, 6.21) | 1.84 (0.539, 6.73) | 1.93 (0.453, 8.28) | <0.01 (<0.01, >100) | 1.99 (0.549, 7.5) | <0.01 (<0.01, >100) | 2.08 (0.356, 12) | 2.21 (0.612, 8.87) | 2.75 (0.706, 11.3) | 2.7 (0.402, 18.9) | 2.91 (0.83, 10.6) | 3.54 (0.728, 17.5) | 3.48 ( 1.1, 11.6) | 4.21 (1.11, 16.1) | 4.49 (1.27, 16.3) | 5.15 (1.48, 18.5) | 5.72 (2.09, 16.7) | 6.67 (2.13, 22.3) | 10.6 (3.18, 36.8) | >100 (>100, >100)
Fondaparinux | 0.537 (0.133, 1.68) | 0.7 (0.188, 2.4) | Fondaparinux | 1.17 (0.56, 2.34) | 1.3 (0.652, 2.45) | 1.35 (0.498, 3.41) | <0.01 (<0.01, >100) | 1.39 (0.661, 2.81) | <0.01 (<0.01, >100) | 1.45 (0.342, 5.52) | 1.55 (0.501, 4.8) | 1.9 (0.788, 4.6) | 1.92 (0.375, 9.32) | 2.04 (0.997, 4) | 2.47 (0.756, 8.07) | 2.45 (1.47, 3.95) | 2.95 (1.35, 6.24) | 3.11 (1.41, 6.78) | 3.62 ( 1.8, 6.84) | 4.01 (1.89, 8.3) | 4.66 (2.53, 8.48) | 7.4 (4.13, 13.1) | >100 (>100, >100)
Edoxaban | 0.455 (0.116, 1.45) | 0.599 (0.161, 2.13) | 0.852 (0.428, 1.79) | Edoxaban | 1.11 (0.563, 2.23) | 1.15 (0.439, 2.98) | <0.01 (<0.01, >100) | 1.19 (0.567, 2.51) | <0.01 (<0.01, >100) | 1.24 (0.293, 4.93) | 1.32 (0.434, 4.28) | 1.63 (0.669, 4.15) | 1.63 (0.324, 8.14) | 1.74 (0.853, 3.56) | 2.11 (0.845, 5.4) | 2.09 (1.24, 3.57) | 2.52 (1.15, 5.54) | 2.66 (1.22, 6.17) | 3.1 (1.55, 6.16) | 3.41 ( 1.6, 7.41) | 4 (2.13, 7.7) | 6.36 (3.64, 11.3) | >100 (>100, >100)
Apixaban | 0.415 (0.105, 1.28) | 0.543 (0.149, 1.86) | 0.767 (0.408, 1.53) | 0.899 (0.449, 1.78) | Apixaban | 1.04 (0.397, 2.61) | <0.01 (<0.01, >100) | 1.07 (0.519, 2.18) | <0.01 (<0.01, >100) | 1.12 (0.27, 4.33) | 1.2 (0.399, 3.72) | 1.47 (0.627, 3.54) | 1.48 (0.294, 7.1) | 1.57 (0.806, 3.04) | 1.91 (0.599, 6.08) | 1.89 (1.19, 2.96) | 2.27 (1.07, 4.8) | 2.39 (1.14, 5.25) | 2.79 (1.46, 5.22) | 3.09 ( 1.5, 6.3) | 3.57 (2.05, 6.49) | 5.73 (3.23, 10.2) | >100 (>100, >100)
Darexaban | 0.397 (0.0855, 1.57) | 0.518 (0.121, 2.21) | 0.743 (0.293, 2.01) | 0.87 (0.336, 2.28) | 0.965 (0.383, 2.52) | Darexaban | <0.01 (<0.01, >100) | 1.04 (0.395, 2.76) | <0.01 (<0.01, >100) | 1.08 (0.218, 5.01) | 1.16 (0.32, 4.43) | 1.43 (0.475, 4.37) | 1.45 (0.248, 8.05) | 1.51 (0.584, 4.05) | 1.82 (0.485, 7.14) | 1.83 (0.804, 4.26) | 2.18 (0.814, 6.06) | 2.31 (0.831, 6.78) | 2.7 (1.06, 7.05) | 2.99 ( 1.1, 8.35) | 3.47 (1.42, 8.86) | 5.51 (2.51, 12.9) | >100 (>100, >100)
Flexion | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | Flexion | >100 (<0.01, >100) | <0.01 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (0.0125, >100)
Dabigatran | 0.383 (0.096, 1.25) | 0.503 (0.133, 1.82) | 0.719 (0.356, 1.51) | 0.837 (0.398, 1.76) | 0.931 (0.459, 1.93) | 0.96 (0.363, 2.53) | <0.01 (<0.01, >100) | Dabigatran | <0.01 (<0.01, >100) | 1.04 (0.249, 4.15) | 1.12 (0.365, 3.62) | 1.37 (0.547, 3.46) | 1.38 (0.271, 6.79) | 1.47 (0.696, 3.1) | 1.77 (0.536, 5.95) | 1.76 (1.02, 3.08) | 2.12 (0.939, 4.71) | 2.23 ( 1, 5.3) | 2.6 (1.29, 5.29) | 2.87 (1.33, 6.42) | 3.35 (1.76, 6.6) | 5.35 ( 3.1, 9.28) | >100 (>100, >100)
Enoxaparin+VFP | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | Enoxaparin+VFP | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100)
Enoxaparin+IPC | 0.363 (0.0607, 2.03) | 0.481 (0.0835, 2.81) | 0.692 (0.181, 2.93) | 0.805 (0.203, 3.42) | 0.895 (0.231, 3.71) | 0.922 ( 0.2, 4.58) | <0.01 (<0.01, >100) | 0.962 (0.241, 4.01) | <0.01 (<0.01, >100) | Enoxaparin+IPC | 1.07 (0.218, 5.7) | 1.31 (0.306, 5.96) | 1.32 (0.619, 2.87) | 1.4 (0.359, 5.83) | 1.71 (0.318, 9.43) | 1.69 (0.475, 6.53) | 2.03 (0.513, 8.72) | 2.16 (0.54, 9.64) | 2.5 (0.662, 10.3) | 2.75 (0.696, 11.6) | 3.23 (0.868, 13.1) | 5.11 (1.38, 20.9) | >100 (>100, >100)
IPC | 0.346 (0.0717, 1.33) | 0.453 (0.113, 1.63) | 0.643 (0.208, 2) | 0.756 (0.234, 2.3) | 0.835 (0.269, 2.51) | 0.863 (0.226, 3.13) | <0.01 (<0.01, >100) | 0.897 (0.277, 2.74) | <0.01 (<0.01, >100) | 0.938 (0.175, 4.59) | IPC | 1.24 (0.353, 4.28) | 1.25 ( 0.2, 7.45) | 1.31 (0.416, 3.97) | 1.59 (0.36, 6.86) | 1.57 (0.556, 4.28) | 1.92 (0.577, 6.17) | 1.99 (0.646, 6.27) | 2.33 (0.752, 6.97) | 2.59 (1.09, 5.95) | 3 (1.09, 8.34) | 4.77 ( 1.6, 13.8) | >100 (>100, >100)
FXIASO | 0.276 (0.0645, 1.03) | 0.363 (0.0884, 1.42) | 0.525 (0.218, 1.27) | 0.612 (0.241, 1.5) | 0.68 (0.282, 1.59) | 0.697 (0.229, 2.1) | <0.01 (<0.01, >100) | 0.728 (0.289, 1.83) | <0.01 (<0.01, >100) | 0.761 (0.168, 3.27) | 0.809 (0.234, 2.83) | FXIASO | 1 (0.182, 5.33) | 1.07 (0.438, 2.54) | 1.29 (0.341, 4.81) | 1.29 (0.606, 2.65) | 1.54 (0.582, 3.93) | 1.63 (0.628, 4.28) | 1.91 (0.781, 4.38) | 2.1 (0.818, 5.24) | 2.44 (1.07, 5.54) | 3.9 (1.68, 8.91) | >100 (>100, >100)
Aspirin+IPC | 0.275 (0.0395, 1.79) | 0.37 (0.0529, 2.48) | 0.52 (0.107, 2.67) | 0.614 (0.123, 3.09) | 0.674 (0.141, 3.4) | 0.688 (0.124, 4.03) | <0.01 (<0.01, >100) | 0.724 (0.147, 3.69) | <0.01 (<0.01, >100) | 0.755 (0.348, 1.62) | 0.798 (0.134, 5.01) | 0.997 (0.188, 5.49) | Aspirin+IPC | 1.05 (0.22, 5.37) | 1.29 (0.202, 8.32) | 1.28 (0.283, 5.98) | 1.54 (0.312, 8.04) | 1.62 (0.321, 8.64) | 1.88 ( 0.4, 9.33) | 2.08 (0.422, 10.5) | 2.44 (0.517, 11.9) | 3.86 (0.828, 19) | >100 (>100, >100)
Semuloparin | 0.267 (0.0668, 0.828) | 0.344 (0.0941, 1.2) | 0.491 (0.25, 1) | 0.575 (0.281, 1.17) | 0.639 (0.329, 1.24) | 0.661 (0.247, 1.71) | <0.01 (<0.01, >100) | 0.682 (0.322, 1.44) | <0.01 (<0.01, >100) | 0.714 (0.172, 2.79) | 0.765 (0.252, 2.4) | 0.937 (0.394, 2.28) | 0.95 (0.186, 4.55) | Semuloparin | 1.22 (0.374, 3.92) | 1.2 (0.734, 1.97) | 1.45 (0.66, 3.17) | 1.53 (0.707, 3.44) | 1.78 (0.906, 3.41) | 1.97 (0.942, 4.2) | 2.29 (1.27, 4.27) | 3.65 (1.99, 6.72) | >100 (>100, >100)
Edoxaban+VFP | 0.216 (0.0404, 0.964) | 0.283 (0.0572, 1.37) | 0.405 (0.124, 1.32) | 0.475 (0.185, 1.18) | 0.525 (0.165, 1.67) | 0.55 (0.14, 2.06) | <0.01 (<0.01, >100) | 0.566 (0.168, 1.87) | <0.01 (<0.01, >100) | 0.586 (0.106, 3.14) | 0.628 (0.146, 2.78) | 0.777 (0.208, 2.94) | 0.777 (0.12, 4.94) | 0.821 (0.255, 2.68) | Edoxaban+VFP | 0.991 (0.337, 2.91) | 1.2 (0.353, 3.98) | 1.26 (0.37, 4.46) | 1.47 (0.459, 4.64) | 1.62 (0.484, 5.48) | 1.88 (0.604, 5.89) | 3.01 ( 1, 9.06) | >100 (>100, >100)
Enoxaparin | 0.221 (0.0598, 0.62) | 0.287 (0.0859, 0.905) | 0.409 (0.253, 0.678) | 0.478 (0.28, 0.807) | 0.53 (0.338, 0.838) | 0.548 (0.235, 1.24) | <0.01 (<0.01, >100) | 0.569 (0.325, 0.982) | <0.01 (<0.01, >100) | 0.592 (0.153, 2.11) | 0.636 (0.234, 1.8) | 0.778 (0.378, 1.65) | 0.784 (0.167, 3.54) | 0.832 (0.509, 1.36) | 1.01 (0.344, 2.97) | Enoxaparin | 1.21 (0.649, 2.2) | 1.27 (0.699, 2.41) | 1.48 (0.938, 2.29) | 1.64 (0.93, 2.87) | 1.9 (1.35, 2.77) | 3.04 (2.12, 4.38) | >100 (>100, >100)
VFP | 0.181 (0.0438, 0.605) | 0.237 (0.0621, 0.898) | 0.339 (0.16, 0.742) | 0.397 (0.181, 0.872) | 0.44 (0.208, 0.936) | 0.459 (0.165, 1.23) | <0.01 (<0.01, >100) | 0.471 (0.212, 1.07) | <0.01 (<0.01, >100) | 0.492 (0.115, 1.95) | 0.521 (0.162, 1.73) | 0.648 (0.254, 1.72) | 0.649 (0.124, 3.2) | 0.688 (0.316, 1.52) | 0.833 (0.251, 2.83) | 0.829 (0.455, 1.54) | VFP | 1.05 (0.454, 2.52) | 1.22 (0.58, 2.58) | 1.35 ( 0.6, 3.2) | 1.58 (0.795, 3.25) | 2.51 (1.32, 4.85) | >100 (>100, >100)
Tinzaparin | 0.173 (0.0416, 0.556) | 0.223 (0.0615, 0.787) | 0.321 (0.147, 0.709) | 0.375 (0.162, 0.818) | 0.418 (0.191, 0.879) | 0.433 (0.148, 1.2) | <0.01 (<0.01, >100) | 0.448 (0.189, 0.998) | <0.01 (<0.01, >100) | 0.463 (0.104, 1.85) | 0.503 (0.16, 1.55) | 0.614 (0.234, 1.59) | 0.615 (0.116, 3.12) | 0.654 (0.291, 1.41) | 0.795 (0.224, 2.71) | 0.788 (0.415, 1.43) | 0.948 (0.396, 2.2) | Tinzaparin | 1.17 (0.523, 2.45) | 1.29 (0.594, 2.71) | 1.5 (0.898, 2.48) | 2.39 (1.15, 4.81) | >100 (>100, >100)
Heparin | 0.149 (0.0378, 0.462) | 0.194 (0.0542, 0.676) | 0.276 (0.146, 0.555) | 0.323 (0.162, 0.644) | 0.359 (0.192, 0.685) | 0.371 (0.142, 0.946) | <0.01 (<0.01, >100) | 0.385 (0.189, 0.777) | <0.01 (<0.01, >100) | 0.401 (0.0968, 1.51) | 0.429 (0.144, 1.33) | 0.525 (0.228, 1.28) | 0.533 (0.107, 2.5) | 0.562 (0.293, 1.1) | 0.682 (0.216, 2.18) | 0.675 (0.437, 1.07) | 0.818 (0.387, 1.72) | 0.858 (0.408, 1.91) | Heparin | 1.11 (0.542, 2.33) | 1.29 (0.741, 2.34) | 2.05 (1.17, 3.68) | >100 (>100, >100)
Aspirin | 0.134 (0.0363, 0.394) | 0.175 (0.0599, 0.478) | 0.25 (0.121, 0.529) | 0.293 (0.135, 0.626) | 0.323 (0.159, 0.669) | 0.334 (0.12, 0.913) | <0.01 (<0.01, >100) | 0.348 (0.156, 0.75) | <0.01 (<0.01, >100) | 0.363 (0.0861, 1.44) | 0.386 (0.168, 0.914) | 0.475 (0.191, 1.22) | 0.481 (0.095, 2.37) | 0.509 (0.238, 1.06) | 0.616 (0.183, 2.07) | 0.611 (0.348, 1.08) | 0.739 (0.312, 1.67) | 0.776 (0.369, 1.68) | 0.904 (0.43, 1.84) | Aspirin | 1.16 (0.671, 2.05) | 1.85 (0.951, 3.59) | >100 (>100, >100)
Warfarin | 0.116 (0.0306, 0.334) | 0.15 (0.0448, 0.469) | 0.215 (0.118, 0.395) | 0.25 (0.13, 0.47) | 0.28 (0.154, 0.488) | 0.288 (0.113, 0.703) | <0.01 (<0.01, >100) | 0.298 (0.152, 0.569) | <0.01 (<0.01, >100) | 0.309 (0.0765, 1.15) | 0.333 (0.12, 0.921) | 0.41 (0.181, 0.937) | 0.41 (0.0841, 1.94) | 0.437 (0.234, 0.789) | 0.531 (0.17, 1.66) | 0.526 (0.361, 0.742) | 0.633 (0.307, 1.26) | 0.667 (0.403, 1.11) | 0.778 (0.427, 1.35) | 0.86 (0.488, 1.49) | Warfarin | 1.59 (0.954, 2.63) | >100 (>100, >100)
Placebo | 0.0726 (0.019, 0.218) | 0.0943 (0.0272, 0.314) | 0.135 (0.0763, 0.242) | 0.157 (0.0883, 0.275) | 0.174 (0.0983, 0.31) | 0.182 (0.0777, 0.399) | <0.01 (<0.01, >100) | 0.187 (0.108, 0.323) | <0.01 (<0.01, >100) | 0.196 (0.0479, 0.723) | 0.21 (0.0723, 0.625) | 0.256 (0.112, 0.594) | 0.259 (0.0527, 1.21) | 0.274 (0.149, 0.503) | 0.332 (0.11, 1) | 0.329 (0.228, 0.472) | 0.398 (0.206, 0.76) | 0.418 (0.208, 0.871) | 0.489 (0.272, 0.855) | 0.54 (0.278, 1.05) | 0.628 (0.38, 1.05) | Placebo | >100 (67.6, >100)
Enoxaparin+GCS | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, 80.3) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, >100) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, <0.01) | <0.01 (<0.01, 0.0148) | Enoxaparin+GCS

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all interventions. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class. Statistically significant differences are bold.

Abbreviations: DVT = deep vein thrombosis, FXIASO = factor XI antisense oligonuclide, GCS = graduated compression stocking, IPC = intermittent pneumatic compression, TKR = total hip replacement, VFP = venous foot pump.

Table F7.7 Network meta-analysis pairwise results: Total knee replacement, intervention class comparisons of major bleeding

| VKA | LMWH | UFH | Placebo | DTI | FXaI+Mechanical | FXaI | FXIi
VKA | VKA | 2.1 (0.533, 8.63) | 2.14 (0.108, 43.4) | 2.25 (0.191, 24.2) | 2.71 (0.48, 18.3) | 4.01 (0.171, 116) | 3.72 (0.696, 25.6) | >100 (<0.01, >100)
LMWH | 0.477 (0.116, 1.88) | LMWH | 1.02 (0.0713, 14.6) | 1.07 (0.135, 7.29) | 1.28 (0.433, 4.52) | 1.94 (0.106, 39.5) | 1.78 (0.612, 6.27) | >100 (<0.01, >100)
UFH | 0.467 (0.023, 9.25) | 0.979 (0.0686, 14) | UFH | 1.04 (0.0362, 28.3) | 1.26 (0.0745, 25.1) | 1.87 (0.0363, 110) | 1.75 (0.106, 35.6) | >100 (<0.01, >100)
Placebo | 0.445 (0.0413, 5.22) | 0.938 (0.137, 7.4) | 0.965 (0.0354, 27.6) | Placebo | 1.21 (0.171, 10.8) | 1.8 (0.062, 68) | 1.67 (0.206, 18.3) | >100 (<0.01, >100)
DTI | 0.369 (0.0546, 2.09) | 0.78 (0.221, 2.31) | 0.791 (0.0398, 13.4) | 0.828 (0.0922, 5.84) | DTI | 1.5 (0.0626, 35) | 1.38 (0.282, 7.17) | >100 (<0.01, >100)
FXaI+Mechanical | 0.25 (0.00862, 5.86) | 0.517 (0.0253, 9.46) | 0.533 (0.00912, 27.6) | 0.555 (0.0147, 16.1) | 0.668 (0.0286, 16) | FXaI+Mechanical | 0.93 (0.062, 14.6) | >100 (<0.01, >100)
FXaI | 0.269 (0.0391, 1.44) | 0.563 (0.16, 1.64) | 0.572 (0.0281, 9.46) | 0.598 (0.0545, 4.86) | 0.723 (0.139, 3.54) | 1.08 (0.0687, 16.1) | FXaI | >100 (<0.01, >100)
FXIi | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | <0.01 (<0.01, >100) | FXIi

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all classes. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.

Abbreviations: DTI = direct thrombin inhibitor, FXaI = factor Xa inhibitor, FXIi = factor XI inhibitor, LMWH = low molecular weight heparin, TKR = total knee replacement, UFH = unfractionated heparin, VKA = vitamin K antagonist.

Table F7.8 Network meta-analysis pairwise results: Total knee replacement, specific intervention comparisons of major bleeding

| Warfarin | FXIASO | Eribaxaban | Apixaban | TAK442 | Semuloparin | Enoxaparin | Heparin | Dabigatran | Placebo | Tinzaparin | Edoxaban+VFP | Edoxaban | Fondaparinux | Darexaban
Warfarin | Warfarin | <0.01 (<0.01, >100) | 0.8 (0.0141, 25) | 1.05 (0.0756, 16.2) | 1.03 (0.0398, 24.9) | 1.2 (0.0635, 23.7) | 1.69 (0.359, 8.82) | 1.73 (0.0844, 37.4) | 2.15 (0.365, 18.1) | 2.41 (0.188, 34.9) | 3.38 (0.32, 40.8) | 10.4 (0.161, >100) | 9.2 (0.374, >100) | 27.1 (1.18, >100) | >100 (3.68, >100)
FXIASO | >100 (<0.01, >100) | FXIASO | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100) | >100 (<0.01, >100)
Eribaxaban | 1.25 (0.04, 70.7) | <0.01 (<0.01, >100) | Eribaxaban | 1.32 (0.0335, 95.4) | 1.29 (0.0204, 125) | 1.49 (0.0289, 137) | 2.08 (0.106, 89.2) | 2.19 (0.0398, 199) | 2.7 (0.126, 146) | 3.05 (0.0819, 215) | 4.41 (0.064, 501) | 13.6 (0.0933, >100) | 12 (0.18, >100) | 35.2 (0.588, >100) | >100 (3.37, >100)
Apixaban | 0.949 (0.0616, 13.2) | <0.01 (<0.01, >100) | 0.76 (0.0105, 29.8) | Apixaban | 0.958 (0.0277, 29.6) | 1.14 (0.0411, 30.6) | 1.6 (0.187, 14.2) | 1.63 (0.0549, 46.1) | 2 (0.209, 27.6) | 2.3 (0.118, 45.9) | 3.23 (0.0913, 113) | 9.83 (0.112, >100) | 8.73 (0.258, >100) | 25.9 (0.828, >100) | >100 (3.41, >100)
TAK442 | 0.972 (0.0402, 25.1) | <0.01 (<0.01, >100) | 0.778 (0.00797, 48.9) | 1.04 (0.0338, 36.1) | TAK442 | 1.17 (0.0278, 55.9) | 1.65 (0.11, 28.4) | 1.71 (0.0388, 77.4) | 2.13 (0.125, 49.6) | 2.35 (0.0798, 86.6) | 3.35 (0.0617, 208) | 10.5 (0.0854, >100) | 9.33 (0.182, >100) | 27.5 (0.559, >100) | >100 (2.98, >100)
Semuloparin | 0.834 (0.0422, 15.7) | <0.01 (<0.01, >100) | 0.672 (0.0073, 34.5) | 0.878 (0.0327, 24.3) | 0.856 (0.0179, 36) | Semuloparin | 1.41 (0.116, 18) | 1.45 (0.0398, 54.6) | 1.8 (0.129, 33.2) | 2.01 (0.0832, 55.6) | 2.85 (0.062, 139) | 8.61 (0.0849, >100) | 7.78 (0.177, >100) | 23.2 (0.556, >100) | >100 (2.51, >100)
Enoxaparin | 0.591 (0.113, 2.79) | <0.01 (<0.01, >100) | 0.481 (0.0112, 9.41) | 0.624 (0.0704, 5.36) | 0.605 (0.0352, 9.1) | 0.707 (0.0554, 8.59) | Enoxaparin | 1.03 (0.0724, 13.8) | 1.27 (0.469, 4.53) | 1.42 (0.187, 11.6) | 2.01 (0.109, 37.5) | 6.04 (0.124, >100) | 5.35 (0.321, >100) | 15.6 (1.09, >100) | >100 (2.53, >100)
Heparin | 0.579 (0.0267, 11.8) | <0.01 (<0.01, >100) | 0.456 (0.00502, 25.1) | 0.613 (0.0217, 18.2) | 0.586 (0.0129, 25.7) | 0.689 (0.0183, 25.1) | 0.97 (0.0725, 13.8) | Heparin | 1.24 (0.0808, 24.5) | 1.42 (0.05, 40.2) | 2 (0.0403, 100) | 6.11 (0.0537, >100) | 5.45 (0.114, >100) | 16.1 (0.371, >100) | >100 (1.73, >100)
Dabigatran | 0.465 (0.0552, 2.74) | <0.01 (<0.01, >100) | 0.371 (0.00687, 7.96) | 0.499 (0.0362, 4.78) | 0.47 (0.0202, 7.99) | 0.554 (0.0301, 7.73) | 0.787 (0.221, 2.13) | 0.806 (0.0408, 12.4) | Dabigatran | 1.12 (0.13, 8.34) | 1.59 (0.0605, 31.7) | 4.73 (0.0736, >100) | 4.21 (0.185, >100) | 12.2 (0.613, >100) | >100 (1.85, >100)
Placebo | 0.415 (0.0287, 5.31) | <0.01 (<0.01, >100) | 0.328 (0.00466, 12.2) | 0.434 (0.0218, 8.46) | 0.426 (0.0116, 12.5) | 0.498 (0.018, 12) | 0.703 (0.0859, 5.34) | 0.706 (0.0249, 20) | 0.895 (0.12, 7.7) | Placebo | 1.41 (0.0385, 50.1) | 4.26 (0.0525, >100) | 3.9 (0.119, >100) | 11.2 (0.365, >100) | >100 (1.89, >100)
Tinzaparin | 0.296 (0.0245, 3.13) | <0.01 (<0.01, >100) | 0.227 (0.00199, 15.6) | 0.31 (0.00882, 11) | 0.298 (0.0048, 16.2) | 0.351 (0.00719, 16.1) | 0.498 (0.0267, 9.2) | 0.501 (0.00998, 24.8) | 0.63 (0.0315, 16.5) | 0.708 (0.02, 26) | Tinzaparin | 2.98 (0.0231, >100) | 2.68 (0.0475, >100) | 7.96 (0.154, >100) | >100 (0.844, >100)
Edoxaban+VFP | 0.0958 (<0.01, 6.2) | <0.01 (<0.01, >100) | 0.0738 (<0.01, 10.7) | 0.102 (<0.01, 8.96) | 0.0952 (<0.01, 11.7) | 0.116 (<0.01, 11.8) | 0.166 (<0.01, 8.09) | 0.164 (<0.01, 18.6) | 0.212 (<0.01, 13.6) | 0.235 (<0.01, 19) | 0.335 (<0.01, 43.2) | Edoxaban+VFP | 0.922 (0.0693, 12.6) | 2.76 (0.0139, >100) | >100 (0.163, >100)
Edoxaban | 0.109 (<0.01, 2.67) | <0.01 (<0.01, >100) | 0.0836 (<0.01, 5.56) | 0.114 (<0.01, 3.88) | 0.107 (<0.01, 5.5) | 0.129 (<0.01, 5.66) | 0.187 (<0.01, 3.12) | 0.184 (<0.01, 8.8) | 0.238 (<0.01, 5.42) | 0.257 (<0.01, 8.39) | 0.374 (<0.01, 21) | 1.08 (0.0792, 14.4) | Edoxaban | 2.96 (0.0299, >100) | >100 (0.232, >100)
Fondaparinux | 0.037 (<0.01, 0.847) | <0.01 (<0.01, >100) | 0.0284 (<0.01, 1.7) | 0.0386 (<0.01, 1.21) | 0.0364 (<0.01, 1.79) | 0.043 (<0.01, 1.8) | 0.0641 (<0.01, 0.917) | 0.0623 (<0.01, 2.7) | 0.0822 (<0.01, 1.63) | 0.0891 (<0.01, 2.74) | 0.126 (<0.01, 6.49) | 0.362 (<0.01, 72.2) | 0.338 (<0.01, 33.5) | Fondaparinux | >100 (0.0891, >100)
Darexaban | <0.01 (<0.01, 0.272) | <0.01 (<0.01, >100) | <0.01 (<0.01, 0.297) | <0.01 (<0.01, 0.293) | <0.01 (<0.01, 0.335) | <0.01 (<0.01, 0.399) | <0.01 (<0.01, 0.396) | <0.01 (<0.01, 0.577) | <0.01 (<0.01, 0.54) | <0.01 (<0.01, 0.53) | <0.01 (<0.01, 1.18) | <0.01 (<0.01, 6.15) | <0.01 (<0.01, 4.32) | <0.01 (<0.01, 11.2) | Darexaban

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all interventions. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.

Abbreviations: FXIASO = factor XI antisense oligonuclide, TKR = total knee replacement.

Table F7.9 Network meta-analysis pairwise results: Hip fracture surgery, intervention class comparisons of DVT

| UFH | FXaI | LMWH | Placebo
UFH | UFH | 1.38 (0.167, 15.5) | 3.25 (0.45, 24) | 8.84 (0.908, 103)
FXaI | 0.725 (0.0646, 5.99) | FXaI | 2.4 (0.654, 6.18) | 6.41 (1.31, 26.4)
LMWH | 0.308 (0.0417, 2.22) | 0.417 (0.162, 1.53) | LMWH | 2.73 (0.779, 10.9)
Placebo | 0.113 (0.0097, 1.1) | 0.156 (0.0379, 0.762) | 0.367 (0.0917, 1.28) | Placebo

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all classes. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class. Statistically significant differences are bold.

Abbreviations: DVT = deep vein thrombosis, FXaI = factor Xa inhibitor, HFx = hip fracture, LMWH = low molecular weight heparin, UFH = unfractionated heparin.

Table F7.10 Network meta-analysis pairwise results: Hip fracture surgery, specific intervention comparisons of DVT

| Heparin | Fondaparinux | Dalteparin | Semuloparin | Enoxaparin | Edoxaban | Placebo
Heparin | Heparin | 2.53 (0.214, 28.5) | 3.26 (0.562, 20.1) | 5.41 (0.366, 84.4) | 7.43 (0.786, 76.9) | 18.1 (0.572, 1.15e+03) | 13.4 (1.38, 135)
Fondaparinux | 0.395 (0.035, 4.67) | Fondaparinux | 1.31 (0.248, 7.11) | 2.12 (0.35, 14.8) | 2.94 (1.03, 9.49) | 7.04 (0.415, 280) | 5.32 (1.27, 25)
Dalteparin | 0.307 (0.0499, 1.78) | 0.766 (0.141, 4.02) | Dalteparin | 1.64 (0.214, 13.1) | 2.26 (0.564, 9.75) | 5.42 (0.265, 239) | 4.08 (0.977, 17.5)
Semuloparin | 0.185 (0.0119, 2.73) | 0.472 (0.0675, 2.86) | 0.609 (0.0763, 4.67) | Semuloparin | 1.38 (0.307, 6.15) | 3.26 (0.156, 138) | 2.5 (0.332, 18.5)
Enoxaparin | 0.135 (0.013, 1.27) | 0.34 (0.105, 0.97) | 0.442 (0.103, 1.77) | 0.726 (0.162, 3.25) | Enoxaparin | 2.32 (0.163, 78) | 1.81 (0.462, 7.06)
Edoxaban | 0.0551 (0.000873, 1.75) | 0.142 (0.00358, 2.41) | 0.185 (0.00419, 3.78) | 0.307 (0.00722, 6.43) | 0.43 (0.0128, 6.13) | Edoxaban | 0.755 (0.0179, 15.1)
Placebo | 0.0744 (0.00741, 0.725) | 0.188 (0.0401, 0.788) | 0.245 (0.0572, 1.02) | 0.401 (0.054, 3.02) | 0.554 (0.142, 2.16) | 1.32 (0.0664, 55.9) | Placebo

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all interventions. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class. Statistically significant differences are bold.

Abbreviations: DVT = deep vein thrombosis.

Table F7.11 Network meta-analysis pairwise results: Hip fracture surgery, intervention class comparisons of major bleeding

| Antiplatelet | VKA | Placebo | LMWH | FXaI
Antiplatelet | Antiplatelet | 7.54 (0.406, >100) | 7.83 (0.423, >100) | >100 (3.73, >100) | >100 (5.34, >100)
VKA | 0.133 (<0.01, 2.46) | VKA | 1.04 (0.086, 13.1) | >100 (0.659, >100) | >100 (0.934, >100)
Placebo | 0.128 (<0.01, 2.37) | 0.964 (0.077, 11.6) | Placebo | >100 (0.862, >100) | >100 (1.23, >100)
LMWH | <0.01 (<0.01, 0.268) | <0.01 (<0.01, 1.52) | <0.01 (<0.01, 1.16) | LMWH | 1.25 (0.289, 8.69)
FXaI | <0.01 (<0.01, 0.187) | <0.01 (<0.019, 1.07) | <0.01 (<0.01, 0.816) | 0.803 (0.115, 3.46) | FXaI

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all classes. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.

Abbreviations: FXaI = factor Xa inhibitor, HFx = hip fracture, LMWH = low molecular weight heparin, VKA = vitamin K antagonist.

Table F7.12 Network meta-analysis pairwise results: Hip fracture surgery, specific intervention comparisons of major bleeding

| Aspirin | Warfarin | Placebo | Dalteparin | Edoxaban | Enoxaparin | Semuloparin | Fondaparinux
Aspirin | Aspirin | 7.76 (0.359, >100) | 8.11 (0.377, >100) | >100 (1.35, >100) | >100 (1.64, >100) | >100 (6.35, >100) | >100 (8.44, >100) | >100 (12.3, >100)
Warfarin | 0.129 (<0.01, 2.79) | Warfarin | 1.03 (0.076, 13.9) | >100 (0.191, >100) | >100 (0.207, >100) | >100 (0.976, >100) | >100 (1.23, >100) | >100 ( 1.8, >100)
Placebo | 0.123 (<0.01, 2.65) | 0.971 (0.072, 13.2) | Placebo | >100 (0.242, >100) | >100 (0.258, >100) | >100 (1.24, >100) | >100 (1.62, >100) | >100 (2.45, >100)
Dalteparin | <0.01 (<0.01, 0.741) | <0.01 (<0.01, 5.25) | <0.01 (<0.01, 4.13) | Dalteparin | 1.27 (0.00549, 384) | 2.47 (0.0801, 134) | 4.52 (0.0609, 577) | 4.27 (0.097, 483)
Edoxaban | <0.01 (<0.01, 0.61) | <0.01 (<0.01, 4.83) | <0.01 (<0.01, 3.87) | 0.785 (0.00261, 182) | Edoxaban | 2.03 (0.0303, 145) | 3.61 (0.0246, 568) | 3.4 (0.0388, 508)
Enoxaparin | <0.01 (<0.01, 0.157) | <0.01 (<0.01, 1.02) | <0.01 (<0.01, 0.805) | 0.405 (0.00747, 12.5) | 0.493 (0.0069, 33) | Enoxaparin | 1.79 (0.125, 28.4) | 1.56 (0.29, 20.6)
Semuloparin | <0.01 (<0.01, 0.118) | <0.01 (<0.01, 0.81) | <0.01 (<0.01, 0.618) | 0.221 (0.00173, 16.4) | 0.277 (0.00176, 40.6) | 0.559 (0.0352, 7.97) | Semuloparin | 0.903 (0.0402, 40)
Fondaparinux | <0.01 (<0.01, 0.0812) | <0.01 (<0.01, 0.556) | <0.01 (<0.01, 0.408) | 0.234 (0.00207, 10.3) | 0.294 (0.00197, 25.8) | 0.64 (0.0486, 3.45) | 1.11 (0.025, 24.9) | Fondaparinux

Pairwise meta-analysis results of odds ratio (with 95% credible interval) from network meta-analysis comparing all interventions. Values above diagonal compare row with column such that estimates >1 favor the column class. Values below the diagonal compare the column with the row such that estimates >1 favor the row class.

Abbreviations: HFx = hip fracture.