# Appendix E Study Arm Details

Table E1 Total hip replacement: Randomized controlled trials

Author Year PMID Country | Arm^†^ | Class | Drug dose, route, duration, INR/PTT/PT | Initiation time
Alfaro 1986 3535158 Spain | Aspirin 500 mg | Antiplatelet | 500 mg BID, Oral, 7 days | Preoperative
Alfaro 1986 3535158 Spain | Aspirin 125 mg | Antiplatelet | 125 mg BID, Oral, 7 days | Preoperative
Andersen 1997 9690480 Denmark | Dalteparin 5–7 days | LMWH | 5000 IU qD, SC, 5–7 days | Preoperative stared the evening before surgery
Andersen 1997 9690480 Denmark | Dalteparin 35 days | LMWH | 5000 IU qD, SC, 35 days | Preoperative stared the evening before surgery
Anderson 2013 23732713 Canada | [underlined: Dalteparin] then Aspirin | LMWH then Antiplatelet | 5000 U qD, SC, 10 days | Postoperative started the morning after surgery
Anderson 2013 23732713 Canada | Dalteparin then [underlined: Aspirin] | LMWH then Antiplatelet | 81 mg qD, Oral, 28 days | Postoperative
Anderson 2013 23732713 Canada | Dalteparin | LMWH | 5000 U qD, SC, 38 days | Postoperative started the morning after surgery
Avikainen 1995 7645915 Finland | Enoxaparin | LMWH | 40 mg/0.4 ml BID, SC, 10 days | Preoperative 12 hr
Avikainen 1995 7645915 Finland | Heparin | UFH | 500 IU BID, SC, 10 days | Preoperative 2 hr
Bailey 1991 1774568 USA | IPC | Mechanical | Continuously except bathing and physical therapy, until discharge | Postoperative immediately after surgery (recovery room)
Bailey 1991 1774568 USA | Warfarin | VKA | Oral, PT: 14–18 s | Preoperative started the evening before surgery
Barre 1987 2834500 France | Dalteparin | LMWH | 2500 anti-Xa U q12h, SC, 10 days | Preoperative 2 hr
Barre 1987 2834500 France | Heparin | UFH | q8h, SC, 10 days | Preoperative 2 hr
Borgen 2012 22476844 Europe | Dalteparin (preop) | LMWH | 5000 IU qD, SC, 35 days | Preoperative 12 hr
Borgen 2012 22476844 Europe | Dalteparin (postop) | LMWH | 5000 IU qD, SC, 35 days | Postoperative 6 hr
Bramlage 2012 22713698 Germany | Certoparin 5000 IU | LMWH | 5000 IU qD, SC, 8–16 days | Preoperative >2 hr
Bramlage 2012 22713698 Germany | Certoparin 3000 IU | LMWH | 3000 IU qD, SC, 8–16 days | Preoperative >2 hr
Colwell 1994 8288662 USA | Enoxaparin 30 mg q12h | LMWH | 30 mg q12h, SC, 7 days | Postoperative <= 24 hr
Colwell 1994 8288662 USA | Enoxaparin 40 mg qD | LMWH | 40 mg qD, SC, 7 days | Postoperative <= 24 hr
Colwell 1994 8288662 USA | Heparin | UFH | 5000 U q8h, SC, 7 days | Postoperative <= 24 hr
Colwell 1999 10428124 USA | Enoxaparin | LMWH | 30 mg q12h, SC, until discharge (mean 7.3 days) | Postoperative <= 24 hr
Colwell 1999 10428124 USA | Warfarin | VKA | Oral, until discharge (mean 7.3 days), INR: 2.0–3.0 | Postoperative <= 24 hr (could be initiated 48h pre-operatively)
Colwell 2010 20194309 USA | Continuous Enhanced Circulation Therapy + Synchronized Flow Technology | Mechanical | 20 hr/day, ~11 days | Intraoperative after induction of anesthesia
Colwell 2010 20194309 USA | [underlined: Enoxaparin] then Enoxaparin | LMWH | 30 mg BID, SC, until discharge | Postoperative started the morning after surgery
Colwell 2010 20194309 USA | Enoxaparin then [underlined: Enoxaparin] | LMWH | 40 mg qD, SC, 10 days | Postoperative started on the day of discharge
Comp 2001 11263636 USA | Enoxaparin 7–10 days | LMWH | 30 mg BID, SC, 7–10 days | Postoperative 12–24 hr
Comp 2001 11263636 USA | Enoxaparin [underlined: 7–10 days] then 3 weeks | LMWH | 30 mg BID, SC, 7–10 days | Postoperative 12–24 hr
| Enoxaparin 7–10 days then [underlined: 3 weeks] | LMWH | 40 mg qD, SC, 3 weeks | Postoperative 7–10 days
Dahl 1997 9031444 Norway | Dalteparin 7 days | LMWH | 5000 IU qD, SC, 7 days | Preoperative started the evening before surgery
Dahl 1997 9031444 Norway | Dalteparin 35 days | LMWH | 5000 IU qD, SC, 35 days | Preoperative started the evening before surgery
Dechavanne 1989 2537787 France | Dalteparin 2500 U q12h | LMWH | 2500 anti-Xa U q12h, SC, 10–13 days | Preoperative 2 hr
Dechavanne 1989 2537787 France | Dalteparin [underlined: 2500 U qD] then 5000 U qD | LMWH | 2500 anti-Xa U qD, SC, 48 hr | Preoperative 2 hr
Dechavanne 1989 2537787 France | Dalteparin 2500 U qD then [underlined: 5000 U qD] | LMWH | 5000 U qD, SC, 10–13 days | Postoperative 48 hr
Dechavanne 1989 2537787 France | Heparin | UFH | dose according to PTT BID, SC, 10–13 days | Preoperative 2 hr
Edwards 2008 18534421 USA | [underlined: Enoxaparin] + IPC | LMWH + Mechanical | 30 mg q12h, SC, 7–8 days | Postoperative started the morning after surgery
Edwards 2008 18534421 USA | Enoxaparin + [underlined: IPC] | LMWH + Mechanical | ActiveCare DVT, till discharge | In the operation room
Edwards 2008 18534421 USA | Enoxaparin | LMWH | 30 mg q12h, SC, 7–8 days | Postoperative started the morning after surgery
Eisele 2007 17473143 Germany | [underlined: Certoparin] + IPC | LMWH + Mechanical | 3000 aXa qD, SC, until discharge | Preoperative 12 hr
| Certoparin + [underlined: IPC] | LMWH + Mechanical | 6s/session, every 1 min, 1–16 days | NR
| Certoparin | LMWH | 3000 aXa qD, SC, until discharge | Preoperative 12 hr
Eriksson 1991 2013587 Sweden | Dalteparin | LMWH | 5000 IU qD, SC, 10 days | Preoperative started the evening before surgery
Eriksson 1991 2013587 Sweden | Heparin | UFH | 5000 IU TID, SC, 10 days | Preoperative 2 hr
Eriksson 1996 8596376 Europe | Desirudin | Hirudin | 15 mg BID, , 8–11 days | Preoperative after induction of regional block anesthesia
Eriksson 1996 8596376 Europe | Heparin | UFH | 5000 IU TID, SC, 8–11 days | Preoperative 2 hr
Eriksson 1997A 9070519 Sweden, Denmark | Desirudin | Hirudin | 15 mg BID, SC, 8–11 days | Preoperative 30 min (after induction of anesthesia)
Eriksson 1997A 9070519 Sweden, Denmark | Heparin | UFH | 5000 IU TID, SC, 8–11 days | Preoperative 2 hr
Eriksson 1997B 9358126 10 European countries | Desirudin | Hirudin | 15 mg BID, SC, 8–12 days | Preoperative 30 min (after induction of regional block anesthesia)
Eriksson 1997B 9358126 10 European countries | Enoxaparin | LMWH | 40 mg qD, SC, 8–12 days | Preoperative started the evening before surgery
Eriksson 2005 15634273 11 European countries, South Africa | Dabigatran 225 mg BID | DTI | 225 mg BID, Oral, until venography (6–10 days) | Postoperative 1–4 hr
Eriksson 2005 15634273 11 European countries, South Africa | Dabigatran 150 mg BID | DTI | 150 mg BID, Oral, until venography (6–10 days) | Postoperative 1–4 hr
Eriksson 2005 15634273 11 European countries, South Africa | Dabigatran 300 mg qD | DTI | 300 mg qD, Oral, until venography (6–10 days) | Postoperative 1–4 hr
Eriksson 2005 15634273 11 European countries, South Africa | Dabigatran 50 mg BID | DTI | 50 mg BID, Oral, until venography (6–10 days) | Postoperative 1–4 hr
Eriksson 2005 15634273 11 European countries, South Africa | Enoxaprin | LMWH | 40 mg qD, SC, until venography (6–10 days) | Preoperative 12 hr
Eriksson 2007B 17869635 13 European countries, Australia, South Africa | Dabigatran 220mg | DTI | 220 mg qD, Oral, 28–35 days | Postoperative 1–4 hr
Eriksson 2007B 17869635 13 European countries, Australia, South Africa | Dabigatran 150mg | DTI | 150 mg qD, Oral, 28–35 days | Postoperative 1–4 hr
Eriksson 2007B 17869635 13 European countries, Australia, South Africa | Enoxaparin | LMWH | 40 mg qD, SC, 28–35 days | Preoperative started the evening before surgery (post-operative in some countries)
Eriksson 2010 20088935 Europe | Darexaban 120 mg | DTI | 120 mg qD, Oral, 5 weeks | Postoperative 6–10 hr
Eriksson 2010 20088935 Europe | Darexaban 60 mg | DTI | 60 mg qD, Oral, 5 weeks | Postoperative 6–10 hr
| Darexaban 30 mg | DTI | 30 mg qD, Oral, 5 weeks | Postoperative 6–10 hr
| Darexaban 10 mg | DTI | 10 mg qD, Oral, 5 weeks | Postoperative 6–10 hr
| Darexaban 5 mg | DTI | 5 mg qD, Oral, 5 weeks | Postoperative 6–10 hr
| Enoxaparin 40 mg | LMWH | 40 mg qD, SC, 5 weeks | Preoperative 12 hr
Eriksson 2011 21225098 19 countries | Dabigatran | DTI | 220 mg qD, Oral, 28–35 days | Postoperative 1–4 hr
Eriksson 2011 21225098 19 countries | Enoxaparin | LMWH | 40 mg qD, SC, 28–35 days | Preoperative started the evening before surgery (post-operative in some countries)
Eriksson 2014 24136153 N/S America, Israel, South Africa, India | Darexaban 30 mg BID | DTI | 30 mg BID, Oral, 35 days | Postoperative 6–10 hr
Eriksson 2014 24136153 N/S America, Israel, South Africa, India | Darexaban 60 mg qD | DTI | 60 mg qD, Oral, 35 days | Postoperative 6–10 hr
Eriksson 2014 24136153 N/S America, Israel, South Africa, India | Darexaban 15 mg BID | DTI | 15 mg BID, Oral, 35 days | Postoperative 6–10 hr
Eriksson 2014 24136153 N/S America, Israel, South Africa, India | Darexaban 30 mg qD | DTI | 30 mg qD, Oral, 35 days | Postoperative 6–10 hr
Eriksson 2014 24136153 N/S America, Israel, South Africa, India | Enoxaparin 40 mg qD | LMWH | 40 mg qD, SC, 35 days | Preoperative 12 hr
Francis 1992 1583760 USA | IPC | Mechanical | Continuously while in bed, until venography | Preoperative immediately before surgery (operating room)
Francis 1992 1583760 USA | Warfarin | VKA | Oral, until venography, INR 1.5 surgery day, 2.5 post-op | Preoperative 10–14 days
Francis 1997 9314399 USA | Dalteparin | LMWH | 5000 IU qD, SC, until venography | Preoperative <=2 hr
Francis 1997 9314399 USA | Warfarin | VKA | qD, Oral, until venography, INR: 2.5 | Preoperative started the evening before surgery
Fuji 2008 18843459 Japan | Enoxaparin 40 mg qD | LMWH | 40 mg qD, SC, 14 days | Postoperative 24–36 hr
Fuji 2008 18843459 Japan | Enoxaparin 20 mg BID | LMWH | 20 mg BID, SC, 14 days | Postoperative 24–36 hr
Fuji 2014D 22952213 4 Asian countries | Darexaban 30 mg | FXaI | 30 mg BID, Oral, 10–14 days | Postoperative 12–24 hr
Fuji 2014D 22952213 4 Asian countries | Darexaban 15 mg | FXaI | 15 mg BID, Oral, 10–14 days | Postoperative 12–24 hr
Fuji 2014D 22952213 4 Asian countries | Enoxaparin | LMWH | 20 mg (2000 IU) BID (q12h), SC, 10–14 days | Postoperative 24–36 hr
Fuji 2014A 25047458 Japan, Taiwan | Edoxaban 30 mg | FXaI | 30 mg qD, Oral, 11–14 days | Postoperative 6–24 hr
Fuji 2014A 25047458 Japan, Taiwan | Edoxaban 15 mg | FXaI | 15 mg qD, Oral, 11–14 days | Postoperative 6–24 hr
Fuji 2014A 25047458 Japan, Taiwan | Enoxaparin 20 mg BID | LMWH | 20 mg BID, SC, 11–14 days | Postoperative 24–36 hr
Fuji 2015 26269694 Japan | Edoxaban | FXaI | 30 mg qD, Oral, 11–14 days | Postoperative 6–24 hr
Fuji 2015 26269694 Japan | Enoxaparin | LMWH | 2000 IU BID, SC, 11–14 days | Postoperative 24–36 hr
Hull 1993 8413432 USA, Canada | Tinzaparin | LMWH | 75 IU/kg qD, SC, 14 days^§^ | Postoperative 18–24 hr
Hull 1993 8413432 USA, Canada | Warfarin | VKA | qD, Oral, 14 days^§^, INR 2.0–3.0 | Preoperative started the evening before surgery
Hull 2000 10904464 USA, Canada | Dalteparin preoperative | LMWH | 5000 IU qD, SC | Preoperative 49 min (49)
Hull 2000 10904464 USA, Canada | Dalteparin postoperative | LMWH | 5000 IU qD, SC | Postoperative 6.6 hr (2.4)
Hull 2000 10904464 USA, Canada | Warfarin | VKA | qD, Oral, INR: 2.0–3.0 | Postoperative started the evening of the surgery
Kalodiki 1996 8803642 NR | [underlined: Enoxaparin] + GCS | LMWH + Mechanical | 40 mg qD, SC, until discharge | Preoperative 12 hr
Kalodiki 1996 8803642 NR | Enoxaparin + [underlined: GCS] | LMWH + Mechanical | Bilaterally, until discharge | Preoperative
Kalodiki 1996 8803642 NR | Enoxaparin | LMWH | 40 mg qD, SC, until discharge | Preoperative 12 hr
Kim 2016 | Rivaroxaban | FXaI | 10 mg, qD, 2 weeks | Postoperative 12 hr
Kim 2016 | Enoxaparin | LMWH | 40 mg qD, SC, 2 weeks | Postoperative 12 hr
Kim 2016A | Rivaroxaban | FXaI | 10 mg, qD, 2 weeks | Postoperative 12 hr
Kim 2016A | Enoxaparin | LMWH | 40 mg qD, SC, 2 weeks | Postoperative 12 hr
Lassen 1998 9669750 Denmark | Dalteparin 7 days | LMWH | 5000 antifactor Xa U qD, SC, 7 days | Preoperative 12 hr
Lassen 1998 9669750 Denmark | Dalteparin 42 days | LMWH | 5000 antifactor Xa U qD, SC, 42 days | Preoperative 12 hr
Lassen 2002 12049858 16 European countries | Fondaparinux | FXaI | 2.5 mg qD, SC, 5–9 days | Postoperative 6 hr (2)
Lassen 2002 12049858 16 European countries | Enoxaparin | LMWH | 40 mg qD, SC, 5–9 days | Preoperative 12 hr (2)
Lassen 2010A 21175312 USA | Apixaban | FXaI | 2.5 mg BID, Oral, 34.0 days (7.7) [32–38] | Postoperative 19.0 hr (4.6) [12–24]
Lassen 2010A 21175312 USA | Enoxaparin | LMWH | 40 mg qD, SC, 33.9 days (7.8) [32–38] | Preoperative 13.6 hr (2.1) [12±3]
Lassen 2012 22429800 Multinational | Enoxaparin | LMWH | 20 or 40 mg qD^*^, 8.2 days (1.5) | Postoperative 12 hr (1)
Lassen 2012 22429800 Multinational | Semuloparin | LMWH | 10 or 20 mg qD^*^, 8.2 days (1.5) | Postoperative 8 hr (1)
Levine 1991 1848054 Canada | Enoxaparin | LMWH | 30 mg BID, SC, 14 days^\|\|^ | Postoperative 12–24 hr
Levine 1991 1848054 Canada | Heparin | UFH | 7500 U BID, SC, 14 days^\|\|^ | Postoperative 12–24 hr
Lieberman 1994 8126039 USA | [underlined: Aspirin] + IPC | Antiplatelet + Mechanical | 325 mg BID, Oral, 3 weeks | Started on the day of surgery
Lieberman 1994 8126039 USA | Aspirin + [underlined: IPC] | Antiplatelet + Mechanical | Continuously, until venogram (postoperative day 6–8) | Postoperative in the recovery room
Lieberman 1994 8126039 USA | Aspirin | Antiplatelet | 325 mg BID, Oral, 3 weeks | Started on the day of surgery
Lotke 1996 8595765 USA | Aspirin | Antiplatelet | 325 mg BID, Oral, 6 weeks | Preoperative started the day of admission
Lotke 1996 8595765 USA | Warfarin | VKA | qD, Oral, 6 weeks, PT: 1.2–1.5 X control value | Postoperative started the night of surgery
Menzin 1994 8173149 USA | Enoxaparin 30 mg q12h | LMWH | 30 mg q12h, SC, >= 7 days | Postoperative <=24 hr
Menzin 1994 8173149 USA | Enoxaparin 40 mg qD | LMWH | 40 mg qD, SC, >= 7 days | Postoperative <=24 hr
Menzin 1994 8173149 USA | Heparin | UFH | 5000 U q8h, SC, >= 7 days | Postoperative <=24 hr
Nilsson 1997 9048404 Sweden | Enoxaparin 9 days | LMWH | 40 mg qD, SC, 9±2 days | Preoperative 12 hr
Nilsson 1997 9048404 Sweden | Enoxaparin 30 days | LMWH | 40 mg qD, SC, 30±4 days | Preoperative 12 hr
Paiement 1987 3572408 USA | IPC | Mechanical | Continuously, bilateral | Postoperative in the recovery room
Paiement 1987 3572408 USA | Warfarin | VKA | until at least 2 days after radiographic phlebography, if the result was negative, PTT: 11–12 s | Preoperative started the night before surgery
Planes 1988 2853459 France | Enoxaparin | LMWH | 40 mg qD, SC, until 14 days or discharge | Preoperative 12 hr
Planes 1988 2853459 France | Heparin | UFH | 5000 IU q8h, SC, until 14 days or discharge | Preoperative 12 hr
Planes 1997 9048403 France | Enoxaparin to discharge | LMWH | 40 mg qD, SC, until just before discharge | Preoperative immediately before surgery
Planes 1997 9048403 France | Enoxaparin 21 days post-discharge | LMWH | 40 mg qD, SC, until the 21st day after discharge | Preoperative immediately before surgery
Planès 1999 10348714 France | Enoxaparin | LMWH | 40 mg qD, SC, 15 days | Preoperative 12 hr
Planès 1999 10348714 France | Tinzaparin | LMWH | 4500 antifactor IU Xa qD, SC, 15 days | Preoperative 12 hr
Prandoni 2002 12230419 Italy | Warfarin until hospital discharge | VKA | 5 mg qD, Oral, until discharge | Preoperative started the 2nd pre-op day
Prandoni 2002 12230419 Italy | Warfarin 28 days | VKA | 5 mg qD, Oral, 28 days | Preoperative started the 2nd pre-op day
Rader 1998 9526211 Germany | [underlined: Heparin] then Enoxaparin | UFH then LMWH | 5000 IU the night before the operation as well as in the morning and the evening of the operation day, SC, 1 day | Preoperative started the night before surgery
Rader 1998 9526211 Germany | Heparin then [underlined: Enoxaparin] | UFH then LMWH | 40 mg qD, SC, until discharge (mean 16.7 days) | Preoperative started the night before surgery
Rader 1998 9526211 Germany | [underlined: Heparin] then Heparin | UFH | 5000 IU the night before the operation as well as in the morning and the evening of the operation day, SC, 1 day | Preoperative started the night before surgery
Rader 1998 9526211 Germany | Heparin then [underlined: Heparin] | UFH | 5000 IU TID, SC, 3 days; then 7500 IU TID, SC, 1 day, PTT: 40s | Postperative after the first 3 doses
Raskob 2010 20589317 USA, Canada, Russia, 4 European countries | Edoxaban 90 mg | FXaI | 90 mg qD, Oral, 7–10 days | Postoperative 6–8 hr
Raskob 2010 20589317 USA, Canada, Russia, 4 European countries | Edoxaban 60 mg | FXaI | 60 mg qD, Oral, 7–10 days | Postoperative 6–8 hr
Raskob 2010 20589317 USA, Canada, Russia, 4 European countries | Edoxaban 30 mg | FXaI | 30 mg qD, Oral, 7–10 days | Postoperative 6–8 hr
Raskob 2010 20589317 USA, Canada, Russia, 4 European countries | Edoxaban 15 mg | FXaI | 15 mg qD, Oral, 7–10 days | Postoperative 6–8 hr
Raskob 2010 20589317 USA, Canada, Russia, 4 European countries | Dalteparin 5000 IU | LMWH | 5000 IU qD, SC, 7–10 days | Postoperative 6–8 hr
Ryan 2002 12429761 USA | IPC | Mechanical | Continuously, until 4–5 days after patient able to stand independently | Postoperative immediately after surgery
Ryan 2002 12429761 USA | GCS | Mechanical | Continuously, until 4–5 days after patient able to stand independently | Postoperative immediately after surgery
Santori 1994 8027144 Italy | VFP | Mechanical | Continuously, 7–10 days | Postoperative immediately after surgery
Santori 1994 8027144 Italy | Heparin | UFH | 5000 IU TID, SC, 10 days | Preoperative started the day before surgery
Schwartsmann 1996 Embase 1996366023 Brazil | Enoxaparin | LMWH | 40 mg qD, SC, 10 days | Postoperative started immediately after surgery
Schwartsmann 1996 Embase 1996366023 Brazil | Heparin | UFH | 5000 IU q8h, SC, 10 days | Postoperative started immediately after surgery
Senaran 2006 16333632 Turkey | Enoxaparin | LMWH | 40 mg qD, SC, 7–10 days post-op or until discharge | Preoperative 12 hr
Senaran 2006 16333632 Turkey | Heparin | UFH | 5000 IU q8h, SC, 7–10 days post-op or until discharge | Preoperative 12 hr
Silbersack 2004 15330019 Germany | [underlined: Enoxaparin] + IPC | LMWH + Mechanical | 40 mg qD, SC, until 30 days post–op | Preoperative started the evening before surgery
Silbersack 2004 15330019 Germany | Enoxaparin + [underlined: IPC] | LMWH + Mechanical | Continuously, bilateral, until post-op day 10 | Postoperative in the recovery room
Silbersack 2004 15330019 Germany | [underlined: Enoxaparin] + GCS | LMWH + Mechanical | 40 mg qD, SC, until 30 days post–op | Preoperative started the evening before surgery
Silbersack 2004 15330019 Germany | Enoxaparin + [underlined: GCS] | LMWH + Mechanical | <= 90 days | Postoperative
Stannard 1996 8640382 USA | [underlined: Heparin] then Aspirin + VFP | UFH then Antiplatelet + Mechanical | 5000 U qD, SC, 3 days | NR
Stannard 1996 8640382 USA | Heparin then [underlined: Aspirin] + VFP | UFH then Antiplatelet + Mechanical | 325 mg BID, Oral | NR
| Heparin then Aspirin + [underlined: VFP] | UFH then Antiplatelet + Mechanical | 16h/d for first 3 days, 12h/d for the remainder, bilateral | Postoperative immediately after surgery
| [underlined: Heparin] then Aspirin | UFH then Antiplatelet | 5000 U qD, SC, 3 days | NR
| Heparin then [underlined: Aspirin] | UFH then Antiplatelet | 325 mg BID, Oral | NR
| VFP | Mechanical | 16h/d for first 3 days, 12h/d for the remainder, bilateral | Postoperative immediately after surgery
Stone 1996 9049766 UK | IPC | Mechanical | Until discharge or 10 days post-op | Intraoperative the opposite limb, postoperative operated limb
Stone 1996 9049766 UK | Enoxaparin | LMWH | 40 mg qD, SC, until discharge or 10 days post-op | Preoperative started the evening before surgery
Turpie 2002 12049860 Canada, USA, Australia | Fondaparinux | FXaI | 2.5 mg qD, SC, 5–9 days | Postoperative 4–8 hr
Turpie 2002 12049860 Canada, USA, Australia | Enoxaparin | LMWH | 30 mg BID, SC, 5–9 days | Postoperative 12–24 hr
Verhamme 2013 23615791 8 European countries, Russia | Rivaroxaban 10 mg | FXaI | 10 mg qD, Oral, 35 days | Postoperative 6–8 hr
Verhamme 2013 23615791 8 European countries, Russia | TB-402 50 mg | FVIII Inhibitor | 50 mg^‡^, IV | Postoperative 2–4 hr
Verhamme 2013 23615791 8 European countries, Russia | TB-402 25 mg | FVIII Inhibitor | 25 mg^‡^, IV | Postoperative 2–4 hr
Warwick 1998 9730125 UK | VFP | Mechanical | Continuously, until the 8th post-op day | Postoperative in the recovery room
Warwick 1998 9730125 UK | Enoxaparin | LMWH | 40 mg q24h, SC, untill 8th post-op day | Preoperative 12 hr
Woolson 1991 2013589 USA | [underlined: Aspirin] + IPC | Antiplatelet + Mechanical | 650 mg BID, Oral | Preoperative started the evening before surgery
Woolson 1991 2013589 USA | Aspirin + [underlined: IPC] | Antiplatelet + Mechanical | Bilaterally, until DVT screening | Intraoperative
Woolson 1991 2013589 USA | [underlined: Wafarin] + IPC | VKA + Mechanical | Oral, PT: 1.2 to 1.3 X the control | Preoperative started the evening before surgery
Woolson 1991 2013589 USA | Wafarin + [underlined: IPC] | VKA + Mechanical | Bilaterally, until DVT screening | Intraoperative
Woolson 1991 2013589 USA | IPC | Mechanical | Bilaterally, until DVT screening | Intraoperative
Yokote 2011 21282767 Japan | Fondaparinux | FXaI | 2.5 mg qD, SC, 10 days | Postoperative 18 hr (mean)
Yokote 2011 21282767 Japan | Enoxaparin | LMWH | 40 mg qD, SC, 10 days | Postoperative 17 hr (mean)
Zhang 2013 EMBASE 2014592535 China | Rivaroxaban | FXaI | 10 mg/d, 5 weeks | Postoperative 6 hr
Zhang 2013 EMBASE 2014592535 China | LMWH | LMWH | 4100 U/d, 2 weeks | Postoperative 6 hr
Zhang 2014 24767296 China | Rivaroxaban 7 days | FXaI | 10 mg/d, Oral, 7 days | Postoperative 6–10 hr
Zhang 2014 24767296 China | Rivaroxaban 35 days | FXaI | 10 mg/d, Oral, 35 days | Postoperative 6–10 hr
Zhirova 2014 25831700 Russia | [underlined: Enoxaparin] + Rivaroxaban | LMWH + FXaI | 40 mg | Preoperative 12 hr
Zhirova 2014 25831700 Russia | Enoxaparin + [underlined: Rivaroxaban] | LMWH + FXaI | 10 mg | NR
Zhirova 2014 25831700 Russia | [underlined: Enoxaparin] + Dabigatran | LMWH + DTI | 40 mg | Preoperative 12 hr
| Enoxaparin + [underlined: Dabigatran] | LMWH + DTI | 220 mg | NR
| Enoxaparin | LMWH | 40 mg | Preoperative 12 hr

Abbreviation list: LMWH= Low molecular weight heparin, DTI= Direct thrombin inhibitor, FXaI= Factor Xa inhibitor, UFH= Heparin, unfractionated, VKA= Vitamin K antagonis, FVIII= Factor VIII, FXI= Factor XI, (e)= Enoxaparin, (t)= Tinzaparin, (d)= Dalteparin, INR= International Normalized Ratio, PPT= Partial Thromboplastin Time, PT= Prothrombin Time

* Dose or frequency was determined based on creatinine clearance.

† For studies with more than one treatment modalities in a single arm, each modality is described separately in a single row. The underline indicates which one is described in the row.

‡ Only single dose was provided.

§ Until 14th day postoperatively, venography or discharge.

|| For certain days or until hospital discharge, whichever occurred first.

Table E2 Total knee replacement: Randomized controlled trials

Author Year PMID Country/Region | Arm^†^ | Class | Drug dose, route, duration, INR/PTT/PT | Initiation time
Barrellier 2010 20797774 France | Anticoagulation (mixed) 10+−2 days | LMWH, FXaI, or UFH | 4000 IU (e)/5000 IU (d)/4500 (t), 11.2 days | Postoperative
Barrellier 2010 20797774 France | Anticoagulation (mixed) 35+−5 days | LMWH, FXaI, or UFH | 4000 IU (e)/5000 IU (d)/4500 (t), 33.9 days | Postoperative
Bauer 2001 11794149 North America | Fondaparinux | FXaI | 2.5 mg qD, SC, till 5th to 9th post-op day | Postoperative 6 hr (2)
Bauer 2001 11794149 North America | Enoxaparin | LMWH | 30 mg BID, SC, till 5th to 9th post-op day | Postoperative 12–24 hr
Bonneux 2006 16387501 Belgium | Fondaparinux | FXaI | 2.5 mg qD, 6 weeks | Postoperative 6–12 hr
Bonneux 2006 16387501 Belgium | Enoxaparin | LMWH | 40 mg qD, 6 weeks | Preoperative started the evening before surgery
Büller 2015 25482425 Canada, 4 S/SE European countries | FXI-ASO 300 | FXI Inhibitor | 300 mg qOD for the 1st week then qW, SC, 39 days | Preoperative 36 days
Büller 2015 25482425 Canada, 4 S/SE European countries | FXI-ASO 200 | FXI Inhibitor | 200 mg qOD for the 1st week then qW, SC, 39 days | Preoperative 36 days
Büller 2015 25482425 Canada, 4 S/SE European countries | Enoxaparin | LMWH | 40 mg qD, SC, 10 days | Pre or post-operative (depending on investigator)
Choi 2015 24408881 Korea | IPC | Mechanical | 90 cycles/h (fixed), 28 sec/cycle, 2 sessions/day, 16.4 days (5.4) | Postoperative started the day of surgery
Choi 2015 24408881 Korea | IPC | Mechanical | 78.9 cycles/h (variable), 12 sec/cycle, 2 sessions/day, 16.4 days (5.4) | Postoperative started the day of surgery
Cohen 2013 23782955 Australia, Canada, Europe, Russia, South Africa, USA | Eribaxaban 10 mg | FXaI | 10 mg qD, 6–14 days | Postoperative 6–8 hr
Cohen 2013 23782955 Australia, Canada, Europe, Russia, South Africa, USA | Eribaxaban 4 mg | FXaI | 4 mg qD, 6–14 days | Postoperative 6–8 hr
Cohen 2013 23782955 Australia, Canada, Europe, Russia, South Africa, USA | Eribaxaban 2.5 mg | FXaI | 2.5 mg qD, 6–14 days | Postoperative 6–8 hr
Cohen 2013 23782955 Australia, Canada, Europe, Russia, South Africa, USA | Eribaxaban 1 mg | FXaI | 1 mg qD, 6–14 days | Postoperative 6–8 hr
Cohen 2013 23782955 Australia, Canada, Europe, Russia, South Africa, USA | Eribaxaban 0.5 mg | FXaI | 0.5 mg qD, 6–14 days | Postoperative 6–8 hr
Cohen 2013 23782955 Australia, Canada, Europe, Russia, South Africa, USA | Eribaxaban 0.3 mg | FXaI | 0.3 mg qD, Oral, 6–14 days | Postoperative 6–8 hr
Cohen 2013 23782955 Australia, Canada, Europe, Russia, South Africa, USA | Eribaxaban 0.1 mg | FXaI | 0.1 mg qD, Oral, 6–14 days | Postoperative 6–8 hr
Cohen 2013 23782955 Australia, Canada, Europe, Russia, South Africa, USA | Enoxaparin 30 mg BID | LMWH | 30 mg BID, SC, 6–14 days | Postoperative ~19.3 hr
Colwell 1995 7497668 USA | Enoxaparin | LMWH | 30 mg q12h, SC, 7 days | Postoperative <= 8 hr
Colwell 1995 7497668 USA | Heparin | UFH | 5000 U q8h, SC, 7 days | Postoperative <= 8 hr
Comp 2001 11263636 USA | Enoxaparin 7–10 days | LMWH | 30 mg BID, SC, 7–10 days | Postoperative 12–24 hr
Comp 2001 11263636 USA | Enoxaparin [underlined: 7–10 days] then 3 weeks | LMWH | 30 mg BID, SC, 7–10 days | Postoperative 12–24 hr
Comp 2001 11263636 USA | Enoxaparin 7–10 days then [underlined: 3 weeks] | LMWH | 40 mg qD, SC, 3 weeks | Postoperative 7–10 days
Edwards 2008 18534421 USA | [underlined: Enoxaparin] + IPC | LMWH + Mechanical | 30 mg q12h, SC, 7–8 days | Postoperative started the morning after surgery
Edwards 2008 18534421 USA | Enoxaparin + [underlined: IPC] | LMWH + Mechanical | ActiveCare DVT, till discharge | In the operation room
Edwards 2008 18534421 USA | Enoxaparin | LMWH | 30 mg q12h, SC, 7–8 days | Postoperative started the morning after surgery
Eisele 2007 17473143 Germany | [underlined: Certoparin] + IPC | LMWH + Mechanical | 3000 aXa qD, SC, until discharge | Preoperative 12 hr
Eisele 2007 17473143 Germany | Certoparin + [underlined: IPC] | LMWH + Mechanical | 6s/session, every 1 min, 1–16 days | NR
Eisele 2007 17473143 Germany | Certoparin | LMWH | 3000 aXa qD, SC, until discharge | Preoperative 12 hr
Eriksson 2005 15634273 11 European countries, South Africa | Dabigatran 225 mg BID | DTI | 225 mg BID, Oral, until venography (6–10 days) | Postoperative 1–4 hr
Eriksson 2005 15634273 11 European countries, South Africa | Dabigatran 150 mg BID | DTI | 150 mg BID, Oral, until venography (6–10 days) | Postoperative 1–4 hr
Eriksson 2005 15634273 11 European countries, South Africa | Dabigatran 300 mg qD | DTI | 300 mg qD, Oral, until venography (6–10 days) | Postoperative 1–4 hr
Eriksson 2005 15634273 11 European countries, South Africa | Dabigatran 50 mg BID | DTI | 50 mg BID, Oral, until venography (6–10 days) | Postoperative 1–4 hr
Eriksson 2005 15634273 11 European countries, South Africa | Enoxaprin | LMWH | 40 mg qD, SC, until venography (6–10 days) | Preoperative 12 hr
Eriksson 2007A 17764540 13 European countries, Australia, South Africa | Dabigatran 220 mg | DTI | 220 mg qD, Oral, 6–10 days | Postoperative 1–4 hr
Eriksson 2007A 17764540 13 European countries, Australia, South Africa | Dabigatran 150 mg | DTI | 150 mg qD, Oral, 6–10 days | Postoperative 1–4 hr
Eriksson 2007A 17764540 13 European countries, Australia, South Africa | Enoxaparin | LMWH | 40mg qD, SC, 6–10 days | Preoperative started the evening before surgery (post-operative in some countries)
Faunø 1994 7989386 Finland, Denmark | Enoxaparin | LMWH | 40 mg qD, SC, 7–10 days | Preoperative started the evening before surgery
Faunø 1994 7989386 Finland, Denmark | Heparin | UFH | 5000 IU TID, SC, 7–10 days | Preoperative started the evening before surgery
Fitzgerald 2001 11407799 NR | Enoxaparin | LMWH | 30 mg q12h, SC, 4–14 days | Postoperative <=8 hr after wound closure
Fitzgerald 2001 11407799 NR | Warfarin | VKA | Oral, 4–14 days, INR: 2–3 | Postoperative <=8 hr after wound closure
Fuji 2008 18843459 Japan | Enoxaparin 40 mg qD | LMWH | 40 mg qD, SC, 14 days | Postoperative 24–36 hr
Fuji 2008 18843459 Japan | Enoxaparin 20 mg BID | LMWH | 20 mg BID, SC, 14 days | Postoperative 24–36 hr
Fuji 2010A 19854610 Japan | Dabigatran 220 mg | DTI | 220 mg qD, Oral, 11–14 days | Postoperative >=2 hr after removing indwelling catheter + confirming absence of abnormal bleeding at drainage site
Fuji 2010A 19854610 Japan | Dabigatran 150 mg | DTI | 150 mg qD, Oral, 11–14 days | Postoperative >=2 hr after removing indwelling catheter + confirming absence of abnormal bleeding at drainage site
Fuji 2010B 20723033 Japan | Edoxaban 60 mg | FXaI | 60 mg qD, Oral, 11–14 days | Postoperative 6–24 hr
Fuji 2010B 20723033 Japan | Edoxaban 30 mg | FXaI | 30 mg qD, Oral, 11–14 days | Postoperative 6–24 hr
Fuji 2010B 20723033 Japan | Edoxaban 15 mg | FXaI | 15 mg qD, Oral, 11–14 days | Postoperative 6–24 hr
Fuji 2010B 20723033 Japan | Edoxaban 5 mg | FXaI | 5 mg qD, Oral, 11–14 days | Postoperative 6–24 hr
Fuji 2014D 22952213 3 Asian countries | Darexaban 30 mg | FXaI | 30 mg BID, Oral, 10–14 days | Postoperative 12–24 hr
Fuji 2014D 22952213 3 Asian countries | Darexaban 15 mg | FXaI | 15 mg BID, Oral, 10–14 days | Postoperative 12–24 hr
Fuji 2014D 22952213 3 Asian countries | Enoxaparin | LMWH | 20 mg (2000 IU) BID (q12h), SC, 10–14 days | Postoperative 24–36 hr
Fuji 2014C 25294589 Japan, Taiwan | Edoxaban | FXaI | 30 mg qD, Oral, 11–14 days | Postoperative 6–24 hr
Fuji 2014C 25294589 Japan, Taiwan | Enoxaparin | LMWH | 2000 IU BID, SC, 11–14 days | Postoperative 24–36 hr
Ginsberg 2009 18534438 N/S America, UK | Dabigatran 220 mg | DTI | 220 mg qD, Oral, 12–15 days | Postoperative 6–12 hr
| Dabigatran 150 mg | DTI | 150 mg qD, Oral, 12–15 days | Postoperative 6–12 hr
| Enoxaparin | LMWH | 30 mg BID, SC, 12–15 days | Postoperative 12–24 hr
Haas 1990 2404020 USA | IPC | Mechanical | Continuously, until the morning after lung scan | Preoperative uninvolved limb, postoperative operated limb
Haas 1990 2404020 USA | Aspirin | Antiplatelet | 650 mg BID, Oral, until discharge | Preoperative started the day before surgery
Hu 2015 No PMID China | Rivaroxaban | FXaI | 10 mg qD, Oral, 2 weeks | Postoperative 6 hr
Hu 2015 No PMID China | Enoxaparin | LMWH | 5000 U qD, SC, 2 weeks | Preoperative 12 hr
Hull 1993 8413432 USA, Canada | Tinzaparin | LMWH | 75 IU/kg qD, SC, 14 days^§^ | Postoperative 18–24 hr
Hull 1993 8413432 USA, Canada | Warfarin | VKA | qD, Oral, 14 days^§^, INR: 2.0–3.0 | Preoperative started the evening before surgery
Iliopoulos 2011 Abstract P104 Greece | Fondaparinux | FXaI | 2.5 mg | Postoperative 6 hr
Iliopoulos 2011 Abstract P104 Greece | Dabigatran | DTI | 110 mg | Postoperative 6 hr
Iliopoulos 2011 Abstract P104 Greece | Enoxaparin | LMWH | 40 mg | Postoperative 6 hr
Iliopoulos 2011 Abstract P104 Greece | Tinzaparin | LMWH | 0.45 mg | Postoperative 6 hr
Jiang 2014 24931228 China | [underlined: LMWH] then rivaroxaban | LMWH then FXaI | 5000 U qD, SC, 1–5 days | Postoperative
Jiang 2014 24931228 China | LMWH then [underlined: rivaroxaban] | LMWH then FXaI | 10 mg qD, Oral, 5–14 days | Postoperative
Jiang 2014 24931228 China | Aspirin | Antiplatelet | 100 mg qD, Oral, 14 days | Postoperative
Koo 2014 25436073 S Korea | IPC | Mechanical | 12 sec/cycle, 2 hours/session, 6 sessions/day | Postoperative
Koo 2014 25436073 S Korea | IPC | Mechanical | 11 sec/cycle, 2 hours/session, 6 sessions/day | Postoperative
Lachiewicz 2004 15568526 USA | IPC | Mechanical | >=12–16 h/d, Venaflow | Preoperative contralateral limb (in the OR), postoperative operated limb
Lachiewicz 2004 15568526 USA | IPC | Mechanical | >=12–16 h/d, Kendal | Preoperative contralateral limb (in the OR), postoperative operated limb
Lassen 2007 17868430 N/S America, Australia, Denmark, Israel, Poland | Enoxaparin | LMWH | 30 mg Q12h, SC, 12 +/− 2 days | Postoperative 12–24 hr after skin wound closure
Lassen 2007 17868430 N/S America, Australia, Denmark, Israel, Poland | Warfarin | VKA | 5 mg qD, Oral, 12 +/− 2 days | Postoperative started the evening of surgery
Lassen 2010B 20206776 27 countries | Apixaban | FXaI | 2.5 mg BID, Oral, 10–14 days | Postoperative 12–24 hr
Lassen 2010B 20206776 27 countries | Enoxaparin | LMWH | 40 mg qD, SC, 10–14 days | Preoperative 12 hr
Lassen 2012 22429800 Multinational | Semuloparin | LMWH | 10 or 20 mg qD^*^, 8.3 days (1.7) | Postoperative 8 hr (1)
Lassen 2012 22429800 Multinational | Enoxaparin | LMWH | 20 or 40 mg qD^*^, 8.3 days (1.7) | Postoperative 12 hr (1)
Leclerc 1996 8607589 Canada | Enoxaparin | LMWH | 30 mg q12h, SC, 14 days^\|\|^ | Postoperative started the 1st day after surgery
Leclerc 1996 8607589 Canada | Warfarin | VKA | qD, 14 days^\|\|^, INR 2.0–3.0 | Postoperative started the evening of surgery
Lotke 1996 8595765 USA | Aspirin | Antiplatelet | 325 mg BID, Oral, 6 weeks | Preoperative started the day of admission
Lotke 1996 8595765 USA | Warfarin | VKA | qD, Oral, 6 weeks, PT: 1.2–1.5 X control value | Postoperative started the night of surgery
Mirdamadi 2014 25815018 Iran | Dabigatran | DTI | 225 mg qD, Oral, 15 days | Postoperative 4 hr
Mirdamadi 2014 25815018 Iran | Enoxaparin | LMWH | 40 mg qD, SC, 15 days | Preoperative 12 hr
Rader 1998 9526211 Germany | [underlined: Heparin] then Enoxaparin | UFH then LMWH | 5000 IU the night before the operation as well as in the morning and the evening of the operation day, SC, 1 day | Preoperative started the night before surgery
Rader 1998 9526211 Germany | Heparin then [underlined: Enoxaparin] | UFH then LMWH | 40 mg qD, SC, until discharge (mean 16.7 days) | Preoperative started the night before surgery
Rader 1998 9526211 Germany | [underlined: Heparin] then Heparin | UFH | 5000 IU the night before the operation as well as in the morning and the evening of the operation day, SC, 1 day | Preoperative started the night before surgery
Rader 1998 9526211 Germany | Heparin then [underlined: Heparin] | UFH | 5000 IU TID, SC, 3 days; then 7500 IU TID, SC, 1 day, PTT: 40s | Postperative after the first 3 doses
Sakai 2016 26735531 | Edoxaban + IPC | FXai + Mechanical | 15 mg qD, ~11 days; 1 second compressions of 130 mgHg, 20/minute, 4 days | Postoperative 12 hr
Sakai 2016 26735531 | Edoxaban | FXai | 15 mg qD, ~11 days | Postoperative 12 hr
Silbersack 2004 15330019 Germany | [underlined: Enoxaparin] + IPC | LMWH + Mechanical | 40 mg qD, SC, until 30 days post–op | Preoperative started the evening before surgery
Silbersack 2004 15330019 Germany | Enoxaparin + [underlined: IPC] | LMWH + Mechanical | Continuously, bilateral, until post-op day 10 | Postoperative in the recovery room
Silbersack 2004 15330019 Germany | [underlined: Enoxaparin] + GCS | LMWH + Mechanical | 40 mg qD, SC, until 30 days post–op | Preoperative started the evening before surgery
Silbersack 2004 15330019 Germany | Enoxaparin + [underlined: GCS] | LMWH + Mechanical | <= 90 days | Postoperative
Verhamme 2011 21284801 5 European countries, Israel, Russia | [underlined: Enoxaparin] then TB-402 1.2 mg/kg | LMWH then FVIII Ihibitor | 40 mg^‡^, SC | Preoperative started the night before surgery
Verhamme 2011 21284801 5 European countries, Israel, Russia | Enoxaparin then [underlined: TB-402 1.2 mg/kg] | LMWH then FVIII Ihibitor | 1.2 mg/kg^‡^, IV | Postperative started the day after surgery
Verhamme 2011 21284801 5 European countries, Israel, Russia | [underlined: Enoxaparin] then TB-402 0.6 mg/kg | LMWH then FVIII Ihibitor | 40 mg^‡^, SC | Preoperative started the night before surgery
Verhamme 2011 21284801 5 European countries, Israel, Russia | Enoxaparin then [underlined: TB-402 0.6 mg/kg] | LMWH then FVIII Ihibitor | 0.6 mg/kg^‡^, IV | Postperative started the day after surgery
Verhamme 2011 21284801 5 European countries, Israel, Russia | [underlined: Enoxaparin] then TB-402 0.3 mg/kg | LMWH then FVIII Ihibitor | 40 mg^‡^, SC | Preoperative started the night before surgery
Verhamme 2011 21284801 5 European countries, Israel, Russia | Enoxaparin then [underlined: TB-402 0.3 mg/kg] | LMWH then FVIII Ihibitor | 0.3 mg/kg^‡^, IV | Postperative started the day after surgery
Verhamme 2011 21284801 5 European countries, Israel, Russia | Enoxaparin | LMWH | 40 mg qD, SC, ~11 days | Preoperative started the night before surgery
Warwick 2002 12002490 UK | Enoxaparin | LMWH | 40 mg q24h, SC, untill discharge | Preoperative 12 hr
Warwick 2002 12002490 UK | VFP | Mechanical | Continuously, until discharges | Postoperative in the recovery room
Weitz 2010 20886185 USA, Canada | TAK-442 80 BID | FXaI | 80 mg BID, Oral, 10 days | Postoperative 6–8 hr
Weitz 2010 20886185 USA, Canada | TAK-442 40 BID | FXaI | 40 mg BID, Oral, 10 days | Postoperative 6–8 hr
Weitz 2010 20886185 USA, Canada | TAK-442 80 qD | FXaI | 80 mg qD, Oral, 10 days | Postoperative 6–8 hr
Weitz 2010 20886185 USA, Canada | TAK-442 20 BID | FXaI | 20 mg BID, Oral, 10 days | Postoperative 6–8 hr
Weitz 2010 20886185 USA, Canada | TAK-442 40 qD | FXaI | 40 mg qD, Oral, 10 days | Postoperative 6–8 hr
Weitz 2010 20886185 USA, Canada | TAK-442 10 BID | FXaI | 10 mg BID, Oral, 10 days | Postoperative 6–8 hr
Weitz 2010 20886185 USA, Canada | Enoxaparin | LMWH | 30 mg BID, SC, 10 days | Postoperative 12–14 hr
Westrich 1996 8666599 USA | [underlined: Aspirin]+ VFP | Antiplatelet + Mechanical | 325 mg BID, Oral, for the study duration | Postoperative started the night of surgery
Westrich 1996 8666599 USA | Aspirin+ [underlined: VFP] | Antiplatelet + Mechanical | Continuously, until venogram | Postoperative in the recovery room
Westrich 1996 8666599 USA | Aspirin | Antiplatelet | 325 mg BID, Oral, for the study duration | Postoperative started the night of surgery
Westrich 2006 16950076 USA | [underlined: Enoxaparin] + Venoflow | LMWH + Mechanical | 30 mg BID, until discharge, then 40 mg qD for 3 weeks | Postoperative 2 hr
| Enoxaparin + [underlined: Venoflow] | LMWH + Mechanical | Entire hospital stay, bilateral | Postoperative in recovery room
| [underlined: Aspirin] + Venoflow | Antiplatelet + Mechanical | 325 mg BID, Oral, 4 weeks | Postoperative in recovery room
| Aspirin + [underlined: Venoflow] | Antiplatelet + Mechanical | Entire hospital stay, bilateral | Postoperative in recovery room
Windisch 2011 20652250 Germany | [underlined: Enoxaparin] + VFP | LMWH + Mechanical | 40 mg qD, SC, 8 days | Preoperative 24 hr
Windisch 2011 20652250 Germany | Enoxaparin + [underlined: VFP] | LMWH + Mechanical | 24 hours | Postoperative in recovery room
Windisch 2011 20652250 Germany | Enoxaparin | LMWH | 40 mg qD, SC, 8 days | Preoperative 24 hr
Yilmaz 2015 25852131 Turkey | [underlined: Enoxaparin] + Electrostimulation device (The Geko) | LMWH + Mechanical | 1 mg BID, SC, 6 days | Postoperative 6 hr
Yilmaz 2015 25852131 Turkey | Enoxaparin + [underlined: Electrostimulation device (The Geko)] | LMWH + Mechanical | 1 hr/session, 6 sessions/day, 6 days | Postoperative
Yilmaz 2015 25852131 Turkey | Enoxaparin | LMWH | 1 mg BID, SC, 6 days | Postoperative 6 hr
Zou 2014 24695091 China | Rivaroxaban | FXaI | 10 mg qD, Oral, 14 days | Postoperative 12 hr
Zou 2014 24695091 China | Enoxaparin | LMWH | 0.4 ml qD, SC, 14 days | Postoperative 12 hr
Zou 2014 24695091 China | Aspirin | Antiplatelet | 100 mg qD, Oral, 14 days | Postoperative 12 hr
NCT00595426 | Wafarin | VKA | Oral, INR 2.0–3.0 | ND
NCT00595426 | Darexaban 30 mg BID | FXaI | 30 mg BID, Oral | ND
NCT00595426 | Darexaban 60 mg QD | FXaI | 60 mg QD, Oral | ND
NCT00595426 | Darexaban 60 mg BID | FXaI | 60 mg BID, Oral | ND
NCT00595426 | Darexaban 120 mg QD | FXaI | 120 mg QD, Oral | ND
NCT00246025 | Dabigatran Etexilate 110 mg | DTI | 110 mg qD, Oral, 2 weeks | ND
NCT00246025 | Dabigatran Etexilate 150 mg | DTI | 150 mg qD, Oral, 2 weeks | ND
NCT00246025 | Dabigatran Etexilate 220 mg | DTI | 220 mg qD, Oral, 2 weeks | ND

Abbreviation list: LMWH= Low molecular weight heparin, DTI= Direct thrombin inhibitor, FXaI= Factor Xa inhibitor, UFH= Heparin, unfractionated, VKA= Vitamin K antagonis, FVIII= Factor VIII, FXI= Factor XI, (e)= Enoxaparin, (t)= Tinzaparin, (d)= Dalteparin, INR= International Normalized Ratio, PPT= Partial Thromboplastin Time, PT= Prothrombin Time

* Dose or frequency was determined based on creatinine clearance.

† For studies with more than one treatment modalities in a single arm, each modality is described separately in a single row. The underline indicates which one is described in the row.

‡ Only single dose was provided.

§ Until 14th day postoperatively, venography or discharge.

|| For certain days or until hospital discharge, whichever occurred first.

Table E3 Hip fracture surgery: Randomized controlled trials

Author Year PMID Country/Region | Arm^†^ | Class | Drug dose, route, duration, INR/PTT/PT | Initiation time
Eriksson 2001 11794148 21 countries | Fondaparinux | FXaI | 2.5 mg qD, SC, 5–9 days | Postoperative 6 hr (2) (if surgery was on time) or 12 hr (2) (if surgery was delayed)
Eriksson 2001 11794148 21 countries | Enoxaparin | LMWH | 40 mg qD, SC, 5–9 days | Preoperative 12 hr (2)
Eriksson 2003 12796070 Europe and South America | Fondaparinux 6–8 days | FXaI | 2.5 mg qD, SC, 6–8 days | Started <2 hr after randomization
Eriksson 2003 12796070 Europe and South America | Fondaparinux 25–31 days | FXaI | 2.5 mg qD, SC, 25–31 days | Started <2 hr after randomization
Fisher 2013 23539696 Multinational | Semuloparin 8 days | LMWH | 20 mg qD, SC, ~7.9 days | Postoperative 8 hr
Fisher 2013 23539696 Multinational | Semuloparin 28 days | LMWH | 20 mg qD, SC, ~27.8 days | Postoperative 8 hr
Fuji 2014B 24680549 Japan | Edoxaban | FXaI | 30 mg qD, Oral, 11–14 days | Postoperative 6–24 hr
Fuji 2014B 24680549 Japan | Enoxaparin | LMWH | 2000 IU BID, SC, 11–14 days | Postoperative 24–36 hr
Kennedy 2000 10697085 NR | VFP | Mechanical | >=18 h/d, until the patient was fully ambulatory | Postoperative in the recovery room
Kennedy 2000 10697085 NR | Aspirin | Antiplatelet | 325 mg BID, Oral | Postoperative started the surgery day (as soon as the patient was able to tolerate pills orally)
Lassen 2012 22429800 HFx Multinational | Enoxaparin | LMWH | 20 or 30 mg qD^*^, 8.4 days (1.6) | Postoperative 12 hr (1)
Lassen 2012 22429800 HFx Multinational | Semuloparin | LMWH | 10 or 20 mg qD^*^, 8.4 days (1.6) | Postoperative 8 hr (1)
Monreal 1989 2544742 Spain | Dalteparin | LMWH | 5000 U qD, SC, 9 days | Preoperative 2 hr
Monreal 1989 2544742 Spain | Heparin | UFH | 5000 U q8h, SC, 9 days | Preoperative 2 hr
Powers 1989 2650646 Canada | Aspirin | Antiplatelet | 650 mg BID, Oral, 21 days^\|\|^ | Postoperative
Powers 1989 2650646 Canada | Warfarin | VKA | 10 mg, Oral, 21 days^\|\|^ | Postoperative
Sasaki 2011 21293896 Japan | Fondaparinux | FXaI | 1.5 or 2.5 mg qD^*^, SC, 14 days | Postoperative started the day after surgery
Sasaki 2011 21293896 Japan | Enoxaparin | LMWH | 2000 IU qD or BID^*^, SC, 14 days | Postoperative started the day after surgery
The TIFDED Study Group 1999 10844404 4 European countries | Dalteparin | LMWH | 5000 U qD, SC, 9–11 days | Preoperative 2 hr
The TIFDED Study Group 1999 10844404 4 European countries | Enoxaparin | LMWH | 40 mg qD, SC, 9–11 days | Preoperative the last preoperative dose at 2 hr before surgery

Abbreviation list: LMWH= Low molecular weight heparin, DTI= Direct thrombin inhibitor, FXaI= Factor Xa inhibitor, UFH= Heparin, unfractionated, VKA= Vitamin K antagonis, FVIII= Factor VIII, FXI= Factor XI, INR= International Normalized Ratio, PPT= Partial Thromboplastin Time, PT= Prothrombin Time

* Dose or frequency was determined based on creatinine clearance.

† For studies with more than one treatment modalities in a single arm, each modality is described separately in a single row. The underline indicates which one is described in the row.

|| For certain days or until hospital discharge, whichever occurred first.

Table E4 Nonrandomized controlled studies

Author Year PMID Country/Region | Arm | Drug dose, route, duration | Device/IVC filter duration | Initiation time
Total hip replacement
Bloch 2014 24395322 UK | LMWH
Bloch 2014 24395322 UK | LMWH + aspirin (antiplatelet)
Bloch 2014 24395322 UK | Dabigatran (DTI) | 220 mg qD | | Four hours after surgery
Bottle 201510.1016/j.artd.2015.03.004 | Aspirin
Bottle 201510.1016/j.artd.2015.03.004 | Rivaroxaban, Apixaban, Dabigatran
Bottle 201510.1016/j.artd.2015.03.004 | LMWH (standard duration)
Bottle 201510.1016/j.artd.2015.03.004 | LMWH (extended duration)
Ishibe 2011 22101618 Japan | Fondaparinux (FXaI) + mechanical | 2.5 mg qD | Mechanical: 3 h/day for several days | Postoperative immediately after surgery
Ishibe 2011 22101618 Japan | Enoxaparin (LMWH) + mechanical | 20 mg BID | Mechanical: 3 h/day for several days | Postoperative immediately after surgery
Jameson 2011 22058295 UK | Aspirin (antiplatelet)
Jameson 2011 22058295 UK | LMWH
Khatod 2011 22005861 U.S. | compression stockings (mechanical, passive)
Khatod 2011 22005861 U.S. | SCD or VFP (mechanical, active)
Khatod 2011 22005861 U.S. | Aspirin (antiplatelet)
Khatod 2011 22005861 U.S. | aspirin (antiplatelet) + mechanical
Khatod 2011 22005861 U.S. | aspirin (antiplatelet) +/− mechanical
Khatod 2011 22005861 U.S. | Coumadin (warfarin)
Khatod 2011 22005861 U.S. | coumadin (warfarin) + mechanical
Khatod 2011 22005861 U.S. | coumadin (warfarin) +/− mechanical
Khatod 2011 22005861 U.S. | LMWH
Khatod 2011 22005861 U.S. | LMWH + mechanical
Khatod 2011 22005861 U.S. | LMWH +/− mechanical
Pedersen 2015 25511580 Denmark | Anticoagulation (mixed) Short duration (0–6 days) | 6 days
Pedersen 2015 25511580 Denmark | Anticoagulation (mixed) Standard duration (7–27 days) | 27 days
Pedersen 2015 25511580 Denmark | Anticoagulation (mixed) Extended duration (>=28 days) | 28+ days
Vulcano 2012 22684546 U.S. | Aspirin (antiplatelet) | 325 mg, BID, oral, 6 weeks | | Postoperative started the night of surgery
Vulcano 2012 22684546 U.S. | Warfarin | 5 mg, INR goal = 2, 6 weeks | | Postoperative started the night of surgery
Wells 2010 21348557 U.S. | Anticoagulation (mixed) 1–14 days
Wells 2010 21348557 U.S. | Anticoagulation (mixed) >14 days
Wells 2010 21348557 U.S. | Anticoagulation (mixed) 1–21 days
Wells 2010 21348557 U.S. | Anticoagulation (mixed) >21 days
Wells 2010 21348557 U.S. | Anticoagulation (mixed) 1–28 days
Wells 2010 21348557 U.S. | Anticoagulation (mixed) >28 days
Total knee replacement
Bloch 2014 24395322 UK | LMWH
Bloch 2014 24395322 UK | LMWH + aspirin (antiplatelet)
Bloch 2014 24395322 UK | Dabigatran (DTI) | 220 mg qD | | Four hours after surgery
Bottle 2015 10.1016/j.artd.2015.03.004 | Aspirin
Bottle 2015 10.1016/j.artd.2015.03.004 | Rivaroxaban, Apixaban, Dabigatran
Bottle 2015 10.1016/j.artd.2015.03.004 | LMWH (standard duration)
Bottle 2015 10.1016/j.artd.2015.03.004 | LMWH (extended duration)
Bozic 2010 19679434 US | Warfarin
Bozic 2010 19679434 US | Aspirin (antiplatelet)
Jameson 2012 22733945 UK | Aspirin (antiplatelet)
Jameson 2012 22733945 UK | LMWH
Kang 2015 25963358 China | foot pump (mechanical, active) + LMWH
Kang 2015 25963358 China | LMWH
Khatod 2012 21641758 U.S. | compression stockings (mechanical, passive)
Khatod 2012 21641758 U.S. | SCD or VFP (mechanical, active)
Khatod 2012 21641758 U.S. | Aspirin (antiplatelet)
Khatod 2012 21641758 U.S. | aspirin (antiplatelet) + mechanical
Khatod 2012 21641758 U.S. | aspirin (antiplatelet) +/− mechanical
Khatod 2012 21641758 U.S. | Coumadin (warfarin)
Khatod 2012 21641758 U.S. | coumadin (warfarin) + mechanical
Khatod 2012 21641758 U.S. | coumadin (warfarin) +/− mechanical
Khatod 2012 21641758 U.S. | LMWH
Khatod 2012 21641758 U.S. | LMWH + mechanical
Khatod 2012 21641758 U.S. | LMWH +/− mechanical
Llau 2011 Abstract 6AP3-2 Spain | Enoxaparin (LMWH) (start before) | | | Preoperative 12 hours
Llau 2011 Abstract 6AP3-2 Spain | Enoxaparin (LMWH) (start after) | | | Postoperative 6–12 hours
Rath 2013 23566737 UK | Rivaroxaban (FXaI) | 10 mg, 14 days | | Postoperative 6–12 hours
Rath 2013 23566737 UK | aspirin (antiplatelet) +/− enoxaparin (LMWH) | aspirin 150 mg, enoxaparin 40 mg, qD, 6 weeks
Wells 2010 21348557 U.S. | Anticoagulation (mixed) 1–14 days
Wells 2010 21348557 U.S. | Anticoagulation (mixed) >14 days
Wells 2010 21348557 U.S. | Anticoagulation (mixed) 1–21 days
Wells 2010 21348557 U.S. | Anticoagulation (mixed) >21 days
Wells 2010 21348557 U.S. | Anticoagulation (mixed) 1–28 days
Wells 2010 21348557 U.S. | Anticoagulation (mixed) >28 days
Hip fracture surgery
Tsuda 2014 25034972 Japan | Mechanical
Tsuda 2014 25034972 Japan | Mechanical + fondaparinux (FXaI)

Abbreviation list: qD = daily, LMWH = low molecular weight heparin; SCD = Sequential Compression Device; TED = Thromboembolic Deterrent; VFP = venous foot pump; PMID = PubMed ID; DTI = Direct thrombin inhibitor: FXaI = Factor Xa Inhibitor;