# Appendix D Study Design and Baseline Characteristics

Table D1 Total hip replacement: Randomized controlled trials

Study | Article Type; Centers | Funding | Percent Female | Mean Age (SD), Years | KQ 1 | KQ 2 | KQ 3 | KQ 4 | KQ 6
Alfaro 1986 | Peer reviewed publication; Single center | No industry support | 47 | ~64.1 (10.2) | | | X
Andersen 1997 | Peer reviewed publication; Single center | No industry support | 44 | ~67 (Range 34, 84) | | | X
Anderson 2013 | Peer reviewed publication; Multicenter | No industry support | 43 | ~57.8 (12) | X
Avikainen 1995 | Peer reviewed publication; Single center | NR | 67 | ~65.5 (Range 27, 86) | X
Bailey 1991 | Peer reviewed publication; Single center | Industry funded | 52 | ~64.9 (41, 88) | X
Barre 1987 | Peer reviewed publication; Unclear | NR | 54 | ~63.2 | X
Borgen 2012 | Peer reviewed publication; Single center | NR | 65 | ~68 (8.7) | | | | | X
Bramlage 2012 | Peer reviewed publication; Multicenter | Industry funded | 65 | ~71.1 (10.1) | | | X
Colwell 1994 | Peer reviewed publication; Multicenter | Industry funded | 51 | ~65.4 (11.0) | X | | X
Colwell 1999 | Peer reviewed publication; Multicenter | Industry funded | 56 | ~64.0 (13.2) | X
Colwell 2010 | Peer reviewed publication; Multicenter | Industry funded | 55 | ~63 (Range 20, 88) | X
Comp 2001 | Peer reviewed publication; Multicenter | Industry funded | 50 | ~63.9 (Range 26, 90) | | | X
Dahl 1997 | Peer reviewed publication; Multicenter | NR | 71 | ~71.1 | | | X
Dechavanne 1989 | Peer reviewed publication; Multicenter | NR | 55 | ~63.6 (10.7) | X
Edwards 2008 | Peer reviewed publication; Unclear | Industry funded | 57 | ~65.9 (range 31.6, 87.7) | | | | X
Eisele 2007 | Peer reviewed publication; Single center | No industry support | NR | NR | | | | X
Eriksson 1991 | Peer reviewed publication; Unclear | No industry support | 58 | ~68.7 (8.1) | X
Eriksson 1996 | Peer reviewed publication; Multicenter | NR | 62 | ~66.7 (9.8) | X
Eriksson 1997A | Peer reviewed publication; Multicenter | NR | 58 | ~68.4 (9.6) | X
Eriksson 1997B | Peer reviewed publication; Multicenter | Industry funded | 58 | [~66.5 (18, 90)] | X
Eriksson 2005 | Peer reviewed publication; Multicenter | Industry funded | 61 | ~65.9 (range 21, 93) | X
Eriksson 2007B | Peer reviewed publication; Multicenter | Industry funded | 56 | ~64.0 (10.7) | X
Eriksson 2010 | Peer reviewed publication; Multicenter | Industry funded | 53 | ~60.0 (Range 22, 85) | X
Eriksson 2011 | Peer reviewed publication; Multicenter | Industry funded | 52 | ~62.0 (11.5) | X
Eriksson 2014 | Peer reviewed publication; Multicenter | Industry funded | 52 | ~60.1 (9.0) | X
Francis 1992 | Peer reviewed publication; Multicenter | No industry support | 53 | ~64.0 (12.0) | X
Francis 1997 | Peer reviewed publication; Multicenter | NR | 53 | ~63.0 (13.5) | X
Fuji 2008 | Peer reviewed publication; Multicenter | Industry funded | 88 | ~61.9 (9.7) | | | X
Fuji 2014A | Peer reviewed publication; Multicenter | Industry funded | 85 | 60.3 (10.2) | X
Fuji 2014D | Peer reviewed publication; Multicenter | Industry funded | 80 | ~61.6 (10.7) | X
Fuji 2015 | Peer reviewed publication; Multicenter | Industry funded | 86 | 62.8 | X
Hull 1993 | Peer reviewed publication; Multicenter | NR | 59 | ~66.0 (12.0) | X
Hull 2000 | Peer reviewed publication; Multicenter | Industry funded | 52 | ~63.3 (12.7) | X | | | | X
Kalodiki 1996 | Peer reviewed publication; Single center | Industry funded | 50 | ~68 (Range 53, 85) | X
Kim 2016 | Peer reviewed publication; Single center | NR | 42 | 44.2 (9.0) | X
Kim 2016A | Peer reviewed publication; Single center | NR | 63 | 69.0 (6.6) | X
Lassen 1998 | Peer reviewed publication; Multicenter | NR | 54 | ~69.0 (Range 28, 94) | | | X
Lassen 2002 | Peer reviewed publication; Multicenter | Industry funded | 63 | ~66.5 (Range 24, 97) | X
Lassen 2010A | Peer reviewed publication; Multicenter | Industry funded | 53 | 60.8 (Range 19, 93) | X
Lassen 2012 | Peer reviewed publication; Multicenter | Industry funded | 54 | [~59.5 (19, 90)] | | X
Levine 1991 | Peer reviewed publication; Unclear | No industry support | 54 | ~66.5 (9.8) | X
Lieberman 1994 | Peer reviewed publication; Single center | No industry support | 58 | ~66.5 (Range 40, 87) | | | | X
Lotke 1996 | Peer reviewed publication; Unclear | No industry support | 61 | ~66.7 | X
Menzin 1994 8173149 | Peer reviewed publication; Multicenter | Industry funded | 51 | ~65.5 (11.0) | X
Nilsson 1997 | Peer reviewed publication; Single center | NR | 57 | ~70 (Range 44–87) | | | X
Paiement 1987 | Peer reviewed publication; Single center | Industry funded | NR | NR | X
Planès 1988 | Peer reviewed publication; Multicenter | NR | 55 | ~65.8 (10.9) | X
Planès 1997 | Peer reviewed publication; Single center | Industry funded | 43 | ~69.1 (8.7) | | | X
Planès 1999 | Peer reviewed publication; Multicenter | Industry funded | 56 | ~64.5 (11.0) | | X
Prandoni 2002 | Peer reviewed publication; Single center | NR | 55 | ~68.5 (Range 44, 87) | | | X
Rader 1998 | Peer reviewed publication; Single center | NR | 70 | ~69.0 (12.1) | X
Raskob 2010 | Peer reviewed publication; Multicenter | Industry funded | 60 | ~57.8 (9.8) | X
Ryan 2002 | Peer reviewed publication; Single center | Industry funded | 62 | ~68.8 | | X
Santori 1994 | Peer reviewed publication; Unclear | NR | 74 | ~71.1 (6.6) | X
Schwartsmann 1996 | Peer reviewed publication; Unclear | NR | 59 | ~60.1 (10.7) | X
Senaran 2006 | Peer reviewed publication; Single center | Industry funded | 71 | ~53.8 (10.0) | X
Silbersack 2004 | Peer reviewed publication; Single center | Industry funded | 64 | ~64.0 (Range 29, 90) | | | | X
Stannard 1996 | Peer reviewed publication; Single center | NR | NR | ~67.8 (Range 28, 86) | | | | X
Stone 1996 | Peer reviewed publication; Unclear | NR | 64 | ~64.0 (Range 37, 83) | X
Turpie 2002 | Peer reviewed publication; Multicenter | Industry funded | 53 | [~67 (Range 18, 92)] | X
Verhamme 2013 | Peer reviewed publication; Multicenter | Industry funded | 56 | 61 (Range 20, 88) | X
Warwick 1998 | Peer reviewed publication; Single center | Industry supplied materials | 38 | ~68 (11) | X
Woolson 1991 | Peer reviewed publication; Single center | No industry support | 56 | ~65.4 | | | | X
Yokote 2011 | Peer reviewed publication; Single center | NR | 82 | ~63.3 (11.0) | X
Zhang 2013 | Peer reviewed publication; Single center | NR | 43 | ~64.6 (6.4) | X
Zhang 2014 | Peer reviewed publication; Single center | NR | 58 | ~60.7 (Range 37, 78) | | | X
Zhirova 2014 | Peer reviewed publication; Unclear | NR | NR | NR | X | | | X

Abbreviation list: SD= Standard deviation, KQ= Key question, NR= Not reported

Table D2 Total knee replacement: Randomized controlled trials

Study | Article Type; Centers | Funding | Percent Female | Mean Age (SD), Years | KQ1 | KQ2 | KQ3 | KQ4 | KQ6
Barrellier 2010 | Peer reviewed publication; Multicenter | NR | 63 | 70 | | | X
Bauer 2001 | Peer reviewed publication; Multicenter | Industry funded | 59 | ~67.5 (10.5) | X
Bonneux 2006 | Peer reviewed publication; Single center | NR | 79 | ~66.3 (9.5) | X
Büller 2015 | Peer reviewed publication; Multicenter | Industry funded | 81 | ~63.2 (8.8) | X | | X
Choi 2015 | Peer reviewed publication; Single center | Industry supplied materials | 91 | 70.2 (7.4) | | | X
Cohen 2013 | Peer reviewed publication; Multicenter | Industry funded | 64 | ~66.9 (Range 28, 88) | X | | X
Colwell 1995 | Peer reviewed publication; Multicenter | NR | 56 | ~68.0 (9.2) | X
Comp 2001 | Peer reviewed publication; Multicenter | Industry funded | 57 | ~66.3 (Range 34, 88) | | | X
Edwards 2008 | Peer reviewed publication; Unclear | Industry funded | 56 | ~68.4 (range 46.4, 88.1) | | | | X
Eisele 2007 | Peer reviewed publication; Single center | No industry support | NR | NR | | | | X
Eriksson 2005 | Peer reviewed publication; Multicenter | Industry funded | 61 | ~65.9 (range 21, 93) | X | | X
Eriksson 2007A | Peer reviewed publication; Multicenter | Industry funded | 66 | ~66.7 (9) | X | | X
Faunø 1994 | Peer reviewed publication; Multicenter | Industry funded | 61 | ~70.5 (10.5) | X
Fitzgerald 2001 | Peer reviewed publication; Multicenter | Industry funded | 56 | ~68.1 (9.1) | X
Fuji 2008 | Peer reviewed publication; Multicenter | Industry funded | 90 | ~69.1 (9.1) | | | X
Fuji 2010A | Peer reviewed publication; Multicenter | Industry funded | 84 | ~71.6 (7.7) | | | X
Fuji 2010B | Peer reviewed publication; Multicenter | Industry funded | 79 | 71.3 | | | X
Fuji 2014C | Peer reviewed publication; Multicenter | Industry funded | 80 | 72 | X
Fuji 2014D | Peer reviewed publication; Multicenter | Industry funded | 88 | ~72.0 (7.6) | X | | X
Ginsberg 2009 | Peer reviewed publication; Multicenter | Industry funded | 58 | ~66.1 (9.5) | X | | X
Haas 1990 | Peer reviewed publication; Single center | NR | 66 | ~69.5 | X
Hu 2015 | Peer reviewed publication; Single center | NR | 45 | ~61.0 (3.6) | X
Hull 1993 | Peer reviewed publication; Multicenter | NR | 59 | ~66.0 (12.0) | X
Iliopoulos 2011 | Conference abstract; Single center | NR | 87 | NR | X | X
Jiang 2014 | Peer reviewed publication; Single center | NR | 93 | ~64.5 (7.1) | X
Koo 2014 | Peer reviewed publication; Single center | No industry support | NR | NR | | | X
Lachiewicz 2004 | Peer reviewed publication; Single center | Industry funded | 65 | ~66.8 (Range 23, 94) | | | X
Lassen 2007 | Peer reviewed publication; Multicenter | NR | 61 | ~66.7 (range 36, 88) | X
Lassen 2010B | Peer reviewed publication; Multicenter | Industry funded | 73 | [~67 (IQR 59, 73 )] | X
Lassen 2012 | Peer reviewed publication; Multicenter | Industry funded | 71 | [~64.5 (Range 22, 88)] | | X
Leclerc 1996 | Peer reviewed publication; Multicenter | Industry funded | 63 | ~68.6 (9.3) | X
Lotke 1996 | Peer reviewed publication; Unclear | No industry support | 61 | ~66.7 | X
Mirdamadi 2014 | Peer reviewed publication; Single center | NR | 58 | 70 (9) | X
Rader 1998 | Peer reviewed publication; Single center | NR | 70 | ~69.0 (12.1) | X
Sakai 2016 | Peer reviewed publication; Single center | No industry support | 83 | 73.7 (6.7) | | | | X
Silbersack 2004 | Peer reviewed publication; Single center | Industry funded | 64 | ~64.0 (Range 29, 90) | | | | X
Verhamme 2011 | Peer reviewed publication; Multicenter | Industry funded | 78 | 65 (Range 38, 81) | X | | X
Warwick 2002 | Peer reviewed publication; Single center | NR | 65 | ~72.0 (9.6) | X
Weitz 2010 | Peer reviewed publication; Multicenter | Industry funded | 63 | ~64.5 (Range 38, 90) | X | | X
Westrich 1996 | Peer reviewed publication; Single center | No industry support | 67 | NR | | | | X
Westrich 2006 | Peer reviewed publication; Single center | Industry supplied materials | 67 | 68.9 (10.9) | | | | X
Windisch 2011 | Peer reviewed publication; Single center | NR | NR | ~68.5 | | | | X
Yilmaz 2015 | Peer reviewed publication; Single center | No industry support | 56 | ~63.6 (6.7) | | | | X
Zou 2014 | Peer reviewed publication; Single center | No industry support | 75 | ~ 64 (Range 47, 82) | X
NCT00595426 | ClinicalTrials.org; Multicenter | Industry funded | 53.3 to 64.9 | NR | X | | X
NCT00246025 | ClinicalTrials.org; Multicenter | Industry funded | 83 | 71.6 (7.5) | | | X

Abbreviation list: SD= Standard deviation, KQ= Key question, NR= Not reported

Table D3 Hip fracture surgery: Randomized controlled trials

Study | Article Type; Centers | Funding | Percent Female | Mean Age (SD), Years | KQ1 | KQ2 | KQ3 | KQ4 | KQ6
Eriksson 2001 | Peer reviewed publication; Multicenter | Industry funded | 75 | ~77.1 (12.5) | X
Eriksson 2003 | Peer reviewed publication; Multicenter | Industry funded | 71 | [~79 (Range 23, 96)] | | | X
Fisher 2013 | Peer reviewed publication; Multicenter | Industry funded | 64 | ~71.5 (Range 18, 98) | | | X
Fuji 2014B | Peer reviewed publication; Multicenter | Industry funded | 80 | 76.3 (11.2) | X
Kennedy 2000 | Peer reviewed publication; Unclear | NR | 52 | ~76.5 | X
Lassen 2012 | Peer reviewed publication; Multicenter | Industry funded | 65 | [~75.5 (Range 18, 102)] | | X
Monreal 1989 | Peer reviewed publication; Unclear | NR | 82 | ~77.0 (11.1) | X
Powers 1989 | Peer reviewed publication; Multicenter | Industry supplied materials | 68 | ~73.7 (Range 43, 90) | X
Sasaki 2011 | Peer reviewed publication; Single center | NR | 78 | ~81.7 (9.0) | X
The TIFDED Study Group 1999 | Peer reviewed publication; Multicenter | No industry support | 76 | ~76.5 (10.5) | | X

Abbreviation list: SD= Standard deviation, KQ= Key question, NR= Not reported

Table D4 Nonrandomized controlled studies

Study | Study design | Funding | Percent female | Mean age (SD) | KQ 1 | KQ 3 | KQ 4 | KQ 6
Total hip replacement
Bloch 2014{Bloch, 2014 #27} | Peer reviewed publication; Prospective; Single center | No industry support | 58 | 68 (Range 26–93) | X | | X
Bottle 2015 | Peer reviewed publication; Retrospective; Single center | NR | 60 | | X | | X
Ishibe 2011{Ishibe, 2011 #42} | Peer reviewed publication; Retrospective; Single center | No industry support | 92.0 | 56.5 (Range 28–80) | X
Jameson 2011{Jameson, 2011 #43} | Peer reviewed publication; Retrospective; Regional registry | No industry support | 60 | | X
Khatod 2011{Khatod, 2011 #44} | Peer reviewed publication; Prospective; Regional registry | No industry support | 56.9 | 65.9 (11.8) | X | | X
Pedersen 2015{Pedersen, 2015 #16} | Peer reviewed publication; Prospective; Regional registry | No industry support | 56.8 | [~69 (Range 10, 80+)] | | X
Vulcano 2012{Vulcano, 2012 #38} | Peer reviewed publication; Retrospective; Single center | No industry support | 61.4 | 63 (13) | X
Wells 2010{Wells, 2010 #47} | Peer reviewed publication; Retrospective; Regional registry | Industry funded | 48 | 58.14 (10.93) | | | X
Total knee replacement
Bloch 2014{Bloch, 2014 #27} | Peer reviewed publication; Prospective; Single center | No industry support | 58 | 68 (Range 26–93) | X
Bottle 2015 | Peer reviewed publication; Retrospective; Single center | NR | 60 | | X | | X
Bozic 2010{Bozic, 2010 #64} | Peer reviewed publication; Retrospective; Multicenter | No industry support | 65 | ~67.2 (10.4) | X
Jameson 2012{Jameson, 2012 #36} | Peer reviewed publication; Retrospective; Regional registry | No industry support | 57.5 | | X
Kang 2015{Kang, 2015 #12} | Peer reviewed publication; Retrospective; Single center | No industry support | 63.3 | 76.8 (11.4) | | | X
Khatod 2012{Khatod, 2012 #46} | Peer reviewed publication; Prospective; Regional registry | No industry support | 63.6 | 68 (Range 18–101) | X | | X
Llau 2011{Llau, 2011 #164} | Conference abstract; Retrospective; Multicenter | Industry funded | | | | | | X
Rath 2013{Rath, 2013 #163} | Peer reviewed publication; Prospective; Single center | No industry support | 60 | 68 | X | | X
Wells 2010{Wells, 2010 #47} | Peer reviewed publication; Retrospective; Regional registry | Industry funded | 62 | 61.18 (9.41) | X | X
Hip fracture surgery
Tsuda 2014{Tsuda, 2014 #21} | Peer reviewed publication; Retrospective; Regional registry | No industry support | 80 | 79.5 (9.4) | | | X