# Appendix C Risk of Bias Assessment

Table C1 RCT risk of bias (total hip replacement)

Study | Adequate generation of a randomized sequence | Allocation concealment | Blinding of PATIENTS | Blinding of PROVIDERS | Blinding of OUTCOME ASSESSORS | Intention-to-treat-analysis | Incomplete results data (attrition bias) | Selective Reporting (reporting bias) | Group similarity at baseline (selection bias) | Compliance with interventions | Outcome assessment timing (across interventions) | Assessment of outcome | Adverse events precisely defined
Alfaro 1986 | Unclear | Unclear | Unclear | Unclear | Unclear | Low | Unclear | NR | Low | NR | NR | Low | NR
Andersen 1997 | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Anderson 2013 | Low | Low | Low | Low | Low | Low | Low | High | Low | Low | Unclear | High | Low
Avikainen 1995 | Unclear | High | High | High | Unclear | Low | Low | NR | Low | NR | NR | Low | NR
Bailey 1991 | Low | Low | High | High | Low | Low | Low | NR | Low | NR | NR | Low | NR
Barre 1987 | Unclear | Unclear | High | High | Unclear | Low | Low | NR | Low | NR | NR | Low | NR
Borgen 2012 | Low | Low | Low | Low | Low | Low | Low | High | Low | Low | Low | High | High
Bramlage 2012 | Unclear | Unclear | Low | Low | Low | Unclear | High | High | High | Unclear | Unclear | High | High
Colwell 1994 | Low | Low | High | High | Unclear | Low | Low | NR | Low | NR | NR | Low | NR
Colwell 1999 | Unclear | Unclear | High | High | Unclear | Low | Low | NR | Low | NR | NR | Low | NR
Colwell 2010 | Low | High | High | High | Low | Low | Low | High | Low | Unclear | Low | Low | Low
Comp 2001 | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Dahl 1997 | Unclear | Unclear | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Dechavanne 1989 | Unclear | Low | Unclear | Unclear | Unclear | Low | Low | NR | Low | NR | NR | Low | NR
Edwards 2008 | Unclear | Unclear | High | High | High | Low | Low | NR | Low | NR | NR | Low | NR
Eisele 2006 | Unclear | Unclear | Unclear | Unclear | High | Low | Low | High | Unclear | Unclear | High | Low | NR
Eriksson 1991 | Unclear | Unclear | Low | Low | Low | High | Low | NR | Low | NR | NR | Low | NR
Eriksson 1996 | Unclear | Unclear | Low | Low | High | Low | Low | NR | Low | NR | NR | Low | NR
Eriksson 1997A | Low | Low | Low | Low | High | High | Low | NR | Low | NR | NR | Low | NR
Eriksson 1997B | Unclear | Unclear | Low | Low | High | High | High | NR | Low | NR | NR | Low | NR
Eriksson 2005 | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Eriksson 2007B | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Eriksson 2010 | Low | Unclear | Unclear | Unclear | Low | Unclear | Unclear | Low | Low | Low | High | Low | Low
Eriksson 2011 | Low | Low | Low | Low | Low | Low | High | Low | Low | Low | Unclear | Low | Unclear
Eriksson 2014 | Low | Unclear | Low | Low | Low | Low | High | High | Low | Low | Low | Low | Low
Francis 1992 | Low | Low | High | High | Low | High | Low | NR | Low | NR | NR | Low | NR
Francis 1997 | Unclear | Unclear | High | High | Low | Low | Low | NR | Low | NR | NR | Low | NR
Fuji 2008 | Unclear | Unclear | Low | Low | High | Low | Low | NR | Low | NR | NR | Low | NR
Fuji 2014A | Low | High | High | High | Low | High | High | Low | Low | Low | High | Low | Low
Fuji 2014D | Unclear | Unclear | High | High | Unclear | High | High | Low | Low | Unclear | Unclear | High | Low
Fuji 2015 | Unclear | Unclear | Low | Low | Low | Low | Unclear | Low | Low | Low | Unclear | Low | Low
Hull 1993 | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Hull 2000 | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Kim 2016 | Low | Unclear | Low | Unclear | Low | High | Low | High | Low | Unclear | High | High | Low
Kim 2016A | Low | Unclear | Low | Unclear | Low | High | Low | High | Low | Unclear | High | High | Low
Kalodiki 1996 | Low | Low | NR | NR | Low | High | Low | NR | Low | NR | NR | NR | NR
Lassen 1998 | Unclear | Unclear | Low | Low | Low | High | Low | NR | Low | NR | NR | Low | NR
Lassen 2002 | Low | Low | Low | Low | Low | High | High | NR | Low | NR | NR | Low | NR
Lassen 2010A | Low | Low | Low | Low | Low | High | Mixed^*^ | Low | Low | Low | Low | Low | Low
Lassen 2012 | Low | Low | Low | Unclear | Low | High | High | High | Low | Unclear | Unclear | Low | Low
Levine 1991 | Unclear | Unclear | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Lieberman 1994 | Low | Unclear | High | High | Low | Low | Low | NR | Low | NR | NR | Low | NR
Lotke 1996 | Unclear | Unclear | High | High | Low | Low | Low | NR | Low | NR | NR | Low | NR
Menzin 1994 | Unclear | Unclear | High | High | Unclear | Low | Low | NR | Low | NR | NR | Low | NR
Nilsson 1997 | Unclear | Unclear | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Paiement 1987 | Unclear | Unclear | High | High | Low | Low | Low | NR | Low | NR | NR | Low | NR
Planès 1988 | Unclear | Unclear | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Planès 1997 | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Planès 1999 | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Prandoni 2002 | Low | Low | Unclear | Unclear | Low | Low | Low | NR | Low | NR | NR | Low | NR
Rader 1998 | Unclear | Unclear | Unclear | Unclear | Unclear | Low | Low | NR | Low | NR | NR | Low | NR
Raskob 2010 | Low | Low | Low | Low | Low | Unclear | Unclear | High | Low | Unclear | Unclear | Low | Low
Ryan 2002 | Unclear | Unclear | High | High | Low | Low | Low | NR | Low | NR | NR | Low | NR
Santori 1994 | Low | Low | High | High | Unclear | Low | Low | NR | Low | NR | NR | Low | NR
Schwartsmann 1996 | Unclear | Unclear | High | High | Unclear | Low | Low | NR | Low | NR | NR | Low | NR
Senaran 2006 | Unclear | Unclear | High | High | Unclear | Low | Low | NR | Low | NR | NR | Low | NR
Silbersack 2004 | Unclear | Unclear | High | High | Low | Low | Low | NR | Low | NR | NR | Low | NR
Stannard 1996 | Unclear | Unclear | High | High | Low | Low | Low | NR | Low | NR | NR | Low | NR
Stone 1996 | Unclear | Unclear | Low | Low | Unclear | Low | Low | NR | Low | NR | NR | Low | NR
Turpie 2002 | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Verhamme 2013 | Unclear | Unclear | Low | Low | Low | Low | Unclear | Low | Low | Unclear | Low | Low | Low
Warwick 1998 | Low | Low | High | High | High | Low | Low | NR | Low | NR | NR | Low | NR
Woolson 1991 | Low | Low | High | High | Unclear | Low | Low | NR | Low | NR | NR | Low | NR
Yokote 2011 | Unclear | Unclear | Unclear | Unclear | High | Low | Low | NR | Low | NR | NR | Low | NR
Zhang 2013 | Unclear | Unclear | Unclear | Unclear | Unclear | Low | High | High | Unclear | Unclear | Unclear | Low | NR
Zhang 2014 | Low | Unclear | High | High | Unclear | Low | Low | High | Unclear | Unclear | Low | Low | NR
Zhirova 2014 | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | High | Unclear | Unclear | Unclear | Unclear | High

Table C2 RCT risk of bias (total knee replacement)

Study | Adequate generation of a randomized sequence | Allocation concealment | Blinding of PATIENTS | Blinding of PROVIDERS | Blinding of OUTCOME ASSESSORS | Intention-to-treat-analysis | Incomplete results data (attrition bias) | Selective Reporting (reporting bias) | Group similarity at baseline (selection bias) | Compliance with interventions | Outcome assessment timing (across interventions) | Assessment of outcome | Adverse events precisely defined
Barrellier 2010 | Unclear | Low | High | High | High | Low | Low | High | Low | Low | Low | Low | Low
Bauer 2001 | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Bonneux 2006 | Low | Low | High | High | Unclear | High | Low | NR | Low | NR | NR | Low | NR
Büller 2015 | Low | Low | High | High | Low | High | Unclear | Low | Low | Low | High | Low | Low
Choi 2015 | Unclear | Unclear | Low | High | High | Low | Low | High | High | Low | Low | Low | NR
Cohen 2013 | Unclear | Unclear | Unclear | Unclear | Low | High | High | Low | Low | Low | Unclear | Low | Low
Colwell 1995 | Unclear | Unclear | High | High | Low | Low | Low | NR | Low | NR | NR | Low | NR
Comp 2001 | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Edwards 2008 | Unclear | Unclear | High | High | High | Low | Low | NR | Low | NR | NR | Low | NR
Eisele 2006 | Unclear | Unclear | Unclear | Unclear | High | Low | Low | High | Unclear | Unclear | High | Low | NR
Eriksson 2005 | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Eriksson 2007A | Low | Low | Low | Low | Low | High | Low | NR | Low | NR | NR | Low | NR
Faunø 1994 | Low | Low | High | Unclear | High | Low | Low | NR | Low | NR | NR | Low | NR
Fitzgerald 2001 | Low | Low | High | High | High | Low | Low | NR | Low | NR | NR | Low | NR
Fuji 2008 | Unclear | Unclear | Low | Low | High | Low | Low | NR | Low | NR | NR | Low | NR
Fuji 2010A | Low | Low | Low | Low | High | Unclear | Low | NR | Low | NR | NR | Low | NR
Fuji 2010B | Low | Unclear | Low | Unclear | Low | Low | High | Low | Low | Low | Low | High | Low
Fuji 2014C | Low | Unclear | Low | Low | Low | High | High | Low | Low | Unclear | Unclear | Low | Low
Fuji 2014D | Unclear | Unclear | High | High | Unclear | High | High | Low | Low | Low | Low | High | Low
Ginsberg 2009 | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Haas 1990 | Unclear | Unclear | High | High | Low | Low | Low | NR | Low | NR | NR | Low | NR
Hu 2015 | Unclear | Unclear | High | High | Unclear | Low | Low | High | Unclear | Unclear | Unclear | Low | NR
Hull 1993 | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Iliopoulos 2011 | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | High | Low | Unclear | Unclear | Unclear | Unclear
Jiang 2014 | Low | Unclear | High | High | Unclear | Low | Low | High | Low | Unclear | Low | Unclear | Low
Koo 2014 | Low | Unclear | Unclear | Unclear | Unclear | Low | Low | High | High | Unclear | Low | Low | NR
Lachiewicz 2004 | Low | Low | High | High | Low | Low | Low | NR | Low | NR | NR | Low | NR
Lassen 2007 | Low | Low | High | Unclear | Low | Low | Low | NR | Low | NR | NR | Low | NR
Lassen 2010B | Low | Low | Low | Unclear | Low | Low | High | Low | Low | Unclear | Low | High | Low
Lassen 2012 | Low | Low | Low | Unclear | Low | High | High | High | Low | Unclear | Unclear | Low | Low
Leclerc 1996 | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Lotke 1996 | Unclear | Unclear | High | High | Low | Low | Low | NR | Low | NR | NR | Low | NR
Mirdamadi 2014 | Low | Unclear | High | High | Low | Low | Low | High | Low | Unclear | Low | Low | Low
Rader 1998 | Unclear | Unclear | Unclear | Unclear | Unclear | Low | Low | NR | Low | NR | NR | Low | NR
Sakai 2016 | Low | Unclear | High | High | High | Low | Low | High | Low | Low | Low | Unclear | Low
Silbersack 2004 | Unclear | Unclear | High | High | Low | Low | Low | NR | Low | NR | NR | Low | NR
Verhamme 2011 | Low | Low | High | High | Low | Low | Unclear | Low | Low | Low | Low | High | Low
Warwick 2002 | Low | Low | High | High | Low | High | Low | NR | Low | NR | NR | Low | NR
Weitz 2010 | Unclear | Low | Unclear | Unclear | Low | High | High | Low | Low | Unclear | Low | Low | Low
Westrich 1996 | Low | Low | High | High | Low | Low | Low | High | Unclear | Unclear | Low | Low | NR
Westrich 2006 | Unclear | Unclear | Unclear | Unclear | Unclear | High | High | High | Low | Low | Low | High | High
Windisch 2011 | Unclear | Unclear | High | High | Low | Low | Low | High | Unclear | Unclear | Low | Low | NR
Yilmaz 2015 | Low | Unclear | High | High | Low | Low | Low | Low | Low | Unclear | Unclear | Unclear | NR
Zou 2014 | Low | High | High | High | Unclear | Low | Low | High | Low | Unclear | Low | Low | Low
NCT00595426 | Unclear | Unclear | Low | Low | High | Unclear | Unclear | High | Unclear | Unclear | Unclear | Unclear | High
NCT00246025 | Unclear | Unclear | Low | Low | High | Low | Low | Unclear | Unclear | Unclear | Low | Unclear | Low

Table C3 RCT risk of bias (hip fracture surgery)

Study | Adequate generation of a randomized sequence | Allocation concealment | Blinding of PATIENTS | Blinding of PROVIDERS | Blinding of OUTCOME ASSESSORS | Intention-to-treat-analysis | Incomplete results data (attrition bias) | Selective Reporting (reporting bias) | Group similarity at baseline (selection bias) | Compliance with interventions | Outcome assessment timing (across interventions) | Assessment of outcome | Adverse events precisely defined
Eriksson 2001 | Low | Low | Low | Low | Low | High | High | NR | Low | NR | NR | Low | NR
Eriksson 2003 | Low | Low | Low | Low | Low | Low | Low | NR | Low | NR | NR | Low | NR
Fisher 2013 | Low | Low | Low | Low | Low | High | High | High | Low | Low | High | Unclear | Low
Fuji 2014B | Unclear | Unclear | High | High | Unclear | Unclear | High | Low | Low | Low | High | Low | Low
Kennedy 2000 | Unclear | Unclear | High | High | Low | High | Low | NR | Low | NR | NR | Low | NR
Lassen 2012 | Low | Low | Low | Unclear | Low | High | High | High | Low | Unclear | Unclear | Low | Low
Monreal 1989 | Low | Low | Low | Low | Unclear | High | High | NR | Low | NR | NR | Low | NR
Powers 1989 | Low | Low | High | High | High | Low | Low | NR | Low | NR | NR | Low | NR
Sasaki 2011 | High | High | High | High | Unclear | Low | Low | High | Low | Unclear | Unclear | High | Low
The TIFDED Study Group 1999 | Unclear | Unclear | High | High | Low | Low | Low | NR | Low | NR | NR | Low | NR

Table C4 NRCS risk of bias

Author Year PMID Country/Region | Blinding of outcome assessors | Incomplete results data | Selective Reporting | Group similarity at baseline | Compliance with interventions | Outcome assessment timing | Assessment of outcome | Patients selected in equivalent manner | Adverse events precisely defined
Total hip replacement
Bloch 2014 24395322 UK | High | Low | Low | Unclear | Low | Unclear | Low | Low | Low
Bottle 2015 | Unclear | Low | High | Unclear | Low | Low | High | Low | Low
Ishibe 2011 22101618 Japan | High | Low | High | Low | Low | Low | Unclear | Low | Unclear
Jameson 2011 22058295 UK | High | Low | Low | High | Unclear | Low | High | Low | Low
Khatod 2011 22005861 U.S. | Low | Low | High | Low | Low | Low | High | Low | Low
Pedersen 2015 25511580 Denmark | High | Low | Low | Low | Low | Low | High | Low | Low
Vulcano 2012 22684546 U.S. | Low | Low | High | High | High | Low | Low | High | Low
Wells 2010 21348557 U.S. | Unclear | Unclear | High | High | Low | Low | Unclear | Low | Low
Total knee replacement
Bloch 2014 24395322 UK | High | Low | Low | Unclear | Low | Unclear | Low | Low | Low
Bottle 2015 | Unclear | Low | High | Unclear | Low | Low | High | Low | Low
Bozic 2010 19679434 US | Unclear | Low | NR | High | NR | NR | High | Low | NR
Jameson 2012 22733945 UK | High | Low | Low | High | Unclear | Low | High | Low | Low
Kang 2015 25963358 China | Unclear | Low | High | Unclear | Low | Low | Low | Low | NR
Khatod 2012 21641758 U.S. | Low | Low | High | High | Low | Low | Unclear | Low | Low
Llau 2011 Abstract 6AP3-2 Spain | Unclear | Low | High | Unclear | Low | Low | Unclear | Unclear | NR
Rath 2013 23566737 UK | High | Low | Low | Unclear | Low | Low | Low | Low | Low
Wells 2010 21348557 U.S. | Unclear | Unclear | High | High | Low | Low | Unclear | Low | Low
Hip fracture surgery
Tsuda 2014 25034972 Japan | High | Low | Low | Low | Low | Unclear | High | Low | High