# Appendix A Search Strategy

## PubMed Search

(“Arthroplasty, Replacement, Knee”[Mesh] or (“Arthroplasty”[Mesh] and (knee or hip)) or total knee replacement or knee arthroplasty or tkr or “Knee Prosthesis”[Mesh] or knee prosthesis or knee joint or “Arthroplasty, Replacement, Hip”[Mesh] or total hip replacement or hip arthroplasty or thr or “Hip Prosthesis”[Mesh] or Hip Prosthesis or hip fracture surgery or hfs or ((“Fracture Fixation, Internal”[Mesh] or “Fracture Fixation, Intramedullary”[Mesh]) and (hip femur or femor* or tibia* or ankle or foot)) or (arthroscop* and (knee or meniscectomy or synovectomy or cruciate ligament)) or “Casts, Surgical”[Mesh] or surgical cast or plaster cast or splint* or “Splints”[Mesh] or Achilles tendon or tibial plateau fracture or distal femur fracture or (lumbar and (laminectomy or discectomy or fusion)) or (osteotomy AND (femur OR femor* OR tibia*)))

AND

(“Pulmonary Embolism”[Mesh] or pulmonary embol* or pulmonary thromboembol* or PE or deep vein thrombos* or deep venous thrombos* or deep venous thromboembol* or deep vein thromboembol* or DVT or “Venous Thromboembolism”[Mesh] or venous thromboembol* or VTE or “Venous Thrombosis”[Mesh] or venous thrombos* or clot)

AND

(“Anticoagulants”[Mesh] OR “Aspirin”[Mesh] or aspirin or clopidogrel or ticlopidine or prasugrel or “Heparin”[Mesh] or “Heparinoids”[Mesh] or heparin or UFH or LMWH or enoxaparin or dalteparin or nadroparin or ardeparin or bemiparin or certoparin or parnaparin or reviparin or tinzaparin or danaparoid or fondaparinux or idraparinux or rivaroxaban or apixaban or enoxaparin or “Hirudins”[Mesh] or desirudin or argatroban or bivalirudin or lepirudin or dabigatran or “Warfarin”[Mesh] or warfarin or “4-Hydroxycoumarins”[Mesh] or acenocoumarol or dicoumarol or “Dextran Sulfate”[Mesh] or dextran sulfate or “Stockings, Compression”[Mesh] or ((compression or elastic) and (stocking* or boot*)) or GCS or venous foot pump or VFP or “Intermittent Pneumatic Compression Devices”[Mesh] or pneumatic compression or pneumatic hose or pneumatic compression hose or IPC or “Vena Cava Filters”[Mesh] or vena cava filter* or IVC or “Factor Xa Inhibitors”[Mesh])

AND

(“Cohort Studies”[Mesh] OR cohort OR “Clinical Trial” [Publication Type] OR “Clinical Trials as Topic”[Mesh] OR (follow-up or followup) OR longitudinal OR “Placebos”[Mesh] OR placebo* OR “Research Design”[Mesh] OR “Evaluation Studies” [Publication Type] OR “Evaluation Studies as Topic”[Mesh] OR “Comparative Study” [Publication Type] OR ((comparative or Intervention) AND study) OR “Intervention Studies”[Mesh] OR pretest* OR pre test* OR posttest* OR post test* OR prepost* OR pre post* OR “before and after” OR interrupted time* OR time serie* OR intervention* OR ((“quasi-experiment*” OR quasiexperiment* OR quasi or experimental) and (method or study or trial or design*)) OR “Case-Control Studies”[Mesh] OR (case and control) OR “Clinical Studies” [Publication Type] OR “Clinical Studies as Topic”[Mesh] OR random allocation [mh] OR double-blind method[mh] OR single-blind method[mh] OR random* OR “Clinical Trial” [Publication Type] OR “Clinical Trials as Topic”[Mesh] OR “Placebos”[Mesh] OR placebo OR ((clinical OR controlled) and trial*) OR ((singl* or doubl* or trebl* or tripl*) and (blind* or mask*)) OR rct)

Limit 2010-

## Cochrane

((Arthroplasty and (knee or hip)) or total knee replacement or knee arthroplasty or tkr or “Knee Prosthesis”[Mesh] or knee prosthesis or knee joint or total hip replacement or hip arthroplasty or thr or Hip Prosthesis or hip fracture surgery or hfs or ((Fracture Fixation Internal or Fracture Fixation Intramedullary) and (hip femur or femor* or tibia* or ankle or foot)) or (arthroscop* and (knee or meniscectomy or synovectomy or cruciate ligament)) or surgical cast or plaster cast or splint* or Achilles tendon or tibial plateau fracture or distal femur fracture or (lumbar and (laminectomy or discectomy or fusion)) or (osteotomy AND (femur OR femor* OR tibia*)))

AND

(Pulmonary Embolism or pulmonary embol* or pulmonary thromboembol* or PE or deep vein thrombos* or deep venous thrombos* or deep venous thromboembol* or deep vein thromboembol* or DVT or Venous Thromboembolism or venous thromboembol* or VTE or Venous Thrombosis or venous thrombos* or clot)

AND

(Anticoagulants or Aspirin or clopidogrel or ticlopidine or prasugrel or Heparin or Heparinoids or UFH or LMWH or enoxaparin or dalteparin or nadroparin or ardeparin or bemiparin or certoparin or parnaparin or reviparin or tinzaparin or danaparoid or fondaparinux or idraparinux or rivaroxaban or apixaban or enoxaparin or Hirudins or desirudin or argatroban or bivalirudin or lepirudin or dabigatran or Warfarin or warfarin or 4-Hydroxycoumarins or acenocoumarol or dicoumarol or (dextran and sulfate) or ((compression or elastic) and (stocking* or boot*)) or venous foot pump or VFP or “Intermittent Pneumatic Compression Devices” or pneumatic compression or pneumatic hose or pneumatic compression hose or IPC or vena cava filter* or IVC or Factor Xa Inhibitors)

Limit 2010-

## Embase

((Arthroplasty and (knee or hip)) or total knee replacement or knee arthroplasty or tkr or knee prosthesis or knee joint or total hip replacement or hip arthroplasty or Hip Prosthesis or hip fracture surgery or (Fracture Fixation and (femur or femor*)) )

AND

(Pulmonary Embolism or pulmonary embol* or pulmonary thromboembol* or deep vein thrombos* or deep venous thrombos* or deep venous thromboembol* or deep vein thromboembol* or DVT or Venous Thromboembolism or venous thromboembol* or VTE or Venous Thrombosis or venous thrombos* or clot)

AND

(Anticoagulants or Aspirin or clopidogrel or ticlopidine or prasugrel or Heparin or Heparinoids or UFH or LMWH or enoxaparin or dalteparin or nadroparin or ardeparin or bemiparin or certoparin or parnaparin or reviparin or tinzaparin or danaparoid or fondaparinux or idraparinux or rivaroxaban or apixaban or enoxaparin or Hirudins or desirudin or argatroban or bivalirudin or lepirudin or dabigatran or Warfarin or warfarin or 4-Hydroxycoumarins or acenocoumarol or dicoumarol or (dextran and sulfate) or ((compression or elastic) and (stocking* or boot*)) or venous foot pump or VFP or “Intermittent Pneumatic Compression Devices” or pneumatic compression or pneumatic hose or pneumatic compression hose or IPC or vena cava filter* or IVC or Factor Xa Inhibitors)

AND

(cohort OR (follow-up or followup) OR longitudinal OR placebo* OR ((comparative or Intervention) AND study) OR pretest* OR pre test* OR posttest* OR post test* OR prepost* OR pre post* OR (before and after) OR interrupted time* OR time serie* OR intervention* OR ((quasi-experiment* OR quasiexperiment* OR quasi or experimental) and (method or study or trial or design*)) OR (case and control) OR clinical stud* OR clinical trial OR random allocation OR double-blind method OR single-blind method OR random* OR ((clinical OR controlled) and trial*) OR ((singl* or doubl* or trebl* or tripl*) and (blind* or mask*)) OR rct)

AND

Limit 2010-

## Surveillance Search

For this surveillance document, we searched PubMed on July 16, 2015, using the following strategy:

(“Arthroplasty, Replacement, Knee”[Mesh] or (“Arthroplasty”[Mesh] and (knee or hip)) or total knee replacement or knee arthroplasty or tkr or “Knee Prosthesis”[Mesh] or knee prosthesis or knee joint or “Arthroplasty, Replacement, Hip”[Mesh] or total hip replacement or hip arthroplasty or thr or “Hip Prosthesis”[Mesh] or Hip Prosthesis or hip fracture surgery or hfs or ((“Fracture Fixation, Internal”[Mesh] or “Fracture Fixation, Intramedullary”[Mesh]) and (hip femur or femor* or tibia* or ankle or foot)) or (arthroscop* and (knee or meniscectomy or synovectomy or cruciate ligament)) or “Casts, Surgical”[Mesh] or surgical cast or plaster cast or splint* or “Splints”[Mesh] or Achilles tendon or tibial plateau fracture or distal femur fracture or (lumbar and (laminectomy or discectomy or fusion)) or (osteotomy AND (femur OR femor* OR tibia*)))

AND

(“Pulmonary Embolism”[Mesh] or pulmonary embol* or pulmonary thromboembol* or PE or deep vein thrombos* or deep venous thrombos* or deep venous thromboembol* or deep vein thromboembol* or DVT or “Venous Thromboembolism”[Mesh] or venous thromboembol* or VTE or “Venous Thrombosis”[Mesh] or venous thrombos* or clot)

AND

(“Anticoagulants”[Mesh] OR “Aspirin”[Mesh] or aspirin or clopidogrel or ticlopidine or prasugrel or “Heparin”[Mesh] or “Heparinoids”[Mesh] or heparin or UFH or LMWH or enoxaparin or dalteparin or nadroparin or ardeparin or bemiparin or certoparin or parnaparin or reviparin or tinzaparin or danaparoid or fondaparinux or idraparinux or rivaroxaban or “Hirudins”[Mesh] or desirudin or argatroban or bivalirudin or lepirudin or dabigatran or “Warfarin”[Mesh] or warfarin or “4-Hydroxycoumarins”[Mesh] or acenocoumarol or dicoumarol or “Dextran Sulfate”[Mesh] or dextran sulfate or “Stockings, Compression”[Mesh] or ((compression or elastic) and (stocking* or boot*)) or [struck: GCS] or venous foot pump or VFP or “Intermittent Pneumatic Compression Devices”[Mesh] or pneumatic compression or pneumatic hose or pneumatic compression hose or IPC or “Vena Cava Filters”[Mesh] or vena cava filter* or IVC or “Factor Xa Inhibitors”[Mesh])

AND

((randomized controlled trial [pt] or controlled clinical trial [pt] or random* or placebo or trial or groups or blind) not (animals not humans))