# Results

This section first describes the results of the literature searches, followed by descriptions of the studies that met inclusion criteria for each of the Key Questions (KQs) and the key points (conclusions).

## Results of Literature Searches

Our searches identified 11,229 titles/abstracts. An additional search of grey literature and ClinicalTrials.gov resulted in 1,674 titles. Fifty-five references were suggested by experts or were meetings abstracts. This yielded 12,958 titles/abstracts that went out for dual screening, of which 9,433 titles were excluded. At abstract screening, 2,134 were excluded for the following reasons: not human (38), not a population of interest (87), not on osteoarthritis (OA) of the knee (215), not on treating or managing OA of the knee (192), not an intervention of interest (338), not an outcome of interest (247), study design (including editorials, letters, cross sectional study design, and protocols) (582), study was included in a previous Evidence-based Practice Center (EPC) review (135), maximum followup was less than 30 days (7), duplicate study (13), no abstract was indexed (245), or we were unable to retrieve the article (35).

We reviewed 647 full text articles, of which 541 were excluded for the following reasons: not human (6), not a population of interest (6), not on OA of the knee (28), not on treating or managing OA of the knee (6), not an intervention of interest (95), intervention (glucosamine) with a sample size of less than 50 (32), not an outcome of interest (28), study design (including editorials, letters, cross sectional study design, and protocols) (85), study was included in a previous EPC review (3), maximum followup was less than 30 days (36), comparators not of interest (70), no usable data (80), multi-component interventions (27), duplicate study (39). A list of references by exclusion reason can be found in Appendix B.

The Federal Register posting did not yield any additional materials to review for possible inclusion.

We include 107 new articles in our report of which 57 reported adverse events (AEs). Our literature flow diagram (Figure 2) displays our screening results. Appendix D contains our data abstraction tools that were used for abstracting the data of the 107 included studies. Appendix E shows strength of evidence, and Appendix F contains the quality assessment of each of the included studies.

Figure 2 Literature flow diagram

Figure notes: *Only glucosamine intervention with a sample size less than 50 participants were excluded; EPC=Evidence-based Practice Center; OA=osteoarthritis

Figure B and Figure 2. Literature flow diagram. This figure is the flow chart that summarizes the study retrieval and selection process for articles. The information displayed in the figure is described in the section entitled Results of Literature Searches.

## Key Question 1a: What is the clinical effectiveness of cell-based therapies, oral glucosamine and/or chondroitin, physical treatment interventions, weight loss, or home-based and self-management therapies in patients with OA of the knee, compared with appropriate placebo/sham controls or compared with other active interventions? Key Question 1b: How do the outcomes of each intervention differ by the following population and study characteristics: sex, disease subtype (lateral, patellofemoral), severity (stage/baseline pain and functional status), weight status (body mass index), baseline fitness (activity level), comorbidities, prior or concurrent treatments (including self-initiated therapies), and treatment duration or intensity?

### Description of Included Studies

#### Cell-Based Therapies

Cell-based therapies that were considered for treatment of OA of the knee included intra-articular injection of platelet-rich plasma (PRP) as well as introduction of stem cells. We did not identify any studies of stem cell treatments that met the inclusion criteria.

##### Key Points

- Among the cell-based therapies, only PRP was assessed in RCTs that met inclusion criteria for this review.
- A low strength of evidence based on four RCTs supports a beneficial effect of PRP on medium-term pain and quality of life.
- A low strength of evidence based on three RCTs supports a beneficial effect of PRP on medium-term quality of life.
- Evidence was insufficient to draw conclusions regarding the effects of PRP on medium-term function.
- Evidence was insufficient to draw conclusions regarding outcomes at shorter or longer times.

##### Findings

###### Platelet-Rich Plasma

Studies of PRP were included if they compared PRP to sham injections or to use of analgesics but not to injections of other potential therapeutic agents of unclear efficacy. We identified 5 RCTs that compared the use of autologous PRP to that of a sham control or analgesic.^23–27^ The longest followup time was 6 months from baseline for all studies.

Short-term effects on pain. Three studies reported on short-term effects of PRP treatment on pain.^23, 26, 27^

A 2013 double-blind RCT conducted in India by Patel and coworkers randomized 78 patients into three treatment groups: a group that received one injection, a group that received two injections at baseline and at 3 weeks, and a control group, which received saline injections (RoB moderate).^23^ WOMAC pain scores at 6 weeks’ followup were significantly decreased from baseline and from that of the control group in both active treatment groups (MD −5.22 for one injection, MD −5.10 two injections, at 6 weeks). No significant difference in pain scores or in mean duration of benefit (17 days) was seen between those receiving one injection and those receiving two injections. Response was positively associated with disease severity but not associated with age, sex, or BMI.

A 2014 RCT conducted in Mexico by Acosta-Olivo randomized 42 patients to receive two injections of PRP or instructions to take paracetamol 3 times daily for 30 days; each group also received a 6-month supervised physical rehabilitation program (RoB unclear).^26^ At 4 months, KOOS pain scores were 51.2(15.4) and 42.2(14.7) for the PRP and control groups, and showed a nonsignificant between-group difference (MD −9.00, 95% CI −18.11, 0.11).

A 2016 RCT conducted in Mexico by Simental-Mendia and colleagues randomized 65 patients with grade 1 or 2 OA to receive three injections of leukocyte-poor PRP, biweekly, over 6 weeks, or to take acetaminophen (500 mg) 3 times daily for 6 weeks (RoB low).^27^ At the end of the 6 weeks and at 12 weeks, VAS pain scores showed significantly greater improvement in the PRP group than in the control group (MD−2.20, 95% CI −3.25, −1.15).

Short-term effects on function. Patel^23^ also assessed the effects of PRP on function and stiffness. At 6 weeks’ followup, WOMAC function scores were significantly decreased from those of the control group in both active treatment groups (single injection: MD −15.56, dual injections: −16.24).

Short-term effects on other outcomes. Patel^23^ also assessed the effects of PRP on WOMAC total scores. At 6 weeks follow-up, the MD was −21.42 for a single injection and −21.82 for dual injections.

At 12 weeks, Simental-Mendia^27^ also reported a significant improvement in WOMAC total scores compared with analgesic (MD −13.4, 95% CI −20.00, −6.71) and on the physical domain of the SF-12 (MD −7.60, 95% CI −11.76, −3.48).

Medium-term effects on pain. Five RCTs assessed the effects of PRP injections at 6 months followup.^23–27^

Patel^23^ reported increases in VAS and WOMAC pain scores in both the single- and double-injection groups compared with the earlier follow-up time, although scores remained significantly lower than control and baseline scores (MD −5.87 for one injection, MD −4.69 for two injections). VAS Pain was significantly decreased in both treatment groups compared with the control (single injection MD −2.45, 95% CI −2.92, −1.98; dual injections MD −2.07, 95% CI −2.59, −1.55).

A 2015 double-blind RCT conducted in Turkey by Görmeli and coworkers randomized 136 consecutive patients to receive a single injection of PRP, three injections of PRP, or a single saline injection (a fourth group received hyaluronic acid; results for this group will not be reported here) (RoB Low).^24^ EuroQol VAS pain scores at 6 months’ followup showed significant between-group differences for one injection (MD−14.00, 95% CI −11.56, −16.44) and three injections (MD−23.40, 95% CI −19.66, −27.14) of PRP compared with the control; three injections had significantly greater effects than a single injection (p<0.001). Treatment response was affected by severity of OA: patients with early (K-L grade I–III) OA achieved significantly greater pain control with three injections than with one injection (p<0.005), whereas among patients with advanced (K-L grade IV) OA three injections provided the same improvement as one injection.

A 2014 RCT conducted in Iran by Rayegani randomized 65 patients to receive two injections of PRP 4 weeks apart or no treatment.^25^ Both groups were enrolled in an exercise protocol and prescribed acetaminophen as needed (RoB High). At 6 months’ follow-up, the PRP group showed nonsignificantly greater improvement in WOMAC pain scores than did the control group (MD −0.96, 95% CI −2.88, 0.96).

At 6 months’ followup, the Acosta-Olivo study reported that KOOS pain scores for the PRP group were significantly improved compared with the paracetamol group (MD −6.90, 95% CI−18.29, 4.49, p=0.0008) and a slight but insignificant decrease from the 4-month score.^26^

At 6 months, Simental-Mendia^27^ reported no significant improvement in VAS pain scores compared with analgesic.

Medium-term effects on function. Patel^23^ assessed the effects of PRP on function and stiffness. At 6 months’ followup, WOMAC function scores were significantly decreased from that of the control group in both active treatment groups (MD −19.38 for single injection; −17.06 for dual injections).

The 2014 RCT by Rayegani showed no significant between-group difference in WOMAC function scores at 6 months.^25^

Medium-term effects on other outcomes. In the Patel study, WOMAC total scores in both treatment groups at 6 months’ followup were also significantly decreased from those of the control group (MD −25.91 for single injection; MD −22.61 for dual injections).^24^

At 6 months followup, the study by Rayegani^25^ showed a significant improvement in the SF-36 physical domain for the PRP-treated group compared with the control group (MD −1.00, variance not reported).

The 2015 Görmeli RCT reported significant between-group differences in quality of life in favor of PRP, as assessed with the EuroQuol (MD −14.00 95% CI −16.44, −11.56 for one injection; MD −23.40, 95% CI −27.14, −19.66 for three injections).^24^

At 6 months followup, the study by Simental-Mendia showed a sustained significant improvement in WOMAC total scores in the PRP-treated group compared with the analgesic group (MD −12.3, 95% CI −19.59, −5.01) and in the SF-12 physical domain (MD −9.90, 95% CI −14.67, −5.73).^27^

Long-term effects. No studies reported on long-term effects of PRP.

###### Other Cell-Based Therapies

No studies were identified on other cell-based therapies that met the inclusion criteria for the report.

#### Glucosamine With or Without Chondroitin or Chondroitin Alone

##### Key Points

- Glucosamine, chondroitin, and the combination of glucosamine plus chondroitin have shown somewhat inconsistent beneficial effects in large, multi-site placebo-controlled and head-to-head trials.
- Glucosamine + chondroitin: Three large, multi-site RCTs and one smaller RCT found low strength of evidence for a medium-term effect on pain and function but moderate strength of evidence for no long-term benefit on pain and function.
  ○ Two of three trials showed a medium-term benefit of glucosamine plus chondroitin on both pain and function (low strength of evidence).
  ○ A random effects pooled estimate for three studies showed no effect of long-term treatment on pain compared with control (pooled effect size −0.73, 95% CI −4.03; 2.57) (moderate strength of evidence).
  ○ A random effects pooled estimate for all three studies showed no effect of long-term treatment on function compared with control (pooled effect size −0.45, 95% CI −2.75; 1.84) (moderate strength of evidence).
- Glucosamine alone: No RCTs met inclusion criteria for short- or medium-term outcomes. Three RCTs that assessed effects of long-term glucosamine showed a moderate strength of evidence for no beneficial effects on pain and low strength of evidence for no benefit on function.
  ○ A random effects pooled estimate of three studies showed no effect of long-term glucosamine treatment compared with control on pain (n=1007; pooled effect size −0.05, 95% CI −0.22; 0.12; I^2^ 0%) (moderate strength of evidence)
  ○ Effects of long-term glucosamine on function showed no consistent benefit (low strength of evidence)
- Chondroitin alone: Three RCTs that assessed effects of chondroitin alone on pain and function showed inconsistent effects across time and outcomes.
  ○ Two large RCTs showed significant medium-term benefit of chondroitin alone for pain (low strength of evidence). Evidence was insufficient to assess medium-term effects on function.
  ○ Three large RCTs showed no long-term benefit of chondroitin alone on pain (moderate strength of evidence) or function (low strength of evidence).
- No studies were identified that compared glucosamine sulfate with glucosamine hydrochloride.
- No studies analyzed the time course of effects of glucosamine and/or chondroitin, but studies that examined effects at multiple time points showed that the maximum effects are achieved at 3 to 6 months.

##### Findings

Because of the existence of several large RCTs, we limited our assessment to studies that enrolled at least 50 participants per study arm. The studies identified for this report include a 2-year followup assessment of GAIT results.^28^

###### Glucosamine Plus Chondroitin

Five RCTs identified for this report assessed the effects of glucosamine plus (combined with) chondroitin.^28–32^ No studies reported on short-term outcomes as primary outcomes, although one study reported the trajectory of effects over 6 months.

Medium-term effects on pain. Three studies assessed medium-term effects of glucosamine plus chondroitin on pain.^29, 30, 32^

The Multicentre Osteoarthritis interVEntion trial with SYSADOA (MOVES) study is a 2016 multicenter noninferiority RCT aimed at comparing the efficacy and safety of glucosamine hydrochloride and/or chondroitin sulfate with that of celecoxib among patients with severe baseline knee pain (RoB low).^29^ Six hundred three participants were randomized to receive 400 mg chondroitin sulfate plus 500 mg glucosamine hydrochloride three times a day or 200 mg celecoxib for 6 months. The adjusted mean difference in WOMAC pain and the VAS with glucosamine hydrochloride + chondroitin sulfate showed no difference compared with celecoxib, confirming equivalence, and the decrease in pain was considered clinically significant (RR 1.00, 95% CI 0.85, 1.17).

A 2014 open RCT conducted in India by Bellare and colleagues randomized 117 overweight adults with knee OA to a low calorie weight loss diet with glucosamine (1500 mg/d) and chondroitin sulfate (1200 mg/d) supplementation or diet alone (RoB unclear).^30^ The chemical form of glucosamine was not specified, and the diet only group did not receive a placebo. At 6 months, weight loss was the same in both groups. The group that received glucosamine and chondroitin had significantly greater improvements in pain than the diet only group, as shown by decrease in WOMAC pain scores (MD −1.59, 95% CI −2.31, −0.87) for the glucosamine plus chondroitin group compared with the diet only group, p<0.05) and VAS scores (MD −2.08, 95% CI −2.40, −1.76).

A 2016 RCT conducted in Spain by Roman-Blas (Herrero-Beaumont and colleagues) randomized 164 patients with knee OA (KL grade II–III) to a daily dose of glucosamine (1500 mg/d) and chondroitin sulfate (1200 mg/d) or placebo for 6 months (RoB low).^32^ The placebo provided better pain relief than did the glucosamine-chondroitin, as measured on the VAS and on WOMAC scales.

Medium-term effects on function. The MOVES,^29^ the diet study^30^ and the Roman-Blas study^32^ also reported on the medium-term effects of glucosamine plus chondroitin on function.

The MOVES Trial found no differences at 6 months between treatment groups in the WOMAC function score, with a decrease of 45.5% in the glucosamine plus chondroitin group compared with a decrease of 46.4% in the celecoxib group (p=0.53). The reduction in function was considered clinically important (RR 1.02, 95% CI 0.86, 1.21).

The Bellare diet study^30^ reported significant improvements in WOMAC function scores and Lequesne function scores in both treatment groups. The group that received glucosamine plus sulfate showed significantly greater improvements in both WOMAC (MD −3.86, 95% CI −6.16, −1.56) and Lequesne (MD −2.56, 95% CI −3.35, −1.77) function measures than did the diet only group.

The Roman-Blas study found no difference between glucosamine plus chondroitin and placebo in WOMAC function.^32^

Medium-term effects on other outcomes. The MOVES study reported no difference in WOMAC stiffness scores between glucosamine plus chondroitin and celecoxib groups, with a decrease of 46.9% in the combination group, compared with a decrease of 49.2% in the celecoxib group (p=0.43). The improvement in stiffness was considered clinically significant.^29^

The Bellare study reported improvements in WOMAC stiffness scores in both groups with the group that received glucosamine plus chondroitin reporting greater improvements than the diet-only group (5.29[1.12] to 2.60[0.56] vs. 4.94[1.08] to 3.00[0.82], p<0.05).^30^

The MOVES study reported an OMERACT OARSI response rate of 79%. Similarly, no differences were observed in patients’ (p=0.51) and physicians’ (p=0.33) global assessments of disease activity or response to therapy (p=0.74 and 0.70, respectively) or in the Euroquol-5D assessment of HRQoL (MD 0.00).^29^

Long-term effects on pain. Three trials that met inclusion criteria assessed long-term effects of glucosamine and chondroitin on pain.^28, 30, 31^ Because one study did not report variation, no pooling was possible.

The GAIT trial, whose 6-month outcomes were reported in the original report, compared the effects of glucosamine sulfate + chondroitin to those of placebo and celecoxib on the decrease in WOMAC pain score from baseline and on the likelihood of experiencing a 20% improvement in pain at 2 years compared with placebo and with celecoxib (RoB low).^28^ No significant sustained decreases in pain were seen between glucosamine plus chondroitin and placebo (MD 1.04, 95% CI −21.44, 23.51) or celecoxib and placebo (−13.54 (95% CI −35.92, 8.84). The likelihood of achieving a 20% improvement in WOMAC pain scores also did not differ between glucosamine plus chondroitin and celecoxib compared with placebo (OR 0.83, 95% CI 0.51, 1.34 vs. 1.21, 95% CI 0.71, 2.07). All results were adjusted for baseline age, sex, BMI, and K-L grade.

The Bellare open RCT described above assessed the effects of glucosamine plus chondroitin on pain at 12 months. Weight loss was the same in both groups. The group that received glucosamine and chondroitin had significantly greater improvements in pain than the diet only group, as shown by decrease in WOMAC pain scores (MD −3.10, 95% CI −3.69, −2.51) and VAS scores (MD −1.70, 95% −1.99, −1.41).^30^

The Long term Evaluation of Glucosamine Sulfate (LEGS) study, a 2014 placebo-controlled RCT, randomized 605 participants to receive glucosamine sulfate (750 mg) or placebo and chondroitin sulfate (400mg) or placebo once daily for 24 months (RoB low).^31^ The primary outcomes for this study were joint space width (JSW) narrowing and pain. At both 1 and 2 years, participants who received glucosamine plus chondroitin experienced decreases in VAS and WOMAC pain scores (adjusted or unadjusted) that did not differ from those in the placebo group.

A random effects pooled estimate for all three studies showed no effect of treatment compared with the control on long-term pain; study heterogeneity was very high (pooled effect size −0.73, 95% CI −4.03; 2.57; I^2^ 97%) (Figure 3).

Figure 3 Forest plot for long-term effects of glucosamine-chondroitin on WOMAC pain score

Figure notes: CI=confidence interval; EPC=Evidence-based Practice Center; SMD=standardized mean difference; OA=osteoarthritis; WOMAC=Western Ontario and McMaster Arthritis Index

Figure 3. Forest Plot for Long-term effects of Glucosamine-Chondroitin on WOMAC pain. This figure lists the included trials by first author name and year in the far left column, then depicts the standardized mean differences and the 95 percent confidence intervals for each trial along a vertical plane as small boxes (with the sizes of the boxes proportional to the number of participants enrolled in the study and the sizes of the confidence intervals shown as horizontal bars). At the base of the stack of boxes is a horizontal diamond that represents the standardized mean difference (SMD). The mean differences and confidence intervals, and SMD are also shown in a column to the right of the figure. The I-squared value for heterogeneity is shown underneath the list of authors.

Long-term effects on function. Three studies assessed the longer term effects of glucosamine plus chondroitin on function.^28, 30, 31^ Because one study failed to report variation, no pooling was possible.

The GAIT trial found decreases (improvement) in WOMAC function scores at 2 years that did not differ from those of placebo or celecoxib.^28^

The Bellare open RCT described above assessed the effects of glucosamine plus chondroitin on function at 12 months. The group that received glucosamine and chondroitin had significantly greater improvements in WOMAC function, (MD −7.90, 95% CI −10.06, −5.74) and Lequesne scores (0–24 points, MD −3.20, 95% CI −3.86, −2.54) than the diet only group.^30^

The LEGS study found at both 1 and 2 years that participants who received glucosamine plus chondroitin experienced decreases in WOMAC function scores (adjusted or unadjusted) that did not differ from those in the placebo group.

A random effects pooled estimate for all three studies showed no effect of treatment compared with the control on long-term function; study heterogeneity was very high (pooled effect size −0.45, 95% CI −2.75; 1.84; I^2^ 95%) (Figure 4).

Figure 4 Forest plot for long-term effects of glucosamine on WOMAC function score

Figure notes: CI=confidence interval; SMD=standardized mean difference; WOMAC=Western Ontario and McMaster Arthritis Index

Figure 4. Forest Plot for Long-term effects of Glucosamine-Chondroitin on WOMAC function. This figure lists the included trials by first author name and year in the far left column, then depicts the standardized mean differences and the 95 percent confidence intervals for each trial along a vertical plane as small boxes (with the sizes of the boxes proportional to the number of participants enrolled in the study and the sizes of the confidence intervals shown as horizontal bars). At the base of the stack of boxes is a horizontal diamond that represents the standardized mean difference (SMD). The mean differences and confidence intervals, and SMD are also shown in a column to the right of the figure. The I-squared value for heterogeneity is shown underneath the list of authors.

Long-term effects on other outcomes. Two studies assessed the longer term effects of glucosamine plus chondroitin on other outcomes.^30, 31^

The Bellare open RCT assessed effects of the combined supplement on the change in WOMAC stiffness scores at 12 months. The supplemented group experienced a significantly greater improvement in stiffness than the diet only group (mean change −3.95[1.15] vs. −2.80[1.01], p<0.05).^30^

The LEGS trial study found no difference between placebo and glucosamine-chondroitin in SF-12 physical domain scores at 12 months and 24 months.^31^

###### Glucosamine Alone

No studies that met inclusion criteria assessed the short- or medium-term effects of glucosamine alone. Two RCTs assessed the longer-term effects of glucosamine alone on pain and function among individuals with OA of the knee,^28, 31^ and one post hoc analysis of two RCTs assessed the association between glucosamine sulfate supplementation and election to receive total knee replacement.^33^

Long-term effects on pain. The GAIT trial compared the effects of glucosamine sulfate alone to those of placebo and celecoxib on the decrease in WOMAC pain score from baseline and on the likelihood of experiencing a 20 percent improvement in pain at 2 years compared with placebo and with celecoxib.^28^ Decreases from baseline did not differ between either treatment group and placebo. The likelihood of achieving a 20 percent improvement in WOMAC pain scores also did not differ between glucosamine and celecoxib compared with placebo (OR 1.16, 95% CI 0.65, 2.04 vs. 1.21, 95% CI 0.71, 2.07). All results were adjusted for baseline age, sex, BMI, and K-L grade.

The LEGS study found that at both 1 and 2 years, participants who received glucosamine sulfate alone experienced decreases in WOMAC pain scores (adjusted or unadjusted) that did not differ from those in the placebo group.^31^

A 2015 RCT conducted in Bulgaria by Stambolova Ivanova randomized 190 individuals with OA of the knee to receive glucosamine sulfate (1500 mg per day) or a placebo daily for 4 months per year for 3 years (RoB unclear; study reported as a conference proceeding abstract).^34^ Both groups also participated in a physical activity program. At the end of the 3-year period, both groups demonstrated an increase in pain compared to baseline; however, the increase in pain, as measured with the VAS, was significantly lower for the group that received glucosamine (MD −4.60).

A random effects pooled estimate for all three studies showed no effect of glucosamine treatment compared with the control on long-term pain; study heterogeneity was very low (n=1007, pooled effect size −0.05, 95% CI −0.22; 0.12; I^2^ 0%) (Figure 5).

Figure 5 Forest plot for long-term effects of glucosamine on WOMAC pain score

Figure notes: CI=confidence interval; SMD=standardized mean difference; WOMAC=Western Ontario and McMaster Arthritis Index

Figure 5. Forest Plot for Long-term effects of Glucosamine-Chondroitin on WOMAC pain. This figure lists the included trials by first author name and year in the far left column, then depicts the standardized mean differences and the 95 percent confidence intervals for each trial along a vertical plane as small boxes (with the sizes of the boxes proportional to the number of participants enrolled in the study and the sizes of the confidence intervals shown as horizontal bars). At the base of the stack of boxes is a horizontal diamond that represents the standardized mean difference (SMD). The mean differences and confidence intervals, and SMD are also shown in a column to the right of the figure. The I-squared value for heterogeneity is shown underneath the list of authors.

Long-term effects on function. The GAIT trial compared the effects of daily glucosamine sulfate alone to those of placebo and celecoxib on change in WOMAC function scores from baseline to 2 years compared with placebo and with celecoxib.^28^ Changes from baseline did not differ between either treatment group and placebo: glucosamine 9.56 (95% CI −79.79, 98.91), celecoxib-15.82 (95% CI −102.31, 70.67). Results were adjusted for baseline age, sex, BMI, and K-L grade.

The LEGS study found that at both 1 and 2 years, participants who received glucosamine sulfate alone experienced decreases in WOMAC function scores (adjusted or unadjusted) that did not differ from those in the placebo group.^31^

The Stambolova Ivanova study compared function between the glucosamine sulfate and placebo-treated groups at 3 years using the Lequesne Index.^34^ They reported that the placebo group experienced significantly worse function over the 3 years compared with that of the glucosamine treated group.

Long-term effects on other outcomes. Three studies assessed the longer-term effects of glucosamine alone on other outcomes.^28, 31, 33^

The GAIT trial compared the effects of glucosamine sulfate alone to those of placebo and celecoxib on the likelihood of achieving a 20 percent improvement in OMERACT-OARSI scores.^28^ The risk did not differ between glucosamine compared with placebo or celecoxib compared with placebo (OR 1.16, 95% CI 0.74, 1.83 vs. 1.45, 95% CI 0.86, 2.42). All results were adjusted for baseline age, sex, BMI, and K-L grade.

The LEGS study found that at both 1 and 2 years, participants who received glucosamine sulfate alone experienced improvements in SF-12 physical component summary scores that did not differ from those in the placebo group.^31^

Bruyere and colleagues pooled the data from two 3-year placebo-controlled trials of glucosamine sulfate conducted in 2001 and 2002 to assess the association between use of the dietary supplement and long-term risk for TKR among some 414 adults with knee OA.^33, 35, 36^ The primary outcome of the original trials had been joint space narrowing. Among 340 participants with 12 to 36 months of treatment, of whom 275 could be contacted, the average treatment follow up was 5 years. The risk for TKR was over twice as great among placebo treated participants as among the active (Risk of Bias low based on the two original RCTs).

###### Chondroitin Alone

Four trials assessed the effects of chondroitin alone compared with placebo.^28, 31, 37, 38^

Short-term effects on pain. One study that met inclusion criteria assessed short-term effects of chondroitin on pain. A 2013 multicenter placebo-controlled RCT by Zegels and colleagues compared the efficacy and safety of two dosing strategies for chondroitin sulfate among 353 participants over 3 months: a single 1200mg/d dose vs. 400mg/d, three times daily (RoB low).^37^ The outcome for pain was the 100mm VAS scale. Per protocol analysis was used to test equivalence, and ITT analysis was used to test the comparison with placebo. At 1 and 2 months, no statistically significant differences were observed in VAS scores between the active treatment groups or between active treatments and placebo (p=0.43 and p=0.18, respectively).

Short-term effects on function. The dosing equivalence study by Zegels assessed the effects of chondroitin on function, as measured by the Lequesne Index, at 2 and 3 months of treatment.^37^ At 2 months, no difference was observed between the two treatment groups: Both dosing forms showed significant benefit of the chondroitin sulfate compared with the placebo group (MD −1.50, 95% CI −2.62, −0.38 for one 1200mg dose and −1.50, 95% CI −2.59, −0.41) for three 400mg doses). At 3 months, the two active treatment groups showed identical mean differences in Lequesne scores (MD −1.90, 95% CI −3.11, −0.69 and −2.20, 95% CI −3.57, −1.03), which were significantly improved compared with the placebo group.^37^

Medium-term effects on pain. Two RCTs that met inclusion criteria for this report assessed medium-term effects of chondroitin on pain.^37, 38^

At 3 months post baseline, the dosing equivalence study by Zegels and colleagues found that both dosing options (1200mg once a day or 400 mg 3 times per day) had identical effects on VAS pain, significantly greater than the placebo effect (MD −7.70, 95% CI −14.43, −0.97 versus MD −8.30, 95% CI −15.20, −1.40).^37^

The Study on Osteoarthritis Progression Prevention (STOPP) was a two-year placebo-controlled multi-center RCT that assessed the efficacy and safety of chondroitin sulfate (800 mg/d for 24 months) on 622 participants with mild-to-moderate OA of the knee; the primary outcome was JSW (RoB low).^38^ The (secondary) effects on pain were reported as the percent of responders. The percent of responders in the chondroitin group significantly exceeded that in the placebo group for 40mm decrease in VAS (RR 0.68, 95% CI 0.51, 0.91), 60mm decrease in VAS (RR 0–.44, 95% CI 0.23, 0.85), and 40 percent reduction in WOMAC pain (RR 0.83, 95% CI 0.68, 1.02).

Medium-term effects on function. The STOPP Trial reported no difference between chondroitin sulfate and placebo in WOMAC function scores at 6 months (data not reported).^38^

At 3 months post baseline, the dosing equivalence study by Zegels and colleagues found that both dosing options (1200mg once a day or 400 mg 3 times per day) had similar effects on function, as measured by the Lequesne Index, both significantly greater than the placebo effect (MD −2.20, 95% CI −3.37, −1.03 versus MD −1.90, 95% CI −1.90, 95% CI −3.11, −0.69).^37^

Long-term effects on pain. Three RCTs reported on long-term WOMAC pain scores but no pooling was possible because one study failed to report variance.^28, 31, 38^

At 24 months, the STOPP Trial demonstrated sustained decreases in pain, as measured by the VAS and WOMAC; however, the difference between the chondroitin group and the placebo group was not significant.^38^

The 2-year follow up of the GAIT trial showed that chondroitin sulfate did not achieve a significant change in WOMAC pain (11.50, 95% CI −15.40, 38.40) or a clinically meaningful pain response (OR 0.69, 95% CI 0.40, 1.21) compared with placebo.^28^

At years 1 and 2, the LEGS Trial showed significant improvements from baseline for chondroitin in WOMAC pain scores, but no difference from that of the placebo group.^31^

Long-term effects on function. Two RCTs reported on long-term effects on function.^28, 31^

The 2-year follow up of the GAIT trial showed that chondroitin sulfate did not achieve a significant decrease in WOMAC function (OR 36.64, 95% CI −64.57, 37.86) compared with placebo.^28^

At years 1 and 2, the LEGS Trial showed significant improvements from baseline for chondroitin in WOMAC function scores, but no difference from that of the placebo group.^31^

Long-term effects on other outcomes. The STOPP Trial found no difference between groups in cumulative use of acetaminophen but a trend toward decreased use of NSAIDS in the chondroitin group compared with the placebo group at 2 years.^38^

#### Aerobic Exercise

##### Key Points

- Based on five trials, aerobic exercise alone shows no long-term benefit on function; evidence was insufficient to draw conclusions regarding its effects on short- or medium-term outcomes or on long-term pain for patients with knee OA.
  ○ Evidence was insufficient to draw conclusions about short-term effects of aerobic exercise on pain, function, and total WOMAC scores (one RCT).
  ○ Evidence was insufficient to draw conclusions about medium-term effects of aerobic exercise on pain, function, and total WOMAC scores (two RCTs).
  ○ Evidence was insufficient to draw conclusions on effects of long-term aerobic exercise on pain (2 RCTs)
  ○ Aerobic exercise showed no significant long-term effects on function, based on three RCTs (low evidence).

##### Findings

Aerobic exercise for the treatment of OA of the knee was limited to aerobic based exercise programs that did not include other exercise interventions, such as strength training. Studies were included if they compared aerobic exercise to a control group, but not to other exercise programs. We identified five RCTs that compared an aerobic exercise program to a control group. ^39–43^ The longest follow-up time was 18 months.

Short-term effects on pain. One RCT reported on short-term effects of aerobic exercise on pain.^40^

A 2015 RCT conducted in Turkey by Samut and colleagues randomized 27 postmenopausal women and men 50 years of age or older with knee OA to a 3-session-per-week, 6-week progressive aerobic exercise (treadmill) intervention or to a usual care control group (Unclear RoB ).^40^ At 6 weeks, a significant between-group difference was observed in WOMAC pain scores, favoring the aerobic exercise intervention (MD −4.02, 95% CI −6.01, −2.03).

Short-term effects on function. At 6 weeks, the 2015 Samut RCT showed a significant between-group difference in WOMAC function scores (MD −15.35, 95% CI −24.02, −6.68).^40^

Short-term effects on other outcomes. At 6 weeks, the 2015 Samut RCT showed a significant between-group difference in WOMAC total scores (MD −18.58, 95% CI −29.65, −7.51), but not on the 6-minute walk test.^40^

Medium-term effects on pain. A 2012 RCT conducted in the US by Salacinski and colleagues randomized 37 adults with mild-to-moderate knee OA to a 12-week group cycling program or a wait list control group (Low RoB).^43^ At the end of the 12-week period, a significant between-group difference was seen in WOMAC pain, favoring cycling (0–100 point scale, MD −14.9, 95% CI −27.0, −2.6).

Medium-term effects on function. Two studies reported on medium-term effects of aerobic exercise on function. As a feasibility study for the STAR intervention, a 2011 RCT conducted in the US randomized 26 overweight and obese adults, 50 years and over, to a 6-month walking program (moderate RoB).^42^ The aim was to develop and test self-efficacy strategies to promote fitness walking in an individually delivered home-based program for overweight and obese older adults with knee OA. At the end of the 6-month program, no significant between-group differences were seen in WOMAC function or in performance on the 6-minute walk test.

At 12 weeks, the 2012 Salacinski RCT showed no significant between-group differences in WOMAC function scores.^43^

Medium-term effects on other outcomes. At 12 weeks, the 2012 Salacinski RCT showed a significant between-group difference in WOMAC stiffness scores (MD −10.8, 95% CI −21.3, −0.7) but not in WOMAC total scores or KOOS ADL scores.^43^

Long-term effects on pain. Three RCTs reported on the long-term effects of aerobic exercise on pain.^39, 41, 42^

A 2012 single-blind RCT conducted in Canada by Brosseau and colleagues randomized 222 patients into three treatment groups: a group that received a supervised aerobic walking program, behavioral intervention, and an educational brochure; a group that received a supervised walking program and an educational brochure; and a control group that received an educational brochure (RoB high).^39^ The group receiving the behavioral intervention and walking program was excluded from this analysis. At 18-months follow-up, WOMAC pain scores were not significantly different between the control group and the aerobic walking program.

A 2015 RCT conducted in Finland by Koli and colleagues randomized 80 postmenopausal women with mild knee OA to a 3 times per week aerobics class or to an inactive control group for 12 months (moderate RoB ).^41^ At 12 months, no significant between-group differences were observed in KOOS pain.

Long-term effects on function. Three RCTs reported on the long-term effects of aerobic exercise on function.

The 2011 STAR feasibility test found no significant followup effects of the aerobic walking intervention at 12 months from baseline.^42^

Brosseau^39^ examined the effects of their aerobic walking program on function as measured by WOMAC function scores. At 18 months follow-up, WOMAC function was not significantly different between the control group and the aerobic walking group.

The 2015 Koli RCT reported no significant effect of the aerobic exercise program on KOOS physical functioning at 12 months.^41^

Long-term effects on other outcomes. At 18 months follow-up, Brosseau ^39^ also reported no significant differences in total WOMAC scores, SF-36 functional domain scores, TUG scores, or 6-minute walk test distances between the control group and aerobic walking group.

#### Strength or Resistance Training

##### Key Points

- It is unclear whether strength and resistance training have a beneficial effect on patients with OA of the knee. Pooled analyses support a nonstatistically significant benefit, and individual study findings suggest possible benefit on pain and function and significant benefit on total WOMAC scores.
- Strength and resistance training had no statistically significant beneficial effect on short-term pain or function based on pooled analyses of 5 RCTs but a significant short-term beneficial effect on the composite WOMAC total score based on 3 RCTs (low strength of evidence).
- Strength and resistance training showed a nonsignificant medium-term beneficial effect on function in a pooled analysis of 3 RCTs (low strength of evidence).
- Evidence was insufficient to assess long-term effects of strength and resistance training.
- No studies assessed the effects of any factors such as sex, obesity, or disease severity on outcomes of strength and resistance training.

##### Findings

The current review defined an intervention as a strength- or resistance training intervention if the study authors explicitly called the intervention a strength or resistance training intervention or if the primary activity of the intervention (based on time spent on that activity) was aimed at improving strength or resistance. These studies generally included several sessions per week of therapist-led individual or group exercise (including a brief period of warm-up aerobic exercise prior to the strength training period and a cool down period following the strength training) with instructions to perform some exercises at home on the other days. The strength training protocols usually commenced with a level of resistance tailored to the individual that increased progressively with gain in strength. The details are described in the evidence table in Appendix C.

Short-term effects on pain. Five RCTs (reported in 6 publications) met our inclusion criteria for assessing short-term effects of strength training interventions on pain.^44–49^

A 2012 Brazilian RCT randomized 100 individuals with OA of the knee to an exercise femoral quadriceps strengthening (exercise) group or an educational group (RoB low).^47, 48^ The exercise group attended an 8-week twice weekly physiotherapist-led class in which resistance loads were individualized based on a ten-repetition maximum test. Both the exercise and the control groups received an educational manual about knee care (with no exercise instructions) and permission to use paracetamol. At 8 weeks, no significant between-group differences were seen in the exercise group compared with the instruction group in WOMAC pain scores^47^ but a significant group difference was seen in NRS pain scores (MD −1.47, 95% CI −2.71, −0.23).^48^

A 2012 single-blind RCT conducted in Ireland by Bruce-Brand and colleagues randomized 41 adults with moderate to severe knee OA to a 6-week therapist-supervised home-based resistance training program, neuromuscular electrical stimulation, or a control group (education and physical therapy) (RoB moderate).^44^ No improvement was observed in WOMAC pain scores at 8 weeks in the resistance training group compared with the control group. At baseline, the intervention groups differed in WOMAC pain scores, and the dropout rate was exceptionally high at followup.

A 2012 US RCT by Wortley randomized 31 older adults with OA of the knee to a 10-week resistance training program, a tai chi program, or a control group (RoB high).^45^ At 10 weeks, WOMAC pain scores were not improved significantly compared to the control group.

A 2012 RCT conducted in the US by Rogers and coworkers randomized 44 adults age 50 and over to one of four 8-week home-based interventions: kinesthesia, balance, and agility (KBA) training alone, resistance training (RT) alone, a combination of KBA and RT, and a control group that received no intervention (RoB moderate).^46^ At 4 and 8 weeks, WOMAC pain scores improved significantly for the strength training group compared with the control group (0–20 points, MD −3.75, 95% CI −6.39, −1.11).

A 2015 RCT conducted in Brazil by Jorge and coworkers randomized 60 postmenopausal women knee OA to a 12-week progressive knee and hip strength training program or to a wait-list control group (low RoB).^49^ At 6 weeks, the resistance training group showed significant improvements in WOMAC (0–20 point scale, MD −3.40, 95% CI −5.10, −1.70) and VAS (0–10 point scale, MD −1.10, 95% CI −2.20, −0.17) pain scores compared with the control group.

Pooling the results for WOMAC pain for the five studies showed that resistance training had no significant effect on short-term pain; heterogeneity was moderately high (n=215; random effects estimate MD −0.55, 95% CI −1.46, 0.37; I^2^ 72%) (Figure 6).

Figure 6 Forest plot for short-term effects of strength training on WOMAC pain score

Figure notes: CI=confidence interval; SMD=standardized mean difference; WOMAC=Western Ontario and McMaster Arthritis Index

Figure 6. Forest Plot for Short-term effects of Strength Training on WOMAC pain. This figure lists the included trials by first author name and year in the far left column, then depicts the standardized mean differences and the 95 percent confidence intervals for each trial along a vertical plane as small boxes (with the sizes of the boxes proportional to the number of participants enrolled in the study and the sizes of the confidence intervals shown as horizontal bars). At the base of the stack of boxes is a horizontal diamond that represents the standardized mean difference (SMD). The mean differences and confidence intervals, and SMD are also shown in a column to the right of the figure. The I-squared value for heterogeneity is shown underneath the list of authors.

Short-term effects on function. Six RCTs met our inclusion criteria for assessing short-term effects of strength training interventions on function.^44–47, 49, 50^

The 2012 Brazilian RCT found that the 8-week strengthening program improved function compared with the educational control group based on Lequesne Index scores (MD −1.98, 95% CI −3.75, −0.21) but the difference was not reflected in WOMAC function scores.^47^

The study by Bruce-Brand reported no change in WOMAC function scores between the resistance training and control groups at 8 weeks.^44^ However, three other function tests, the primary outcomes of the study, showed significant improvements from baseline to 8 weeks compared to the control group (described below).

The 2012 RCT conducted by Rogers and coworkers found that at 2 months, WOMAC function scores improved significantly compared with the control group (MD −9.62, 95% CI −19.04, −0.20),^46^ and met the MCID.

The 2012 U.S. study by Wortley that compared resistance training with Tai Chi and no activity among older adults showed no significant impact of the resistance training intervention on the WOMAC function score compared with the control condition.^45^

The 2015 study by Jorge that compared resistance training with a wait-list control found no significant benefit of the program on short-term WOMAC function compared with the control group.^49^

A 2016 RCT conducted in India by Singh and coworkers that randomized 30 adults with medial compartmental knee OA to a 6-week 5-day per week hip-strengthening program or to a conventional exercise program found a significant benefit of the program on WOMAC function at 6 weeks compared with conventional exercise (MD −23.27, 95% CI −32.73, −13.81) (low RoB).^50^ Pooling the results for WOMAC function for five studies showed that the effect of resistance training on short-term function was nonsignificant; heterogeneity was moderate (n=245; random effects estimate SMD −0.60, 95% CI − 1.38; 0.17; I^2^ 68%) (Figure 7).

Figure 7 Forest plot for short-term effects of strength training on WOMAC function score

Figure notes: CI=confidence interval; SMD=standardized mean difference; WOMAC=Western Ontario and McMaster Arthritis Index

Figure 7. Forest Plot for Short-term effects of Strength Training on WOMAC function. This figure lists the included trials by first author name and year in the far left column, then depicts the standardized mean differences and the 95 percent confidence intervals for each trial along a vertical plane as small boxes (with the sizes of the boxes proportional to the number of participants enrolled in the study and the sizes of the confidence intervals shown as horizontal bars). At the base of the stack of boxes is a horizontal diamond that represents the standardized mean difference (SMD). The mean differences and confidence intervals, and SMD are also shown in a column to the right of the figure. The I-squared value for heterogeneity is shown underneath the list of authors.

Short-term effects on other outcomes. Eight RCTs (described in nine publications) met our inclusion criteria for assessing short-term effects of strength training interventions on other outcomes of interest.^44–52^

The 2012 RCT conducted in the US by Rogers and coworkers reported the WOMAC total scores at 2 months.^46^ The resistance training and control groups showed a significant between-group difference (MD −13.62, 95% CI −26.27, −0.87).

The 2012 Brazilian RCT assessed the effects of a strengthening program on two additional outcomes of interest: TUG and the physical function domain of the SF-36. The exercise group had a statistically significantly greater improvement in TUG (MD −1.80, 95% CI −2.83, −0.77) compared with the instruction group. The physical domain of the SF-36 showed no significant difference between the groups.^47, 48^

The 2012 study by Bruce-Brand reported significant improvements from baseline to 8 weeks compared to the control group in three function tests that were the primary outcomes of the study (a chair rise test, walk test, and stair climb test [p<0.005]) but did not find significant between-group differences in the SF-36 Physical domain.^44^

The 2012 U.S. study by Wortley compared results for the WOMAC stiffness scale, the TUG, and 6-minute walk tests between intervention groups.^45^ After the 10-week intervention, participants in the resistance training group showed no between-group improvement compared with the control group on the TUG or the 6-minute walk test.

A 2014 RCT conducted in the Republic of Korea by Nam randomized 30 sedentary adults (age 60 and older) with knee OA to a program of strength-training exercises carried out on an aero step XL™ or the same exercises performed on a flat surface (3 times a week for 6 weeks) (RoB moderate).^51^ At 6 weeks, a significant between-group difference was observed in total WOMAC scores (MD −2.99, 95% CI −5.48, −0.50).

The 2015 study by Jorge that compared resistance training with a wait-list control found a significant short-term benefit of the training on WOMAC total scores (MD −8.20, 95% CI −14.78, −1.62) and on the physical domain of the SF-36 (MD −8.80, 95% CI −17.26, −0. 34) but not on the 6-minute walk.^49^

The 2016 study by Singh and coworkers found a significant benefit of their hip strengthening program on 6-minute walk test performance (MD −58.30, 95% CI −85.68, −30.92).^50^

Medium-term effects on pain. Four RCTs met our inclusion criteria for assessing medium-term effects of strength training on pain.^44, 49, 52, 53^

A 2011 Australian RCT, the REACH study, randomized 54 women to a 6-month resistance training or sham training program (consisting of less intense resistance training) (RoB low).^52^ The primary outcome was assessment of dynamic alignment; WOMAC scores were secondary outcomes. At the end of the intervention, WOMAC pain scores showed no significant between-group differences.^52^

The 2012 study by Bruce-Brand found no improvement in WOMAC pain scores at 14 weeks (6 weeks post intervention) in the resistance training group compared with the control group.^44^

The 2016 trial by Jorge that compared a 12-week strength training program with a weight list control found a significant benefit of the program at 12 weeks on WOMAC (MD −4.60, 95% CI −6.50,− 2.70) and VAS (MD −2.30, −3.55, −1.05) pain scores.^49^

A 2016 double-blind (participants and assessors) RCT conducted at two sites in Australia by Bennell and colleagues assessed the effect of strength training combined with pain coping skills training (PCST) compared with PCST or strength training exercises alone (RoB low).^53^ This study randomized 222 individuals with moderate to severe knee OA to three 12-week treatment programs and followed them for 12 months. Comparisons used a model that took into account the physical therapist training, baseline scores, site, and sex. The group that received strength training alone was considered the control. Overall pain was assessed on a 100mm VAS scale with a MCID set at 18mm. At 12 weeks, the strength training plus PCST group showed a significant improvement in WOMAC pain scores compared with those of the group that received only PCST (0–20 point scale, MD −1.50, 95% CI −2.50,− 0.50) but no between-group differences were seen in VAS pain. The findings for the comparison between PCST plus strength and strength alone are presented in a later section on PCST. A higher proportion of the PCST + strength training group showed global improvement in pain than did the strength training alone group (RR 1.3, 95% CI 1.1, 1.6).

Medium-term effects on function. Four RCTs met our inclusion criteria for assessing medium-term effects of strength training on pain.^44, 49, 52, 53^

The REACH study found no difference in WOMAC function between groups.^52^

The 2012 Bruce-Brand study found no difference in WOMAC physical function at 14 weeks in the resistance training group compared with the control group, however several other outcomes indicative of physical function (described below) suggest some at least sustained improvement from the first followup.^44^ The 2016 trial by Jorge that compared a 12-week strength training program with a weight list control found a significant benefit of the program at 12 weeks on WOMAC function (0–68 point scale, MD −9.40, 95% CI −15.17,− 3.63) scores.^49^

The 2016 study by Bennell and colleagues found significantly greater improvements in WOMAC function at 12 weeks in the combined PCST + resistance training group compared with PCST alone (0–68 point scale MD −8.10, 95% CI −11.46, −4.74). A significantly greater proportion of participants in the PCST + resistance training group achieved global improvement in function (6 units or more) (94%) than in the PCST only group (69%, RR 1.4, 95% CI 1.2, 1.6).

Pooling the results for WOMAC function for three studies showed that the effect of resistance training on medium-term function was nonsignificant; heterogeneity was moderate (n=187; random effects estimate SMD −0.43, 95% CI −2.16; 1.30; I^2^ 69%) (Figure 8).

Figure 8 Forest plot for medium-term effects of strength training on WOMAC function score

Figure notes: CI=confidence interval; SMD=standardized mean difference; WOMAC=Western Ontario and McMaster Arthritis Index

Figure 8. Forest plot for Medium-term effects of Strength Training on WOMAC Function. This figure lists the included trials by first author name and year in the far left column, then depicts the standardized mean differences and the 95 percent confidence intervals for each trial along a vertical plane as small boxes (with the sizes of the boxes proportional to the number of participants enrolled in the study and the sizes of the confidence intervals shown as horizontal bars). At the base of the stack of boxes is a horizontal diamond that represents the standardized mean difference (SMD). The mean differences and confidence intervals, and SMD are also shown in a column to the right of the figure. The I-squared value for heterogeneity is shown underneath the list of authors.

Medium-term effects on other outcomes. Three RCTs reported on medium-term effects of resistance training on additional outcomes.^44, 49, 54^

The 2011 REACH study showed a significant between-group difference in WOMAC total scores at 3 months (0–96 point scale, MD −10.40, 95% CI −20.56, −0.24).^52^

The 2012 Bruce-Brand study observed no significant difference in WOMAC stiffness scores in the resistance training group compared with the control group.^44^ This study also found no effects of resistance training on the physical health domain of the SF-36 compared with the control group. However, significant short-term improvements observed in the walking test and chair rise test were maintained in the medium-term (p<0.006).

The 2016 Jorge study that compared a 12-week strength training program with a weight list control found a significant benefit of the program at 12 weeks on WOMAC Total (0–96 point scale MD −14.20, 95% CI −22.03, −6.37) and SF-36 physical domain (0–100 point scale MD −19.00, 95% CI −28.93, −9.07) but not on 6-minute walk scores.^49^

Long-term effects on pain. One RCT that met inclusion criteria assessed the long-term effect of a strength training intervention on pain.^53^

The 2016 study by Bennell on PCST and resistance training reported no significant improvements in VAS pain or WOMAC pain at 52 weeks in the group that received both interventions compared with PCST alone.

Long-term effects on function. One RCT that met inclusion criteria assessed the long-term effect of a strength training intervention on function.^53^

The 2016 study by Bennell reported significant improvements in WOMAC function in the PCST plus resistance training group compared with the grouping receiving PCST alone at both 32 weeks (MD −6.6, 95% CI −2.3, −10.8) and 52 weeks (MD −5.30, 95% CI −8.82, −1.78) (p<0.01).^53^ This study also reported significant improvements in TUG performance in the PCST plus resistance training group compared with the PCST group at both 32 weeks (MD −1.10, 95% CI −1.97, −0.23) and 52 weeks (MD −1.10, 95% CI −1.84, −0.36).

#### Agility Training

##### Key Points

- It is unclear whether agility training alone has any benefit for patients with knee OA. Identified studies showed inconsistent effects across time points and outcomes.
- Agility training showed significant short-term beneficial effects on pain but not on function in 3 RCTs (low strength of evidence).
- Agility training showed no consistent beneficial effects on medium-term pain or function.
- Agility training showed no long-term beneficial effect on pain (3 RCTs) or function (2 RCTs) (low strength of evidence).

##### Findings

For the current review, we identified eight studies that assessed the effects of agility training.^46, 55–61^ The current review defined an intervention as an agility training intervention if the study authors explicitly referred to the intervention as agility training or if they used the terms joint stabilization, or neuromuscular exercise or proprioception, or if the primary activity of the intervention (based on time spent on that activity) was aimed at improving those functions. These studies generally included several sessions per week of therapist-led individual or group exercise (including a brief period of warm-up aerobic exercise prior to the strength training period and a cool down period following the strength training) with instructions to perform some exercises at home on the other days. The details are described in the evidence table in Appendix C.

Short-term effects on pain. We identified three RCTs that met inclusion criteria and assessed the effects of a short- or medium length agility training intervention on short-term pain.^46, 57, 61^

A 2012 RCT conducted in the US by Rogers and coworkers randomized 44 adults age 50 and over to one of four 8-week home-based interventions: kinesthesia, balance, and agility (KBA) training alone, resistance training (RT) alone, a combination of KBA and RT, and a control group that received no intervention (RoB moderate).^46^ At 8 weeks, WOMAC pain scores for the agility training group showed a significant between-group difference compared with those of the control group (MD −3.13, 95% CI, −5.86, −0.40).

A 2013 RCT conducted in the Netherlands by Knoop and coworkers randomized 159 adults to a 12-week program comprising knee joint stabilization therapy plus muscle strengthening or to a program of muscle strengthening alone (RoB low).^61^ The first week of therapy consisted of hydrotherapy in both groups. At 6 weeks, no significant between-group differences were seen in NRS-measured knee pain. The proportion of responders (based on an MCID of 15%) was also the same in both groups: 70 percent compared with 72 percent.

A 2015 RCT conducted in Korea by Ju and colleagues randomized 14 women, 60 years or older, with knee OA to an 8-week program of proprioceptive circuit exercise or a control group (RoB unclear).^57^ At 8 weeks, VAS pain scores improved significantly in the intervention group compared with the control group (1–10 cm: MD −4.00, 95% CI −5.32, −2.68).

Short-term effects on function. We identified three RCTs that met inclusion criteria and assessed the effects of an agility training intervention on short-term function.^46, 58, 61^

The 2012 Rogers study reported no significant improvements in WOMAC function at 8 weeks compared with the sham control group.^46^

A 2015 RCT conducted in Brazil by da Silva and colleagues randomized 41 participants with moderate to severe knee OA to an 8-week rehabilitation program that included mobility, functional, and balance exercises in addition to strength training or to a control condition: Both groups received self-management educational sessions (RoB moderate).^58^ At 8 weeks, no between-group difference was seen in Lequesne composite scores. Both exceeded the MCID (defined by the authors as an effect size greater than 0.01).

The 2013 study by Knoop and colleagues assessed WOMAC physical function as its primary outcome.^61^ At 12 weeks, no significant between-group differences were seen, and no difference in the proportion of responders (66% vs. 63%), based on an MCID of 12 percent.

Short-term effects on other outcomes. The 2015 RCT by da Silva found that at 8 weeks, the intervention group performed significantly better on the TUG (MD −2.05, 95% CI −3.12, −0.98) and the 6-minute walk (MD −50.40, 95% CI −94.26, −6.54) than did the control (education) group. This study also reported a significant difference in scores on the SF-36 Physical Function domain (MD −14.00, 95% CI −26.24, −1.76).^58^

The 2012 Rogers study reported no significant improvements in WOMAC total scores at 8 weeks compared with the control group.^46^

Medium-term effects on pain. Three RCTs reported on medium-term effects of agility training on pain.^56, 60, 61^

The 2013 3-month RCT by Knoop found a nonsignificant between-group difference in NRS pain at 3 months.^61^

A 2014 RCT conducted in Denmark by Henriksen and coworkers randomized 60 individuals with OA of the knee to a 12-week program of facility-based neuromuscular exercise therapy or to a no-attention control group (RoB Low).^56^ The primary outcome was sensitivity to pressure pain. At 12 weeks, KOOS pain, a secondary outcome, was statistically significantly improved in the intervention group compared to the control group (MD −6.80, 95% CI −12.18, −1.42)).

A 2015 RCT conducted in the US by Segal and colleagues randomized adults 60 years and older with knee OA and mobility limitations 2 to 1 to a gait-training intervention or to a usual care control group (RoB low).^60^ At 6 months, no between-group differences were observed using the KOOS pain measure.

Medium-term effects on function. The 2013 RCT by Knoop found no significant between-group differences in function at 3 months.^61^

The 2014 RCT by Henriksen found no significant differences in function between the agility training and the usual care group.^56^

Medium-term effects on other outcomes. Three RCTs reported on medium-term effects of agility training on other outcomes of interest.^59, 61^

The 2013 RCT by Knoop found no significant between-group differences in timed up and go (TUG) at 3 months.^61^

A 2013 RCT conducted in Brazil by Barduzzi randomized 15 older adults ( 60 to 80 years) with OA of the knee to receive water based agility kinesiotherapy, land-based agility kinesiotherapy, or a control condition (RoB High).^59^ The intervention consisted of 24 sessions over 4 months with a 45-day break between the 12^th^ and 13^th^ session. At the end of the 4-month period, the water-therapy group showed a significantly better walking speed than the control group (p<0.007). The land-based agility exercise group showed no between-group differences from the control group.

The 2014 RCT by Henriksen found no significant differences in KOOS quality of life scores between the agility training and the usual care group.^56^

Long-term effects on pain. Three RCTs assessed the effects of agility training on long-term pain.^55, 60, 61^

A 2011 U.S. RCT by Fitzgerald and colleagues randomized 183 individuals with knee OA to a group that received a standard exercise program with agility training for 6 months or to a group that received only the standard exercise program (RoB low).^55^ NRS-assessed knee pain scores were measured at 2 months, 6 months, and 12 months, but only the 12-month measures underwent ITT analysis. No between-group differences in pain were seen.

The 2013 study by Knoop and colleagues assessed pain at 38 weeks (6 months after the end of the intervention).^61^ A nonsignificant between-group difference was seen in NRS-measured pain. The proportion of responders was 72 percent for the intervention group and 57 percent for the control group, based on an MCID of 12 percent.

The 20015 U.S. RCT by Segal and colleagues that assessed the effects of gait training found no between-group differences in KOOS-estimated pain at 12 months.^60^

Long-term effects on function. Two RCTs assessed the effects of agility training on long-term function.^55, 61^

The 2011 Fitzgerald study assessed the effects of the agility training intervention on WOMAC function.^55^ No between-group differences were seen.

The 2013 study by Knoop and colleagues assessed WOMAC physical function at 38 weeks after baseline (6 months after the end of the intervention).^61^ At 38 weeks, no between-group differences were seen in WOMAC function, and no difference was observed in the proportion of responders (62% vs. 61%), based on an MCID of 12 percent.

Long-term effects on other outcomes. In the 2011 study by Fitzgerald and colleagues, total WOMAC scores at 12 months (10-months after the end of the intervention period) showed no differences between the agility group and the standard exercise group.^55^

#### General Exercise Therapy

##### Key Points

- General exercise programs appear to have beneficial medium-term effects on pain and function and long-term effects on pain for patients with knee OA, based on a relatively small number of heterogeneous RCTs.
  ○ Evidence was insufficient to assess the effects of general exercise therapy programs on short-term pain or function.
  ○ General exercise therapy programs had a beneficial effect on medium term pain and function, based on two RCTs (low strength of evidence).
  ○ General exercise therapy programs showed beneficial long-term effects on pain, based on 4 RCTs (low strength of evidence), but evidence was insufficient to assess long-term effects on function or quality of life.

##### Findings

For the current review, we identified six RCTs whose exercise interventions did not fit the definitions of any of the other types of exercise therapy.^62–67^ These studies generally included several sessions per week of therapist-led individual or group exercise (including a brief period of warm-up aerobic exercise prior to, and a cool down period following some combination of exercises) with instructions to perform some exercises at home on the other days. One RCT compared aquatherapy to a program of similar exercises performed on the land.^63^ The details are described in the evidence table in Appendix C.

Short-term effects on pain. One RCT assessed short-term effects of general exercise interventions on pain.^63, 66^

A 2016 RCT conducted in the Netherlands by de Rooij and colleagues randomized 126 adults with knee OA and at least one comorbidity to a 20-week (two sessions per week) exercise program that was individually tailored to accommodate the participants’ comorbidities or to a wait list control (RoB low).^66^ At 10 weeks’ followup, no between group differences were seen in WOMAC pain or NRS pain measures.

Short-term effects on function. At 10 weeks’ followup, the de Rooij RCT also showed no beneficial effects of the exercise intervention on WOMAC function scores.^66^

Short-term effects on other outcomes. One RCT compared the short-term effects of a general water-based exercise program to those of a land-based program of similar exercises and to a control group (Low RoB ).^63^ This 2010 study conducted in the Republic of Korea by Lim and colleagues, randomized 75 obese adults with knee OA to an 8-week program (3 sessions per week) of aquatic exercise, land-based exercise, or a usual care control group. At 8 weeks, neither the aquatic exercise group nor the land-based exercise group showed significant improvements in WOMAC total scores compared with the control group.

The Lim RCT also reported nonsignificant improvements in SF-36 physical domain scores in the aquatic fitness and land-based exercise groups compared with the control group.^63^

At 10 weeks, the de Rooij RCT showed no between group differences in the TUG or the 6-minute walk tests.^66^

Medium-term effects on pain. Two RCTs assessed medium-term effects of general exercise interventions on pain.^64, 66^

A 2014 RCT conducted in Canada by Rosedale and colleagues randomized 180 individuals with knee OA to an exercise group (120) or a nonexercise control group (60) (RoB low).^64^ The exercise intervention that was implemented depended on the intervention participants’ responses to the McKenzie System of Mechanical Diagnosis and Therapy (MDT); responders are defined as those who show knee derangements when asked to perform particular movements, and the exercises were focused on these derangements. At 3 months, the combined exercise group had significant improvements in KOOS pain scores (0–100: MD −10.00, 95% CI −15.28, −4.72) and P4 pain scores (0–40: MD −3.00, 95% CI −5.84, −0.16) compared to the control group.

At 20 weeks, the de Rooij RCT showed significant beneficial effects of the exercise program on both WOMAC (0–17 point scale, MD −1.90, 95% CI −3.28, −0.52) and NRS (0–10 point scale, MD −1.50, 95% CI −2.26, −0.74) pain scores compared with the control group. ^66^

Medium-term effects on function. At 3 months, the combined exercise groups in the study by Rosedale and colleagues had significantly higher KOOS function scores (indicating improvement) than did the control group (0–100 scale: MD −9.00, 95% CI −14.28, −3.72). Comparisons are not shown for the two exercise subgroups, as they were not randomly allocated.^64^

At 20 weeks, the de Rooij RCT showed significant beneficial effects of the exercise program on WOMAC function scores (0–68 point scale, MD −5.10, 95% CI −9.81, −0.39).^66^

Medium-term effects on other outcomes. At 20 weeks, the de Rooij RCT showed significant beneficial effects of the exercise program on SF-36 physical domain scores (0–20 point scale, MD −1.90, 95% CI −3.62, −0.18) but not on TUG or 6-minute walk test scores.^66^

Long-term effects on pain. Four RCTs assessed the long-term effects of general exercise interventions on pain.^65–68^

A 2015 RCT conducted in New Zealand by Abbott and colleagues randomized 75 adults with OA of the knee to one of four interventions: 12 weekly exercise sessions, 8 weekly sessions plus four additional (booster) sessions every three months over the course of the following 9 months, exercise plus 12 manual therapy sessions, or manual therapy alone (RoB moderate).^65^ The group that received 12 consecutive weekly exercise sessions was considered the control. The outcomes for the manual therapy groups are discussed below with outcomes for other manual therapy studies. Compared with 12 consecutive exercise sessions, the group that received booster exercise classes over the course of the year had significantly improved VAS pain intensity scores (1–10mm scale: MD −2.00, 95% CI −3.84, −0.16).

A 2016 RCT conducted by the same research group employed the same study design with a larger population, randomizing 300 participants to the same four interventions (Low RoB).^67^ At one year, the group that received the initial 12-week intervention plus the booster sessions had significantly improved pain scores compared with the group that received only the initial exercise intervention (MD −0.60, 95% CI −0.78, −0.42).

A 2015 RCT conducted in Denmark, the CAROT trial, randomized 192 adults who had completed an intensive 4-month weight loss program to continue in a weight maintenance group, to enter an exercise program, or to receive no further interventions for 1 year (RoB low).^62^ The effects of the weight loss phase of the program on outcomes of interest are reported below in the section on weight loss programs.^68^ The exercise program comprised three 1-hour sessions per week of circuit training, which transitioned from group sessions to home-based sessions. Over the year, the weight maintenance group regained the least weight, followed by the control group and the exercise group. At 1 year, no significant group differences were seen between the exercise group and the control group in VAS pain.

At 32 weeks, the de Rooij RCT continued to show significant beneficial effects of the exercise program on both WOMAC (0–17 point scale, MD −2.00, 95% CI −3.37, −0.63) and NRS (0–10 point scale, MD −1.50, 95% CI −2.26, −0.74) pain scores compared with the control group.^66^

Long-term effects on function. The CAROT trial found no between-group differences in KOOS daily function scores.^62^

At 32 weeks, the de Rooij RCT continued to show significant beneficial effects of the exercise program on WOMAC function (0–68 point scale, MD –7.90, 95% CI −12.78, −3.02) scores compared with the control group.^66^

Long-term effects on other outcomes. Four RCTs assessed the long-term effects of general exercise interventions on other outcomes.^62, 65, 66, 67^

The CAROT trial found no between-group differences in outcomes for the six-minute walk or for SF-36 physical domain scores at the end of 1 year.^62^

The Abbott RCT reported a significant difference in total WOMAC scores at 12 months between the exercise and the exercise plus booster session groups, favoring the booster session group (0–240 point scale: MD −56.10, 95% CI −92.70, −19.50).^65^ Booster sessions had no significant effect on the outcomes of the TUG. In contrast, the larger follow-on study by this group found no significant effect of booster exercise sessions on WOMAC total scores (the primary outcome) at one year but did find a small but significant effect on the TUG (MD −0.60, 95% CI −0.78, −0.42).^67^

At 32 weeks, the de Rooij RCT showed significant beneficial effects of the exercise program on SF-36 physical domain scores (0–20 point scale, MD −2.50, 95% CI −4.26, −0.74) as well as on the TUG (seconds, MD −1.40, 95% CI −2.69, −0.11) and 6-minute walk test scores (meters, MD −42.30, 95% CI −82.63, −1.97).^66^

#### Tai Chi

##### Key Points

- Tai chi appears to have some short- and medium-term benefit for patients with OA of the knee, based on three small, short-term RCTs and one larger, 18-week RCT (total n=290).
  ○ Tai chi showed significant beneficial short-term effects on pain, comparable with those of conventional physical therapy, in one large RCT, but no significant effects in two small, brief RCTs (low strength of evidence).
  ○ Tai chi showed beneficial effects on short-term function compared with physical therapy and education but not compared with strength training, based on three RCTs (low strength of evidence).
  ○ Tai chi showed significant benefit for medium-term pain and function in 2 RCTs (low strength of evidence).
  ○ Evidence was insufficient to assess long-term effects of Tai chi on pain, function, and other outcomes.

##### Findings

Studies of Tai chi were included if they compared Tai chi to standard aerobic or strength training regimens, attention control, or treatment as usual (TAU) but not to other specialized exercise interventions of unknown efficacy. We found three RCTs that compared the participation in Tai chi to strength training, health education classes, or treatment as usual. ^45, 69, 70^ One study followed patients for 10 weeks, a second did so for 21 weeks, and a third followed patients for 52 weeks.

Short-term effects on pain. Three studies reported on the short-term effects of tai chi on pain. ^45, 69, 70^

In a 2013 RCT based in the US, Wortley and colleagues assigned participants to one of three trial arms for 10 weeks: resistance strength training, tai chi, or usual medication and physical activity (RoB high).^45^ WOMAC pain scores decreased significantly more in the resistance training group than in the Tai chi or TAU groups over the 10-week period.

In another 2013 RCT conducted in the US, Tsai and colleagues randomized participants to 20 weeks of Tai chi or to an attention control (health education and social activities) (RoB unclear).^69^ At 9 weeks, WOMAC pain scores did not decrease significantly more in the tai chi group than in the attention control group.

A 2016 RCT conducted in the US by Wang and colleagues randomized 204 knee OA patients to an 18-week intervention of Tai chi or conventional physical therapy; the first 12 weeks was conducted in a clinic and the remaining 6 weeks was to be completed at home (RoB low).^70^ At 12 weeks, both the Tai chi and the conventional physical therapy groups showed comparable beneficial effects of the interventions on WOMAC pain scores.

Short-term effects on function. All three studies examined short-term effects on function.^45, 69, 70^

Wortley found that WOMAC function scores improved in the resistance training group but not in the Tai chi group compared to the TAU group.^45^ Timed up and go and 6-minute walk scores also did not significantly decrease in the Tai chi group compared to changes in the other groups.

Tsai reported that at 9 weeks, treatment effects were significantly larger in the Tai chi group for WOMAC function (MD −5.54 95% CI −9.72, −1.36) and get up and go (MD −1.54, 95% CI −0.32, −2.76), but not for WOMAC stiffness, and sit to stand scores.^69^

Wang reported that at 12 weeks, both Tai chi and physical therapy improved WOMAC function scores to a comparable extent.^70^

Medium-term effects on pain. Two RCTs assessed medium-term effects on pain.^69^

In the 20-week RCT by Tsai and colleagues^70^, pain decreased significantly more in the Tai chi group than in the attention control group at 21 weeks (MD −1.58, 95% CI −2.76, −0.40). At that point, pain had decreased by 2.6 points in the Tai chi group and by 1.02 points in the attention control group (p=0.006).

At 24 weeks, the Wang RCT reported that both the Tai chi and physical therapy groups experienced similar decreases in WOMAC pain scores with no significant difference between them.^70^

Medium-term effects on function. Tsai found a significant difference in WOMAC function between groups at 21 weeks (MD −5.52, 95% CI −9.70, −1.34), favoring Tai chi.^69^ In addition, WOMAC stiffness significantly decreased by 1.79 points in the Tai chi group compared to only 0.22 points in the attention control group at 21 weeks (p=0.01) but not for get up and go, and sit to stand scores.

The 2016 Wang RCT showed a significant beneficial effect of Tai chi on WOMAC function scores compared with conventional physical therapy at 24 weeks (0–1700 point scale: MD −131.10, 95% CI −251.35, −10.85).

Medium-term effects on other outcomes. At 24 weeks, the Wang RCT found a significant benefit for Tai chi on SF-36 physical domain scores compared with conventional physical therapy (0–100 point scale: MD −3.70, 95% CI −6.53, −0.87) but no difference between intervention types in 6-minute walk test scores.^70^

Long-term effects on pain, function, and other outcomes. At 52 weeks, the Wang RCT continued to show no difference between Tai chi and conventional physical therapy in the long-term benefits on WOMAC pain, function, SF-36 physical domain scores, and 6-minute walk scores.^70^

#### Yoga

##### Key Points

- It is unclear whether yoga has any benefit for patients with OA of the knee, as we identified only one small RCT (n=36).

##### Findings

Studies of yoga were included if they compared yoga to standard aerobic or strength training regimens, a waitlist, an attention control or treatment as usual (TAU) but not other specialized exercise interventions of unknown efficacy. We found 1 RCT that compared the participation in tai chi to a waitlist control group.^71^ This study followed patients for 20 weeks.

Short-term effects on pain. In a 2014 RCT based in the US, Cheung and colleagues assigned participants to either a yoga intervention or a waitlist control for 8 weeks. (Risk of bias 7/10) ^71^ WOMAC pain scores decreased significantly from 8.3 points to 5.8 points for the yoga group (p=0.01).

Short-term effects on function. The Cheung study also reported short-term effects on function. ^71^ Authors found that WOMAC function decreased from 35 points to 22 points in the yoga group, but that this drop did not significantly differ from the change see in the control group. Short Physical Performance Battery (SPPB) repeated chair stands scores significantly increased from 2.4 to 2.8 in the yoga group (p=0.03), but there was no significant change in SPPB global, balance, and eight-foot walk scores.

Medium-term effects. This study did not examine the medium-term effects of yoga.

Long-term effects. This study did not examine the long-term effects of yoga.

#### Balneotherapy and Mud Treatment

##### Key Points

- Balneotherapy had a beneficial effect on medium-term function, and a beneficial, but inconsistent effect on medium term pain across two single-blind RCTs (low strength of evidence). No studies assessed effects of balneotherapy on short- or long-term outcomes.
- Evidence was insufficient for an effect of mud (mud baths or topical mud) on short-term outcomes.

##### Findings

For the current review, we identified two RCTs that assessed the effects of balneotherapy, ^72, 73^ one RCT that tested topical application of mud,^74^ and one RCT of mud bath therapy.^75^ The details are described in the evidence table in Appendix C.

###### Balneotherapy

Short-term effects on pain, function, or other outcomes. No studies that assessed short-term effects of balneotherapy met inclusion criteria.

Medium-term effects on pain. A 2012 RCT conducted in Italy by Fiorvanti and colleagues randomized 60 adults with bilateral knee OA to treatment that consisted of daily baths in sulfate-bicarbonate-calcium water (20 minutes per treatment, 6 treatments per week for two weeks) or usual care (RoB moderate).^72^ After 12 weeks followup, a significant between-group difference was observed in VAS pain scores (0–100mm: MD−42.50, 95% CI −53.67, −31.33) and WOMAC pain scores (MD −25.70, 95% CI −34.06, −17.34).

A 2014 RCT conducted in Hungary by Kulisch and colleagues randomized 77 adults with mild to moderate OA of the knee to baths in Lake Heviz (30 minutes each, 5 times a week for 3 weeks) or to similar baths in tap water (RoB moderate).^73^ The water temperature was the same for both groups, 34C. At week 15, participants who received the mineral bath treatment had significantly greater changes in VAS pain scores at rest (MD −16.00, 95% CI −26.68, −5.32) and on exertion (MD −16.60, 95% CI −25.79, −7.41) than did those who bathed in tap water. WOMAC pain scores did not differ between the two groups

Medium-term effects on function. The 2012 study on balneotherapy by Fiorvanti found significant between-group differences in WOMAC function scores (MD −37.47, 95% CI −46.61, −28.33) and Lequesne scores (MD −7.50, −9.57, −5.43).^72^

The 2014 RCT by Kulisch reported a significant improvement in WOMAC function in the balneotherapy group compared to the control group at 15 weeks (MD −8.10, 95% CI −15.82, −0.38).^73^

Medium-term effects on other outcomes. The 2012 study on balneotherapy by Fiorvanti found significant between-group differences at 12 weeks for the SF-36 functional domain (MD −32.60, 95% CI −49.62, −15.58), and use of rescue pain medication (NSAIDs and acetaminophen) (p<0.001).^72^

The 2014 RCT by Kulisch found no difference in WOMAC stiffness scores between treatment groups at 15 weeks.^76^ The study also reported significant improvements in EQ-5D measure of general HRQoL.

Long-term effects on pain, function, or other outcomes. No RCTs that assessed long-term outcomes of interest met the inclusion criteria.

###### Mud Bath or Mud Therapy

Short-term effects on pain. A 2009 RCT conducted in Iran by Mahboob randomized 50 participants with OA of the knee to receive topical applications of Lake Urmia mud (prepared as a gel) or a placebo gel (20 minutes per day for 30 days) (RoB unclear).^74^ At the end of the intervention, no significant between-group differences were seen in WOMAC pain scores.

Short-term effects on function. The Mahboob RCT found no significant difference in WOMAC function at the end of the trial, although both groups improved significantly from baseline.^74^

Short-term effects on other outcomes. The Mahboob RCT found significantly greater improvement in stiffness for the intervention group than for the placebo group (p<0.05).^74^

Medium-term effects on pain. A 2015 RCT conducted in Italy by Fiorvanti and colleagues randomized 103 adults 40 to 80 years of age with bilateral knee OA, K-L grade I–III to receive daily mud bath therapy (a combination of warm (42C) mud packs prepared from local mud (15 minutes) and bathing in the warm (37C) spring from which the mud was prepared (20 minutes), in addition to their usual therapy or treatment as usual alone for 2 weeks (RoB moderate).^75^

At 6 months, the study reported a significant between-group difference in VAS pain scores (0–100 point scale: MD −15.00, 95% CI −25.63, −4.37).^75^

Medium-term effects on function. At 6 months, the Fiorvanti study found a significant difference in WOMAC function scores between the intervention and control group (0–100 point scale: MD −10.00, −15.00, −5.00).^75^

Medium-term effects on other outcomes. At 6 months, the Fiorvanti study showed significantly improved WOMAC stiffness scores for the group that received the intervention, compared with the control group.^75^ This study also reported significant improvement in the SF-12 physical domain (MD −2.46, 95% CI −22.12, −2.80) and the EQ-5D (MD −0.24, variance not reported).

Long-term effects on pain. At 12 months, the Fiorvanti study reported no significant between-group differences in WOMAC pain scores or in VAS pain scores.^75^

Long-term effects on function. At 12 months, the Fiorvanti study found a significant between-group differenced in WOMAC function scores (0–100 point scale, MD −5.50, 95% CI −10.81, −0.19).^75^

Long-term effects on other outcomes. At 12 months, the Fiorvanti study showed no between-group differences in WOMAC stiffness scores.^75^ The study reported no significant differences in the SF-12 physical component or the EQ-5D.

#### Heat, Infrared, and Therapeutic Ultrasound

##### Key Points

- Insufficient evidence was identified to determine whether heat or infrared have any beneficial effects on any outcomes in patients with knee OA.
- Insufficient evidence was identified to determine whether continuous or pulsed therapeutic ultrasound (U/S) have beneficial effects on any outcomes.

##### Findings

For the current review, we identified one RCT that assessed the effects of heat, ^77^ one that assessed the effects of infrared,^78^ and three that assessed the effects of pulsed and continuous U/S on outcomes of interest.^79–81^ The details are described in the evidence table in Appendix C.

Short-term effects on pain. For the current review we identified one RCT that assessed the effects of heat, one that assessed the effects of infrared, and two that assessed the effects of ultrasound on short-term pain outcomes.^77, 78, 80, 81^

A 2010 RCT conducted in Turkey by Yildirim and colleagues randomized 46 adults seen in a physical therapy clinic for OA of the knee to receive 4 weeks of heat treatment every other day or to continue with usual pharmacotherapy (RoB unclear).^77^ WOMAC pain scores improved significantly more in the heat therapy group at 4 weeks than in the control group (0–20-point scale: MD −1.85, 95% CI −3.15, −0.55), however the intervention group was not barred from using analgesics.

A 2012 RCT conducted in Taiwan by Hsieh and colleagues randomized 72 individuals with knee OA to two weeks of infrared treatment (three times weekly) or to a passive control (RoB low).^78^ At 4 weeks after baseline, no difference was seen in KOOS pain scores between the two groups.

A 2012 RCT conducted in Brazil by Carlos and colleagues randomized 30 adults 50 to 75 years of age to an 8-week intervention consisting of 4 weeks pulsed U/S plus 4 weeks exercise (strength/resistance training), 4 weeks continuous ultrasound plus 4 weeks exercise, or 8 weeks exercise alone as the control group (RoB unclear).^80^ At 8 weeks, the exercise-only group showed no significant between-group differences in WOMAC or VAS pain compared with either the continuous or pulsed U/S. No difference was seen between continuous and pulsed U/S.

A 2015 RCT conducted in Turkey by Yildiz randomized 90 adults with bilateral knee OA (KL grade II–III) to receive continuous U/S, pulse U/S, or placebo U/S ( 5 days per week for 2 weeks) and to perform daily exercises at home (High RoB).^81^ At 2 months from baseline, both continuous and pulsed U/S groups experienced significant benefit on VAS pain (0–10 point scale: MD −1.33, 95% CI −2.55, −0.11) and (MD −1.56, 95% CI −2.82, −0.30) compared with the sham control.

Short-term effects on function. The 2010 RCT by Yildirim found a significant effect of the heat therapy on WOMAC function compared with that of pharmacotherapy alone (0–68 point scale: MD −6.05, 95% CI −9.65, −2.45).^77^

The 2012 RCT by Carlos found no significant effect of continuous U/S or pulsed U/S on WOMAC function compared with exercise alone.^80^

The 2015 Yildiz RCT found a significant benefit of both the continuous and pulsed U/S on Lequesne function scores compared with the sham control group (Scale not described; MD −2.35, 95% CI −4.11, −0.59) and (MD −2.65, 95% CI −4.27, −1.03).^81^

Short-term effects on other outcomes. The 2010 RCT by Yildirim found no significant effect of the heat therapy on WOMAC stiffness compared with that of pharmacotherapy alone but did find a significant effect on SF-36 Physical function domain score in favor of the control (MD −12.61, 95% CI, −21.49, −3.73).^77^

The 2012 RCT by Carlos found no between-group differences in the effects of U/S on total WOMAC scores.^80^

Medium-term effects on pain. At 4 months, Yildiz reported a significant benefit for both continuous (MD −3.30, 95% CI −4.62, −1.98) and pulsed (MD −3.37, 95% CI −4.70, −2.04) U/S for VAS pain, compared with sham.^81^

Medium-term effects on function. Yildiz also reported improvement in function for both continuous(MD −6.28, 95% CI −8.31, −4.25) and pulsed (MD −5.71, 95% CI −7.68, −3.74) U/S, as assessed using the Lequesne.^81^

Long-term effects on pain. A 2014 RCT conducted in Turkey by Cakir and colleagues randomized 60 adults with OA of the knee to a 2-week intervention of continuous U/S, pulsed U/S, or sham U/S (RoB moderate).^79^ All three groups participated in a simultaneous exercise program. At the end of 6 months, no significant differences were observed in WOMAC pain or VAS pain between either the continuous or pulsed U/S groups and the sham U/S group. All three groups experienced comparable improvement, defined as 40 percent improvement or a decrease of 8 units in the WOMAC pain score from baseline.

Long-term effects on function. The 2014 Cakir study found no difference between either the continuous or pulsed U/S group and the sham U/S group in WOMAC function at 6 months.^79^

#### Neuromuscular Electrical Stimulation (NMES)

##### Key Points

- Evidence was insufficient to assess the short-term effects of NMES combined with exercise compared with exercise alone (or NMES compared with a sham control) on pain or function, based on three RCTs.
- Evidence was insufficient to assess the medium- and long-term effect of NMES on pain and function.

##### Findings

Studies of NMES were included if they compared NMES to sham or to use of analgesics but not to other treatments of unclear efficacy. We identified 5 RCTs that compared NMES to a control or exercise with NMES to exercise alone.^44, 82–85^ The longest followup time ranged from 6 weeks to 18 weeks from baseline.

Short-term effects on pain. Four studies reported on short-term effects of NMES treatment on pain.^44, 83–85^

A 2012 single-blind RCT conducted in Ireland by Bruce-Brand et al randomized 41 patients into three treatment groups: a group that received one 20-minute NMES session daily, 5 days per week for 6 weeks, a group that received three 30-minute home-based resistance trainings (RT) per week for 6 weeks, and a control group, which received standard care (RoB moderate).^44^ WOMAC pain score at 8 weeks’ followup was significantly decreased from baseline in the NMES group (p<0.005); however, no significant differences in pain were noted between groups after treatments.

A 2013 RCT conducted in Brazil by Imoto and colleagues randomized 100 patients into two treatment groups: a group that received NMES combined with exercise and a group that received exercise alone; both groups received the treatments twice a week, for 8 weeks, with each session lasting about 40 minutes (RoB low).^83^ At 8 weeks’ followup, NRS and WOMAC pain scores were significantly decreased from baseline in both NMES+ exercise and exercise groups (p<0.0001), whereas no significant differences between groups were found.

Another 2013 RCT conducted in Brazil by Imoto and coworkers randomized 100 patients into two groups: one that received an educational guide and strength training with NMES and one that received an educational guide and two phone calls as a control group (RoB low).^84^ NRS pain scores at 8 weeks’ followup were significantly decreased in the NMES group compared with the control group (MD −1.44, 95% CI −2.65, −0.23; p<0.05).

A 2013 RCT conducted in Israel by Elboim-Gabyzon and colleagues randomized 63 patients to receive 12 biweekly exercise-only treatments or exercise combined with NMES treatments (RoB moderate).^85^ At 6 weeks’ followup, VAS pain scores were significantly improved for the exercise + NMES group compared with those of the exercise-only group (MD −1.70. 95% CI −2.92, −0.42; p<0.05).

Short-term effects on function. Bruce-Brand and Imoto^44, 83, 84^ also assessed the effects of NMES on function. At 8 weeks’ followup, Bruce-Brand^44^ found no significant differences in WOMAC function either from baseline or between groups; Imoto ^83^ reported significant decreases in WOMAC function from baseline in both NMES + exercise and exercise groups (p<0.0001) but no significant differences between groups. In the other 2013 RCT conducted by Imoto,^84^ the NMES group showed significantly greater improvement in Lequesne index scores than did the control group (MD −2.81, 95% CI −4.53, −1.09; p<0.05) at 8 weeks’ followup.

Medium-term effects on pain. At 14 weeks’ followup, Bruce-Brand^44^ found no significant between-group differences in WOMAC pain scores. Following up patients in the 2013 RCT conducted by Elboim-Gabyzon^85^ for another 12 weeks, Laufer^82^ reported that the greater improvement in VAS pain scores remained for those who received exercise combined with NMES (−1.90, 95% CI −3.25, −0.55; p<0.05)(RoB moderate).

Medium-term effects on function. Bruce-Brand^44^ assessed the medium-term effects of NMES on function. At 14 weeks’ followup, WOMAC function scores were significantly decreased from baseline in the NMES group (p<0.005) while no differences were seen between the NMES and RT groups or between the NMES and control groups.

Long-term effects. No studies reported on long-term effects of NMES.

#### TENS

##### Key Points

- TENS showed a small but significant beneficial short-term effect on pain compared with sham controls based on pooled analysis of four RCTs (moderate strength of evidence), but no benefit for short-term function or other outcomes (low strength of evidence). The beneficial effect on pain was not sustained over the medium term.

##### Findings

For the current review, we identified four RCTs that assessed the effects of TENS.^86–89^ The details are described in the evidence table in Appendix C.

Short-term effects on pain. Four RCTs assessed the short-term effects of TENS on pain ^86–89^

A 2010 RCT conducted in Germany by Gschiel and colleagues randomized 45 participants with uni- or bilateral OA of the knee to receive TENS or sham TENS therapy, 30 minutes twice a day for 3 weeks (RoB moderate).^86^ At week 5, no significant difference was observed in WOMAC pain between the active and sham treatment.

A 2012 RCT conducted in Turkey by Atamaz and colleagues randomized 74 participants to TENS or sham TENS treatment 20 minutes per day, 5 times a week for 3 weeks (RoB low).^87^ All participants also participated in an exercise program, 3 times per week for 3 weeks and received a single educational session. At week 4, no between-group differences were seen in VAS pain scores or WOMAC scores.

A 2014 RCT conducted in the UK by Palmer and colleagues randomized 224 participants with knee OA to receive self-administered TENS plus exercise, sham TENS plus exercise, or exercise alone for 6 weeks (RoB low).^88^ All groups received education sessions. The primary outcome was WOMAC function (below). At 6 weeks, a significant between-group difference was seen in WOMAC pain (MD-2.00, 95% CI −3.46, −0.54) between the TENS and the sham TENS groups.

A 2016 RCT conducted in Turkey by Inal and colleagues randomized 93 women with symptomatic knee OA to two weeks (5 sessions per week) of low-frequency TENS, high-frequency TENS, or sham TENS (Unclear RoB).^89^ Although the study authors reported significant improvements in pain immediately after treatment (at 2 weeks), no significant differences were reported in VAS pain at rest or WOMAC pain scores at 6 weeks among the low frequency, high frequency, and sham groups.^89^

A random effects pooled estimate for all four studies showed a small significant effect of TENS treatment on WOMAC pain compared with a sham control that did not exceed the prespecified MCID (pooled effect size −0.31, 95% CI−0.56, −0.06) (Figure 9).

Figure 9 Forest plot for short-term effects of TENS on WOMAC pain score

Figure notes: CI=confidence interval; SMD=standardized mean difference; WOMAC=Western Ontario and McMaster Arthritis Index

Figure 9. Forest Plot for Short-term effects of TENS) on WOMAC pain. This figure lists the included trials by first author name and year in the far left column, then depicts the standardized mean differences and the 95 percent confidence intervals for each trial along a vertical plane as small boxes (with the sizes of the boxes proportional to the number of participants enrolled in the study and the sizes of the confidence intervals shown as horizontal bars). At the base of the stack of boxes is a horizontal diamond that represents the standardized mean difference (SMD). The mean differences and confidence intervals, and SMD are also shown in a column to the right of the figure. The I-squared value for heterogeneity is shown underneath the list of authors.

Short-term effects on function. Three of the RCTs reported short-term effects of TENS on WOMAC function.

At 4 weeks, Atamaz^87^ found no significant difference between groups in WOMAC function scores.

At 6 weeks, Palmer^88^ found no difference in WOMAC function scores for TENS vs sham TENS. The percent of participants in the active TENS group who achieved a clinically significant improvement in function was lower than that for the sham TENS group or the exercise group (RR 1.08, 95% CI 0.69, 1.69).

At 6 weeks, Inal^89^ found no significant difference in WOMAC function between either the high or low-frequency TENS treated and the sham-treated groups.

Short-term effects on other outcomes. At 4 weeks, Gschiel^86^ reported no difference in total WOMAC scores between the TENS and sham-TENS treated groups.

At 6 weeks, Palmer^88^ reported no difference in WOMAC stiffness or total WOMAC scores between TENS and sham-TENS groups.

At 6 weeks, Inal^89^ found no significant difference in WOMAC total scores between either the high or low-frequency TENS treated and the sham-treated groups.

Medium-term effects on pain. Two RCTs reported on medium-term effects on pain.^87, 88^ At 6 months, (4 months after the intervention), Atamaz^87^ reported no between-group differences in VAS pain or WOMAC pain scores.

Palmer^88^ reported no between-group differences in WOMAC pain between active- and sham TENS groups at 6 months.

Medium-term effects on function. Two of the RCTs reported medium-term effects of TENS on WOMAC function.

At 6 months, although improvements persisted from 4 weeks, Atamaz^87^ found no significant difference between groups in WOMAC function scores.

At 6 months, Palmer^88^ found no between-group differences in WOMAC function scores for TENS vs sham TENS.

Medium-term effects on other outcomes. At 6 months, Palmer^88^ reported no difference in WOMAC stiffness or total WOMAC scores between TENS and sham-TENS groups.

#### Pulsed Electromagnetic Field (PEMF)

##### Key Points

- PEMF had a statistically nonsignificant beneficial effect on short-term pain based on a pooled analysis of three RCTs (low SoE).^90–92^
- Evidence is insufficient to assess the effects of PEMF on short-term function or other outcomes.

##### Findings

Studies of PEMF were included if they compared PEMF to sham or to use of analgesics but not to other potential therapeutic agents of unclear efficacy. We identified three RCTs that compared the use of PEMF to that of a sham control.^90–92^ The longest followup times were 42 days and 4 weeks from baseline.

Short-term effects on pain. A 2013 double-blind RCT conducted in the US by Nelson and colleagues randomized 34 patients into two treatment groups: a group that received PEMF and a group that received sham control (RoB low).^90^ Mean maximum VAS pain scores at 14 days’ and 42 days’ followup were significantly decreased from baseline and from that of the control group in the active treatment group (VAS 0–10 scale: MD −1.92, 95% CI −2.35, −1.49) (exceeding a MCID of −0.9).

A 2015 double-blind RCT conducted in Turkey by Dundar and colleagues randomized 40 patients to receive PEMF or sham PEMF; each group also received conventional physical therapy (including hot pack, ultrasound, transcutaneous nerve stimulation (TENS) and isometric knee exercise)(RoB moderate).^91^ At 4 weeks’ followup, no significant difference in VAS or WOMAC pain scores was found between the active and control groups.

A 2016 RCT conducted in Italy by Bagnato and colleagues randomized 66 knee OA patients to receive 1 month of daily PEMF treatment (12 hours per day, usually during sleep). This study found a significant beneficial effect of PEMF on WOMAC pain scores at 1 month compared with a sham control (MD −5.20, 95% CI −9.72, −0.68) (low RoB).^92^

A random effects pooled estimate for all four studies showed a nonsignificant short-term effect of PEMF treatment on VAS pain compared with a sham control; heterogeneity was moderately high (pooled effect size −12.44, 95% CI −34.41, 9.54; I^2^ 76%) (Figure 10).

Figure 10 Forest plot for short-term effects of PEMF on VAS pain score

Figure notes: CI=confidence interval; SMD=standardized mean difference; VAS=Visual Analog Scale

Figure 10. Forest Plot for Short-term effects of PEMF on VAS Pain. This figure lists the included trials by first author name and year in the far left column, then depicts the standardized mean differences and the 95 percent confidence intervals for each trial along a vertical plane as small boxes (with the sizes of the boxes proportional to the number of participants enrolled in the study and the sizes of the confidence intervals shown as horizontal bars). At the base of the stack of boxes is a horizontal diamond that represents the standardized mean difference (SMD). The mean differences and confidence intervals, and SMD are also shown in a column to the right of the figure. The I-squared value for heterogeneity is shown underneath the list of authors.

Short-term effects on function. The Bagnato RCT identified no significant beneficial effect of PEMF on WOMAC function at 1 month, compared with the sham control (MD −8.00, 95% CI −26.32, 10.32).^92^

Short-term effects on other outcomes. The Bagnato RCT identified no beneficial effect of PEMF on WOMAC total scores or on the SF-36 physical domain.^92^

Longer term effects. No studies reported on longer term effects of PEMF.

#### Whole-Body Vibration

##### Key Points

- It is unclear whether WBV has a beneficial effect on patients with knee OA, as pooled analysis showed inconsistent effects on pain and function.
- WBV combined with exercise demonstrated no short-term beneficial effects on pain compared with exercise performed on a stable surface or not combined with WBV, based on three RCTs (low strength of evidence).
- Evidence is insufficient to draw conclusions on short-term effects of WBV on function or other outcomes.
- WBV-based exercise showed no beneficial medium-term effects on pain, based on pooled analysis of four RCTs (low strength of evidence).
- WBV-based exercise showed a small but statistically significant medium-term beneficial effect on WOMAC function, based on pooled analysis of 4 RCTs (n=180; SMD −0.26, 95% CI −0.45, 0.06) (low strength of evidence) that did not meet the MCID of −0.37. However no beneficial medium-term effect was observed on the 6-minute walk, based on pooled analysis of four RCTs (low strength of evidence).

##### Findings

For the current review, we identified seven RCTs that assessed the effects of WBV. The details are described in the evidence table in Appendix C.^93–99^

Short-term effects on pain. We identified three RCTs that assessed the short-term effects of exercise done while undergoing WBV on measures of pain or exercise followed immediately by WBV.^95, 98, 99^

A 2013 RCT conducted in South Korea by Park randomized 44 women age 50 and over to two groups (RoB unclear).^98^ The intervention group received 2 months of WBV (three times per week for 20 minutes each) and was taught a set of exercises to perform at home. The control group received only the home-based exercise instruction. At 2 months, the experimental group reported significantly less NRS-assessed pain than did the control group (MD −2.00, 95% CI −3.77, −0.23).

A 2015 RCT conducted in China by Wang randomized 99 individuals (age 40 to 65) to a strength-training program conducted with WBV or a control strength training program on a stable surface (30 minutes per day, 5 days per week for 6 months) (RoB low).^95^ At 1 month, no significant between-group difference was observed in VAS pain scores (10 cm scale, MD −0.50, 95% CI −1.10, 0.10) or WOMAC pain scores (maximum 20 points, MD −0.45, 95% CI −1.40, 0.50).

A 2016 RCT conducted in Iran by Bokaeian and colleagues randomized 28 individuals with knee OA to 8 weeks of strength training sessions (three sessions per week) followed by WBV or without WBV (High RoB).^99^ At 8 weeks, no significant difference was reported in VAS pain scores between the groups.

Short-term effects on function. One RCT assessed the short term effects of WBV on function.^95^ At 1 month followup, Wang found no between-group differences in WOMAC function scores (maximum 68 points, MD 0.21, 95% CI −2.63, 3.05)

Short-term effects on other outcomes. The study by Park showed that WOMAC total scores decreased in both the WBV plus exercise and exercise-only groups, with no difference between groups (MD −3.36, 95% CI −10.01, 3.29).^98^

Wang^95^ identified no between-group differences at 1 month in performance on the 6-minute walk test (MD −3.14, 95% CI −333.26, 326.98), TUG (MD −0.26, 95% CI −1.2, 0.70) or in SF-36 physical domain scores (MD −1.89, 95% CI −5.03, 1.25).

At 8 weeks, Bokaeian found no significant difference in total WOMAC scores between participants who received WBV after strength training sessions and those who received no WBV.^99^

Medium-term effects on pain. Four RCTs conducted by two groups reported medium-term effects of WBV on pain.^93, 95–97^

A 2011 RCT conducted in Brazil by Avelar randomized 23 adults age 60 and older with knee OA to a 12-week program of strength training (3 times per week for 3 months) conducted with WBV or without WBV on a stable surface (RoB unclear).^93^ At 3 months, no between-group difference was seen in the WOMAC pain score (MD 24.00, 95% CI −60.64, 108.64).

A 2012 RCT conducted in Brazil by Simao randomized 32 individuals, 60 years of age or older, to a strength training program (3 times per week for 3 months) conducted with WBV, a strength training program without WBV, or a no-activity control group (RoB moderate).^97^ At 3 months, neither the WBV group nor the squat training alone group showed differences in WOMAC pain compared with the control group (MD 0.00, 95% CI −98.49, 98.49; MD −25.00, 95% CI −118.39, 68.39, respectively), and they did not differ from each other (MD 25.00, 95% CI −93.83, 143.83).

At 6 months, Wang^95^ reported a significant between-group difference in VAS pain scores (MD −0.71, 95% CI −1.21, −0.21) and in WOMAC pain scores (MD −2.49, 95% CI −3.53, −1.45).

Another RCT by the same group randomized 39 individuals with medial knee OA to a pilot trial of the same program, a strength-training program conducted with WBV or a control strength training program on a stable surface (30 minutes per day, 5 days per week for 4 months) (RoB low).^96^ At 4 months, no between-group differences were observed in VAS pain scores (MD −0.60, 95% CI −1.39, 0.19) or WOMAC pain scores (MD −0.10, 95% CI −2.17, 1.97).

A random effects meta-analysis of WOMAC pain scores for these four RCTs showed no significant improvement in WOMAC pain scores with whole-body vibration compared with a control condition (SMD −0.20, 95% CI −1.12, 0.71) (Figure 11).

Figure 11 Forest plot for medium-term effects of whole body vibration on WOMAC pain score

Figure notes: CI=confidence interval; SMD=standardized mean difference; WOMAC=Western Ontario and McMaster Arthritis Index

Figure 11. Forest Plot for Medium-term effects of Whole Body Vibration on WOMAC Pain. This figure lists the included trials by first author name and year in the far left column, then depicts the standardized mean differences and the 95 percent confidence intervals for each trial along a vertical plane as small boxes (with the sizes of the boxes proportional to the number of participants enrolled in the study and the sizes of the confidence intervals shown as horizontal bars). At the base of the stack of boxes is a horizontal diamond that represents the standardized mean difference (SMD). The mean differences and confidence intervals, and SMD are also shown in a column to the right of the figure. The I-squared value for heterogeneity is shown underneath the list of authors.

Medium-term effects on function. At 3 months, the 2011 RCT by Avelar reported no between-group difference in WOMAC function scores (MD −59.00, 95% CI −373.43, 255.43).^93^

The 2012 RCT by Simao also reported no differences between the WBV group and the exercise only group in WOMAC function (MD −122.50, 95% CI −551.90, 306.90) and no between-group differences (MD −122.5, 95% CI −551.9, 306.9).^97^

At 6 months, Wang^95^ reported no between-group difference in WOMAC function scores (MD −2.63, 95% CI −5.63, 0.37) and a small but significant improvement in Lequesne scores (MD −1.19, 95% CI −2.30, −0.08).

At 4 months, Wang^96^ reported no between-group differences in WOMAC function scores in the participants with medial knee OA (maximum WOMAC function score 68 points, MD −0.60, 95% CI −4.78, 3.58).

A random effects meta-analysis of WOMAC function scores for these four RCTs showed a small but significant improvement with whole-body vibration compared with a control condition (n=180, SMD −0.26, 95% CI −0.45, −0.06 (Figure 12).

Figure 12 Forest plot for medium-term effects of whole body vibration on WOMAC function score

Figure notes: CI=confidence interval; SMD=standardized mean difference; WOMAC=Western Ontario and McMaster Arthritis Index

Figure 12. Forest Plot for Medium-term effects of Whole Body Vibration on WOMAC Function. This figure lists the included trials by first author name and year in the far left column, then depicts the standardized mean differences and the 95 percent confidence intervals for each trial along a vertical plane as small boxes (with the sizes of the boxes proportional to the number of participants enrolled in the study and the sizes of the confidence intervals shown as horizontal bars). At the base of the stack of boxes is a horizontal diamond that represents the standardized mean difference (SMD). The mean differences and confidence intervals, and SMD are also shown in a column to the right of the figure. The I-squared value for heterogeneity is shown underneath the list of authors.

Medium-term effects on other outcomes. At 3 months, Avelar reported no significant between-group differences in the 6-minute walk test or the TUG between the WBV group and the stable strength training group.^93^

Simao reported no significant between-group differences in WOMAC stiffness scores or the 6-minute walk test between the WBV group and the control (MD −8.00, 95% CI −56.10, 40.10) and no between-group differences.^97^

At 6 months, Wang^95^ reported a significant between-group difference in the 6-minute walk (MD −77.07, 95% CI −119.18, −34.96) and the TUG (MD −3.01, 95% CI −3.92, −2.10).

A 2015 RCT conducted in Italy by Rabini and colleagues randomized 50 adults (age 60 or over) to receive focal muscle vibration or a sham treatment, 3 treatments per day for 3 days (RoB low).^94^ At 6 months’ follow-up, significant between-group differences were observed in total WOMAC scores (MD −19.04, 95% CI −27.43, −10.65).

A random effects meta-analysis of 6-minute walk distances for these four RCTs showed no significant improvement in distances walked with whole-body vibration compared with a control condition; heterogeneity was moderately high (n=180; MD −31.17, 95% CI − 82.60, 20.26; I^2^ 76%) (Figure 13).

Figure 13 Forest plot for medium-term effects of whole body vibration on 6-minute walk distance

Figure notes: CI=confidence interval; MD=mean difference;

Figure 13. Forest Plot for Medium-term effects of Whole Body Vibration on 6-minute Walk Distance. This figure lists the included trials by first author name and year in the far left column, then depicts the standardized mean differences and the 95 percent confidence intervals for each trial along a vertical plane as small boxes (with the sizes of the boxes proportional to the number of participants enrolled in the study and the sizes of the confidence intervals shown as horizontal bars). At the base of the stack of boxes is a horizontal diamond that represents the standardized mean difference (SMD). The mean differences and confidence intervals, and SMD are also shown in a column to the right of the figure. The I-squared value for heterogeneity is shown underneath the list of authors.

#### Orthoses (Knee Braces, Shoe Inserts, and Specially Designed Shoes)

##### Key Points

- It is unclear whether knee braces or other orthoses have a beneficial effect on patients with knee OA. Only a small number of RCTs on braces were identified, and studies of shoe inserts and specially designed shoes showed inconsistent effects across time points and outcomes.
- Knee Braces: Evidence was insufficient to determine whether custom knee braces had significant beneficial effects on any outcomes.
- Shoe Inserts showed no consistent beneficial effects across outcomes or follow-up times.
  ○ Custom shoe inserts had no consistent beneficial short-term effects on pain (based on four RCTs), function (three RCTs), or WOMAC total scores (pooled analysis of three RCTs) (low strength of evidence).
  ○ Shoe inserts showed no statistically significant beneficial effects on medium-term WOMAC pain (based on pooled analysis of three RCTs) or medium-term function (based on four RCTs) (low strength of evidence).
  ○ Evidence was insufficient to determine long-term effects of shoe inserts on pain, but they showed no benefit for long-term function (low strength of evidence).
- Custom shoes: Evidence was insufficient to assess medium- or long-term effects on pain or function.
- Cane Use: Insufficient evidence exists to assess the benefit of cane use on pain, physical function, and quality of life.

##### Findings

For the current report, we identified three RCTs on braces, eight RCTs on shoe inserts,, four RCTs on footwear, and one RCT on cane use that met inclusions criteria. The details are described in the evidence table in Appendix C.

###### Braces

Short-term effects on pain. A 2015 RCT conducted in the UK by Callaghan and colleagues randomized 126 individuals (40–70 years) with patellofemoral OA to the use of a patellar tracking brace or no brace daily for 6 weeks (brace use averaged 7 hours per day) (RoB moderate).^100^ At 6 weeks, significant between-group differences were seen in pain measured using the VAS (0–10 cm) (MD −1.30, 95% CI −2.01, −0.59) and the KOOS (MD −5.70, 95% CI −10.76, −0.64).

Medium-term effects on pain. A 2015 RCT conducted in the US by Cherian and colleagues randomized 59 adults with moderate to severe (end-stage) knee OA to a custom pneumatic brace or to usual care; the brace group also underwent gait training 3 times a week for 6 weeks (RoB unclear).^101^ At 3 months, a significant decrease in VAS pain (0–10cm scale) was observed in the brace group compared with the TAU group (MD −2.30, variance not reported).

Long-term effects on pain. A 2011 RCT conducted in Iran by Sattari and Ashraf randomized 60 patients with medial compartment knee OA (35–65 years of age) to receive a custom 3-point valgus knee support, or lateral wedge insoles, or TAU (RoB unclear).^102^ At 9 months, significant differences were seen in VAS pain scores between the brace group and the TAU group favoring the braces (MD −2.80, 95% CI −3.58, −2.02). Among the brace group, 17 of 20 reported significant pain relief.

###### Shoe Inserts

Short-term effects on pain. Four RCTs assessed the short-term effects of orthoses on pain.^103–106^

A 2008 RCT conducted in Brazil by Rodrigues that was cited in the 2012 SR but whose data were not included in the analyses randomized 30 women with valgus knee OA to receive and wear a medial 8-mm insole or a neutral insole for 8 weeks (RoB moderate).^103^ At 8 weeks, significant between-group differences were seen in VAS pain with movement (MD −2.20, 95% CI −4.04, −0.36) but not at rest.

A 2009 RCT conducted in Turkey by Koca randomized 37 women with moderate knee OA to receive and wear 6mm wedge insoles or no insoles. Both groups attended an exercise program (RoB unclear).^104^ At 1 month, significant between-group differences were observed in WOMAC pain (MD −3.14, 95% CI −5.96, −0.32) but not in VAS pain at rest or during movement.

A 2014 RCT conducted in Iran by Hatef randomized 118 adults with mild to moderate medial knee OA to wear lateral wedged insoles (5 degrees) or neutral wedged insoles for 2 months (RoB moderate).^105^ At 2 months, pain measured on a 0–100mm VAS showed significant between-group differences (MD−23.05, 95% CI −28.34, −17.76); pain reduction was significant in women but not in men. The likelihood of experiencing a reduction in pain to mild (RR 0.13, 95% CI 0.05, 0.36) or none (RR 0.23, 95% CI 0.03, 2.03) was also assessed and found to be greater in the lateral wedge group.

A 2015 RCT conducted in Brazil by Campos randomized 58 adults with medial knee OA to wear lateral wedge insoles with subtalar strapping or a neutral wedge insole with strapping, bilaterally, for 6 months (RoB low).^106^ At 2 months, no between-group differences were seen in VAS pain or WOMAC pain measures.

Short-term effects on function. Three RCTs were identified that assessed short-term effects of insoles on function.

At 2 months, Rodrigues’ RCT showed a nonsignificant between-group difference in function, as assessed using the Lequesne test (however, the between-group difference in improvements from baseline to followup was significant, p<0.002).^103^ In addition, 100 percent of participants in the medial insole group showed clinically meaningful improvements in function, compared with 78.5 percent of the neutral insole group (RR 0.79, 95% CI 0.59, 1.06).

At 1 month, the 2009 RCT by Koca showed a significant between-group difference in WOMAC function scores in favor of the insole group (MD −10.06, 95% CI −19.68, −0.44).^104^

At 2 months, Campos reported no between-group differences in Lequesne scores.^106^

Short-term effects on other outcomes. Three RCTs assessed the effects of insoles on total WOMAC scores.

Rodrigues reported no between-group differences in total WOMAC scores at 2 months.^103^ At 1 month, Koca found a significant impact of insole wear on total WOMAC scores (total possible scores not reported) (MD −15.16, 95% CI −28.42, −1.90).^104^ At 2 months, Campos also reported no between-group differences in total WOMAC scores.^106^

A random-effects meta-analysis of the three trials showed no significant short-term effect of orthotic use on WOMAC total scores (n=131; SMD −0.37, 95% CI −1.26, 0.53) (Figure 14).

Figure 14 Forest plot for short-term effects of orthotics on WOMAC total score

Figure notes: CI=confidence interval; SMD=standardized mean difference; WOMAC=Western Ontario and McMaster Arthritis Index

Figure 14. Forest Plot for the Short-term effects of Orthotics WOMAC total. This figure lists the included trials by first author name and year in the far left column, then depicts the standardized mean differences and the 95 percent confidence intervals for each trial along a vertical plane as small boxes (with the sizes of the boxes proportional to the number of participants enrolled in the study and the sizes of the confidence intervals shown as horizontal bars). At the base of the stack of boxes is a horizontal diamond that represents the standardized mean difference (SMD). The mean differences and confidence intervals, and SMD are also shown in a column to the right of the figure. The I-squared value for heterogeneity is shown underneath the list of authors.

Medium-term effects on pain. Three RCTs assessed the medium-term effects of insole wear on pain.^104, 106, 107^

At 6 months, Campos found no between-group differences in WOMAC or VAS pain scores.^106^

At 3 months, Koca found no between-group differences in any measure of pain using the VAS but did find a small significant difference in favor of the wedge insole for WOMAC pain (MD −4.02, 95% CI −6.79, −1.25). ^104^

A 2006 RCT conducted in the US as a dissertation project by Wallace randomized 36 adults age 30 or older with moderate-to-severe medial knee OA to wear a lateral 7-degree wedge insole or a neutral insole for 3 months (RoB unclear).^107^ At 3 months, Wallace reported a significant between-group difference in VAS pain on descending stairs (0–100mm scale; MD −15.10, 95% CI −25.69, −4.51) but no differences in walking pain or WOMAC pain scores.

A random-effects meta-analysis of the three trials showed no significant medium-term effect of orthotic use on WOMAC pain scores; heterogeneity was moderate (n=131; SMD −0.48, 95% CI −1.64; 0.69; I^2^ 58%) (Figure 15).

Figure 15 Forest plot for medium-term effects of orthotics on WOMAC pain score

Figure notes: CI=confidence interval; SMD=standardized mean difference; WOMAC=Western Ontario and McMaster Arthritis Index

Figure 15. Forest Plot for the Medium-effects of Orthotics on WOMAC pain. This figure lists the included trials by first author name and year in the far left column, then depicts the standardized mean differences and the 95 percent confidence intervals for each trial along a vertical plane as small boxes (with the sizes of the boxes proportional to the number of participants enrolled in the study and the sizes of the confidence intervals shown as horizontal bars). At the base of the stack of boxes is a horizontal diamond that represents the standardized mean difference (SMD). The mean differences and confidence intervals, and SMD are also shown in a column to the right of the figure. The I-squared value for heterogeneity is shown underneath the list of authors.

Medium-term effects on function. Four RCTs assessed medium-term effects of insoles on function.^104, 106–108^

At 3 months, Koca reported a significant between-group difference in WOMAC function in favor of the lateral insoles (MD −11.78, 95% CI −21.18, −2.38).^104^

Wallace found no significant difference in WOMAC function scores at 3 months.^107^

A 2006 RCT conducted in Japan by Toda and Tsukimura that randomized 61 women with varus deformity knee OA to lateral wedged insoles with subtalar strapping or traditional in-shoe wedged insoles for 2 years found no between-group difference in function as assessed at 6 months using the Lequesne tool (RoB moderate).^108^

At 6 months, the RCT by Campos also found no between-group differences in Lequesne function measures between the lateral-wedged insole group and the neutral insole group.^106^

Medium-term effects on other outcomes. At 3 months, Koca reported a significant between-group difference in WOMAC total scores in favor of the lateral insoles (MD −17.68, 95% CI −30.37, −4.99).^104^

Long-term effects on pain. Two RCTs assessed long-term effects of insoles on pain.^102, 109^

A 2011 RCT conducted by Bennell and colleagues in Australia randomized 200 individuals 50 and over with knee OA to a 5-degree lateral wedged insole or a neutral insole to be worn daily 12 months (RoB low). The authors reported no between-group differences in WOMAC pain at 12 months, and the decreases did not achieve minimum clinically important difference.^109^

The 2011 RCT by Sattari that assessed the effects of a knee brace on pain also assessed the effects of lateral wedged insoles compared with the control group.^102^ At 9 months, the group assigned insoles had a significant improvement in VAS pain compared with the control group (MD −1.60, 95% CI −2.31, −0.89).

Long-term effects on function. Two RCTs assessed long-term effects of insoles on function. ^108, 109^

The 2006 RCT conducted by Toda compared the effects of the wedge with subtalar strapping to that of the shoe insert on Lequesne-assessed function at 2 years. Although the group that wore the insole with the subtalar strap showed a small but significant improvement in function from baseline, the group that wore the inserted insole did not. No significant between-group differences were observed.^108^

The 2011 RCT by Bennell assessed WOMAC function as a secondary outcome, finding no between-group differences at 1 year.^109^

###### Footwear

For the current review, we identified five RCTs that assessed the effects of therapeutic footwear on measures of pain or function.

Short-term effects on pain, function, and other outcomes. No studies that met inclusion criteria assessed short-term effects of footwear on outcomes of interest.

Medium-term effects on pain. Four RCTs were identified that assessed medium-term effects of footwear on pain.^110–113^ Only two studies reported usable data.^112, 113^

A 2013 RCT conducted in Brazil by Goldenstein-Schainberg and colleagues randomized 24 women with moderate knee OA to wear flexible, nonheeled (“minimalist”) Moleca® footwear or normal footwear for at least 6 hours a day for 6 months (RoB unclear).^110^ No data were provided in the conference proceedings that reported the findings. A significant between-group difference was seen in WOMAC pain scale scores at 6 months in favor of the minimalist shoe (p=0.01).

A second 2013 RCT conducted in Brazil by the same group randomized 28 women to the minimalist shoe or normal footwear for the same time period (RoB unclear).^111^ At the end of 6 months, a between-group difference was seen in decreases in WOMAC pain scores favoring the minimalist shoe (MD −44.00, variance not reported).

A 2015 RCT conducted in Brazil by the same group randomized 56 women (60 to 80 years of age) with moderate knee OA to wear flexible, nonheeled (“minimalist”) Moleca® footwear or normal footwear for at least 6 hours a day for 6 months (RoB low).^112^ At 6 months, a significant between-group difference was observed in WOMAC pain (MD −38.60, 95% CI, −41.22, −35.98).

A 2010 RCT conducted in the US by Erhart and colleagues randomized 79 adults with medial knee OA to wear a variable stiffness walking shoe or a constant stiffness shoe bilaterally for 6 months (RoB moderate).^113^ The between-group difference in mean WOMAC pain scores did not achieve statistical significance. The proportion of patients in the intervention group who met the MCID was significantly greater than that of the control group (RR 0.49, 95% CI 0.31, 0.79).

Medium-term effects on function. The 2015 RCT by Trombini-Souza found a significant between-group difference in WOMAC function (68-point scale, MD −43.8, 95% CI −52.70, −34.90) and Lequesne scores (24-point scale, MD −4.20, 95% CI −6.29, −2.11) at 6 months, favoring the minimalist footwear.^112^

Medium-term effects on other outcomes. Two RCTs reported medium-term effects of shoes on other outcomes,^112, 113^ although only one reported the actual data.^112^

The 2010 RCT by Erhart reported no significant between-group difference in WOMAC total scores at 6 months.^113^

The 2015 RCT by Trombini-Souza found a significant beneficial effect of the intervention on WOMAC total scores (0–96 point scale, MD −43.20, 95% CI −55.77, −30.63) but no significant between-group differences in 6-minute walk distances.^112^

Long-term effects on pain. One RCT was identified that assessed long-term effects of a therapeutic shoe on pain.^114^

In a follow-up to their assessment of variable-stiffness walking shoes,^113^ Erhart and colleagues assessed the effects of the shoes on pain at 1 year (RoB 8/10).^114^ WOMAC pain scores were significantly decreased from baseline for both groups, with no significant between-group differences (MD −1.00, variance not reported). Disease severity, as indicated by K-L score, did not affect response to the intervention.

###### Canes

One 2012 RCT conducted in Brazil by Jones randomized 64 patients with knee OA to 2 months of daily cane use or no cane use (RoB low).^115^ At 2 months, a significant between-group difference in VAS pain (0–10cm, MD −2.11, 95% CI −2.83, −1.39) was observed, favoring cane use. Significant between–group improvements were also seen in Lequesne assessments of function (MD −2.34, 95% CI −4.34, −0.72) and SF-36 physical domain scores (0–100 points, MD −9.06, 95% CI −17.81, −0.31), but not WOMAC total scores (0–96 points, MD −1.06, 95% CI −8.87, 6.75).

#### Manual Therapy (Including Massage and Acupressure)

##### Key Points

- It is unclear whether manual therapies have any benefit for patients with knee OA beyond the effects of exercise alone. Across nine RCTs, benefits were inconsistent across time points and outcomes. Pooled analysis showed no statistically significant effect on short term pain, although a clinically important effect could not be ruled out, due to the wide 95% confidence intervals.
- Manual therapy showed no statistically significant beneficial short-term effects on pain compared with treatment as usual, based on pooled analysis of three RCTs and four additional RCTs (low strength of evidence).
- Manual therapy showed no consistent beneficial effects on short-term function, based on four RCTs (low strength of evidence).
- Insufficient evidence was found to assess medium-term effects of manual therapy on pain, function, and other outcomes, based on four RCTs.
- Manual therapy had a small beneficial effect on long-term pain of borderline significance when combined with exercise, compared with exercise alone, based on two studies that conducted 12-month follow-up of three-month interventions (low strength of evidence).
- Evidence was insufficient to assess effects on long-term function.

##### Findings

We identified nine RCTs that assessed the effects of manual therapy techniques, including massage and acupressure, (alone or combined with exercise programs). The details are described in the evidence table in Appendix C.

Short-term effects on pain. Seven RCTs reported on short-term effects of different manual therapies on pain: passive joint mobilization, self-manual therapy (with exercise), acupressure, and combined manipulation and passive mobilization with physical therapy/exercise.^67, 116–121^ Because of the differences in interventions and outcome measures, only the results of three RCTs were pooled.

A 2011 RCT conducted in Malaysia by Azlin randomized 22 adults 40 years and older to passive joint mobilization plus their regular exercise or to exercise alone, two sessions per week for 4 weeks (RoB high).^116^ Among the 13 completers, at 4 weeks, both groups experienced pain relief (improvement in VAS scores) at 4 weeks, and no difference was seen between groups (MD −2.99, 95% CI −21.54, 15.56).

A 2014 RCT conducted in the US by Perlman and colleagues randomized 125 individuals to one of five 8-week interventions, comprising 30- or 60-minute weekly or bi-weekly massages or a TAU group (RoB moderate).^121^ At 8 weeks, participants who got two 30-minute massages per week (MD −16.30, 95% CI −30.17, −2.43) and those who received one or two 60-minute massages per week (MD −30, 95% CI −42.09, −17.91) (MD −21.40, 95% CI −33.42, −9.38 ) had significantly improved VAS pain scores compared with the TAU group but the 30-minute per week massage group did not (MD −4.40, 95% CI −18.27, 9.47). Participants who received one or two 60-minute massages per week (MD −21.60, 95% CI −33.47, −9.73; MD −22.10, 95% CI −33.89, −10.31) had significantly improved WOMAC pain scores compared with the TAU group but the 30-minute once or twice per week massage groups did not (MD −9.50, 95% CI −20.69, 1.69) (MD 3.60, 95% CI −8.70, 15.90 ).

A 2014 RCT conducted in Thailand by Cheawthamai randomized 43 women to a 12-week home-based self-manual therapy and exercise program or exercise alone (RoB moderate).^117^ At 4 weeks, both groups showed improved KOOS pain scores but no significant difference was observed between the groups.

A 2012 pilot RCT conducted in the US by Zhang randomized 36 postmenopausal women to a 12-week self-administered acupressure program (with a training module) or to treatment as usual (RoB moderate).^119^ At 6 weeks, no significant differences were seen in WOMAC pain scores between the two groups (MD −1.15, 95% CI −3.45, 1.15).

A 2014 RCT conducted in Spain by Godoy randomized 18 women to a 6-week intervention comprising either a combination of massage therapy and exercise or exercise alone (RoB low).^118^ At 1-month followup, no differences were observed between groups in VAS pain scores (MD 3.10, 95% CI 0.76, 5.44).

A 2015 two-site pilot RCT conducted in South Africa and the US by Dwyer randomized 83 individuals to one of three 4-week interventions: manual and manipulative therapy (MMT) alone, rehabilitation (rehab, a physical therapist-directed exercise program) alone, and MMT plus rehab (RoB moderate).^120^ At 6 weeks from baseline, participants in the MMT plus rehab group had decreases in WOMAC pain scores (less pain) that did not differ significantly from those of the group that received rehab alone (MD −26.90, 95% CI −68.88, 15.08) using a WOMAC scoring system with a maximum of 500 points).

A 2016 RCT conducted in New Zealand by Fitzgerald randomized 300 patients with knee OA to one of four interventions: 9 weeks exercise alone, 9 weeks exercise plus manual therapy delivered by a physical therapist, or the same two interventions with 8 booster sessions over the subsequent 10 months (Low RoB).^67^ At 9 weeks, no differences were seen in pain scores between the exercise only group and the group that received the exercise plus manual therapy.

A random-effects meta-analysis of three of the trials^119–121^ showed no significant effect of manual therapy (administered by a therapist or by patients themselves) on short-term WOMAC pain (n=137; SMD −0.57, 95% CI −1.60, 0.45) (Figure 16).

Figure 16 Forest plot for short-term effects of massage or acupressure on WOMAC pain score

Figure notes: CI=confidence interval; SMD=standardized mean difference; WOMAC=Western Ontario and McMaster Arthritis Index

Figure 16. Forest Plot for Short-term effects of Massage or Acupressure on WOMAC pain. This figure lists the included trials by first author name and year in the far left column, then depicts the standardized mean differences and the 95 percent confidence intervals for each trial along a vertical plane as small boxes (with the sizes of the boxes proportional to the number of participants enrolled in the study and the sizes of the confidence intervals shown as horizontal bars). At the base of the stack of boxes is a horizontal diamond that represents the standardized mean difference (SMD). The mean differences and confidence intervals, and SMD are also shown in a column to the right of the figure. The I-squared value for heterogeneity is shown underneath the list of authors.

Short-term effects on function. At 6 weeks, both Zhang and Dwyer reported no significant between-group differences in WOMAC function scores at 6 weeks (MD −3.40, 95% CI −12.56, 5.76 and MD −32.80, 95% CI −191.40, 125.80, using a 1700-point tool, respectively).^119, 120^

At 8 weeks, Perlman reported significant improvements in WOMAC function compared with TAU in the groups who received one 30-minute massage per week (MD −11.40, 95% CI −20.90, −1.90) or one or two 60-minute massages per week (MD −14.60, 95% CI−24.50, −4.70 ) (MD −15.40, 95% CI −26.48, −4.32) but not in the group that received two 30-minute massages per week (MD−10.60, 95% CI −21.76, 0.56).

Short-term effects on other outcomes. Five RCTs reported short-term effects on other relevant outcomes.^67, 117–120^

Zhang reported no significant difference between treatment groups in WOMAC total scores (MD −5.51, 95% CI −16.97, 5.95).^119^ Dwyer also reported no significant differences between groups in WOMAC total score (MD −63.20, 95% CI −273.72, 147.32).^120^ Godoy reported no between-group differences in total WOMAC score (MD 21.42, 9.79, 33.05) or TUG (MD 3.94, 95% CI −4.01, 11.89).^118^

Perlman reported differences in total WOMAC scores between the groups who received massages for 30 minutes, twice a week (MD −12.10, 95% CI −23.31, −0.89) and 60 minutes, once a week (MD −17.70, 95% CI −28.02, −7.38) and treatment as usual but not those who received one 30-minute massage or two 60-minute massages per week.^121^

Godoy reported no between-group differences in TUG (MD 3.94, 95% CI −4.01, 11.89).^118^

Cheawthamai reported no significant between-group differences in the 6-minute walk test and the SF-36 physical functioning domain.^117^

Fitzgerald reported significant improvements in WOMAC total scores (MD −4.50, 95% CI −8.66, −0.34) and in TUG scores (MD −0.20, 95% CI −0.36, −0.04) at 9 weeks in the group that received both exercise and manual therapy compared with the group that received exercise alone.^67^

Medium-term effects on pain. A 2013 RCT conducted in the US by Atkins and Eichler randomized 40 adults (age 50 and over) with knee OA to 8 weeks of supervised self-massage and 4 weeks of unsupervised self-massage or to a waiting list control group (RoB unclear).^122^ At the end of the intervention, a significant between-group difference was observed in WOMAC pain scores (MD −0.65, variance not calculable).

At 3-months’ followup, the Godoy RCT found no differences between groups in VAS pain scores (MD 2.28, 95% CI 0.44, 4.12).^118^ At 12 weeks, Zhang reported no between-group differences in WOMAC pain scores (MD −1.88. 95% CI −10.58, 6.82).^119^ At 6 months, Perlman reported no differences in WOMAC pain between groups who received one or two massages per week and the TAU group.^121^

Medium-term effects on function. At 3 months, Zhang reported no between-group differences in WOMAC function scores (MD −1.88. 95% CI −10.58, 6.82).^119^ At 6 months, Perlman reported no differences in WOMAC function scores between groups who received one or two massages per week and the TAU group.^121^ At 3 months, Atkins reported a significant difference in WOMAC function scores (MD −0.80, variance not reported).^122^

Medium-term effects on other outcomes. At 3 months, Zhang reported no between-group differences in WOMAC stiffness or total scores.^119^ Also at 3 months, Atkins reported significant between-group differences in WOMAC stiffness (MD −0.8, no variance reported) and total WOMAC (MD −0.7, no variance reported) scores.^122^ At 6 months, Perlman reported no differences from TAU in WOMAC total among any of the massage groups.^121^

Godoy reported no differences in TUG at 3 months (MD 14.04, 95% CI 4.71, 23.37).^118^

Long-term effects on pain. A 2015 pilot RCT conducted in New Zealand by Abbott and colleagues randomized 75 participants to one of four interventions: 12 sessions of exercise alone (9 weeks), 8 sessions of exercise (9 weeks) plus 4 additional sessions over the ensuing 8 months, exercise plus 12 sessions of manual therapy, or exercise plus extra sessions plus manual therapy (RoB moderate).^65^ At one year, compared with the exercise-only group, the group that received exercise plus manual therapy had significantly improved pain intensity scores compared with the group that received exercise alone (MD −2.30, 95% CI −4.07, −0.53).

At 12 months, the 2016 Fitzgerald RCT, conducted by the same research team that conducted the 2015 pilot RCT by Abbott, found a small improvement in pain of borderline significance among the participants who received 2 months of both exercise and manual therapy compared with exercise alone (MD −0.20, 95% CI −0.36, −0.04) as well as among those who received exercise plus booster sessions plus manual therapy (MD −0.70, 95% CI −0.90, −0.50).

Long-term effects on other outcomes. At 12 months, the Fitzgerald RCT found no difference in WOMAC total (the primary outcome measure) between the participants who received 2 months of both exercise and manual therapy compared with exercise alone as well as between those who received exercise plus booster sessions plus manual therapy and those who received only exercise and booster sessions. However, manual therapy significantly improved TUG scores in the exercise group (MD −0.30, 95% CI −0.46, −0.14) compared with exercise alone.

#### Weight Loss

##### Key Points

- Weight loss with or without exercise has a beneficial effect on medium-term pain and function and on long-term pain but inconsistent effects across studies on long-term function and quality of life.
  ○ Evidence was insufficient to assess short-term effects of dieting, with or without exercise on pain and function,.
  ○ Weight loss had a significant beneficial effect on medium-term pain, based on two RCTs and four single-arm trials. One single-arm trial assessed and reported a dose-response effect between weight and outcomes of interest (moderate-level evidence).
  ○ Weight loss had a significant beneficial effect on medium-term function, based on two RCTs and three single-arm trials (low strength of evidence).
  ○ Weight loss had a significant long-term beneficial effect on pain based on three RCTs and one single-arm trial (low level of evidence) but inconsistent effects on function and quality of life, based on two RCTs (low strength of evidence).

##### Findings

We identified five RCTs^123–127^ and five single-arm trials ^68, 128–132^ reported in six publications that reported on the effects of weight loss trials among individuals with knee OA on outcomes of interest.^123–127^ The details are described in the evidence table in Appendix C.

###### Randomized Controlled Trials

Short-term effects on pain. One trial reported on short-term effects of a weight-loss trial on outcomes of interest. A 2008 RCT conducted in Tunisia by Ghroubi and coworkers randomized 45 obese adults (BMI>35 or between 30 and 35 with one cardiovascular risk factor) and radiographic OA of the knee to an aerobic and strength training program (exercise) alone, diet plus exercise, diet alone, or a no diet/no exercise control (RoB unclear).^123^ At 8 weeks, the diet plus exercise group had lost significantly more weight than the other groups, followed by the diet only group, and then the exercise only group (the control group lost no weight). The diet + exercise group showed a significant between-group difference in VAS pain (1–10cm, MD −4.56, 95% CI −5.82, −3.30) compared with the control, as did the diet alone group (MD −2.10, 95% CI −3.32, −0.88); the exercise only group also showed improvement in pain compared with the control (MD −2.90, 95% CI −4.52, −1.28).

Short-term effects on function. The RCT by Ghroubi assessed the effects of diet with or without exercise on three measures of function.^123^ All three active treatment groups showed comparable improvements in WOMAC function scores (exercise only: MD, −3.09 95% CI −4.46, −1.72; exercise+diet: MD −4.01, 95% CI −5.56, −2.46; diet only: MD −2.34, 95% CI −3.71, −0.97) and Lequesne scores (exercise only: MD −2.41, 95% CI −3,52, −1.30; exercise+diet: MD −3.73, 95% CI −4.65,−2.81; diet only: MD −2.23, 95% CI −3.30, −1.16) compared with the control.

The proportion of participants who achieved a significant improvement in WOMAC function was greater in each of the active treatment groups compared with the control group (exercise only RR 0.23, 95% CI 0.02, 2.23; exercise+diet: RR 0.16, 95% CI 0.02, 1.39; diet only: RR 0.33, 95% CI 0.03, 3.43).

Short-term effects on other outcomes. The Ghroubi RCT found that exercise alone (MD −39.00, 95% CI −46.47, −31.53) and exercise+diet (MD −53.00, 95% CI −59.33, −46.67) significantly improved 6-minute walk distances but diet alone (MD 2.00, 95% CI −6.51, 10.51) did not.^123^

Medium-term effects on pain. Two RCTs assessed the effects of weight loss on medium-term pain.^124, 127^

A 2006 U.S. RCT, the Physical Activity, Inflammation, and Body Composition Trial, randomized 87 obese adults over 60 years to a 6-month intensive weight loss group or a weight maintenance group; the weight loss goal was a 10% body weight loss (RoB moderate).^124^ At 6 months, the weight loss group had lost an average of 8.3±0.8 kg and decreased an average of 8.1±0.7 BMI units (compared with 0.1±0.7 kg and 0.3±0.9 BMI units in the control group). WOMAC pain scores showed a significant between-group difference in favor of the weight loss group (MD −2.00, 95% CI −3.25, −0.75).

The OA Life Study was a 2012 U.S. RCT that randomized 232 obese adults with knee OA to receive standard care, a pain coping skills training (PCST) program, a behavioral weight management (BWM) program alone, or both interventions (RoB moderate).^127^ Both the BWM and BWM+PCST groups had significant weight losses compared with the standard care group; only the BWM+PCST group had a significant decrease in BMI compared with standard care (MD −1.80, 95% CI −2.44, −1.16). No difference was observed in WOMAC pain between the BWM group and the standard care group (MD −2.50, 95% CI −7.67, 2.67), but a significant between-group difference was seen between BWM+PCST and the standard care group (MD −10.80, 95% CI −15.77, −5.83).

Medium-term effects on function. Two RCTs assessed the effects of weight loss on WOMAC function.

The Physical Activity, Inflammation, and Body Composition Trial found a significant between- group difference in WOMAC function between the weight loss and weight maintenance groups, favoring the weight loss group.^124^

The OA Life Study observed a significant difference in WOMAC function between the PCST+BWM group and the standard care group (MD −12.40, 95% CI −17.29, −7.5) but no significant difference between the BWM-only group (which achieved lower weight loss than the PCST+BWM group) and the standard care group (MD−1.50, 95% CI −6.46, 3.46).^127^

Medium-term effects on other outcomes. The Intensive Diet and Exercise for Arthritis (IDEA) Trial is a 2013 U.S. RCT that randomized 454 overweight and obese adults (BMI 27–41) with knee OA to an intensive diet and exercise-based weight loss program, diet alone, or exercise alone (exercise was considered part of standard care) (RoB moderate).^125^ At 6 months, neither diet alone nor diet plus exercise affected scores for the 6-minute walk or the physical domain of the SF-36.

The 2006 Physical Activity, Inflammation, and Body Composition Trial found a significant between-group difference in the distance walked in the 6-minute walk test (MD −51.00, 95% CI −96.03, −5.97) and in WOMAC total scores (scale not reported, MD −10.70, 95% CI −17.01, −4.39).^124^

Long-term effects on pain. A 2011 publication reported on a 2005 RCT conducted in Denmark by Bliddall and colleagues that had randomized 89 knee OA patients to an intensive weight loss program (6 weeks of an intensive low energy diet [LED], along with group counseling) or a control group (moderate calorie restriction and education only); at 1-year, the researchers followed up on the 80 retained patients (RoB moderate).^126^ The LED group had lost significantly more weight than the control group (kg, MD −7.30, 95% CI −9.52, −5.08), and was experiencing significantly less pain than the control group, as assessed on the WOMAC scale (0–100 points, MD −7.20, 95% CI −13.30, −1.10). The primary endpoint, WOMAC total score, is reported below.

In the IDEA Trial, at 18 months, weight loss was slightly but significantly greater in the diet+exercise group than in the diet-only group, compared with the exercise-only group (MD −8.10, 95% CI −11.92, −4.28 versus MD −6.00, 95% CI −9.75, −2.25). Primary outcomes were knee-joint loading and interleukin-6 levels. The diet+exercise group experienced a nonsignificantly greater improvement in WOMAC pain measures than the exercise-only group (20 pts total, MD −0.70, 95% CI −1.41, 0.01), and the diet only group showed no difference in WOMAC pain measures.^125^

At 18 months, the OA Life Study showed that patients in the PCST+BWM group continued to experience less pain than the standard care group (MD −14.00, 95% CI −24.77, −3.23, although all groups had regained some of the lost weight (no statistics reported).^127^

Long-term effects on function. Bliddall found no significant between-group differences in WOMAC function in their diet study.^126^

The IDEA trial reported a significant between-group difference in WOMAC function for the diet+exercise group compared with the exercise only group (MD −3.40, 95% CI −6.02, −0.78); the diet-only group did not differ from the exercise-only group.^125^

Long-term effects on other outcomes. Bliddall found no significant between-group differences in WOMAC total in their diet study.^126^

The IDEA trial reported significant between-group differences in 6-minute walk test performance (meters walked, MD −12.00, 95% CI −33.93, 9.93) and the SF-36 physical domain scores (0–100 points, MD −2.70, 95% CI −4.89, −0.51) for the diet+exercise group compared with the exercise-only group but no significant differences between the diet-only group and the exercise-only group.^125^

###### Single Arm Trials

We identified five single-arm trials reported in six publications^68, 128–132^ that assessed the effects of weight loss on outcomes of interest.

Short-term effects on pain. A 2015 single-arm trial conducted in Australia by Claes and colleagues followed 203 individuals with knee OA in a 12-week hospital-based weight loss program to assess the effects of a weight loss program on the primary outcomes of weight loss and decrease in waist circumference and secondary outcomes related to knee pain and function.^130^ Among 127 completers, percentage weight loss and decrease in BMI were significant at 12 weeks. This group demonstrated a significant improvement in KOOS pain scores (MD 5, 95% CI 2.0, 97.9).

Short-term effects on other outcomes. One trial was identified that reported on the association of weight loss with other short-term outcomes of interest.^130^

The 2015 trial by Claes reported a significant improvement in the timed up and go (seconds, MD−1.4, 95% CI−1.1 to −1.7) and the 6-minute walk test (meters, MD 36.7, 95% CI 27.2, 46.2)) from baseline to 12 weeks.^130^

Medium-term effects on pain. Four studies assessed the association between medium-term weight loss and pain.^68, 128, 130, 131^

A 2014 study conducted in Denmark by Bartels and colleagues followed a cohort of 192 participants (age over 50, BMI 30 or over) in a 16-week weight loss program, part of the CAROT study (Influence of weight loss or exercise on CARtilage in Obese knee osteoarthriTis patients) who experienced a significant weight loss (MD 14, 95% CI 13.3, 14.7).^68^ Weight loss was significantly associated with improvement in KOOS pain scores (MD 10.7, 95% CI 8.5, 12.9).

A 2015 study conducted in Australia by Messier, Bennell, and colleagues (Atukorala et al., 2015) enrolled over 3,000 overweight individuals with knee OA in an 18-week weight loss program and assessed the association between percent body weight loss and change in knee pain in 1,383 completers (94 of whom had lost more than 2.5% of their original body weight).^128^ At 18 weeks, quintiles of weight loss (as % of baseline body weight) showed a significant dose-response relationship with KOOS pain scores (e.g., >10% weight loss [n=431]: MD 16.7, 95% CI 15.2, 18.2) compared to <2.5% weight loss [n=79] MD 6.1, 95% CI 3.2, 9.0; full data reported in Appendix C). Quintiles showed no significant differences in age or sex.

The 2015 study by Claes reported that among 76 participants who were retained at 26 weeks, weight loss was 2.1 ± 4.0 kg and improvement in VAS pain (0–10cm, −0.9 ± 2.0) and changes in KOOS pain at 26 weeks remained significant (MD 5.6, 95% CI 1.6, 9.6).^130^

A 2011 single-arm study conducted in France by Richette prospectively assessed the effects of large-scale weight loss among 44 bariatric surgery patients with moderate to severe OA of the knee on pain after 6 months (RoB not determined).^131^ At 6 months, patients experienced a significant improvement in BMI (10.3, 95% CI 7.4, 13.2), and VAS (0–100 scale, MD 25.5, 95% CI 15.5, 35.5) and WOMAC (no scale, MD 93.2, 95% CI 47.1, 139.3) pain scores were significantly improved compared with baseline.

Medium-term effects on function. Three studies^68, 128, 131^ assessed the association of weight loss with function.

Richette demonstrated significant improvements in WOMAC function scores with weight loss at 6 months (MD 371.3, 95% CI 219.6, 523.0).^131^

The 2014 study conducted by Bartels and colleagues reported a significant improvement in KOOS function associated with weight loss (MD 12.1, 95% CI 10.0, 14.2).^68^

The study by Atukorala found a significant dose-response relationship between percent weight loss and KOOS function scores (>10% loss: MD 17.4, 95% CI 15.9, 18.9 compared with <2.5% loss: MD 7.8, 95% CI 4.8, 10.8).^128^ Achievement of a MCID in KOOS function was associated with a weight loss of 7.7 percent or more (95% CI 5.2, 13.3).

Medium-term effects on other outcomes. We identified three single-arm trials that assessed medium-term effects on other outcomes of interest among weight loss patients with OA.

At 6 months, patients in the bariatric surgery trial by Richette showed significant improvements in WOMAC stiffness scores (MD 31.8, 95% CI 11.7, 51.9).^131^

The 2015 trial by Claes reported a significant improvement in the timed up and go (seconds, MD 2, 95% CI 1.4, 2.6) and the 6-minute walk test (meters, MD 44.0, 95% CI 31.5, 56.5) from baseline to 26 weeks.^130^

The 2015 study by Atukorala also identified a significant dose-response association of percent body weight lost and the SF-12 physical domain (<2.5%: mean 3.16 [SD 8.24]; 2.5–5%: 4.07 [8.02]; 5.1–7.5%: 6.73 [7.83]; 7.6–10%: 6.65 [8.17]; > 10%: 8.60 [8.18], p=0.000).^129^

Long-term effects on pain. We identified one single-arm trial that assessed long-term effects on pain.

A 2015 U.S. study by Stefanik and colleagues, the Osteoarthritis Before and after Bariatric Surgery study, is assessing the effect of large-scale weight loss on knee OA outcomes among individuals with BMI 35 or higher (RoB not assessed).^132^ At 1 year, among 23 individuals who have completed the study so far, VAS (0–100mm, MD 27.8) and WOMAC (0–20 points, MD 5.1) pain scores have improved.

#### Home-Based and Self-Management Interventions

##### Key Points

- A home-based exercise program and a self-management plus exercise program showed significant beneficial short-term effects on pain, based on two RCTs (low strength of evidence).
- Evidence was insufficient to assess the effects of home-based and self-management programs on short-term function but self-management programs had significant beneficial effects on medium-term function compared with control conditions (low strength of evidence.
- Self-management and PCST plus strength training showed beneficial but inconsistent medium-term effects on pain, based on three RCTs (low strength of evidence).
- Evidence was insufficient to assess the medium-term effects of self-management programs on quality of life.
- Evidence was insufficient to assess the long-term effects of self-management on pain or function.

##### Findings

Most RCTs included in the current report expected participants to perform exercises at home, but none of these trials assessed the effects of compliance or adherence with the home exercise assignments. We identified five RCTs that reported on the effects of home-based or self-management interventions (described as self-management or coping skills training) among individuals with knee OA on outcomes of interest.^42, 46, 53, 127, 133^ Three of these studies have been described in previous sections of the report, and the details are described in the evidence table in Appendix C.

###### Randomized Controlled Trials

Short-term effects on pain. Two RCTs that met inclusion criteria assessed short-term effects of self-management or home-based interventions on pain.^46, 133^

A 2012 RCT conducted in the US by Rogers and coworkers randomized 44 adults age 50 and over to one of four 2-month home-based interventions: kinesthesia, balance, and agility (KBA) training alone, resistance training (RT) alone, a combination of KBA and RT, and a control group that was told to apply a lotion to the affected areas (RoB moderate).^46^ At 2 months, WOMAC pain scores improved significantly for all groups compared with the control group (Strength training alone: MD −3.75, 95% CI −6.39, −1.11; agility training alone: MD −3.13, 95% CI −5.86, −0.40; strength+agility training: MD −3.00, 95% CI −5,45, −0.55), with no significant differences between any of the groups.

A 2012 RCT conducted in Australia by Coleman and colleagues, the OAK Self Management Program (OAK) study, randomized 146 adults to a 6-week self-management intervention tailored to knee OA patients (based on the Stanford Arthritis Self-management Program) or to a waiting list control group (RoB low).^133^ At 2 months, a significant between-group difference was seen in WOMAC pain scores (MD −1.50, 95% CI −2.33, −0.67). VAS pain decreased significantly over the same time period (0–10cm MD 2.54, 95% CI 1.66, 3.41), and the likelihood of achieving a minimum clinically important improvement (MCII) was significantly greater in the SM group (RR 0.20, 95% CI 0.08, 0.49).

Short-term effects on function. Two RCTs that met inclusion criteria assessed short-term effects of self-management or home-based interventions on function.^46, 133^

The Rogers trial reported significant between-group differences in WOMAC function at 2 months for the combined strength+agility training group (MD −11.98, 95% CI −19.15, −4.81) and the strength training group (MD −9.62, 95% CI −19.04, −0.20) compared with the controls but not the group that performed agility exercises alone.^46^

The 2012 OAK study found a significant between-group difference in WOMAC function scores at 2 months (MD −5.30, 95% CI −7.24, −3.36).^133^ In addition the proportion achieving a MCII was significantly different (RR 0.24, 99% CI 0.11, 0.51).

Short-term effects on other outcomes. Two RCTs that met inclusion criteria assessed short-term effects of self-management or home-based interventions on other outcomes.^46, 133^

The Rogers trial of home-based interventions reported significant between-group differences in WOMAC total at 2 months for the combined strength+agility training group (MD −15.26, 95% CI −25.16, −5.36) and the strength training group (MD −13.62, 95% CI −26.37, −0.87) compared with the controls but not the group that performed agility exercises alone.^46^

The 2012 OAK self-management study found significant between-group differences in WOMAC total scores at 2 months (MD −7.20, 95% CI −9.97, −4.43). The study also found significant between-group differences in SF-36 physical domain scores at 2 months (MD −5.60, 95% CI −9.48, −1.72) and a significant increase in the likelihood of achieving a MCII (RR 0.57, 95% CI 0.38, 0.84). Significant between-group differences were seen in 2-month TUG scores (MD −1.00, 95% CI −1.55, −0.45) and in the likelihood of achieving a MCII in TUG (RR 0.32, 95% CI 0.20, 0.52).^133^

Medium-term effects on pain. Three RCTs assessed medium-term effects of home-based or self-management interventions on pain.^53, 127, 133^

A 2016 double-blind (participants and assessors) RCT conducted at two sites in Australia by Bennell and colleagues assessed the effect of strength training combined with pain coping skills training (PCST) compared with PCST or strength training exercises (the control) alone (RoB low).^53^ This study randomized 222 individuals with moderate to severe knee OA to one of three 3-month treatment programs and followed them for 12 months. Overall pain was assessed on a 100mm VAS scale with a MCID set at 18mm. Comparisons used a model that took into account the physical therapist training, baseline scores, site, and sex. At 3 months, no significant differences were observed in overall pain in the group that received strength training+PCST or the group that received PCST alone compared with the group that received strength training alone. A significant between-group difference was observed in VAS walking pain, favoring the group that received strength training+PCST over that of strength training alone (MD −8.20, 95% CI −15.32, −1.08). Using WOMAC pain as the outcome, a nonsignificant difference was seen in the strength training+PCST group compared with strength alone and no difference was seen comparing PCST alone with strength training.

The OA Life Study was a 2012 U.S. RCT that randomized 232 obese adults with knee OA to receive standard care, a pain coping skills training (PCST) program, a behavioral weight management (BWM) program alone, or both interventions (RoB moderate).^127^ Both the BWM and BWM+PCST groups had significant weight losses compared with the standard care group; only the BWM+PCST group had a significant decrease in BMI compared with standard care (MD −1.80, 95% CI −2.44, −1.16). No difference was observed in WOMAC pain between the BWM group and the standard care group (MD −2.50, 95% CI −7.67, 2.67), but a significant between-group difference was seen between BWM+PCST and the standard care group (MD −10.80, 95% CI −15.77, −5.83).

The 2012 OAK self-management study found no remaining between-group differences in WOMAC pain at 6 months.^133^

Medium-term effects on function. Four RCTs assessed medium-term effects of home-based or self-management interventions on function.^42, 53, 127, 133^

The Bennell trial that compared strength+PCST training with each one alone observed a significant between-group difference in WOMAC function at 3 months, favoring the strength+PCST group over strength training alone (0–68 points, MD −3.80, 95% CI −7.06, −0.54).^53^

The 2012 OA Life Study observed a significant between-group difference in WOMAC function between the BWM+PCST group and the standard care group (0–100 points, MD−12.40, 95% CI −17.29, −7.51) but no other between-group differences.^127^

At 6 months, the 2012 OAK self-management study found a continuing between-group difference in WOMAC function (MD−3.50, 95% CI −6.14, −0.86) and an increase in the likelihood of achieving a MCII in function compared with the control group (RR 0.56, 95% CI 0.33, 0.95).^133^

The 2011 STAR feasibility study developed and tested self-efficacy strategies to promote fitness walking in an individually delivered home-based program for overweight and obese older adults with knee OA.^42^ At the end of the 6-month program, no significant between-group differences were seen in WOMAC function or in performance on the 6-minute walk test compared with a usual care control group.

Medium-term effects on other outcomes. Two RCTs assessed medium-term effects of self-management or home interventions on other outcomes of interest.^53, 133^

The Bennell trial, which compared strength+PCST training with each one alone observed no between-group differences in TUG or in quality of life at 3 months.^53^

At 6 months, the 2012 OAK self-management study found a continuing between-group difference in WOMAC total scores (MD −4.10, 95% CI −7.43, −0.77). The study also found significant persistent between-group differences in SF-36 physical domain scores at 6 months (MD −5.70, 95% CI −10.97, −0.43) and a significant increase in the likelihood of achieving a MCII (RR 0.73, 95% CI 0.52, 1.02). Significant between-group differences persisted at 6 months in TUG scores (MD −1.00, 95% CI −1.55, −0.45) and in the likelihood of achieving a MCII in TUG (RR 0.68, 95% CI 0.47, 0.99).^133^

Long-term effects on pain. At 1 year, the Bennell trial, which compared strength+PCST training with each one alone, observed no between-group differences in VAS pain or WOMAC pain.^53^

Long-term effects on function. The Bennell trial, which compared strength+PCST training with each one alone, observed no between-group differences in WOMAC function at 1 year.^53^

The 2011 STAR feasibility test found no significant followup effects of the aerobic walking intervention at 12 months from baseline.^42^

Long-term effects on other outcomes. At 1 year, the Bennell RCT identified a significant between-group difference in quality of life (Australian Quol-6D) between the strength+PCST and the strength-only group (range −0.04–1 MD −0.06, 95% CI −0.11, −0.01),^53^ but no differences in the TUG.

## Key Question 2a: What harms are associated with each intervention in patients with primary or secondary OA of the knee? Key Question 2b: How do the harms associated with each intervention differ by the following population or study characteristics: sex, disease subtype (lateral tibiofemoral, patellofemoral), severity (stage/baseline pain and functional status), weight status (body mass index), baseline fitness (activity level), comorbidities, prior or concurrent treatments (including self-initiated therapies), and treatment duration or intensity?

### Key Points

- Of 57 studies that described some assessment of adverse events (AEs), eighteen studies reported on serious adverse events (SAEs). Most reported only whether any SAEs were identified. SAEs were extremely rarely reported and not limited to active treatment groups. AEs are shown by study in Appendix H.
- No studies assessed differences in adverse events by characteristics of subpopulation.

### Detailed Synthesis

Adverse events (AEs) were considered in 57 of the original studies included in the report, 18 of which made reference to SAEs. A large proportion of these studies declared that no AEs or no SAEs were reported. All AEs are shown in Appendix H by study, type, and number and percent per study arm. In this section, we highlight differences in AEs across study arms of interest. No differences in AEs were reported by any patient characteristics.

The quality of AE reporting was assessed using the McHarms tool. Findings are shown in Appendix F and described in the Discussion section.

Platelet-rich plasma (PRP). Of two studies on PRP that reported on AEs, one reported no serious AEs (SAEs),^25^ and the other reported a significant increase in pain and stiffness with single injections, which doubled with two injections.^23^

Glucosamine and/or chondroitin. The GAIT trial reported on a large number of AEs, but almost none were observed across study arms. SAEs were rare and as likely to occur in the celecoxib and placebo controls as in glucosamine or chondroitin treatment groups. Notably, withdrawal due to AEs was slightly but probably not significantly higher for chondroitin alone than for any of the other interventions.^134^ A 2-year trial of chondroitin sulfate compared with placebo found no difference in gastrointestinal AEs or withdrawal due to AEs.^37^ The LEGS trial assessed withdrawals due to blood glucose issues and found no difference from placebo.^31^ A 2016 study of chondroitin sulfate supplementation reported no difference between chondroitin and placebo in the risk for serious AEs or any AEs. The number of AEs related to treatment and the number that resulted in discontinuation were greater in the chondroitin group than in the placebo group but the article did not describe the specific AEs.^32^

Physical interventions. No AEs of note were reported among studies of strength, aerobic, agility, or other physical training interventions. A study of agility interventions (gait training) reported no AEs associated with either the active intervention or the control.^60^ A study that compared Tai chi to conventional physical therapy reported no serious AEs associated with either intervention.^70^

Mud baths were associated with mild hypotension among 5.66 percent of participants compared with no instances among sham controls.^75^

Braces, orthotics, and custom shoes. Among three RCTs that reported on AEs in studies of orthoses (lateral insoles) compared with neutral or no insoles, one reported significantly greater back pain, foot pain, and difficulty with shoe fit, but less knee pain among the lateral insole users.^109^

TENS, NMES, PEMF, and WBV. No differences were seen in AEs between active and control groups with the exception of one case (among 19 participants) of slight low back pain with WBV.^81, 86, 87, 92, 95^

Weight loss with or without exercise. One study of weight loss that tracked a large number of nonSAEs found an increase in minor GI AEs among those in the diet group.^62^

Pain Coping Skills Training (PCST). One study that compared a large number of categories of AEs among participants randomized to a PCST and exercise intervention with those among a group who received only exercise or only PCST found that PCST plus exercise was associated with a lower number of numerous types of AEs than the group that received only exercise.^53^