# References

1 Lawrence RC, Felson DT, Helmick CG, . Estimates of the prevalence of arthritis and other rheumatic conditions in the United States. Part II. Arthritis Rheum. 2008 Jan;58(1):26–35. doi: 10.1002/art.23176. PMID: 18163497.18163497
2 Dillon CF, Rasch EK, Gu Q, . Prevalence of knee osteoarthritis in the United States: arthritis data from the Third National Health and Nutrition Examination Survey 1991–94. J Rheumatol. 2006 Nov;33(11):2271–9. doi: 06/13/1011 [pii]. PMID: 17013996.17013996
3 Richmond SA, Fukuchi RK, Ezzat A, . Are Joint Injury, Sport Activity, Physical Activity, Obesity, or Occupational Activities Predictors for Osteoarthritis? A Systematic Review. J Orthop Sports Phys Ther. 2013 Jun 11doi: 2900 [pii]10.2519/jospt.2013.4796. PMID: 23756344.23756344
4 Murphy L, Schwartz TA, Helmick CG, . Lifetime risk of symptomatic knee osteoarthritis. Arthritis Rheum. 2008 Sep 15;59(9):1207–13. doi: 10.1002/art.24021. PMID: 18759314.18759314
5 Weinstein AM, Rome BN, Reichmann WM, . Estimating the burden of total knee replacement in the United States. J Bone Joint Surg Am. 2013 Mar 6;95(5):385–92. doi: 1555390 [pii]10.2106/JBJS.L.00206. PMID: 23344005.23344005
6 Teichtahl AJ, Wluka AE, Wang Y, . The longitudinal relationship between changes in body weight and changes in medial tibial cartilage, and pain among community-based adults with and without meniscal tears. Ann Rheum Dis. 2013 Jun 6doi: 10.1136/annrheumdis-2013-203210. PMID: 23744978.23744978
7 Samson DJ, Grant MD, Ratko TA, . Treatment of primary and secondary osteoarthritis of the knee. Evidence Report/Technology Assessment No. 157 (Prepared by Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-02-0026) Agency for Healthcare Research and Quality. Rockville, MD: September 2007.
8 Schiphof D, de Klerk BM, Kerkhof HJ, . Impact of different descriptions of the Kellgren and Lawrence classification criteria on the diagnosis of knee osteoarthritis. Ann Rheum Dis. 2011 Aug;70(8):1422–7. doi: 10.1136/ard.2010.147520. PMID: 21555325.21555325
9 Cibere J, Zhang H, Thorne A, . Association of clinical findings with pre-radiographic and radiographic knee osteoarthritis in a population-based study. Arthritis Care Res (Hoboken). 2010 Dec;62(12):1691–8. doi: 10.1002/acr.20314. PMID: 20665737.20665737
10 Hochberg MC, Altman RD, April KT, . American College of Rheumatology 2012 recommendations for the use of nonpharmacologic and pharmacologic therapies in osteoarthritis of the hand, hip, and knee. Arthritis Care Res (Hoboken). 2012 Apr;64(4):465–74. PMID: 22563589.22563589
11 American Academy of Orthopaedic Surgeons. Treatment of Osteoarthritis of the Knee, 2nd Edition: SUMMARY OF RECOMMENDATIONS. http://www.aaos.org/research/guidelines/OAKSummaryofRecommendations.pdf.
12 Newberry SJ, FitzGerald JD, Maglione M, . Systematic Review for Effectiveness of Hyaluronic Acid in the Treatment of Severe Degenerative Joint Disease (DJD) of the Knee. (Prepared by the Southern California Evidence-based Practice Center). Technology Assessment Report. AHRQ. Project ID: DJDTO913. In preparation.
13 Shamliyan TA, Wang SY, Olson-Kellogg B, . Physical Therapy Interventions for Knee Pain Secondary to Osteoarthritis. Rockville (MD): Agency for Healthcare Research and Quality; 2012.
14 Chou R, McDonagh MS, Nakamoto E, . Analgesics for Osteoarthritis: An Update of the 2006 Comparative Effectiveness Review. Comparative Effectiveness Review No. 38. (Prepared by the Oregon Evidence-based Practice Center under Contract No. HHSA 290 2007 10057 I) Agency for Healthcare Research and Quality. Rockville, MD: October 2011.
15 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014. p. Chapters available at: www.effectivehealthcare.ahrq.gov.
16 Osteoarthritis of the Knee. Draft Key Questions. Rockville, MD: AHRQ Effective Health Care Program; 2015. http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displaytopic&topicid=633. Accessed on March 7 2016.
17 Altman R, Asch E, Bloch D, . Development of criteria for the classification and reporting of osteoarthritis. Classification of osteoarthritis of the knee. Diagnostic and Therapeutic Criteria Committee of the American Rheumatism Association. Arthritis Rheum. 1986 Aug;29(8):1039–49. PMID: 3741515.3741515
18 Whitlock EP, Lin JS, Chou R, . Using existing systematic reviews in complex systematic reviews. Ann Intern Med. 2008 May 20;148(10):776–82. PMID: 18490690.18490690
19 Shamliyan TA, Wang SY, Olson-Kellogg B, . AHRQ Comparative Effectiveness Reviews. Physical Therapy Interventions for Knee Pain Secondary to Osteoarthritis. Rockville (MD): Agency for Healthcare Research and Quality (US); 2012.
20 Armijo-Olivo S, da Costa BR, Cummings GG, . PEDro or Cochrane to Assess the Quality of Clinical Trials? A Meta-Epidemiological Study. PLoS One. 2015;10(7):e0132634. doi: 10.1371/journal.pone.0132634. PMID: 26161653.26161653
21 Whiting P, Savovic J, Higgins JP, . ROBIS: A new tool to assess risk of bias in systematic reviews was developed. J Clin Epidemiol. 2016 Jan;69:225–34. doi: 10.1016/j.jclinepi.2015.06.005. PMID: 26092286.26092286
22 IntHout J, Ioannidis JP, Borm GF. The Hartung-Knapp-Sidik-Jonkman method for random effects meta-analysis is straightforward and considerably outperforms the standard DerSimonian-Laird method. BMC Med Res Methodol. 2014;14:25. doi: 10.1186/1471-2288-14-25. PMID: 24548571.24548571
23 Patel S, Dhillon MS, Aggarwal S, . Treatment with platelet-rich plasma is more effective than placebo for knee osteoarthritis: a prospective, double-blind, randomized trial. Am J Sports Med. 2013 Feb;41(2):356–64. doi: 10.1177/0363546512471299. PMID: 23299850.23299850
24 Gormeli G, Gormeli CA, Ataoglu B, . Multiple PRP injections are more effective than single injections and hyaluronic acid in knees with early osteoarthritis: a randomized, double-blind, placebo-controlled trial. Knee Surg Sports Traumatol Arthrosc. 2015 Aug 2 doi: 10.1007/s00167-015-3705-6. PMID: 26233594.26233594
25 Rayegani SM, Raeissadat SA, Taheri MS, . Does intra articular platelet rich plasma injection improve function, pain and quality of life in patients with osteoarthritis of the knee? A randomized clinical trial. Orthop Rev (Pavia). 2014 Aug 8;6(3):5405. doi: 10.4081/or.2014.5405. PMID: 25317308.25317308
26 Acosta-Olivo C, Esponda-Colmenares F, Vilchez-Cavazos F, . Platelet rich plasma versus oral paracetamol for the treatment of early knee osteoarthritis. Preliminar study. Cirugia y Cirujanos. 2014;82(2):163–9.25312315
27 Simental-Mendia M, Vilchez-Cavazos JF, Pena-Martinez VM, . Leukocyte-poor platelet-rich plasma is more effective than the conventional therapy with acetaminophen for the treatment of early knee osteoarthritis. Arch Orthop Trauma Surg. 2016 Aug 9 doi: 10.1007/s00402-016-2545-2. PMID: 27506585.27506585
28 Sawitzke AD, Shi H, Finco MF, . Clinical efficacy and safety of glucosamine, chondroitin sulphate, their combination, celecoxib or placebo taken to treat osteoarthritis of the knee: 2-year results from GAIT. Ann Rheum Dis. 2010 Aug;69(8):1459–64. doi: 10.1136/ard.2009.120469. PMID: 20525840.20525840
29 Hochberg MC, Martel-Pelletier J, Monfort J, . Combined chondroitin sulfate and glucosamine for painful knee osteoarthritis: A multicentre, randomised, double-blind, non-inferiority trial versus celecoxib. Annals of the Rheumatic Diseases. 2016;75:37–44. FULL TEXT LINK http://dx.doi.org/10.1136/annrheumdis-2014-206792.25589511
30 Bellare N, Argekar H, Bhagwat A, . Glucosamine and chondroitin sulphate supplementation along with diet therapy provides better symptomatic relief in osteoarthritic patients as compared to diet therapy alone. International Journal of Pharmaceutical Sciences Review and Research; 2014. p. 215–23.
31 Fransen M, Agaliotis M, Nairn L, . Glucosamine and chondroitin for knee osteoarthritis: A double-blind randomised placebo-controlled clinical trial evaluating single and combination regimens. Annals of the Rheumatic Diseases 2014;6.
32 Herrero-Beaumont G, Roman-Blas J, Castaneda S, . Chondroitin sulfate plus glucosamine sulfate does not show superiority over placebo in a randomised, double blind, placebo-controlled clinical trial in patients with knee osteoarthritis. Osteoarthritis and cartilage; 2016. p. S48–s9.
33 Bruyere O, Pavelka K, Rovati LC, . Total joint replacement after glucosamine sulphate treatment in knee osteoarthritis: results of a mean 8-year observation of patients from two previous 3-year, randomised, placebo-controlled trials. Osteoarthritis Cartilage. 2008 Feb;16(2):254–60. doi: 10.1016/j.joca.2007.06.011. PMID: 17681803.17681803
34 Stambolova Ivanova MP. Maintenance therapy with glucosamine sulfate and physiotherapy on osteoarthritis progression. Osteoporosis International. 2015 February;26(1 SUPPL. 1):S116–S7.
35 Pavelka K, Gatterova J, Olejarova M, . Glucosamine sulfate use and delay of progression of knee osteoarthritis: a 3-year, randomized, placebo-controlled, double-blind study. Arch Intern Med. 2002 Oct 14;162(18):2113–23. PMID: 12374520.12374520
36 Reginster JY, Deroisy R, Rovati LC, . Long-term effects of glucosamine sulphate on osteoarthritis progression: a randomised, placebo-controlled clinical trial. Lancet. 2001 Jan 27;357(9252):251–6. doi: 10.1016/S0140-6736(00)03610-2. PMID: 11214126.11214126
37 Zegels B, Crozes P, Uebelhart D, . Equivalence of a single dose (1200 mg) compared to a three-time a day dose (400 mg) of chondroitin 4&6 sulfate in patients with knee osteoarthritis. Results of a randomized double blind placebo controlled study. Osteoarthritis Cartilage. 2013 Jan;21(1):22–7. doi: 10.1016/j.joca.2012.09.017. PMID: 23059756.23059756
38 Kahan A, Uebelhart D, De Vathaire F, . Long-term effects of chondroitins 4 and 6 sulfate on knee osteoarthritis: the study on osteoarthritis progression prevention, a two-year, randomized, double-blind, placebo-controlled trial. Arthritis Rheum. 2009 Feb;60(2):524–33. doi: 10.1002/art.24255. PMID: 19180484.19180484
39 Brosseau L, Wells GA, Kenny GP, . The implementation of a community-based aerobic walking program for mild to moderate knee osteoarthritis: a knowledge translation randomized controlled trial: part II: clinical outcomes. BMC Public Health. 2012;12:1073. doi: 10.1186/1471-2458-12-1073. PMID: 23234575.23234575
40 Samut G, Dincer F, Ozdemir O. The effect of isokinetic and aerobic exercises on serum interleukin-6 and tumor necrosis factor alpha levels, pain, and functional activity in patients with knee osteoarthritis. Mod Rheumatol. 2015 May 27:1–6. doi: 10.3109/14397595.2015.1038425. PMID: 25849853.25849853
41 Koli J, Multanen J, Kujala UM, . CLINICAL SCIENCES Effects of Exercise on Patellar Cartilage in Women with Mild Knee Osteoarthritis. Medicine & Science in Sports & Exercise. 2015 September 2015;47(9)
42 Schlenk EA, Lias JL, Sereika SM, . Improving physical activity and function in overweight and obese older adults with osteoarthritis of the knee: a feasibility study. Rehabil Nurs. 2011 Jan–Feb;36(1):32–42. PMID: 21290963.21290963
43 Salacinski AJ, Krohn K, Lewis SF, . The effects of group cycling on gait and pain-related disability in individuals with mild-to-moderate knee osteoarthritis: a randomized controlled trial. J Orthop Sports Phys Ther. 2012 Dec;42(12):985–95. doi: 10.2519/jospt.2012.3813. PMID: 22951360.22951360
44 Bruce-Brand RA, Walls RJ, Ong JC, . Effects of home-based resistance training and neuromuscular electrical stimulation in knee osteoarthritis: a randomized controlled trial. BMC Musculoskelet Disord. 2012;13:118. doi: 10.1186/1471-2474-13-118. PMID: 22759883.22759883
45 Wortley M, Zhang S, Paquette M, . Effects of resistance and Tai Ji training on mobility and symptoms in knee osteoarthritis patients. Journal of Sport and Health Science; 2013. p. 209–14.
46 Rogers MW, Tamulevicius N, Semple SJ, . Efficacy of home-based kinesthesia, balance & agility exercise training among persons with symptomatic knee osteoarthritis. J Sports Sci Med. 2012;11(4):751–8. PMID: 24150088.24150088
47 Oliveira AM, Peccin MS, Silva KN, . Impact of exercise on the functional capacity and pain of patients with knee osteoarthritis: a randomized clinical trial. Rev Bras Reumatol. 2012 Dec;52(6):876–82. PMID: 23223698.23223698
48 Imoto AM, Peccin MS, Trevisani VF. Quadriceps strengthening exercises are effective in improving pain, function and quality of life in patients with osteoarthritis of the knee. Acta Ortop Bras. 2012;20(3):174–9. doi: 10.1590/s1413-78522012000300008. PMID: 24453599.24453599
49 Jorge RTB, de Souza MC, Chiari A, . Progressive resistance exercise in women with osteoarthritis of the knee: a randomized controlled trial. Clinical Rehabilitation. 2015 Mar;29(3):234–43. doi: 10.1177/0269215514540920. 24994768
50 Singh S, Pattnaik M, Mohanty P, . Effectiveness of hip abductor strengthening on health status, strength, endurance and six minute walk test in participants with medial compartment symptomatic knee osteoarthritis. J Back Musculoskelet Rehabil. 2016;29(1):65–75. doi: 10.3233/bmr-150599. PMID: 26406217.26406217
51 Nam CW, Kim K, Lee HY. The influence of exercise on an unstable surface on the physical function and muscle strength of patients with osteoarthritis of the knee. J Phys Ther Sci. 2014 Oct;26(10):1609–12. doi: 10.1589/jpts.26.1609. PMID: 25364125.25364125
52 Foroughi N, Smith RM, Lange AK, . Progressive resistance training and dynamic alignment in osteoarthritis: A single-blind randomised controlled trial. Clin Biomech (Bristol, Avon). 2011 Jan;26(1):71–7. doi: 10.1016/j.clinbiomech.2010.08.013. PMID: 20869141.20869141
53 Bennell KL, Ahamed Y, Jull G, . Physical therapist-delivered pain coping skills training and exercise for knee osteoarthritis: Randomized controlled trial. Arthritis Care Res (Hoboken). 2015 Sep 28doi: 10.1002/acr.22744. PMID: 26417720.26417720
54 Mangani I, Cesari M, Kritchevsky SB, . Physical exercise and comorbidity. Results from the Fitness and Arthritis in Seniors Trial (FAST). Aging Clin Exp Res. 2006 Oct;18(5):374–80. PMID: 17167301.17167301
55 Fitzgerald GK, Piva SR, Gil AB, . Agility and perturbation training techniques in exercise therapy for reducing pain and improving function in people with knee osteoarthritis: a randomized clinical trial. Phys Ther. 2011 Apr;91(4):452–69. doi: 10.2522/ptj.20100188. PMID: 21330451.21330451
56 Henriksen M, Klokker L, Graven-Nielsen T, . Association of exercise therapy and reduction of pain sensitivity in patients with knee osteoarthritis: a randomized controlled trial. Arthritis Care Res (Hoboken). 2014 Dec;66(12):1836–43. doi: 10.1002/acr.22375. PMID: 24905427.24905427
57 Ju SB, Park GD, Kim SS. Effects of proprioceptive circuit exercise on knee joint pain and muscle function in patients with knee osteoarthritis. J Phys Ther Sci. 2015 Aug;27(8):2439–41. doi: 10.1589/jpts.27.2439. PMID: 26357422.26357422
58 da Silva FS, de Melo FE, do Amaral MM, . Efficacy of simple integrated group rehabilitation program for patients with knee osteoarthritis: Single-blind randomized controlled trial. J Rehabil Res Dev. 2015;52(3):309–22. doi: 10.1682/jrrd.2014.08.0199. PMID: 26237073.26237073
59 Barduzzi GO, Rocha Júnior PR, Souza Neto JC, . [Functional capacity of elderly with osteoarthritis who undergone to aquatic and land physical therapy]. Fisioterapia em Movimento; 2013. p. 349–60.
60 Segal NA, Glass NA, Teran-Yengle P, . Intensive Gait Training for Older Adults with Symptomatic Knee Osteoarthritis. Am J Phys Med Rehabil. 2015 Oct;94(10 Suppl 1):848–58. doi: 10.1097/phm.0000000000000264. PMID: 25768068.25768068
61 Knoop J, Dekker J, van der Leeden M, . Knee joint stabilization therapy in patients with osteoarthritis of the knee: a randomized, controlled trial. Osteoarthritis Cartilage. 2013 Aug;21(8):1025–34. doi: 10.1016/j.joca.2013.05.012. PMID: 23721797.23721797
62 Christensen R, Henriksen M, Leeds AR, . Effect of weight maintenance on symptoms of knee osteoarthritis in obese patients: a twelve-month randomized controlled trial. Arthritis Care Res (Hoboken). 2015 May;67(5):640–50. doi: 10.1002/acr.22504. PMID: 25370359.25370359
63 Lim JY, Tchai E, Jang SN. Effectiveness of aquatic exercise for obese patients with knee osteoarthritis: a randomized controlled trial. Pm r. 2010 Aug;2(8):723–31; quiz 93. doi: 10.1016/j.pmrj.2010.04.004. PMID: 20709301.20709301
64 Rosedale R, Rastogi R, May S, . Efficacy of exercise intervention as determined by the McKenzie System of Mechanical Diagnosis and Therapy for knee osteoarthritis: a randomized controlled trial. J Orthop Sports Phys Ther. 2014 Mar;44(3):173–81, a1–6. doi: 10.2519/jospt.2014.4791. PMID: 24450370.24450370
65 Abbott JH, Chapple CM, Fitzgerald GK, . The Incremental Effects of Manual Therapy or Booster Sessions in Addition to Exercise Therapy for Knee Osteoarthritis: A Randomized Clinical Trial. J Orthop Sports Phys Ther. 2015 Sep 28:1–9. doi: 10.2519/jospt.2015.6015. PMID: 26416334.26416334
66 de Rooij M, van der Leeden M, Cheung J, . Efficacy of tailored exercise therapy on physical functioning in patients with knee osteoarthritis and comorbidity: A randomized controlled trial. Arthritis Care Res (Hoboken). 2016 Aug 26doi: 10.1002/acr.23013. PMID: 27563831.27563831
67 Fitzgerald GK, Fritz JM, Childs JD, . Exercise, manual therapy, and use of booster sessions in physical therapy for knee osteoarthritis: a multi-center, factorial randomized clinical trial. Osteoarthritis Cartilage. 2016 Aug;24(8):1340–9. doi: 10.1016/j.joca.2016.03.001. PMID: 26973326.26973326
68 Bartels EM, Christensen R, Christensen P, . Effect of a 16 weeks weight loss program on osteoarthritis biomarkers in obese patients with knee osteoarthritis: a prospective cohort study. Osteoarthritis Cartilage. 2014 Nov;22(11):1817–25. doi: 10.1016/j.joca.2014.07.027. PMID: 25106676.25106676
69 Tsai PF, Chang JY, Beck C, . A pilot cluster-randomized trial of a 20-week Tai Chi program in elders with cognitive impairment and osteoarthritic knee: effects on pain and other health outcomes. J Pain Symptom Manage. 2013 Apr;45(4):660–9. doi: 10.1016/j.jpainsymman.2012.04.009. PMID: 23017610.23017610
70 Chenchen W, Schmid CH, Iversen MD, . Comparative Effectiveness of Tai Chi Versus Physical Therapy for Knee Osteoarthritis: A Randomized Trial. Annals of Internal Medicine. 2016;165(2):77–86. doi: 10.7326/M15-2143. Language: English. Entry Date: In Process. Revision Date: 20160817. Publication Type: journal article. Journal Subset: Biomedical.27183035
71 Cheung C, Wyman JF, Resnick B, . Yoga for managing knee osteoarthritis in older women: a pilot randomized controlled trial. BMC Complement Altern Med. 2014;14:160. doi: 10.1186/1472-6882-14-160. PMID: 24886638.24886638
72 Fioravanti A, Giannitti C, Bellisai B, . Efficacy of balneotherapy on pain, function and quality of life in patients with osteoarthritis of the knee. Int J Biometeorol. 2012 Jul;56(4):583–90. doi: 10.1007/s00484-011-0447-0. PMID: 21573819.21573819
73 Kulisch A, Benko A, Bergmann A, . Evaluation of the effect of Lake Heviz thermal mineral water in patients with osteoarthritis of the knee: a randomized, controlled, single-blind, follow-up study. Eur J Phys Rehabil Med. 2014 Aug;50(4):373–81. PMID: 24594851.24594851
74 Mahboob N, Sousan K, Shirzad A, . The efficacy of a topical gel prepared using Lake Urmia mud in patients with knee osteoarthritis. J Altern Complement Med. 2009 Nov;15(11):1239–42. doi: 10.1089/acm.2009.0304. PMID: 19922256.19922256
75 Fioravanti A, Bacaro G, Giannitti C, . One-year follow-up of mud-bath therapy in patients with bilateral knee osteoarthritis: a randomized, single-blind controlled trial. Int J Biometeorol. 2015 Sep;59(9):1333–43. doi: 10.1007/s00484-014-0943-0. PMID: 25516113.25516113
76 Lenssen AF, Crijns YH, Waltje EM, . Efficiency of immediate postoperative inpatient physical therapy following total knee arthroplasty: an RCT. BMC Musculoskelet Disord. 2006;7:71. doi: 10.1186/1471-2474-7-71. PMID: 16942627.16942627
77 Yildirim N, Filiz Ulusoy M, Bodur H. The effect of heat application on pain, stiffness, physical function and quality of life in patients with knee osteoarthritis. J Clin Nurs. 2010 Apr;19(7–8):1113–20. doi: 10.1111/j.1365-2702.2009.03070.x. PMID: 20492056.20492056
78 Hsieh RL, Lo MT, Lee WC, . Therapeutic effects of short-term monochromatic infrared energy therapy on patients with knee osteoarthritis: a double-blind, randomized, placebo-controlled study. J Orthop Sports Phys Ther. 2012 Nov;42(11):947–56. doi: 10.2519/jospt.2012.3881. PMID: 22960644.22960644
79 Cakir S, Hepguler S, Ozturk C, . Efficacy of therapeutic ultrasound for the management of knee osteoarthritis: a randomized, controlled, and double-blind study. Am J Phys Med Rehabil. 2014 May;93(5):405–12. doi: 10.1097/phm.0000000000000033. PMID: 24322433.24322433
80 Carlos KP, Belli BS, Alfredo PP. Effect of pulsed ultrasound and continuous ultrasound linked to exercise in patients with knee osteoarthritis: pilot study. Fisioterapia e Pesquisa; 2012. p. 275–81.
81 Kapci Yildiz S, Unlu Ozkan F, Aktas I, . The effectiveness of ultrasound treatment for the management of knee osteoarthritis: a randomized, placebo-controlled, double-blind study. Turkish Journal of Medical Sciences. 2015;45(6):1187–91. doi: 10.3906/sag-1408-81. 26775369
82 Laufer Y, Shtraker H, Elboim Gabyzon M. The effects of exercise and neuromuscular electrical stimulation in subjects with knee osteoarthritis: a 3-month follow-up study. Clin Interv Aging. 2014;9:1153–61. doi: 10.2147/cia.s64104. PMID: 25083133.25083133
83 Mizusaki Imoto A, Peccin S, Gomes da Silva KN, . Effects of neuromuscular electrical stimulation combined with exercises versus an exercise program on the pain and the function in patients with knee osteoarthritis: a randomized controlled trial. Biomed Res Int. 2013;2013:272018. doi: 10.1155/2013/272018. PMID: 24151589.24151589
84 Imoto AM, Peccin MS, Teixeira LE, . Is neuromuscular electrical stimulation effective for improving pain, function and activities of daily living of knee osteoarthritis patients? A randomized clinical trial. Sao Paulo Med J. 2013;131(2):80–7. PMID: 23657509.23657509
85 Elboim-Gabyzon M, Rozen N, Laufer Y. Does neuromuscular electrical stimulation enhance the effectiveness of an exercise programme in subjects with knee osteoarthritis? A randomized controlled trial. Clin Rehabil. 2013 Mar;27(3):246–57. doi: 10.1177/0269215512456388. PMID: 22952305.22952305
86 Gschiel B, Kager H, Pipam W, . [Analgesic efficacy of TENS therapy in patients with gonarthrosis. A prospective, randomised, placebo-controlled, double-blind study]. Schmerz. 2010 Sep;24(5):494–500. doi: 10.1007/s00482-010-0957-4. PMID: 20706740.20706740
87 Atamaz FC, Durmaz B, Baydar M, . Comparison of the efficacy of transcutaneous electrical nerve stimulation, interferential currents, and shortwave diathermy in knee osteoarthritis: a double-blind, randomized, controlled, multicenter study. Arch Phys Med Rehabil. 2012 May;93(5):748–56. doi: 10.1016/j.apmr.2011.11.037. PMID: 22459699.22459699
88 Palmer S, Domaille M, Cramp F, . Transcutaneous electrical nerve stimulation as an adjunct to education and exercise for knee osteoarthritis: a randomized controlled trial. Arthritis Care Res (Hoboken). 2014 Mar;66(3):387–94. doi: 10.1002/acr.22147. PMID: 23983090.23983090
89 Inal EE, Eroglu P, Yucel SH, . Which is the Appropriate Frequency of TENS in Managing Knee Osteoarthritis: High or Low Frequency? Journal of Clinical and Analytical Medicine. 2016 May;7(3):339–44. doi: 10.4328/JCAM.3387.
90 Nelson FR, Zvirbulis R, Pilla AA. Non-invasive electromagnetic field therapy produces rapid and substantial pain reduction in early knee osteoarthritis: a randomized double-blind pilot study. Rheumatology International. 2013 Aug;33(8):2169–73. 22451021
91 Dundar U, Asik G, Ulasli AM, . Assessment of pulsed electromagnetic field therapy with Serum YKL-40 and ultrasonography in patients with knee osteoarthritis. Int J Rheum Dis. 2015 May 8doi: 10.1111/1756-185x.12565. PMID: 25955771.25955771
92 Bagnato GL, Miceli G, Marino N, . Pulsed electromagnetic fields in knee osteoarthritis: a double blind, placebo-controlled, randomized clinical trial. Rheumatology (Oxford). 2016 Apr;55(4):755–62. doi: 10.1093/rheumatology/kev426. PMID: 26705327.26705327
93 Avelar NC, Simao AP, Tossige-Gomes R, . The effect of adding whole-body vibration to squat training on the functional performance and self-report of disease status in elderly patients with knee osteoarthritis: a randomized, controlled clinical study. J Altern Complement Med. 2011 Dec;17(12):1149–55. doi: 10.1089/acm.2010.0782. PMID: 22087576.22087576
94 Rabini A, De Sire A, Marzetti E, . Effects of focal muscle vibration on physical functioning in patients with knee osteoarthritis: a randomized controlled trial. Eur J Phys Rehabil Med. 2015 Oct;51(5):513–20. PMID: 25990196.25990196
95 Wang P, Yang L, Liu C, . Effects of Whole Body Vibration Exercise associated with Quadriceps Resistance Exercise on functioning and quality of life in patients with knee osteoarthritis: A randomized controlled trial. Clin Rehabil. 2015 Oct 1 doi: 10.1177/0269215515607970. PMID: 26427960.26427960
96 Wang P, Yang L, Li H, . Effects of whole-body vibration training with quadriceps strengthening exercise on functioning and gait parameters in patients with medial compartment knee osteoarthritis: a randomised controlled preliminary study. Physiotherapy. 2015 May 15 doi: 10.1016/j.physio.2015.03.3720. PMID: 26111989.26111989
97 Simao AP, Avelar NC, Tossige-Gomes R, . Functional performance and inflammatory cytokines after squat exercises and whole-body vibration in elderly individuals with knee osteoarthritis. Arch Phys Med Rehabil. 2012 Oct;93(10):1692–700. doi: 10.1016/j.apmr.2012.04.017. PMID: 22546535.22546535
98 Park YG, Kwon BS, Park JW, . Therapeutic effect of whole body vibration on chronic knee osteoarthritis. Ann Rehabil Med. 2013 Aug;37(4):505–15. doi: 10.5535/arm.2013.37.4.505. PMID: 24020031.24020031
99 Bokaeian HR, Bakhtiary AH, Mirmohammadkhani M, . The effect of adding whole body vibration training to strengthening training in the treatment of knee osteoarthritis: A randomized clinical trial. J Bodyw Mov Ther. 2016 Apr;20(2):334–40. doi: 10.1016/j.jbmt.2015.08.005. PMID: 27210851.27210851
100 Callaghan MJ, Parkes MJ. A randomised trial of a brace for patellofemoral osteoarthritis targeting knee pain and bone marrow lesions. 2015 Jun;74(6):1164–70. doi: 10.1136/annrheumdis-2014-206376. PMID: 25596158.25596158
101 Cherian JJ, Bhave A, Kapadia BH, . Strength and Functional Improvement Using Pneumatic Brace with Extension Assist for End-Stage Knee Osteoarthritis: A Prospective, Randomized trial. Journal of Arthroplasty. 2015 1;30(5):747–53. FULL TEXT LINK http://dx.doi.org/10.1016/j.arth.2014.11.036.25499679
102 Sattari S, Ashraf AR. Comparison the effect of 3 point valgus stress knee support and lateral wedge insoles in medial compartment knee osteoarthritis. Iran Red Crescent Med J. 2011 Sep;13(9):624–8. PMID: 22737536.22737536
103 Rodrigues PT, Ferreira AF, Pereira RM, . Effectiveness of medial-wedge insole treatment for valgus knee osteoarthritis. Arthritis and rheumatism; 2008. p. 603–8.18438931
104 Koca B, Oz B, Olmez N, . Effect of lateral-wedge shoe insoles on pain and function in patients with knee osteoarthritis. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi. 2009 December;55(4):158–62.
105 Hatef MR, Mirfeizi Z, Sahebari M, . Superiority of laterally elevated wedged insoles to neutrally wedged insoles in medial knee osteoarthritis symptom relief. Int J Rheum Dis. 2014 Jan;17(1):84–8. doi: 10.1111/1756-185x.12036. PMID: 24472270.24472270
106 Campos GC, Rezende MU, Pasqualin T, . Lateral wedge insole for knee osteoarthritis: randomized clinical trial. Sao Paulo Med J. 2015 Feb;133(1):13–9. doi: 10.1590/1516-3180.2013.6750002. PMID: 25626851.25626851
107 Wallace DA. Efficacy of lateral heel wedge orthotics for the treatment of patients with knee osteoarthritis. Oregon State University 2006
108 Toda Y, Tsukimura N. A 2-year follow-up of a study to compare the efficacy of lateral wedged insoles with subtalar strapping and in-shoe lateral wedged insoles in patients with varus deformity osteoarthritis of the knee. Osteoarthritis and Cartilage. 2006 March;14(3):231–7. MEDLINE PMID 1627148516271485 (http://www.ncbi.nlm.nih.gov/pubmed/16271485) FULL TEXT LINK http://dx.doi.org/10.1016/j.joca.2005.09.006.
109 Bennell KL, Bowles KA, Payne C, . Lateral wedge insoles for medial knee osteoarthritis: 12 Month randomised controlled trial. Bmj 2011;342 (7808) MEDLINE PMID 2159309621593096 (http://www.ncbi.nlm.nih.gov/pubmed/21593096) FULL TEXT LINK http://dx.doi.org/10.1136/bmj.d2912.
110 Goldenstein-Schainberg C, Fuller R, Matias A, . Effectiveness of long-term use of minimalist footwear on pain and function in knee osteoarthritis. Osteoporosis international; 2013. p. S139.
111 Trombini-Souza F, Matias A, Yokota M, . Beneficial effect of long-term use of a low-cost minimalist footwear on joint load, clinical, and functional aspects of elderly women with knee osteoarthritis. Arthritis and rheumatism; 2013. p. S918.
112 Trombini-Souza F, Matias AB, Yokota M, . Long-term use of minimal footwear on pain, self-reported function, analgesic intake, and joint loading in elderly women with knee osteoarthritis: A randomized controlled trial. Clin Biomech (Bristol, Avon). 2015 Aug 14doi: 10.1016/j.clinbiomech.2015.08.004. PMID: 26307181.26307181
113 Erhart JC, Mundermann A, Elspas B, . Changes in Knee Adduction Moment, Pain, and Functionality with a Variable-Stiffness Walking Shoe after 6 Months. Journal of Orthopaedic Research. 2010 Jul;28(7):873–9. 20058261
114 Erhart-Hledik JC, Elspas B, Giori NJ, . Effect of variable-stiffness walking shoes on knee adduction moment, pain, and function in subjects with medial compartment knee osteoarthritis after 1 year. J Orthop Res. 2012 Apr;30(4):514–21. doi: 10.1002/jor.21563. PMID: 21953877.21953877
115 Jones A, Silva PG, Silva AC, . Impact of cane use on pain, function, general health and energy expenditure during gait in patients with knee osteoarthritis: a randomised controlled trial. Ann Rheum Dis. 2012 Feb;71(2):172–9. doi: 10.1136/ard.2010.140178. PMID: 22128081.22128081
116 Azlin MNN, Lyn KS. Effects of Passive Joint Mobilization on Patients with Knee Osteoarthritis. Sains Malaysiana. 2011 Dec;40(12):1461–5.
117 Cheawthamai K, Vongsirinavarat M, Hiengkaew V, . A comparison of home-based exercise programs with and without self-manual therapy in individuals with knee osteoarthritis in community. J Med Assoc Thai. 2014 Jul;97 Suppl 7:S95–100. PMID: 25141536.25141536
118 Cortes Godoy V, Gallego Izquierdo T, Lazaro Navas I, . Effectiveness of massage therapy as co-adjuvant treatment to exercise in osteoarthritis of the knee: a randomized control trial. J Back Musculoskelet Rehabil. 2014;27(4):521–9. doi: 10.3233/bmr-140476. PMID: 24867903.24867903
119 Zhang Y, Shen CL, Peck K, . Training Self-Administered Acupressure Exercise among Postmenopausal Women with Osteoarthritic Knee Pain: A Feasibility Study and Lessons Learned. Evid Based Complement Alternat Med. 2012;2012:570431. doi: 10.1155/2012/570431. PMID: 23193423.23193423
120 Dwyer L, Parkin-Smith GF, Brantingham JW, . Manual and manipulative therapy in addition to rehabilitation for osteoarthritis of the knee: assessor-blind randomized pilot trial. J Manipulative Physiol Ther. 2015 Jan;38(1):1–21.e2. doi: 10.1016/j.jmpt.2014.10.002. PMID: 25455832.25455832
121 Perlman AI, Ali A, Njike VY, . Massage therapy for osteoarthritis of the knee: a randomized dose-finding trial. PLoS One. 2012;7(2):e30248. doi: 10.1371/journal.pone.0030248. PMID: 22347369.22347369
122 Atkins DV, Eichler DA. The effects of self-massage on osteoarthritis of the knee: a randomized, controlled trial. Int J Ther Massage Bodywork. 2013;6(1):4–14. PMID: 23482239.23482239
123 Ghroubi S, Elleuch H, Kaffel N, . [Contribution of exercise and diet in the management of knee osteoarthritis in the obese]. Annales de réadaptation et de médecine physique: revue scientifique de la Société française de rééducation fonctionnelle de réadaptation et de médecine physique; 2008. p. 663–70.
124 Miller GD, Nicklas BJ, Davis C, . Intensive weight loss program improves physical function in older obese adults with knee osteoarthritis. Obesity (Silver Spring). 2006 Jul;14(7):1219–30. doi: 10.1038/oby.2006.139. PMID: 16899803.16899803
125 Messier SP, Mihalko SL, Legault C, . Effects of intensive diet and exercise on knee joint loads, inflammation, and clinical outcomes among overweight and obese adults with knee osteoarthritis: the IDEA randomized clinical trial. Jama. 2013 Sep 25;310(12):1263–73. doi: 10.1001/jama.2013.277669. PMID: 24065013.24065013
126 Bliddal H, Leeds AR, Stigsgaard L, . Weight loss as treatment for knee osteoarthritis symptoms in obese patients: 1-year results from a randomised controlled trial. Ann Rheum Dis. 2011 Oct;70(10):1798–803. doi: 10.1136/ard.2010.142018. PMID: 21821622.21821622
127 Somers TJ, Blumenthal JA, Guilak F, . Pain coping skills training and lifestyle behavioral weight management in patients with knee osteoarthritis: a randomized controlled study. Pain. 2012 Jun;153(6):1199–209. doi: 10.1016/j.pain.2012.02.023. PMID: 22503223.22503223
128 Atukorala I, Makovey J, Lawler L, . Is there a dose response relationship between weight loss and symptom improvement in persons with knee osteoarthritis? Arthritis Care & Research. 2016;[Epub ahead of print] doi: 10.1002/acr.22805.
129 Makovey J, Lawler L, Bennell KL, . Dose response relationship between weight loss and improvement in quality of life in persons with symptomatic knee osteoarthritis. Osteoarthritis and Cartilage. 2015 April;23 SUPPL. 2:A386.
130 Claes BEA, Leung HWC, Matters K, . Interim analysis: An interdisciplinary team approach in facilitating weight reduction and improving function for people with knee or hip osteoarthritis. The Osteoarthritis Chronic Care Program at Royal North Shore Hospital. Nutrition & Dietetics. 2015 Sep;72(3):232–9.
131 Richette P, Poitou C, Garnero P, . Benefits of massive weight loss on symptoms, systemic inflammation and cartilage turnover in obese patients with knee osteoarthritis. Ann Rheum Dis. 2011 Jan;70(1):139–44. doi: 10.1136/ard.2010.134015. PMID: 20980288.20980288
132 Stefanik J, Felson DT, Niu J, . The Relation of Massive Weight Loss to Changes in Knee Pain and Sensitization [abstract]. 2015 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2015;67 (suppl 10):3251.
133 Coleman S, Briffa NK, Carroll G, . A randomised controlled trial of a self-management education program for osteoarthritis of the knee delivered by health care professionals. Arthritis Res Ther. 2012;14(1):R21. doi: 10.1186/ar3703. PMID: 22284848.22284848
134 Hochberg MC, Clegg DO. Potential effects of chondroitin sulfate on joint swelling: a GAIT report. Osteoarthritis Cartilage. 2008;16 Suppl 3:S22–4. doi: 10.1016/j.joca.2008.06.024. PMID: 18768335.18768335
135 Messier SP, Mihalko SL, Beavers DP, . Strength training for arthritis trial (START): Design and rationale. BMC Musculoskeletal Disorders 2013;14 (208) MEDLINE PMID 2385559623855596 (http://www.ncbi.nlm.nih.gov/pubmed/23855596) FULL TEXT LINK http://dx.doi.org/10.1186/1471-2474-14-208.
136 Kan L, Zhang J, Yang Y, . The Effects of Yoga on Pain, Mobility, and Quality of Life in Patients with Knee Osteoarthritis: A Systematic Review. Evid Based Complement Alternat Med. 2016;2016:6016532. doi: 10.1155/2016/6016532. PMID: 27777597.27777597
137 Duivenvoorden T, Brouwer Reinoud W, van Raaij Tom M, . Braces and orthoses for treating osteoarthritis of the knee. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015.
138 Anwer S, Alghadir A, Brismee JM. Effect of Home Exercise Program in Patients With Knee Osteoarthritis: A Systematic Review and Meta-analysis. J Geriatr Phys Ther. 2016 Jan–Mar;39(1):38–48. doi: 10.1519/jpt.0000000000000045. PMID: 25695471.25695471
139 Button K, Roos PE, Spasic I, . The clinical effectiveness of self-care interventions with an exercise component to manage knee conditions: A systematic review. Knee. 2015 Oct;22(5):360–71. 26056046
140 Regnaux JP, Lefevre-Colau MM, Trinquart L, . High-intensity versus low-intensity physical activity or exercise in people with hip or knee osteoarthritis. Cochrane Database Syst Rev. 2015;10:Cd010203. doi: 10.1002/14651858.CD010203.pub2. PMID: 26513223.26513223
141 Tubach F, Ravaud P, Martin-Mola E, . Minimum clinically important improvement and patient acceptable symptom state in pain and function in rheumatoid arthritis, ankylosing spondylitis, chronic back pain, hand osteoarthritis, and hip and knee osteoarthritis: Results from a prospective multinational study. Arthritis Care Res (Hoboken). 2012 Nov;64(11):1699–707. doi: 10.1002/acr.21747. PMID: 22674853.22674853
142 McAlindon TE, Driban JB, Henrotin Y, . OARSI Clinical Trials Recommendations: Design, conduct, and reporting of clinical trials for knee osteoarthritis. Osteoarthritis Cartilage. 2015 May;23(5):747–60. doi: 10.1016/j.joca.2015.03.005. PMID: 25952346.25952346
143 Cho JJ, Kim TW, Park YM, . Tissuegene-C (InvossaTM) in patients with osteoarthritis: A phase II trials. Cytotherapy. 2015 June;17(6 SUPPL. 1):S84.
144 Cho J, Kim T, Park Y, . Tissuegene-C (Invossa™) in patients with osteoarthritis: A phase II trials. Osteoarthritis and Cartilage. 2015 April;23 SUPPL. 2:A170.
145 Lee B, Cho J, Kim T, . Tissuegene-C (TG-C), TGF-β1 transduced chondrocyte, improved clinical scores in patients with osteoarthritis: A phase 2B study. Molecular Therapy. 2014 June;22 SUPPL. 1:S292–S3.
146 Ha CW, Cho JJ, Elmallah RK, . A Multicenter, Single-Blind, Phase IIa Clinical Trial to Evaluate the Efficacy and Safety of a Cell-Mediated Gene Therapy in Degenerative Knee Arthritis Patients. Hum Gene Ther Clin Dev. 2015 Jun;26(2):125–30. doi: 10.1089/humc.2014.145. PMID: 25760423.25760423
147 Messier SP, Callahan LF, Golightly YM, . OARSI Clinical Trials Recommendations: Design and conduct of clinical trials of lifestyle diet and exercise interventions for osteoarthritis. Osteoarthritis and Cartilage. 2015 May;23(5):787–97. 25952349
148 Fitzgerald GK, Hinman RS, Zeni J, Jr., . OARSI Clinical Trials Recommendations: Design and conduct of clinical trials of rehabilitation interventions for osteoarthritis. Osteoarthritis Cartilage. 2015 May;23(5):803–14. doi: 10.1016/j.joca.2015.03.013. PMID: 25952351.25952351