# Methods

The methods used to conduct the systematic review portion of this continuous update are based on the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^15^

## Criteria for Inclusion/Exclusion of Studies in the Review

Included studies are limited to those that fit the inclusion and exclusion criteria listed in Table 1.

Studies in any clinical setting were included as long as they satisfied all other inclusion/exclusion criteria. The results of the report are intended for primary care and acute care settings, and therefore primary and acute settings are preferred. For studies of efficacy and effectiveness, we endeavored to include only randomized controlled trials. However, in the absence of relevant randomized controlled trials, observational studies were included. Observational studies were also included if they reported rare adverse events. Case reports were excluded.

Existing systematic reviews were also considered for inclusion both as sources of original data (reference mining) and for their conclusions, following the methods proposed by Whitlock and colleagues.^18^

### Searching for the Evidence

The inclusion/exclusion criteria by target population, interventions, outcomes, comparators, setting, and study duration are shown in Table 1. Study design and several additional criteria pertaining to the PICOTs (the Population, Intervention, Comparison, Outcome, Timing, Study Design, and Setting that describe the scope of the review) are discussed here and below.

English language studies and those with an English–language abstract were included, if resources were available for translation. We excluded publications with both nonEnglish abstracts and text, because of limited resources. Studies that test interventions that were not available in the US were also excluded. Studies that assessed the effects of glucosamine and/or chondroitin were included only if they enrolled 50 participants or more per arm because of the number of very large clinical trials. Conference proceedings and letters that reported unique data and that reported sufficient information to enable assessment of risk of bias were included.

With the exception of weight loss trials, we limited included studies for assessment of efficacy to randomized controlled trials. We included single-arm trials and prospective cohort studies for weight loss. We included prospective observational studies that reported on adverse events associated with use of the interventions of interest for the treatment of osteoarthritis (OA) of the knee.

Studies without participant and assessor blinding were excluded for dietary supplements and cell-based therapies, based on the findings of prior reviews that the results of such studies can bias the results. However, for studies of physical therapies for which it is difficult to design a placebo control and implement participant blinding, we included studies in which the intervention group was not blinded to their assignment. Studies that compared an intervention of interest only to an intervention with no demonstrated evidence of efficacy (or unclear evidence of efficacy, such as intraarticular hyaluronic acid) were excluded. Also, studies that combined interventions were included only if the control “intervention” allowed assessment of the specific intervention of interest (e.g., neuromuscular electrical stimulation [NMES] plus strength training versus strength training). Studies were not excluded simply because of low study quality (risk of bias).

The searches commenced with the year 2006, one year prior to the latest search dates of the original review we are updating.^7^ However, because we are also updating topics covered in an EPC review conducted in 2012,^19^ we did not re-review studies included in (or actively excluded from) that review unless the study included a treatment group or outcome of interest that the original review did not evaluate. Similarly, when we identified recent systematic reviews on other included topics (e.g., braces and orthotics) that match our review in Key Questions, outcomes of interest, and exclusion/inclusion criteria, we weighed the feasibility of updating those reviews with any newer original studies rather than simply using those reviews as sources of references and conducting entirely new reviews (see Data Synthesis/Analysis). However, ultimately, we did not include any prior systematic reviews as sources of evidence. The full search methodology is in Appendix A. An update search was conducted in September 2016.

#### Literature Search Strategies for Identification of Relevant Studies To Answer the Key Questions

Based on the methods used for the original report and recent reviews on similar topics, we searched the following databases for peer reviewed literature (dates discussed above): PubMed, EMBASE, the Cochrane Collection, Web of Science, and the Physiotherapy Evidence Database (PEDRO). Based on pilot searches of these databases, we did not include PEDRO search results.

The Web of Science and ClinicalTrials.gov was searched for grey literature and as-yet unpublished peer-reviewed articles, respectively; and the abstracts from the past year of professional practice society annual meetings (e.g., American College of Rheumatology, American Academy of Orthopaedic Surgery) were hand searched by members of the team with the appropriate clinical expertise. In addition, relevant stakeholders, including manufacturers of over-the-counter and prescription medications and medical devices used to treat OA of the knee were contacted by the Evidence-based Practice Center (EPC) Program’s Scientific Resource Center for scientific information packets that contain any unpublished information on the efficacy and/or safety of their products when used specifically to treat OA of the knee; no information was obtained from manufacturers. A notice was also placed in the Federal Register requesting any relevant information on the use of dietary supplements containing glucosamine or chondroitin to treat OA of the knee.

Titles identified by literature searches were screened by pairs of experienced literature reviewers using prespecified criteria, without reconciliation of decisions. Abstracts of those titles selected for inclusion by one or both reviewers were dually screened using prespecified criteria, with disagreements reconciled by the project leaders, if necessary. Full text articles or other documents were obtained for included abstracts. DistillerSR™ software was used for screening, abstraction, reconciliation, and tracking. A 10-percent sample of titles for which no abstract could be identified in the databases was obtained and reviewed in full-text to determine whether we should obtain the full-text publications for all titles of interest that lack an abstract. Such publications are typically commentaries, editorials, and letters to journal editors without original data. Based on the sample screen, which identified no studies that met inclusion criteria, we determined that these publications would not be screened further.

Any references that were suggested by members of the TEP, peer reviewers, or public reviewers were obtained and underwent the same screening and abstraction process. Reference lists from recent systematic reviews on the topics of interest were also screened for relevant articles that had not appeared in the search output.

We conducted an update search during peer review and included the relevant studies from the update search into the final report.

### Data Abstraction and Data Management

Study-level details were dually abstracted by the reviewers, using abstraction forms designed and piloted by the group (with at least two design iterations and some 10 to 25 articles piloted per iteration, as suggested by the issues that arose during piloting). Disagreements were reconciled between reviewers with mediation by the project leaders if needed. NonEnglish articles were obtained and abstracted only if a native or knowledgeable speaker was identified. Outcome data were abstracted by experienced reviewers and an experienced biostatistical analyst and audited by an experienced reviewer. Risk of bias was assessed by one reviewer and audited by a second reviewer with extensive systematic review experience. If primary outcome data appeared to be lacking for a particular study, we did not contact study authors.

Studies that reported outcomes in multiple publications were noted, the publications mapped, and the records linked in Distiller to ensure consistency and avoid duplication of descriptions of study conditions. In such cases, risk of bias (RoB) was assessed at the publication (rather than at the study) level.

The following study-level details were abstracted: mean participant age (by study or study arm), sex, mean body mass index, OA diagnoses (stage, pain levels, functional status and activity level), relevant comorbidities, concurrent or prior treatments; numbers of participants enrolled and numbers who completed; inclusion/exclusion criteria; interventions and comparators, type and location of study site; number of sites; study and investigator funding; and potential conflicts of interest. Information collected as part of assessing risk of bias is described below.

### Assessment of Methodological Risk of Bias of Individual Studies

For randomized controlled trials, we employed the Cochrane Risk of Bias Assessment tool to assess RoB of individual studies. We also incorporated a small number of items from the PEDro risk of bias assessment tool. A recent analysis finds that the tools produce different assessments of the same studies, with the Cochrane tool providing a more rigorous assessment.^20^ Characteristics assessed included evidence of accepted methods for ensuring unbiased recruitment, randomization, and allocation concealment (selection bias); participant blinding (performance bias); assessor blinding (detection bias); description of prespecified outcomes (reporting bias); retention (attrition bias), and adherence, use of intention-to-treat analysis, and power calculation (other bias). For each of ten such factors, we assessed whether the factor contributed to a low, high, or unclear risk of bias. Based on the overall assessment, studies were rated as having a low, moderate, high, or unclear risk of bias.

We used the McHarms scale to assess the quality of adverse event assessment and reporting. Adverse events whose numbers were reported separately by treatment group were abstracted and categorized as being serious or nonserious.^21^

### Data Synthesis/Analysis

Results of included studies are described by intervention type. Within each intervention type, studies are described by duration of followup and by outcome type (pain, function, and other). Results of studies that compared different interventions head to head are described in the sections of the Results chapter that pertain to each of the interventions of interest.

Effect sizes and confidence intervals were calculated for each outcome based on differences at follow-up (baseline values were assumed to be statistically similar).

In the case of a continuous outcome, the primary measure collected was the follow-up mean and standard deviation. If the follow-up mean was not reported, then the mean change from baseline was collected. If the standard deviation or standard errors were not reported and could not be calculated from a confidence interval, then the interquartile range or range of the scale was used to estimate a standard error. For binary outcomes, we collected the number of people with the event of interest.

For continuous measures, standardized mean differences were calculated using Cohen’s d. Risk ratios were calculated for binary outcomes.

Outcome data were stratified by length of time from baseline. Short-term outcomes were 4 to 12 weeks, medium-term outcomes were 12 to 26 weeks, and long-term outcomes were longer than 26 weeks. If a study reported outcomes at more than one short-, medium-, or long-term time period, we abstracted the longer one(s).

If three or more studies reported the same outcome measure for the same intervention during the same follow-up time period, we pooled the outcomes using the Hartung Knapp method for random effects meta-analysis.^22^ Because some studies did not report the scales used for outcome measures and because it was not always possible to determine the scales from the data, we report pooled outcomes as standardized mean differences; we did not pool studies that used different tools to measure a similar outcome (e.g., the Visual Analog Scale [VAS] and the Western Ontario and McMaster Universities Arthritis Index [WOMAC] pain measures), as two tools used in the same study on the same participant population sometimes resulted in different outcomes. If a study reported outcomes for pain or function using multiple outcome measures, all outcomes were abstracted, but WOMAC outcomes were given preference in analyses. The findings of meta-analyses are reported quantitatively with forest plots. All studies for which results are included in the report are described qualitatively (narratively) by the type of intervention and the duration of followup. Descriptions of studies of similar interventions were grouped by outcome measures when feasible.

For pooled studies with significant outcomes, we assessed whether these outcomes met a prespecified minimum clinically important difference (MCID). If studies reported whether their outcomes met a prespecified MCID or improvement (MCII) or reported on the percent of participants who achieved a response, we noted that in the narrative descriptions.

### Grading the Strength of Evidence (SoE) for Major Comparisons and Outcomes

We rated the strength of evidence (SoE) of each intervention-outcome-followup time based on the AHRQ Methods Guide. Domains include the following:

- Study limitations (study design, risk of bias [RoB],
- Overall methodological quality),
- Consistency of the direction of effect sizes across studies, or within a single study, if the study reported the same outcome using more than one assessment tool).
- Precision of the estimate (including number of studies), assessed in terms of the similarity in effect sizes, the average variance, and the numbers of studies
- Directness of the relationship between outcomes measured and the clinical outcomes of interest, and
- Magnitude of the effect size.

Based on these domains, we rated the SoE for each comparison of interest as high, moderate, low, or insufficient (if no or too few studies were identified that addressed the outcome):

- High strength of evidence: We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, i.e., another study would not change the conclusions
- Moderate strength of evidence: We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains
- Low strength of evidence: We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect
- Insufficient evidence: We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion

For outcomes for which no pooling was possible, we estimated a rating based on qualitative assessment of the individual studies that met the inclusion criteria. Overall study quality was assessed identically as for pooled studies (considering study design and average RoB). Factors that led to downgrading of SoE were lack of pooling, number of studies fewer than three, inconsistency across or within studies, imprecision (confidence intervals wider than approximately four times the effect size), and poor study quality. Directness was rated but was not a factor, as only studies with clinical outcomes were included. We rated applicability of participant populations and interventions separately, as described below.

Trial design was considered in grading SoE as it was a factor in considering study quality. For assessments of safety, we considered the consistency of the findings across trials in assigning a SoE grade.

### Assessing Applicability

We considered applicability of participants and interventions separately from our assessment of directness for SoE. For assessing applicability of participant populations, studies that enrolled younger age populations (mean age less than 50), those with only early stage or mild disease, those enrolling participants with mean BMI less than 25, or those with a higher activity level at baseline were considered less applicable.

For assessing applicability of interventions, studies of interventions with very high adherence (especially physical activity) were considered somewhat less applicable than studies with lower adherence.

Follow-up times for studies of OA are nearly always too short for a chronic, progressive disease. Studies with shorter maximum follow-up times (less than 3 months) were considered to have lower applicability.

### Peer Review and Public Commentary

A draft version of the draft report was posted for peer review and for public comments on September 12, 2016, and revised in response to comments. However, the findings and conclusions are those of the authors, who are responsible for the contents of the report.