# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Rowland W. Chang, M.D., M.P.H
  Northwestern University Feinberg School of Medicine
  Chicago, IL
- G. Kelley Fitzgerald, P.T., Ph.D., FAPTA
  University of Pittsburgh
  Pittsburgh, PA
- Nancy Lane, M.D.
  Department of Internal Medicine
  University of California, Davis
  Davis, CA
- Jamal Mikdashi, M.D.
  Associate Professor
  University of Maryland School of Medicine
  Baltimore, MD