# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- David Felson, M.D.
  Boston University
  Boston, MA
- Mark D. Grant, M.D., Ph.D.^*^
  Blue Cross Blue Shield Association
  Chicago, IL
- David S. Jevsevar, M.D., M.B.A.^*^
  Geisel School of Medicine at Dartmouth
  Hanover, NH
- Jeffrey N. Katz, M.D., M.S.^*^
  Brigham and Women’s Hospital
  Boston, MA
- Julie J. Keysor, Ph.D, P.T.^*^
  Boston University
  Boston, MA
- Gayle Lester, Ph.D. ^*^
  National Institute of Arthritis and Musculoskeletal and Skin Diseases
  National Institutes of Health
  Bethesda, MD
- Jyme Schafer, M.D., M.P.H.
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Neil Segal, M.D.^*^
  Dr. George Varghese Professor of Rehabilitation Medicine
  Department of Rehabilitation Medicine
  University of Kansas Medical Center
  Kansas City, KS

* Provided input on Draft Report.