# Acknowledgments

The authors gratefully acknowledge Patricia Smith for her administrative support on the project.