# Appendix I MCID Cutoffs

Table I1 MCID cutoffs developed or used in a representative sample of articles

Author, Year | Condition/Intervention/FU | Cutoffs | Notes
Eberle, 1999 PMID: 10489324 (http://www.ncbi.nlm.nih.gov/pubmed/10489324) | Knee OA HA injection, 6 month followup | VAS pain: 8.4mm on a 0–100 mm scale; 0.7 points on Lequesne 24-point scale | Anchor question: complaints reduced
Angst 2001 PMID:11501727 | Knee or hip OA Rehabilitation, 3 month followup | WOMAC pain: 0.75 (0–10 scale) WOMAC function and total: 0.67 SF-36 physical function: 3.3 (0–100 scale) | Anchor question: current subjective health much better, slightly better, no change, slightly worse... Converted all 5 WOMAC pain item scores to a 0–10 scale and took the average) Separate values for worsening and improvement
Salaffi 2004 PMID: 15207508 (http://www.ncbi.nlm.nih.gov/pubmed/15207508) | Chronic musculoskeletal pain (OA knee, OA hip, AS, RA, OA hand) Not described | NRS: 15% or 1 point decrease for minimum improvement, 33% or 2 points for much better (which they regarded as clinical improvement) | Anchor: Patient global impression of change
Tubach 2005 PMID:15208174 (http://www.ncbi.nlm.nih.gov/pubmed/15208174) | Knee or hip OA NSAIDs, 4 weeks | Knee: VAS pain: −19.9mm (−40.8%) WOMAC function: −9.1(−26%) | WOMAC 17 items, 5-point likert scale, total score normalized to 0–100 scale MCII Initial severity affected MCII but age, disease duration, and sex did not
Wandel 2010 PMID: 20847017 | Knee or hip OA Glucosamine-chondroitin vs. placebo network MA | MCID 0.37 SD units, corresponding to 0.9cm (0–10cm VAS scale) | Median pooled SD of 2.5cm used to back transform effect sizes to 10cm VAS scale
OMERACT-OARSI responder criteria Pham 2003 PMID: 12858473 | Knee or hip OA | Clinical response was defined as either; 1. improvement of at least 50% in pain or function and an absolute change of at least 20 points on a scale of 0–100 in the WOMAC pain or function subscores, or; 2. at least 2 of the following criteria: improvement of at least 20% and an absolute change greater than 10 points on a scale of 0–100 in the WOMAC pain score, improvement of at least 20% and an absolute change greater than 10 points (on a 0–100 scale) in the WOMAC function score, or improvement of at least 20% in the patient Global Assessment score and an absolute change >10 points on a scale of 0–100 | WOMAC pain and function scales converted to single 0–100 scores.