# Appendix H Adverse Events

Table H1 Adverse events by treatment (number (%))

Table H1a Platelet-rich plasma (PRP)

Reference | Type | Control | PRP 1 injection | PRP 2 injections
Patel, 2013^23^ | Pain and stiffness | 0 | 6(22.22) | 11(44.00)
| Adverse events (AEs) | 0 | 4(14.8) | 3(12)
Rayegani, 2014^25^ | Significant Complications | 0 | 0
Simental-Mendia, 2016^27^ | Major AEs | 0 | 0
| Pain | 0 | 1(3.0) | 0

Table H1b Glucosamine/chondroitin

Reference | Type | Control | Glucosamine | Chondroitin | Glucosamine+ chondroitin | Celecoxib
Hochberg, 2008^134^ | Death | 0 | 0 | 0 | 0 | 0
| Non-fatal myocardial infarction (MI) | 0 | 0 | 0 | 0 | 0
| GI bleed | 0 | 0 | 0 | 0 | 0
| Cerebrovascular accident (CVA) | 0 | 0 | 0 | 0 | 1 (0.31)
| Transient ischemic attack (TIA) | 0 | 1(0.32) | 0 | 0 | 1(0.31)
| Withdrawal (w/d) due to AE | 11(3.52) | 9(2.84) | 20(6.29) | 12(3.79) | 7(2.20)
Kahan, 2009^38^ | Good or very good tolerability | 291(93) | | 290(94)
| GI side effects | 18(5.9) | | 19(6)
| W/d due to AEs | 17(5) | | 16(5)
Sawitzke, 2010^28^ | MI | 0 | 1(0.75) | 0 | 2(1.55) | 0
| Coronary angioplasty | 1(0.76) | 0 | 0 | 0 | 0
| Hip arthroplasty | 0 | 0 | 0 | 0 | 1(0.70)
| CVA | 0 | 0 | 1(0.75) | 0 | 2(1.41)
| Abdominal wall abscess | 0 | 0 | 0 | 0 | 1
| Suicide | 1(0.76) | 0 | 0 | 0 | 0
| HTN | 1(0.76) | 0 | 0 | 1(0.78) | 0
| Palpitations | 0 | 0 | 0 | 1 | 0
| TIA | 0 | 0 | 0 | 1 | 0
| Serious GI bleed | 0 | 0 | 0 | 0 | 0
Fransen, 2014^31^ | W/d due to AE | 8(5.30) | 8(5.26) | 11(7.28) | 7(4.6)
| w/d due to blood glucose issues | 1(0.66) | 0 | 1(0.66) | 0
| W/d due to cardiac | 1(0.66) | 0 | 0 | 3(1.98)
| W/d due to GI, rash | 5(3.31) | 4(2.63) | 4(2.64) | 2(1.32)
| | Diet alone | | | G/C+ diet
Bellare, 2014^30^ | SAE | 0 | | | 0
Hochberg, 2016^29^ | AEs | | | | 22(7.24) | 22(7.36)

Table H1c Chondroitin

Reference | Type | Control | 1200mg Chondroitin qd/400mg tid
Zegels, 2013^37^ | Serious AE | 2(1.7) | 2(1.7)/4(3.41)
| AEs related to treatment | 49(41) | 31(26)/31(26)

Table H1d Strength training

Reference | Type | Control | Exercise
Oliveira, 2012^47^ | Exercise intolerance | 0 | 2(4)
Foroughi, 2011^52^ | Minor AEs | 1(3.57) | 0
Imoto, 2012^48^ | Significant knee inflammation | 0 | 2(4)
Jorge, 2015^49^ | Knee pain | 0 | 3(10.3)

Table H1e Agility training

Reference | Type | Control | Exercise
Knoop, 2013^61^ | Any serious AEs | 0 | 0
Fitzgerald, 2011^55^ | Serious AEs | 0 | 0

Table H1f Yoga

Reference | | Control | Yoga
Cheung, 2014^71^ | AEs | 0 | 0

Table H1g Manual therapy

Reference | | Control | Exercise | Exercise + booster | Exercise + manual therapy | Exercise + booster+ manual therapy | Massage/Acupressure
Abbott, 2015^65^ | Hip pain | | 1(5.62) | 0 | 0 | 0
| Fall on knee associated with exercise | | 0 | 0 | 0 | 1(5.62)
Zhang, 2012^119^ | AEs | 0 | | | | | 0
Perlman, 2012^121^ | Any AEs | 0 | | | | | 0(30–120-minutes per week
Dwyer, 2015^120^ | Any AEs | | 0 | | 0 | | 0

Table H1h Infrared (IR)

Reference | | Control | IR
Hsieh, 2012^78^ | AEs | 0 | 0

Table H1i Mud bath

Reference | | Control | Mud bath
Fioravanti, 2015^75^ | Mild hypotension | 0 | 3(5.66)
| Febrile episode | 0 | 1(1.89)
| Gastric pyrosis | 3(6) | 0
| Epigastralgia | 2(4) | 0

Table H1j Braces

Reference | | Control | Brace
Callaghan, 2015^100^ | Bilateral leg swelling | 0 | 1(1.59)
Cherian, 2015^101^ | Severe AEs | 0 | 0
| Minor irritation at pad placement sites | 0 | 1(6.90)

Table H1k Orthotics

Reference | | Control | Insole
Bennell, 2011^109^ | Back pain | 1(1.03) | 9(8.74)
| Foot pain | 14(14.43) | 32(31.07)
| Uncomfortable or difficulty fitting in shoes | 4(4.12) | 15(14.56)
| Increased knee pain | 5(5.14) | 2(1.94)
| Instability | 1(1.03) | 0
| Self-reported problems with insoles | 21(21.65) | 42(40.78)
Rodrigues, 2008^103^ | Mild discomfort | 1(7.14) | 0
Campos, 2015^106^ | Ankle pain | 4(13.79) | 5(17.24)

Table H1l Minimalist shoe

Reference | | Control | Shoe
Erhart, 2010^113^ | Hip pain | 1(2.56) | 0
| Shoe discomfort | 4(10.26) | 1(2.5)
| Foot pain | 2(5.13) | 0
| Sciatic pain | 0 | 1(2.5)
| Meniscectomy | 2(5.2) | 1(2.5)
| TKR | 1(2.56) | 0

Table H1m TENS

Reference | | Sham TENS | TENS
Atamaz, 2012^87^ | Worsening of symptoms | 3(8.11) | 3(8.11)
Gschiel, 2010^86^ | AEs | 0 | 0

Table H1n NMES

Reference | | Sham NMES | NMES
Elboim-Gabyzon, 2013^85^ | Pneumonia | 1(3.03) | 1(3.33)
Laufer, 2014^82^ | Adverse reaction to treatment | 0 | 0
Imoto, 2013^84^ | Hypertensive crisis | 0 | 1(2)
| | Exercise | NMES + exercise
Mizusaki Imoto, 2013^83^ | Blood pressure spike | 0 | 1

Table H1o Whole body vibration

Reference | | Control | Treated
Rabini, 2015^94^ | AEs | 0 | 0
Wang, 2015^95^ | AEs | 0 | 0
Wang, 2015^96^ | Slight low back pain | 0 | 1(5.62)
| Severe AEs | 0 | 0
Park, 2013^98^ | Any AE | 0 | 1(9.09)

Table H1p Weight loss

Reference | | Control | Exercise | Diet | Diet + exercise
Messier, 2013^125^ | Heart palpitations | | 1 | 0 | 0
| ALS | | 0 | 0 | 1(0.66)
| Stroke | | 0 | 0 | 1(0.66)
| Lung HTN | | 0 | 0 | 1(0.66)
| Lung infection | | 0 | 0 | 1(0.66)
| Cancer | | 1(0.66) | 1(0.67) | 2(1.32)
| Staph infection | | 0 | 0 | 1(0.66)
Ghroubi, 2008^123^ | Worsening knee pain | 0 | 0 | 0 | 0
Christensen, 2015^62^ | Nausea | 1(1.56) | 8(12.5) | 3(4.69)
| Diarrhea | 4(6.2) | 6(9.38) | 3(4.69)
| Constipation | 8(12.5) | 7(10.94) | 9(14.06)
| Flatulence | 14(21.88) | 10(15.63) | 19(29.69)
| Epigastric pain | 1(1.56) | 7(10.94) | 6(9.38)
| Vomiting | 1(1.56) | 4(6.25) | 3(4.69)
| Abdominal pain | 3(4.69) | 4(6.25) | 6(9.38)
| Heartburn | 3(4.69) | 9(14.06) | 3(4.69)
| Biliary symptoms | 0 | 4(6.25) | 2(3.13)
| Cramps | 8(12.5) | 7(10.93) | 6(9.38)
| Joint pain | 12(18.75) | 12(18.75) | 15(23.44)
| Back pain | 10(15.62) | 6(9.38) | 11(17.19)
| Swollen joints | 11(17.19) | 10(15.63) | 11(17.19)
| Sciatic pain | 9(14.06) | 7(10.94) | 4(6.25)
| Dizziness | 8(12.5) | 10(15.63) | 7(10.94)
| Headache | 5(7.81) | 12(18.75) | 6(9.38)
| Anxiety | 2(3.13) | 5(7.81) | 3(4.69)
| Sleeplessness | 11(17.18) | 11(17.19) | 6(9.38)
| Fatigue | 12(18.75) | 13(20.31) | 8(12.5)
| Mood changes | 5(7.81) | 13(20.31) | 5(7.81)
| Depressive tendencies | 4(6.25) | 5(7.81) | 6(9.38)
| Dry skin | 6(9.38) | 6(9.38) | 4(6.25)
| Allergic rash | 4(6.25) | 7(10.94) | 5(7.81)
| Redness | 2(3.13) | 7(10.94) | 4(6.25)
| Eczema | 3(4.69) | 5(7.81) | 4(6.25)
| Perianal itching | 2(3.13) | 11(17.2) | 5(7.81)
| Skin irritation | 3(4.69) | 8(12.5) | 5(7.81)
| Urticaria | 1(1.56) | 3(4.69) | 3(4.69)
| Cold sensitivity | 6(9.38) | 8(12.5) | 9(14.06)
| Influenza | 2(3.13) | 5(7.8) | 7(10.9)
| Hair loss | 2(3.13) | 7(10.9) | 5(7.8)
| Bad breath | 5(7.8) | 9(14.06) | 6(9.38)
| Toothache | 4(6.25) | 6(9.38) | 4(6.25)
Bliddal, 2011^126^ | Constipation | | | 5(11.36)
| Increased flatulence | | | 4(9.09)
| Dizziness | | | 2(4.55)
| Heightened cold sensitivity | 0 | | 2(4.55)

Table H1q Pain Coping Skills Training (PCST)

Reference | Type | Control | Exercise | PCST | PCST+ exercise | Weight management | PCST+ weight management
Bennell, 2015^53^ | Number reporting AEs during treatment | | 28(37.33) | 4(5.4) | 24(37.3)
| Number AEs during treatment | | 38(50.67) | 7(9.46) | 31(42.47)
| Increased knee pain during treatment | | 22(29.33) | 2(2.70) | 15(20.55)
| Pain in other regions during treatment | | 11(14.67) | 3(5.05) | 11(15.07)
| Swelling/inflammation during treatment | | 2(2.67) | 2(2.70) | 2(2.74)
| Increased stiffness during treatment | | 2(2.67) | 0 | 3(4.11)
| Knee instability during treatment | | 1(1.33) | 0 | 0
| Number participants reporting AEs during followup | | 12(16) | 4(5.41) | 7(9.59)
| Number of AEs during followup | | 15(20) | 4(5.41) | 8(10.96)
| Increased knee pain during followup | | 6(8) | 4(5.41) | 3(4.11)
| Pain in other regions during follow-up | | 7(9.33) | 0 | 2(2.74)
| Swelling/inflammation during followup | | 2(2.67) | 0 | 2(2.74)
| Increased stiffness during followup | | 0 | 0 | 1(1.37)
Somers, 2012^127^ | Fall from treadmill | 0 | | 0 | | 0 | 1(1.61)

Table H1r Self-management

Reference | Type | Control | Self-Management
Coleman, 2012^133^ | Number with serious AEs | 0 | 0

Table H1s Aerobic training

Reference | Type | Control | Aerobic
Salacinski, 2012^43^ | AEs | 0 | 0

Table H1t General exercise

Reference | Type | Control | Aerobic
de Rooij, 2016^66^ | Serious AEs | 0 | 0