# Appendix G Policies, Guidelines, Coverage, and Stakeholder Information on Interventions of Interest

Table G1 Policies, guidelines, coverage, stakeholder information on interventions of interest

Intervention | Current Guidelines | FDA Approval for Indicated Use | CMS Coverage
Glucosamine Chondroitin | ACR: Conditional recommendation against use AAOS: Recommendation against use glucosamine and chondroitin (strong) | Evidence insufficient to demonstrate reduction in risk or disease modification (2004) Unclear regarding treatment of symptoms | Not relevant (over-the-counter)
Platelet Rich Plasma | ACR: not mentioned AAOS: unable to recommend for or against growth factor injections and/or platelet rich plasma (inconclusive) | Off-label use for an FDA-approved product | CMS National Coverage Determination: covered only for certain chronic non-healing wounds
Mesenchymal Stem Cells | ACR: not mentioned AAOS: not mentioned | Not approved by the FDA | Not covered for OA National Coverage Determination for Stem Cell Transplantation: https://www.cms.gov/medicare-coverage-database/details/ncd-details.aspx?NCDId=45&ncdver=5&NCAId=9&IsPopup=y&bc=AAAAAAAAAgAAAA%3D%3D&
Weight loss | ACR: strongly recommends weight loss (for persons who are overweight) AAOS: suggests weight loss for patients with symptomatic osteoarthritis of the knee OAK and a BMI ≥ 25. (moderate) | Not searched | Bariatric Surgery for the Treatment of Morbid Obesity Certain procedures for the treatment of obesity are covered for Medicare beneficiaries who have a BMI ≥35, have at least one co-morbidity related to obesity and have been previously unsuccessful with the medical treatment of obesity. https://www.cms.gov/medicare-coverage-database/details/ncd-details.aspx?NCDId=57&ncdver=5&NCAId=258&NcaName=Bariatric+Surgery+for+the+Treatment+of+Morbid+Obesity&IsPopup=y&bc=AAAAAAAACAAAAA%3D%3D&. Other Treatments for Obesity Nationally Noncovered Indications; 1. Treatments for obesity alone remain non-covered.; 2. Supplemented fasting is not covered under the Medicare program as a general treatment for obesity, with certain exceptions.; Where weight loss is necessary before surgery in order to ameliorate the complications posed by obesity when it coexists with pathological conditions such as cardiac and respiratory diseases, diabetes, or hypertension (and other more conservative techniques to achieve this end are not regarded as appropriate), supplemented fasting with adequate monitoring of the patient is eligible for coverage on a case-by-case basis or pursuant to a local coverage determination. The risks associated with the achievement of rapid weight loss must be carefully balanced against the risk posed by the condition requiring surgical treatment
Physical therapy | ACR: conditionally recommends receiving manual therapy in combination with supervised exercise. AAOS: Not found specifically on physical therapy, although there were studies presented [unless if the following: “We are unable to recommend for or against the use of physical agents (including electrotherapeutic modalities) in patients with symptomatic osteoarthritis of the knee. (inconclusive)” “We are unable to recommend for or against manual therapy in patients with symptomatic osteoarthritis of the knee. (inconclusive)”] | Not relevant | Covered under Part B subject to certain conditions and limitations
TENS/NMES | ACR: conditionally recommends instruction in use of TENS AAOS: found insufficient evidence supporting use of TENS | | Medicare Part B may cover a TENS unit for a patient who has been suffering from chronic pain for at least three months, for which other, standard pain relief methods have failed
Braces and/or orthotics (orthoses or wedges) | ACR: conditionally recommends using medially directed patellar taping; wearing medially wedged insoles if a patient with OAK has lateral compartment OA, wearing laterally wedged subtalar strapped insoles if a patient with OAK have medial compartment OA; has no recommendations on wearing laterally wedged insoles and wearing knee braces. AAOS: cannot suggest that lateral wedge insoles be used for patients with symptomatic medial compartment osteoarthritis of the knee. (moderate) | Unloader braces are approved by the FDA as medical equipment [need to check orthotics] | Medicare Part B covers medically necessary arm, leg, back, and neck braces under the durable medical equipment prefabricated orthotics benefit, subject to certain conditions and limitations. Shoes and foot orthotics are covered under certain circumstances only when criteria are met.