# Appendix F Quality of Included Studies

Table F1 Quality assessment of randomized controlled trials (N=107 studies)

Author, year | Allocation Sequence Generated Adequately | Allocation Treatment Adequately Concealed | Participants or Healthcare Provider Adequately Blinded | Outcome Assessors Blinded | Incomplete outcome data (Attrition bias) due to amount, nature or handling of incomplete outcome data | Selective Outcome Reporting | Intention-to-treat | Group Similarity at Baseline (general) | Incomplete Adherence/Compliance with Interventions Across Groups | Additional bias: Report power calculation/achieve adequate n | Overall Risk of Bias
Abbott JH, et al, 2015^65^ | Low risk | Unclear | High risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | No | Moderate
Acosta-Olivo C, et al, 2014^26^ | Low risk | Unclear | High risk | High risk | Unclear | Unclear | Unclear | Unclear | Low risk | No | Unclear
Atamaz FC, et al, 2012^87^ | Low risk | Unclear | Low risk | Low risk | Low risk | Unclear | Yes | Low risk | Low risk | Yes | Low
Atkins DV, et al, 2013^122^ | Unclear | Unclear | High risk | High risk | Low risk | Unclear | No | Low risk | Unclear | Yes | Unclear
Avelar NC, et al, 2011^93^ | Unclear | Unclear | Unclear | Low risk | Low risk | Unclear | No | High risk | Low risk | Yes | Unclear
Azlin MNN, et al, 2011^116^ | Unclear | Unclear | High risk | High risk | High risk | Unclear | No | High risk | Low risk | No | High
Bagnato GL, et al, 2016^92^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Barduzzi GO, et al, 2013^59^ | Low risk | Low risk | High risk | Unclear | High risk | Unclear | Unclear | Unclear | Low risk | No | Unclear
Bartels EM, et al, 2014^68^ | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Bellare N, et al, 2014^30^ | Unclear | Unclear | High risk | Unclear | Low risk | Unclear | Unclear | Low risk | Low risk | No | Unclear
Bennell KL, et al, 2011^109^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Yes | Low risk | High risk | Yes | Low
Bennell KL, et al, 2015^53^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Bliddal H, et al, 2011^126^ | Low risk | Low risk | Low risk | Low risk | High risk | Unclear | Unclear | Low risk | Low risk | Yes | Moderate
Bokaeian HR, et al, 2016^99^ | Unclear | Low risk | High risk | Low risk | Low risk | Low risk | No | Low risk | Unclear | No | Low
Brosseau L, et al, 2012^39^ | Low risk | Low risk | High risk | Low risk | High risk | Unclear | Unclear | Low risk | High risk | No | High
Bruce-Brand RA, et al, 2012^44^ | Low risk | Unclear | High risk | Low risk | High risk | Low risk | No | Low risk | Low risk | No | Moderate
Bruyere O, et al, 2008^33^ | Low risk | Low risk | Low risk | Low risk | Low risk | Unclear | Yes | Low risk | Low risk | Yes | Low
Cakir S, et al, 2014^79^ | Low risk | Unclear | Low risk | Low risk | Low risk | Unclear | Unclear | Low risk | Low risk | Yes | Moderate
Callaghan MJ, et al, 2015^100^ | Low risk | Low risk | High risk | High risk | Low risk | Low risk | Yes | Low risk | Unclear | Yes | Moderate
Campos GC, et al, 2015^106^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Yes | Low risk | Unclear | Yes | Low
Carlos KP, et al, 2012^80^ | Unclear | Unclear | High risk | Low risk | Low risk | Unclear | Unclear | Low risk | Unclear | No | Unclear
Cheawthamai K, et al, 2014^117^ | Low risk | Low risk | High risk | Low risk | Low risk | Unclear | No | Low risk | Unclear | No | Moderate
Chenchen, et al, 2016^70^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Cherian JJ, et al, 2015^101^ | Unclear | Unclear | High risk | Low risk | Low risk | Unclear | Unclear | Unclear | Unclear | Yes | Unclear
Cheung C, et al, 2014^71^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Yes | High risk | High risk | No | Moderate
Christensen R, et al, 2015^62^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Claes BEA, et al, 2015^130^ | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Coleman S, et al, 2012^133^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Yes | Low risk | Unclear | Yes | Low
Cortes Godoy V, et al, 2014^118^ | Low risk | Low risk | Low risk | Low risk | Low risk | Unclear | Yes | Low risk | Low risk | No | Low
da Silva FS, et al, 2015^58^ | Low risk | Low risk | High risk | Low risk | High risk | Low risk | No | Low risk | Unclear | No | Moderate
de Rooij M, et al, 2016^66^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Dundar U, et al, 2015^91^ | Low risk | Unclear | Low risk | Low risk | Low risk | Unclear | Unclear | Low risk | Low risk | No | Moderate
Dwyer L, et al, 2015^120^ | Low risk | Low risk | High risk | Low risk | Low risk | Unclear | Yes | High risk | Unclear | Yes | Moderate
Elboim-Gabyzon M, et al, 2013^85^ | Unclear | Low risk | High risk | High risk | Low risk | Unclear | No | Low risk | Low risk | Yes | Moderate
Erhart JC, et al, 2010^113^ | Low risk | Unclear | Low risk | Low risk | High risk | Unclear | No | Low risk | Low risk | Yes | Moderate
Erhart-Hledik JC, et al, 2012^114^ | Low risk | Low risk | Low risk | Low risk | High risk | Unclear | Yes | Low risk | Low risk | Yes | Low
Fioravanti A, et al, 2012^72^ | Low risk | Unclear | High risk | Low risk | Low risk | Unclear | Yes | Unclear | Low risk | Yes | Moderate
Fioravanti A, et al, 2015^75^ | Low risk | Low risk | High risk | Low risk | Low risk | Unclear | Yes | Unclear | Low risk | Yes | Moderate
Fitzgerald GK, et al, 2011^55^ | Low risk | Low risk | High risk | Low risk | High risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Fitzgerald GK, et al, 2016^67^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Foroughi N, et al, 2011^52^ | Low risk | Low risk | Low risk | Low risk | High risk | Low risk | No | Low risk | Low risk | Yes | Low
Fransen M, et al, 2014^31^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Ghroubi S, et al, 2008^123^ | Unclear | Unclear | High risk | Unclear | Low risk | Unclear | Unclear | Low risk | Unclear | No | Unclear
Gormeli G, et al, 2015^24^ | Low risk | Low risk | Low risk | Low risk | Low risk | Unclear | No | Low risk | Low risk | Yes | Low
Gschiel B, et al, 2010^86^ | Low risk | Low risk | Low risk | Low risk | Low risk | Unclear | Unclear | Low risk | Unclear | No | Moderate
Hatef MR, et al, 2014^105^ | Unclear | Unclear | Low risk | Low risk | High risk | Unclear | No | Low risk | Low risk | No | Moderate
Henriksen M, et al. 2014^56^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Herrero-Beaumont, et al, 2016^32^ | Low risk | Low risk | Low risk | Low risk | High risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Hochberg MC, et al, 2008^134^ | Unclear | Unclear | Unclear | Unclear | High risk | Unclear | Unclear | Low risk | Unclear | No | Unclear
Hochberg MC, et al, 2015^29^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Low risk | Unclear | Yes | Low
Hsieh RL, et al, 2012^78^ | Low risk | Low risk | Low risk | Low risk | Low risk | Unclear | Yes | Low risk | Low risk | Yes | Low
Imoto AM, et al, 2012^48^ | Unclear | Unclear | High risk | Low risk | Low risk | Unclear | Yes | Low risk | Low risk | Yes | Moderate
Imoto AM, et al, 2013^84^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Yes | High risk | Low risk | Yes | Low
Inal EE, et al, 2016^89^ | Low risk | Low risk | Unclear | Low risk | Unclear | Unclear | Unclear | Low risk | Unclear | No | Unclear
Inoshi Atukorala, et al, 2016^128^ | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Jones A, et al, 2012^115^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Jorge RTB, et al, 2015^49^ | Low risk | Low risk | High risk | Low risk | Low risk | Unclear | Yes | Low risk | Low risk | No | Low
Ju SB, et al, 2015^57^ | Unclear | Unclear | High risk | Unclear | Unclear | Unclear | Unclear | Low risk | Unclear | No | Unclear
Kahan A, et al, 2009^38^ | Low risk | Low risk | Low risk | Low risk | Low risk | Unclear | Yes | Low risk | Low risk | Yes | Low
Kapci Yildiz S, et al, 2015^81^ | Unclear | Low risk | Low risk | Low risk | Low risk | Unclear | No | High risk | Unclear | No | Low
Knoop J, et al, 2013^61^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Koca B, et al, 2009^104^ | Unclear | Unclear | Unclear | Unclear | Low risk | Unclear | Unclear | Low risk | Unclear | No | Unclear
Koli J, et al, 2015^41^ | Low risk | Unclear | Unclear | Low risk | Low risk | Low risk | Yes | Low risk | High risk | Yes | Low
Kulisch A, et al, 2014^73^ | Low risk | Low risk | High risk | Low risk | Low risk | Unclear | Yes | Unclear | Low risk | Yes | Moderate
Laufer Y, et al, 2014^82^ | Unclear | Low risk | Low risk | High risk | Low risk | Low risk | No | Low risk | Low risk | No | Moderate
Lim JY, et al, 2010^63^ | Low risk | Low risk | Low risk | Low risk | Low risk | Unclear | Yes | Low risk | Low risk | Yes | Low
Mahboob N, et al, 2009^74^ | Unclear | Unclear | Low risk | Low risk | Low risk | Unclear | Yes | Unclear | Unclear | No | Unclear
Makovey J, et al, 2015^129^ | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Messier SP, et al, 2013^125^ | Unclear | Unclear | High risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Moderate
Miller GD, et al, 2006^124^ | Unclear | Unclear | High risk | High risk | Low risk | Unclear | No | Low risk | Low risk | No | Moderate
Mizusaki Imoto A, et al, 2013^83^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Nam CW, et al, 2014^51^ | Unclear | Unclear | High risk | Unclear | Low risk | Unclear | Yes | Low risk | Low risk | No | Moderate
Nelson FR, et al, 2013^90^ | Low risk | Low risk | Low risk | Low risk | High risk | Unclear | Yes | Low risk | Low risk | Yes | Low
Oliveira AM, et al, 2012^47^ | Low risk | Low risk | High risk | Low risk | Low risk | Unclear | Yes | Low risk | Low risk | Yes | Low
Palmer S, et al, 2014^88^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Park YG, et al, 2013^98^ | Unclear | Unclear | High risk | Unclear | Unclear | Unclear | Unclear | Low risk | Unclear | No | Unclear
Patel S, et al, 2013^23^ | Low risk | Unclear | Low risk | Low risk | Low risk | Unclear | No | High risk | Low risk | Yes | Moderate
Perlman AI, et al, 2012^121^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Yes | High risk | Low risk | No | Moderate
Rabini A, et al, 2015^94^ | Low risk | Low risk | Low risk | Low risk | Low risk | Unclear | Yes | Low risk | Low risk | Yes | Low
Rayegani SM, et al, 2014^25^ | Low risk | High risk | High risk | High risk | Low risk | Unclear | No | Unclear | Low risk | No | High
Richette P, et al, 2011^131^ | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | No | N/A
Rodrigues PT, et al, 2008^103^ | Unclear | Unclear | Low risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | No | Moderate
Rogers MW, et al, 2012^46^ | Low risk | Unclear | Low risk | High risk | High risk | Low risk | Unclear | Low risk | Low risk | No | Moderate
Rosedale R, et al, 2014^64^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Yes | Low risk | Unclear | Yes | Low
Salacinski AJ, et al, 2012^43^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Yes | High risk | High risk | Yes | Low
Samut G, et al, 2015^40^ | Unclear | Unclear | Unclear | Unclear | Low risk | Unclear | Unclear | Low risk | Low risk | No | Unclear
Sattari S, et al, 2011^102^ | Low risk | Unclear | High risk | High risk | Low risk | Unclear | Unclear | Low risk | Unclear | No | Unclear
Sawitzke AD, et al, 2010^28^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Schlenk EA, et al, 2011^42^ | Low risk | Unclear | High risk | Low risk | Low risk | Low risk | Yes | Low risk | Unclear | Yes | Low
Segal NA, et al, 2015^60^ | Low risk | Low risk | Unclear | Low risk | Low risk | Low risk | No | Low risk | Low risk | Yes | Low
Simao AP, et al, 2012^97^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | No | High risk | Low risk | Yes | Moderate
Simental-Mendia M, et al, 2016^27^ | Unclear | Unclear | Unclear | Unclear | Low risk | Low risk | No | Low risk | Low risk | Yes | Unclear
Singh S, et al, 2016^50^ | Low risk | Unclear | Low risk | Low risk | Low risk | Unclear | Unclear | Low risk | Unclear | No | Low
Somers TJ, et al, 2012^127^ | Low risk | Low risk | High risk | Low risk | Low risk | Unclear | Yes | Unclear | Unclear | Yes | Moderate
Stambolova Ivanova MP, 2015^34^ | Unclear | Unclear | Low risk | Low risk | Unclear | Unclear | Unclear | Unclear | Unclear | No | Unclear
Stefanik J, et al, 2015^132^ | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Toda Y, et al, 2006^108^ | High risk | High risk | Low risk | Low risk | Low risk | Unclear | No | Low risk | Unclear | No | Moderate
Trombini-Souza F, et al, 2013^111^ | Unclear | Unclear | Low risk | Low risk | Unclear | Unclear | Unclear | Unclear | Unclear | No | Unclear
Trombini-Souza F, et al, 2015^112^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Tsai PF, et al, 2013^69^ | Low risk | Unclear | Unclear | Unclear | Low risk | Unclear | Yes | Low risk | Unclear | No | Unclear
Wallace DA, 2006^107^ | Unclear | Unclear | Unclear | Unclear | Low risk | Low risk | Unclear | Unclear | Unclear | No | Unclear
Wang P, et al, 2015^95^ | Low risk | Low risk | Low risk | Low risk | Low risk | Unclear | Yes | Low risk | Low risk | Yes | Low
Wang P, et al, 2015^96^ | Low risk | Low risk | Unclear | Low risk | Low risk | Unclear | Yes | Low risk | Low risk | Yes | Low
Wortley M, et al, 2013^45^ | Unclear | Unclear | High risk | Unclear | High risk | Unclear | No | High risk | Low risk | No | High
Yildirim N, et al, 2010^77^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Low risk | Low risk | Yes | Unclear
Zegels B, et al, 2013^37^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Yes | Low risk | Low risk | Yes | Low
Zhang Y, et al, 2012^119^ | Low risk | Low risk | High risk | High risk | High risk | Unclear | Yes | Low risk | Unclear | No | Moderate

Table F2 Quality assessment of studies reporting harms (N=57)

Author, year | Were the harms predefined using standardized or precise definitions? | Was the mode of harms collected specified as active? | Was the potential occurrence of harmful events collected at pre-specified intervals? | Did the author(s) specify the NUMBER for each TYPE of harmful event for each study group? | Was the TOTAL NUMBER of participants affected by harms specified for each study arm? | If the study reported that there were no serious AE’s reported did they define serious AEs?
Abbott JH, et al, 2015^65^ | No | Unclear | Unclear | Yes | Yes | Not applicable
Atamaz FC, et al, 2012^87^ | Unclear | Unclear | Unclear | No | No | Not applicable
Bagnato GL, et al, 2016^92^ | No | Unclear | Unclear | Yes | Yes | Not applicable
Bellare N, et al, 2014^30^ | No | No | No | No | No | Not applicable
Bennell KL, et al, 2011^109^ | No | Yes | Yes | Yes | Yes | Not applicable
Bennell KL, et al, 2015^53^ | Yes | Yes | Unclear | Yes | Yes | Not applicable
Bliddal H, et al, 2011^126^ | Unclear | Unclear | Unclear | No | No | Not applicable
Callaghan MJ, et al, 2015^100^ | Unclear | Yes | Yes | Yes | Yes | Not applicable
Campos GC, et al, 2015^106^ | Yes | Unclear | Unclear | Yes | Yes | Not applicable
Chenchen, et al, 2016^70^ | Unclear | Yes | Yes | No | No | Yes
Cherian JJ, et al, 2015^101^ | Yes | Unclear | Unclear | No | No | Yes
Cheung C, et al, 2014^71^ | Unclear | Yes | Unclear | Yes | Yes | Not applicable
Christensen R, et al, 2015^62^ | Yes | Yes | Yes | Yes | Yes | Not applicable
Coleman S, et al, 2012^133^ | Unclear | Unclear | Unclear | Yes | Yes | Not applicable
Dwyer L, et al, 2015^120^ | Yes | Unclear | Unclear | Yes | Yes | Not applicable
de Rooij M, et al, 2016^66^ | No | Unclear | Unclear | No | No | No
Elboim-Gabyzon M, et al, 2013^85^ | No | No | Unclear | Yes | Yes | Not applicable
Erhart JC, et al, 2010^113^ | No | No | Unclear | No | No | Not applicable
Fioravanti A, et al, 2015^75^ | No | Unclear | Unclear | Yes | Yes | No
Fitzgerald GK, et al, 2011^55^ | No | Unclear | Unclear | Yes | Yes | No
Fitzgerald GK, et al, 2016^67^ | Unclear | Unclear | Unclear | Yes | Yes | Not applicable
Foroughi N, et al, 2011^52^ | Yes | Yes | Yes | Yes | Yes | Not applicable
Fransen M, et al, 2014^31^ | No | Yes | Yes | No | No | Not applicable
Ghroubi S, et al, 2008^123^ | Unclear | No | No | Unclear | Unclear | Not applicable
Gschiel B, et al, 2010^86^ | Unclear | Unclear | Unclear | Yes | Yes | Not applicable
Herrero-Beaumont, et al, 2016^32^ | No | Unclear | Unclear | No | Yes | Not applicable
Hochberg MC, et al, 2008^134^ | No | Unclear | Unclear | Yes | Yes | Not applicable
Hochberg MC, et al, 2015^29^ | Yes | Unclear | Unclear | Yes | Yes | Not applicable
Hsieh RL, et al, 2012^78^ | No | No | Unclear | Yes | Yes | Not applicable
Imoto AM, et al, 2012^48^ | No | No | No | Yes | Yes | Not applicable
Imoto AM, et al, 2013^84^ | No | Unclear | Unclear | Yes | Yes | Not applicable
Jorge RTB, et al, 2015^49^ | Unclear | No | Unclear | Yes | Unclear | Not applicable
Kahan A, et al, 2009^38^ | No | Unclear | Unclear | No | Yes | Not applicable
Kapci Yildiz S, et al, 2015^81^ | Unclear | Unclear | Unclear | Yes | Yes | Not applicable
Knoop J, et al, 2013^61^ | Yes | Unclear | Unclear | Yes | Yes | Yes
Koli J, et al, 2015^41^ | Unclear | Unclear | Unclear | Yes | Yes | Not applicable
Laufer Y, et al, 2014^82^ | No | No | No | Yes | Yes | Not applicable
Lim JY, et al, 2010^63^ | Unclear | Yes | Unclear | No | No | Not applicable
Messier SP, et al, 2013^125^ | Unclear | Unclear | Unclear | Yes | Yes | Not applicable
Mizusaki Imoto A, et al, 2013^83^ | No | Unclear | Unclear | Yes | Yes | Not applicable
Nelson FR, et al, 2013^90^ | No | Unclear | Unclear | Yes | Yes | Not applicable
Oliveira AM, et al, 2012^47^ | No | Unclear | Unclear | Yes | Yes | Not applicable
Park YG, et al, 2013^98^ | No | Unclear | Unclear | Yes | Yes | Not applicable
Patel S, et al, 2013^23^ | No | Unclear | Unclear | No | Yes | Not applicable
Perlman AI, et al, 2012^121^ | No | Unclear | Unclear | Yes | Yes | Not applicable
Rabini A, et al, 2015^94^ | Unclear | Unclear | Unclear | Yes | Yes | Not applicable
Rayegani SM, et al, 2014^25^ | No | Unclear | Unclear | Yes | Yes | Not applicable
Rodrigues PT, et al, 2008^103^ | Unclear | Unclear | Unclear | Yes | Yes | Not applicable
Salacinski AJ, et al, 2012^43^ | Unclear | Unclear | Unclear | Yes | Yes | Not applicable
Sawitzke AD, et al, 2010^28^ | No | Yes | Yes | Yes | Unclear | Not applicable
Segal NA, et al, 2015^60^ | No | Yes | Yes | Yes | Yes | Not applicable
Simental-Mendia M, et al, 2016^27^ | No | No | Unclear | No | No | No
Somers TJ, et al, 2012^127^ | Unclear | Unclear | Unclear | Yes | Yes | Not applicable
Wang P, et al, 2015^95^ | Unclear | Yes | Yes | Yes | Yes | Not applicable
Wang P, et al, 2015^96^ | No | No | Unclear | Yes | Yes | No
Zegels B, et al, 2013^37^ | No | Unclear | Unclear | No | No | Not applicable
Zhang Y, et al, 2012^119^ | Unclear | Unclear | Unclear | Yes | Yes | Not applicable