# Appendix E Strength of Evidence

Table E1 Strength of evidence

Intervention/Outcome | Number, design of studies (and participants if pooling) | Findings | Study limitations (risk of bias) | Inconsistency | Indirectness | Imprecision | GRADE of evidence
KQ 1 Platelet-rich plasma
Short-term pain (KOOS, WOMAC) | 2 RCTs | Single or dual injections vs. saline: MD −5.22 Single injection PRP vs. paracetamol: no difference | Moderate, unclear | Inconsistent | Direct | imprecise | Insufficient evidence
Short-term function | 1 RCT | Single or dual injections vs. saline: MD –15.56 | Moderate | NA | Direct | Not reported | Insufficient evidence
Short-term WOMAC total | 2 RCTs | Single or dual injections vs. saline: (MD –21.42) (MD –13.4, 95% CI –20.00, –6.71) | Moderate | NA | Direct | Not reported | Insufficient evidence
Short-term QoL (SF-12 physical) | 1 RCT | SF-12 (MD –7.60, 95% CI –11.76, –3.48) | Low
Medium-term pain | 5 RCTs | Single injection vs. saline: Significant benefit Dual injections vs. saline: significant benefit Dual injections vs. TAU: no effect Single injection vs. analgesic: significant benefit | 2 High, Moderate, 2 low | Consistent | Direct | Precise | Low for a positive effect of PRP on medium term pain
Medium-term function | 2 RCT | Injection vs. saline: benefit Injection vs. TAU: no benefit | Moderate | NA | Direct | Not reported | Insufficient evidence
Medium term WOMAC total | 2 RCT | Single or dual injections vs. saline: significant benefit in 1 RCT – | Moderate, low | Unclear | Direct | Not reported | Insufficient
Medium term SF-36 physical domain | 1 RCT | Injection vs. TAU Unclear | High | NA | Direct | Not reported | Insufficient
Medium term EQ-5d | 1 RCT | Significant improvement with 1 or 2 injections | Low | NA | Direct | Precise | Insufficient
Long-term pain | 0 | | | | | | Insufficient evidence
Long-term function | 0 | | | | | | Insufficient evidence
Long-term other | 0 | | | | | | Insufficient evidence
Glucosamine plus chondroitin
Medium term pain | 2 RCTs | | High, low, low | Inconsistent | Direct | Precise | Low for an effect of glucosamine-chondroitin on medium-term pain(3 studies: one head to head, one placebo-controlled, one open)
| 1 RCT (n=603) | WOMAC, VAS: no difference glucosamine sulfate-chondroitin celecoxib in non-inferiority trial and response met MCID | Low | N/A | Direct | Precise
| | WOMAC MD –1.59(–2.31, –0.87); VAS MD–2.08 (–2.40, –1.76) | High | N/A | Direct | Precise
| 1 RCT (n=164) | Placebo-controlled | Low | N/A | Direct | Precise
Medium term function | 3 RCTs | Significant benefit in 2/3 RCTs | 2 low, 1 moderate | Inconsistent | Direct | Precise | Low for an effect of glucosamine-chondroitin on medium term function
Medium-term other outcomes | 2 RCTs | No impact on WOMAC stiffness in 1 RCT, but improvement in 2^nd^ RCT, No impact on Eq-5D | High, low | Inconsistent | Direct | N/R | Insufficient
Long-term pain | 3 RCTs (n=466 in pooled analysis) | WOMAC (SMD −0.73, 95% CI −4.03; 2.57; I^2^ 97%) | High, 2 low | Inconsistent | Direct | Precise | Moderate for no effect of glucosamine-sulfate on long-term pain
Long-term function | 3 RCTs (n=466 in pooled analysis) | WOMAC function –(SMD 0.45, 95% CI −2.75; 1.84; I^2^ 95%) | High, 2 Low | Inconsistent | Direct | Precise | Low for no effect of glucosamine on long-term function
Long-term other outcomes | 2 RCTs | Significant effect on long-term WOMAC stiffness; LEGS trial showed no effect compared with placebo on long-term SF-12 physical domain | | | | | Insufficient evidence
Glucosamine
Short-term pain | 0 RCTs | | | | | | Insufficient evidence
Short-term function | 0 RCTs | | | | | | Insufficient evidence
Short-term other | 0 RCTs | | | | | | Insufficient evidence
Medium-term pain | 0 RCTs | | | | | | Insufficient evidence
Medium-term function | 0 RCTs | | | | | | Insufficient evidence
Medium-term other | 0 RCTs | | | | | | Insufficient evidence
Long-term pain | 3 RCTs (n=1007 in pooled analysis) | WOMAC (SMD −0.05, 95% CI −0.22; 0.12; I^2^ 0%) | High, 2 low | Inconsistent | Direct | Precise | Low for beneficial effect on pain vs. analgesic or placebo at 102 years
Long-term function | 3 RCTs | GAIT Trial: comparable to analgesic LEGS Trial: no effect cf. placebo Bulgarian study: significant benefit cf. placebo | High, 2 low | Inconsistent | Direct | Precise | Low for no consistent benefit
Long-term other outcomes | 2 RCTs | GAIT trial: positive impact on OMERACT-OARSI scores LEGS Trial SF-12 physical domain scores not improved | 2 Low | | | | Insufficient evidence
| 2 pooled RCTs | Risk for undergoing TKR decreased by more than 50% with glucosamine supplementation vs. placebo | Low | | | | Insufficient evidence
Chondroitin-sulfate
Short-term pain | 1 RCT (n=353) | Zegels trial: 2 dosing strategies vs. placebo VAS pain: no differences between doses or vs. placebo | Low | Consistent | Direct | Precise | Low for no effect of chondroitin on short-term pain
Short-term function | 1 RCT (n=353) | Zegels trial: significant improvement in Lequesne scores vs. placebo (p=0.003) | Low | Consistent | Direct | Precise | Low for significant effect of chondroitin on short-term function
Medium-term pain | 2 RCTs (n=975) | Zegels trial: VAS pain significantly improved by both dosing strategies STOPP Trial: benefit on WOMAC and VAS | 2 Low | Consistent | Direct | Precise | Low for an effect of chondroitin on medium-term pain
Medium-term function | 2 RCTs | | 9, 10/10 | Inconsistent | Direct | Precise | Insufficient evidence
| | Zegels trial: significant improvement in Lequesne scores vs. placebo for both dosing strategies: | 10/10 | N/A | Direct | Precise
| | STOPP Trial found no difference in WOMAC function vs. placebo | 9/10 | N/A | Direct | Precise
Long-term pain | 3 RCTs | STOPP Trial, GAIT Trial, and LEGS Trial showed no effect vs. placebo | 3 Low | Consistent | Direct | Precise | Moderate for no long-term effect of chondroitin sulfate on pain
Long-term function | 2 RCTs | GAIT Trial, and LEGS Trial showed no effect vs. placebo | 2 Low | Consistent | Direct | Precise | Low for no significant effect of chondroitin on long-term function
Long-term other | 1 RCT | STOPP Trial showed no significant between-group difference in analgesic use | 9/10 | N/A | Direct | Precise | Insufficient evidence
Strength/resistance Training
Short-term pain | 5 RCTs (n=215 in pooled analysis) | 5 pooled RCTs (n=160) SMD −0.55 (95% CI −1.46, 0.37) | Unclear-low | Inconsistent | Direct | Imprecise | Low for no significant effect of strength training on short-term pain
Short-term function | 5 RCTs (n=245 in pooled analysis) | 5 pooled RCTs SMD −0.60 (95% CI −1.38, 0.17) | Unclear-low | Inconsistent | Direct | Imprecise | Low for no significant effect of strength training on short-term function
Short-term WOMAC total | 3 RCTs | Significant between-group differences | | Consistent | Direct | Precise | Moderate for short-term effect of strength training on WOMAC total
| 2 RCTs | TUG | High, low | Inconsistent | Direct | Precise | Insufficient evidence
| 2 RCTs | SF-36 | Moderate, low | Consistent | Direct | Precise | Insufficient evidence
| 1 RCT | 6-minute walk | High | N/A | Direct | Precise | Insufficient evidence
Medium-term pain | 2 RCTs | No improvements in pain when combined with PCST vs. PCST alone or when compared with other active controls | Moderate, low | Consistent | Direct | Precise | Insufficient evidence
Medium-term function | 3 RCTs (n=187 in pooled analysis) | SMD −0.43, 95% CI −2.16, 1.30 | Moderate, low | Inconsistent | Direct | Precise | Low SoE for a non-significant beneficial effect
Medium-term other | 1 RCT | No effect on SF-36 physical domain | Moderate | N/A | Direct | Precise | Insufficient evidence
Long-term pain | 1 RCT | Significant improvements in VAS and WOMAC pain | Low | N/A | Direct | Precise | Insufficient evidence
Long-term function | 1 RCT | Significant improvement in WOMAC function with strength+ PCST vs. PCST alone | Low | N/A | Direct | Precise | Insufficient evidence
Agility Training
Short-term pain | 3 RCTs | 3 different pain measures: 2/3 showed significant improvement cf. TAU and third showed no difference from strength training | Low-high | Inconsistent but consistent vs. passive controls | Direct | Precise | Low for an effect on short-term pain
Short-term function | 3 RCTs | 2 different function measures | 2 moderate, 1 low | Inconsistent | Direct | Precise | Low for no effect on short-term function
Short-term other | 3 RCTs | 3 different outcome measures: each showed significant improvement | 5/10 | N/A | Direct | Precise | Insufficient evidence
Medium-term pain | 3 RCTs | NRS: no significant difference in pain KOOS pain: significant improvement vs. no-attention control | Low-high | Inconsistent | Direct | Precise | Low for no effect on medium-term pain
Medium term function | 2 RCTs | WOMAC function: no difference vs. strength training | | N/A | Direct | Precise | Low for no effect on medium-term function
Medium-term other | 2 RCTs | TUG improvement comparable to strength training; walking speed improved for water-based agility training but not land-based agility training vs. control | Low, high | N/A | Direct | Precise | Insufficient evidence
Long-term pain | 3 RCTs | 2 of 3 RCTs found benefit comparable to other exercise interventions | 3 Low | Consistent | Direct | Precise | Low for improvement in long-term pain (or comparable improvement with other exercise interventions)
Long-term function | 2 RCTs | No between group differences in WOMAC function vs. other exercise programs | Moderate-Low | Consistent | | Precise | Low for improvement in long-term function (or comparable improvement with other exercise interventions)
Long-term other | 1 RCT | Total WOMAC showed no difference vs. standard exercise | Low | N/A | | | Insufficient evidence
Aerobic Exercise
Short-term pain, function, other outcomes | 0 RCTs | | | | | | Insufficient evidence
Medium-term pain, function, other outcomes | 2 RCTs | No benefit for pain, function | Low-moderate | | | | Insufficient evidence
Long-term pain | 2 RCTs | No significant between-group differences in WOMAC pain vs. educational, passive controls | Moderate-high | | | | Insufficient evidence
Long-term function | 3 RCTs | No significant between-group differences in WOMAC function vs. educational control | 2 Moderate, 1high | Consistent | Direct | NA | Low SoE for no beneficial effect on long-term function
Long-term other | 1 RCT | No significant between-group differences in WOMAC total scores, SF-36 functional domain scores, TUG scores, or 6-minute walk distances vs. educational control | 4/10 | NA | Direct | NA | Insufficient evidence
General exercise therapy
Short-term pain and function | 1 RCT | No effect on pain or function | Low | NA | Direct | NA | Insufficient evidence
Short-term other outcomes | 2 RCTs | No effects on WOMAC total, SF-36 TUG, or 6′-walk | Low | NA | Direct | NA | Low SoE for no short-term effect on other outcomes
Medium-term pain | 2 RCTs | KOOS, P4, and WOMAC pain scores significantly improved over non-exercise control scores | Low | NA | Direct | Precise | Low SoE for benefit on medium-term pain
Medium-term function | 2 RCTs | Significant improvement in KOOS and WOMAC function scores over non-exercise controls | Low | NA | Direct | Precise | Low SoE for benefit on medium-term function
Medium-term other outcomes | 1 RCT | Inconsistent effects on other functions | Low | NA | Direct | Precise | Insufficient evidence
Long-term pain | 4 RCTs | Improvement in VAS and WOMAC pain in 3 of 4 RCTs but no effect in 4^th^ RCT | Moderate, 3 Low | Inconsistent | Direct | Precise | Low SoE for benefit on long-term pain
Long-term function | 2 RCTs | Inconsistent effects of exercise | 2 Low | N/A | Direct | Precise | Low SoE for long-term benefit on function
Long-term other | 4 RCTs | Inconsistent effects on 6″-walk, SF-36, but significant difference in WOMAC total, TUG | 3 Low | Inconsistent | Direct | NA | Low SoE for long-term benefit on other outcomes
Tai Chi
Short-term pain | 3 RCTs | No between-group differences in WOMAC pain vs. resistance training, TAU, or education | | Consistent | Direct | Precise | Low for a beneficial effect on short-term pain
Short-term function | 3 RCTs | | | Inconsistent | Direct | Precise | Low SoE for beneficial effect on short-term function
Short-term other | 1 RCT | Inconsistent differences between Tai chi and TAU | moderate | N/A | Direct | Precise | Insufficient evidence
Medium pain | 2 RCTs | Significant between-group differences in WOMAC pain vs. education | | N/A | Direct | | Low SoE for beneficial medium-term effect on pain
Medium function | 2 RCTs | Significant between-group difference in WOMAC function (MD −5.52, 95% CI −9.70, −1.34) | | N/A | | | Low SoE for beneficial medium term effect on function
Long term pain, function, or other | 0 RCTs | | | | | | Insufficient evidence
Yoga
Short-term pain | 1 RCT | Significant between-group difference in WOMAC pain vs. waitlist control | 7/10 | N/A | Direct | Precise | Insufficient evidence
Short-term function | 1 RCT | No significant between-group differences in WOMAC function | 7/10 | N/A | | | Insufficient evidence
Medium-term pain or function | 0 RCTs | | | | | | Insufficient evidence
Long-term pain or function | 0 RCTs | | | | | | Insufficient evidence
Ultrasound/heat/infrared
Heat and infrared | 3 RCTs | | | | | | Insufficient evidence
Ultrasound
Short-term pain | 3 RCTs | | | | | | Low SoE for a short-term benefit on pain
Short-term function | 1 RCT | | | | | | Insufficient evidence
Short-term other | 2 RCTs | | | | | | Insufficient evidence
Medium and long-term outcomes | | | | | | | Insufficient evidence
Balneotherapy and Mud Therapy
Balneotherapy
Short-term outcomes | 0 RCTs | | | | | | Insufficient evidence
Medium-term pain | 2 RCTs | | | Inconsistent | | | Inconsistent beneficial effect on medium-term pain (low SoE)
Medium-term function | 2 RCTs | | 6,7/10 | Consistent | Direct | Precise | Low SoE for beneficial effect on medium-term function
Medium-term other | 2 RCTs | | 6,7/10 | Consistent for QoL | | | Insufficient evidence
Long-term outcomes | 0 RCTs | | | | | | Insufficient evidence
Mud baths
All outocmes | 1 RCT | No between group differences in WOMAC pain for mud pack vs. placebo | 4/10 | | | | Insufficient evidence
Topical mud therapy
All outcomes | 1 RCT | No between group differences in WOMAC function for mud pack vs. placebo | 4/10 | | | | Insufficient evidence
Manual Therapy
Short-term pain | 7 RCTs (n=137 in pooled analysis of 3 RCTs) | No significant effect of manual therapy (administered by a therapist or by patients themselves) on short-term WOMAC pain (SMD −0.57, 95% CI −1.60, 0.45) (n=244) | 4,6,7/10 | Inconsistent | Direct | Precise | Low SoE for no effect of manual therapy on short-term pain
Short-term function | 4 RCTs | No consistent benefit of any manual therapy compared with exercise or TAU | | Inconsistent | Direct | Precise | Low SoE for no effect of manual therapy on short-term function
Short-term other | 4 RCTs | No significant between-group differences in WOMAC total scores reported in 3 RCTs and in two treatment arms of the 4^th^ RCT but significant effects in the two remaining arms | 4, 6, 7, 8/10 | Inconsistent | Direct | Precise | Low SoE for no short-term effect of manual therapy on WOMAC total
Medium-term outcomes | 4 RCTs | Not possible to compare interventions across trials | 3, 4, 7, 8/10 | Inconsistent | Direct | N/R | Insufficient evidence
Medium-term other | 3 RCTs | | 3, 4, 7/10 | Inconsistent | Direct | N/R | Insufficient evidence for no effect of manual therapy on other medium term outcomes
Long-term pain | 2 RCTs | Significant between group difference vs. exercise alone (MD −2.30, 95% CI −4.07, −0.53) | 7/10 | N/A | Direct | Precise | Low SoE for a beneficial effect of manual therapy on long-term pain
Pulsed Electromagnetic Field
Short-term Pain | 3 RCTs (n=94 in pooled analysis_ | Non-statistically significant effect on VAS pain (SMD −12.44, 95% CI −34.41, 9.54) | 1 moderate, 2 low | Inconsistent | Direct | Precise | Low SoE for an effect on short-term pain
Short-term function and other outcomes | 1 RCT | | | | | | Insufficient evidence
Medium-term outcomes | 0 RCTs | | | | | | Insufficient evidence
Long-term outcomes | 0 RCTs | | | | | | Insufficient evidence
Transcutaneous Electrical Nerve Stimulation (TENS)
Short-term pain | 4 RCTs (n=349) | Significant between-group difference on WOMAC pain vs. sham control 6 (Pooled SMD −0.31, 95% CI −0.56, −0.06) (n=343) | 1 moderate, 1 unclear, 2 low | Inconsistent | Direct | Precise | Moderate for short-term effect of TENS on pain
Short-term function | 3 RCTs | No between-group differences in WOMAC function but a higher % of TENS recipients had MCII than sham recipients in one study | 1 Unclear, 2 low | Consistent | Direct | Precise | Low SoE for no beneficial effect on short-term function
Short-term other outcomes | 2 RCTs | No between group difference in WOMAC total | 1 unclear, 1 low | Consistent | Direct | Precise | Insufficient evidence
Medium-term pain | 2 RCTs | No between-group differences in VAS or WOMAC pain | 2 low | Consistent | Direct | Precise | Low for no effect of TENS on medium-term pain
Medium-term function | 2 RCTs | No between-group differences in WOMAC function | 2 low | Consistent | Direct | Precise | Low for no effect of TENS on medium-term function
Medium-term other outcomes | 1 RCT | No between-group difference in WOMAC total | Low | N/A | Direct | Precise | Insufficient evidence
Long-term outcomes | 0 RCTs | | | | | | Insufficient evidence
Neuromuscular Electrical Stimulation (NMES)
Short-term pain | 4 RCTs | Significant between-group differences in 2 of 4 RCTs with no difference in 2 others | 2 moderate, 2 low | Inconsistent | Direct | Precise | Low SoE for no beneficial effect of NMES on short-term pain
Short-term function | 3 RCTs | 2 RCTs showed no between-group differences in WOMAC function; 1 RCT showed significant between-group differences in Lequesne scores | 1 moderate, 2 low | Inconsistent | Direct | Precise | Low SoE for no beneficial effect of NMES on short-term function
Medium-term pain | 2 RCTs | No between group differences in one RCT, but persistent differences in 2^nd^ RCT | 2 moderate | Inconsistent | Direct | Precise | Insufficient evidence
Medium-term function | 1 RCT | No between-group differences in WOMAC function | Moderate | N/A | Direct | Precise | Insufficient evidence
Long-term outcomes | 0 RCTs | | | | | | Insufficient evidence
Whole-body Vibration(WBV) left off here
Short-term pain | 3 RCTs | Inconsistent beneficial effects of WBV plus exercise (together or sequentially) compared with exercise alone | Low, high, unclear | Inconsistent | Direct | Precise | Low SoE for beneficial short-term effect
Short-term function | 1 RCT | No significant between-group difference in WOMAC function for WBV plus strength training vs. strength training alone | low | N/A | Direct | Precise | Insufficient evidence
Short-term other | 2 RCTs | No between-group differences in WOMAC total for WBV plus home exercise vs. home exercise alone; no differences in 6-minute walk distance, TUG, or SF-36 | Low, high, unclear | N/A | Direct | Precise | Insufficient evidence
Medium-term pain | 4 RCTs (n=193 in pooled analysis) | Pooled analysis showed no significant between-group difference in WOMAC pain (SMD −0.20, 95% CI −1.12, 0.71 | 2 low, moderate, unclear | Inconsistent | Direct | Precise | Low SoE for no medium-term effect of WBV on pain
Medium-term function | 4 RCTs | Pooled analysis showed a small but significant between-group difference in WOMAC function (SMD −0.26, 95% CI −0.45, −0.06)(n=193) | 2 low, moderate, unclear | Inconsistent | Direct | Precise | Low SoE for a beneficial effect of WBV on medium-term function
Medium-term other outcomes | 4 RCTs (n=204 in pooled analysis) | No significant pooled between-group difference in 6-minute walk distances (SMD −31.17, 95% CI −82.60, 20.26) | 2 low, moderate, unclear | Inconsistent | Direct | Imprecise | Low SoE for a medium-term effect on walking speed
| 4 RCTs | No consistent between-group differences in WOMAC total, WOMAC stiffness, TUG | 2 low, moderate, unclear | Inconsistent | Direct | Precise | Insufficient evidence
Long-term outcomes | 0 RCTs | | | | | | Insufficient evidence
Orthoses | [left off here]
Braces
Short-term pain | 1 RCT | Significant between-group difference in VAS pain (0–10 cm MD −1.30, 95% CI −2.01, −0.59) | Moderate | N/A | Direct | Precise | Insufficient evidence
Short-term function and other outcomes | 0 RCTs | | | | | | Insufficient evidence
Medium-term pain | 1 RCT | Significant between group difference in VAS pain (0–10cm MD −2.30, no variance reported) | Unclear | N/A | Direct | N/R | Insufficient evidence
Medium-term function and other outcomes | 0 RCTs | | | | | | Insufficient evidence
Long-term pain | 1 RCT | Significant between-group differences in VAS pain (0–10cm, MD −2.80, 95% CI −3.58, −2.02) | Unclear | N/A | Direct | Precise | Insufficient evidence
Long-term function and other outcomes | 0 RCTs | | | | | | Insufficient evidence
Shoe inserts
Short-term pain | 4 RCTs | 3 of 4 RCTs showed significant between-group differences in at least one measure of VAS pain (no pooling possible); 1 of 2 RCTs showed a significant between-group difference in WOMAC pain | 1 low, 2 moderate, 1 unclear | Inconsistent | Direct | Precise | Low SoE for no beneficial effect on short-term pain
Short-term function | 3 RCTs | 1 of 3 RCTs showed significant between-group differences in function; one that showed no difference did report MCII in 100% of insole users. | Low, moderate, unclear | Inconsistent | Direct | Precise | Low SoE for no beneficial effect on short-term function
Short-term WOMAC total | 3 RCTs (n=125 in pooled analysis) | Pooled outcomes of 3 RCTs showed no significant between group difference in WOMAC total (SMD −0.37, 95% CI −1.26, 0.53) | Low, moderate, unclear | Inconsistent | Direct | Precise | Low SoE for no effect of orthotics on short-term overall improvement
Medium-term pain | 3 RCTs (n=131 in pooled analysis) | Pooled outcomes of 3 RCTs showed no significant between group difference in WOMAC (SMD −0.4, 95% CI −1.35, 0.56) | 1 low, 2 unclear | Inconsistent | Direct | Precise | Low SoE for no effect on medium-term pain
Medium-term function | 4 RCTs | 3 of 4 RCTs reported no between-group differences in function (2 Lequesne, 1 WOMAC) and 1 reported a significant between-group difference in WOMAC function (MD −10.06, 95% CI −19.68, −0.44) | 1 low, 1 moderate, 2 unclear | Inconsistent | Direct | Precise | Low SoE for no beneficial effect on medium-term function
Long-term pain | 2 RCTs | 1 RCT found no between-group differences in WOMAC pain and 1 RCT found a significant difference in VAS pain | Low, unclear | Inconsistent | Direct | Precise | Insufficient evidence
Long-term function | 2 RCTs | No between-group differences in Lequesne (1 RCT) or WOMAC (1 RCT) function | Low, moderate | Consistent | Direct | Precise | Insufficient evidence
Long term other | 0 RCTs | | | | | | Insufficient evidence
Custom Shoes | 5 RCTs
Short-term pain, function, other outcomes | 0 RCTs | | | | | | Insufficient evidence
Medium-term pain | 2 RCTs | 1 RCT reported a significant between group difference, and another RCT reported no significant difference in WOMAC pain scores | Low, unclear | Inconsistent | Direct | N/R | Insufficient evidence
Medium-term function | 1 RCT | Significant between-group difference reported in WOMAC and Lequesne function scores | Low | Consistent | Direct | N/R | Insufficient evidence
Medium-term other | 2 RCTs | No significant between-group differences in WOMAC total or walking distance | Moderate, low | Consistent | Direct | Imprecise | Insufficient evidence
Long-term pain | 1 RCT | No significant between-group difference in WOMAC pain | Low | N/A | Direct | N/R | Insufficient evidence
Long-term function and other outcomes | 0 RCTs | | | | | | Insufficient evidence
Cane
Short-term outcomes | 1 RCT | Significant between-group differences in pain and function | Low | N/A | Direct | Precise | Insufficient evidence
Medium- and long-term outcomes | 0 RCTs | | | | | | Insufficient evidence
Weight-loss
Short-term pain | 1 RCT and 1 single-arm trial | | | | | | Insufficient evidence for short-term effect of weight loss on pain
| 1 RCT | Significant improvement in VAS pain with weight loss across 3 intervention arms (diet+ exercise, exercise, and diet only) but not proportional to actual weight loss | High | Inconsistent | Direct | Precise
| 1 single-arm trial | Significant improvement in KOOS pain with weight loss (MD 5, 95% CI 0.3, 9.7) | Not assessed | N/A | Direct | Precise
Short-term function | 1 RCT | Significant improvement in WOMAC function, Lequesne function, and proportion of individuals with improvements in function with weight loss in all treatment groups | High | Inconsistent | Direct | Precise | Insufficient evidence
Short-term other outcomes | 1 single-arm trial | Significant improvement in TUG (seconds: MD−1.4, 95% CI−3.0 to −0.4) and 6-minute walk from baseline with weight loss | Not assessed | Consistent | Direct | Precise | Insufficient evidence
Medium-term pain | 2 RCTs, 4 single-arm trials | | | Inconsistent | Direct | Precise | Moderate evidence for a medium-term effect of weight loss on pain
| 2 RCTs | Significant between-group difference in WOMAC pain for weight loss vs. no weight loss in 1 RCT, but weight loss associated with decreased pain in only 1 of two treatment arms in 2^nd^ RCT vs. control | Moderate, high | Inconsistent | Direct | Precise
| Single-arm trials | 1 single arm trial found significant decreases in pain with weight loss, and 3 (including CAROT, n=3,000) showed a significant dose-response relationship of weight loss with decreased pain | Not assessed | Consistent | Direct | Precise
Medium-term function | 3 RCTs, 3 single-arm trials | | | | | | Low SoE for an effect of weight loss on medium term function
| RCTs | Weight loss significantly associated with between-group differences in WOMAC function in 2 of 3 RCTs | High, moderate | Inconsistent | Direct | Precise
| 3 single-arm trials | Weight loss significantly associated with WOMAC and KOOS function; dose-response relationship of weight loss and KOOS function | Not rated | Consistent | Direct | Precise
Medium-term other outcomes | | | | | | | Insufficient evidence
| 2 RCTs | Significant between-group differences in WOMAC total function (MD −10.70, 95% CI −17.01, −4.39) and 6-minute walk distance (MD −51.00, 95% CI −96.03, −5.97) | 2 moderate | N/A | Direct | Precise | Insufficient evidence
| 3 single-arm trials | Significant associations of weight loss with improvements in WOMAC stiffness, and TUG and significant dose-response association with SF-12 physical domain | Not rated
Long-term pain | 3 RCTs and 1 single-arm trial | | | | | | Low SoE for effect of weight loss on long-term pain
| 3 RCTs | 1 RCT showed a significant between-group difference in WOMAC pain with weight loss (, MD −7.20, 95% CI −13.30, −1.10); 1 RCT showed a non-significant between-group difference in WOMAC pain (between group differences in weight loss were small); and 1 RCT showed continued relationship between weight loss and decreased pain | 3 moderate | Inconsistent | Direct | Precise
| 1 single-arm trial | Ongoing trial shows improvement in VAS and WOMAC pain at 1 year | Not rated | N/A | Direct | Precise
Long-term function | 2 RCTs | 1 RCT reported no between-group differences in WOMAC function; 1 RCT reported between-group differences WOMAC function by weight loss | 2 moderate | Inconsistent | Direct | Precise | Insufficient evidence for a long-term effect of weight loss on function
Long-term other outcomes | 2 RCTs | 1 RCT reported no difference in WOMAC total scores; 1 RCT reported significant between group differences in 6-minute walk distance (MD −12.00, 95% CI −33.93, −9.93) and SF-36 physical domain scores (MD −2.70, 95% CI −4.89, −0.51) | 2 moderate | Inconsistent | Direct | Imprecise for 6-minute walk | Insufficient evidence
Home-based and Self-Management
Short-term pain | 2 RCTs | | | | | | Low SoE for short-term benefit for pain
| 1 RCT home-based | 1 RCT reported significant between-group differences in WOMAC pain for 3 home-based interventions vs. a sham-control: Strength training alone: MD −3.75, 95% CI −6.39, −1.11; agility training alone: MD −3.13, 95% CI −5.86, −0.40; strength+agility training: MD −3.00, 95% CI −5,45, −0.55 | Moderate | Consistent | Direct | Precise
| 1 RCT self-management | Significant between-group difference in WOMAC pain scores (MD −1.50, 95% CI −2.33, −0.67) and the likelihood of achieving MCII (RR 0.20, 95% CI 0.08, 0.49) | Low | Consistent | Direct | Precise
Short-term function | 2 RCTs | | | | | | Insufficient evidence
| 1 RCT home-based | Significant between-group differences in WOMAC function for combined strength+agility training (MD −11.98, 95% CI −19.15, −4.81) and strength-training (MD −9.62, 95% CI −19.04, −0.20) vs. controls but not agility alone | Moderate | Inconsistent | Direct | Precise
| 1 RCT self-management | Significant between-group difference in WOMAC function (MD −5.30, 95% CI −7.24, −3.36); % achieving MCII was significantly different (RR 0.24, 99% CI 0.11, 0.51) | Low | N/A | Direct | Precise
Short-term other outcomes | 2 RCTs | | Moderate, low | | | | Insufficient evidence
Medium-term pain | 3 RCTs self-management | 1 RCT found significant between-group differences in VAS pain with pain coping skills training (PCST)+strength training vs. strength training alone (0–100: MD −8.20, 95% CI −15.32, −1.08) but not WOMAC pain; an RCT that combined PCST with behavioral weight management (BWM) found a significant between-group difference in WOMAC pain for BWM+PCST vs. BWM alone | Moderate, 2 low | Inconsistent | Direct | Precise | Low SoE for an effect of self-management on medium-term pain
Medium-term function | 4 RCTs self-management | 3 RCTs reported significant between group differences in WOMAC function (ST+PCST vs. ST alone: 0–68 points, MD −3.80, 95% CI −7.06, −0.54; BWM+PCST vs. standard care: 0–100 points, MD−12.40, 95% CI −17.29, −7.51; self-management vs. wait list: MD−3.50, 95% CI −6.14, −0.86); a 4^th^ RCT found no effects | 2 moderate, 2 low | Inconsistent | Direct | Precise | Low SoE for medium-term effect of self-management on function
Medium-term other outcomes | 3 RCTs | 1 RCT found significant between-group differences in WOMAC total (MD −4.10, 95% CI −7.43, −0.77); Significant between-group differences in TUG (MD −1.00, 95% CI −1.55, −0.45) and SF-36 (MD −5.70, 95% CI −10.97, −0.43) in 1 RCT but not another | Low | N/A | Direct | Precise | Insufficient evidence
Long-term outcomes | 1 RCT | No between-group difference in WOMAC pain, function vs. control; significant improvement in Australian Q-6D | Low | | | | Insufficient evidence
Key Question 2 Adverse Events
Non-serious adverse events | 56RCTs, 1 single arm trial | No systematic findings of non-serious AEs by intervention type, with the exception of minor GI complaints among individuals following low-calorie diets | McHarms scores low (high RoB) for all studies | Inconsistent | Direct | N/A | Low SoE for a lack of systematic non-serious AEs among interventions
Serious adverse events | 18 RCTs | No systematic findings of SAEs by intervention type | McHarms scores low for all studies. Only 1 study that reported “no SAEs” defined SAEs | Inconsistent | Direct | N/A | Low SoE for a lack of systematic serious AEs among interventions

Abbreviations: BWM=behavioral weight management; CI=confidence intervals; MCID=minimum clinically important difference; MCII=minimum clinically important improvement; MD=mean difference; N/A=not applicable; NMES=neuromuscular electrical stimulation; N/R=not reported; NRS=Numeric Rating Scale; PCST=pain coping skills training; QoL=quality of life; RCT=randomized controlled trial; RoB=risk of bias; SF=short form; SMD=standardized mean difference; ST=strength training; TENS=transcutaneous electrical nerve stimulation; TUG=timed up and go; VAS=visual analog scale; WBV=whole-body vibration; WOMAC=Western Ontario McMaster Osteoarthritis Index