# Appendix D Data Abstraction Tools

1 Data Abstraction Tool

2 Modified Cochrane Risk of Bias Tool

3 Modified Newcastle-Ottawa Quality Assessment Scale

4 McHarms Tool