# Appendix C Evidence Table for All Included Studies

Table C1 Evidence table for all included studies