# Appendix B List of Excluded Studies

This appendix lists all studies (publications) that were identified in our literature searches that were subsequently excluded during abstract or full-text screening.

## Not Human – N = 6

1 Attur M, Al-Mussawir HE, Patel J, . Prostaglandin E(2) exerts catabolic effects in osteoarthritis cartilage: Evidence for signaling via the EP4 receptor. Journal of Immunology. 2008 Oct;181(7):5082–8.
2 Bougault C, Gosset M, Houard X, . Stress-Induced Cartilage Degradation Does Not Depend on the NLRP3 Inflammasome in Human Osteoarthritis and Mouse Models. Arthritis and Rheumatism. 2012 Dec;64(12):3972–81. 22933232
3 Calado GP, Lopes AJ, Costa Junior LM, . Chenopodium ambrosioides L. Reduces Synovial Inflammation and Pain in Experimental Osteoarthritis. PLoS One. 2015;10(11):e0141886. doi: 10.1371/journal.pone.0141886. PMID: 26524084.26524084
4 Dunn SL, Wilkinson JM, Crawford A, . Cannabinoid WIN-55,212–2 mesylate inhibits interleukin-1 beta induced matrix metalloproteinase and tissue inhibitor of matrix metalloproteinase expression in human chondrocytes. Osteoarthritis and Cartilage. 2014 Jan;22(1):133–44. 24211233
5 Jayasuriya CT, Goldring MB, Terek R, . Matrilin-3 Induction of IL-1 receptor antagonist Is required for up-regulating collagen II and aggrecan and down-regulating ADAMTS-5 gene expression. Arthritis Research & Therapy. 2012;14(5)
6 van Buul GM, Koevoet WL, Kops N, . Platelet-rich plasma releasate inhibits inflammatory processes in osteoarthritic chondrocytes. Am J Sports Med. 2011 Nov;39(11):2362–70. doi: doi: 10.1177/0363546511419278.21856929

## Not a population of interest – N = 6

1 Edwards C, Rogers A, Lynch S, . The effects of bariatric surgery weight loss on knee pain in patients with osteoarthritis of the knee. Arthritis. 2012;2012:504189. doi: 10.1155/2012/504189. PMID: 23243506.23243506
2 Edwards PK, Ackland TR, Ebert JR. Accelerated weightbearing rehabilitation after matrix-induced autologous chondrocyte implantation in the tibiofemoral joint: early clinical and radiological outcomes. Am J Sports Med. 2013 Oct;41(10):2314–24. doi: 10.1177/0363546513495637. PMID: 23880403.23880403
3 Kim YS, Kwon OR, Choi YJ, . Comparative Matched-Pair Analysis of the Injection Versus Implantation of Mesenchymal Stem Cells for Knee Osteoarthritis. Am J Sports Med. 2015 Nov;43(11):2738–46. doi: 10.1177/0363546515599632. PMID: 26337418.26337418
4 Rini C, Porter L, Somers T, . Automated Internet-based pain coping skills training to manage osteoarthritis pain: a randomized controlled trial. Pain; 2015. p. 837–48.25734997
5 Soni A, Joshi A, Mudge N, . Supervised exercise plus acupuncture for moderate to severe knee osteoarthritis: a small randomised controlled trial. Acupunct Med. 2012 Sep;30(3):176–81. doi: 10.1136/acupmed-2012-010128. PMID: 22914302.22914302
6 Yang PF, Li D, Zhang SM, . Efficacy of ultrasound in the treatment of osteoarthritis of the knee. Orthop Surg. 2011 Aug;3(3):181–7. doi: 10.1111/j.1757-7861.2011.00144.x. PMID: 22009649.22009649

## Not on OA of the knee – N = 28

1 Abbott JH, Chapple C, Pinto D, . Exercise therapy, manual therapy, or both, for management of osteoarthritis of the hip or knee: 2-year follow-up of a randomized clinical trial. Osteoarthritis and cartilage; 2014. p. S51.
2 Alkatan M, Baker J, Machin D, . Improved function and reduced pain after swimming and cycling training in patients with osteoarthritis. Journal of rheumatology; 2016. p. 666–72.26773104
3 Allen KD, Yancy WS, Jr, Bosworth HB, . A Combined Patient and Provider Intervention for Management of Osteoarthritis in Veterans: A Randomized Clinical Trial. Ann Intern Med. 2015 Dec 22doi: 10.7326/M15-0378. PMID: 26720751.26720751
4 Barandun M, Iselin LD, Santini F, . Generation and Characterization of Osteochondral Grafts With Human Nasal Chondrocytes. Journal of Orthopaedic Research. 2015 Aug;33(8):1111–9. 25994595
5 Barry BK. Acute resistance exercise and pressure pain sensitivity in knee osteoarthritis: a randomised crossover trial. Osteoarthritis and cartilage; 2014. p. 407–14.24418672
6 Bigoni M, Sacerdote P, Turati M, . Acute and Late Changes in Intraarticular Cytokine Levels Following Anterior Cruciate Ligament Injury. Journal of Orthopaedic Research. 2013 Feb;31(2):315–21. 22886741
7 Bossen D, Veenhof C, Van Beek KE, . Effectiveness of a web-based physical activity intervention in patients with knee and/or hip osteoarthritis: randomized controlled trial. J Med Internet Res. 2013;15(11):e257. doi: 10.2196/jmir.2662. PMID: 24269911.24269911
8 Crossley KM, Marino GP, Macilquham MD, . Can patellar tape reduce the patellar malalignment and pain associated with patellofemoral osteoarthritis? Arthritis Rheum. 2009 Dec 15;61(12):1719–25. doi: 10.1002/art.24872. PMID: 19950307.19950307
9 Ebert JR, Smith A, Fallon M, . Incidence, degree, and development of graft hypertrophy 24 months after matrix-induced autologous chondrocyte implantation: association with clinical outcomes. Am J Sports Med. 2015 Sep;43(9):2208–15. doi: 10.1177/0363546515591257. PMID: 26163536.26163536
10 Gaynor PJ, Liu P, Weller MA, . Comparison of safety outcomes among Caucasian, Hispanic, Black, and Asian patients in duloxetine studies of chronic painful conditions. Current Medical Research and Opinion. 2013 May;29(5):549–60. PMID: WOS:000317593000013.23477538
11 Hale LA, Waters D, Herbison P. A randomized controlled trial to investigate the effects of water-based exercise to improve falls risk and physical function in older adults with lower-extremity osteoarthritis. Arch Phys Med Rehabil. 2012 Jan;93(1):27–34. doi: 10.1016/j.apmr.2011.08.004. PMID: 21982325.21982325
12 Hinman RS, McCrory P, Pirotta M, . Acupuncture for chronic knee pain: a randomized clinical trial. Deutsche Zeitschrift Fur Akupunktur. 2015;58(2):27–9.
13 Hughes SL, Seymour RB, Campbell RT, . Fit and Strong!: Bolstering Maintenance of Physical Activity Among Older Adults With Lower-extremity Osteoarthritis. American Journal of Health Behavior. 2010;34(6):750–63. 20604699
14 Jimenez SC, Fernandez GR, Zurita OF, . [Effects of education and strength training on functional tests among older people with osteoarthritis]. Rev Med Chil. 2014 Apr;142(4):436–42. doi: 10.4067/s0034-98872014000400004. PMID: 25117033.25117033
15 Kanzaki N, Ono Y, Shibata H, . Glucosamine-containing supplement improves locomotor functions in subjects with knee pain: A randomized, double-blind, placebo-controlled study. Clinical Interventions in Aging. 2015 28;10:1743–53. FULL TEXT LINK http://dx.doi.org/10.2147/CIA.S93077.26604721
16 Lansdown H, Howard K, Brealey S, . Acupuncture for pain and osteoarthritis of the knee: a pilot study for an open parallel-arm randomised controlled trial. BMC Musculoskelet Disord. 2009;10:130. doi: 10.1186/1471-2474-10-130. PMID: 19852841.19852841
17 Martins F, Kaster T, Schutzler L, . Factors influencing further acupuncture usage and a more positive outcome in patients with osteoarthritis of the knee and the hip: a 3-year follow-up of a randomized pragmatic trial. Clin J Pain. 2014 Nov;30(11):953–9. doi: 10.1097/ajp.0000000000000062. PMID: 24346625.24346625
18 Nawaz SZ, Dhinsa B, Gallagher KR, . Autologous chondrocyte implantation does not prevent the need for arthroplasty in patients with pre-existing osteoarthritis. Arthroscopy - Journal of Arthroscopic and Related Surgery. 2011 October;27(10 SUPPL. 1):e170–e1.
19 Parlar S, Fadiloglu C, Argon G, . The effects of self-pain management on the intensity of pain and pain management methods in arthritic patients. Pain Manag Nurs. 2013 Sep;14(3):133–42. doi: 10.1016/j.pmn.2010.08.002. PMID: 23972864.23972864
20 Pisters M, Veenhof C, Schellevis F, . Long-term effect of exercise therapy in patients with osteoarthritis: A randomized controlled trial comparing two different physiotherapy interventions. Physiotherapy (United Kingdom); 2011. p. eS1005.
21 Satpute A, Bhatt DL, Kashyap S, . Effects of Bariatric Surgery on Long-Term Quality of Life Outcomes for Obese Patients with Osteoarthritis [abstract]. . Arthritis Rheumatol 2015;67(suppl 10).
22 Tollefsrud I, Askmann E. Effect of exercise and lifestyle interventions on an outpatient rehabilitation programme for patients with hip or knee OA. Scandinavian Journal of Rheumatology. 2014 2014;43 SUPPL. 127:78–9.24446586
23 Tsuji T, Yoon J, Kitano N, . Effects of N-acetyl glucosamine and chondroitin sulfate supplementation on knee pain and self-reported knee function in middle-aged and older Japanese adults: a randomized, double-blind, placebo-controlled trial. Aging Clin Exp Res. 2015 Jul 16doi: 10.1007/s40520-015-0412-6. PMID: 26178634.26178634
24 Veenhof C, Van den Ende CH, Dekker J, . Which patients with osteoarthritis of hip and/or knee benefit most from behavioral graded activity? Int J Behav Med. 2007;14(2):86–91. PMID: 17926436.17926436
25 Villacis J, Rice TR, Bucci LR, . Do shrimp-allergic individuals tolerate shrimp-derived glucosamine? Clinical and Experimental Allergy. 2006 Nov;36(11):1457–61. 17083356
26 Westfall PH, Krishen A. Optimally weighted, fixed sequence and gatekeeper multiple testing procedures. J Stat Plann Infer. 2001;99(1):25–40.
27 White DK, Neogi T, Rejeski WJ, . Can an Intensive Diet and Exercise Program Prevent Knee Pain Among Overweight Adults at High Risk? Arthritis Care & Research. 2015 July;67(7):965–71.25692781
28 Yip YB, Tam AC. An experimental study on the effectiveness of massage with aromatic ginger and orange essential oil for moderate-to-severe knee pain among the elderly in Hong Kong. Complement Ther Med. 2008 Jun;16(3):131–8. doi: 10.1016/j.ctim.2007.12.003. PMID: 18534325.18534325

## Not on treating/managing OA of the knee – N = 6

1 Bennell KL, Campbell PK, Egerton T, . Telephone coaching to enhance a home-based physical activity program for knee osteoarthritis: A randomised clinical trial. Arthritis Care Res (Hoboken). 2016 Apr 25doi: 10.1002/acr.22915. PMID: 27111441.27111441
2 Catay E, Ruta S, Rosa J, . Ultrasound (US) Findings in Patients with Knee Pain: Sensitivity and Specificity for the Diagnosis of Knee Osteoarthritis and Development of an US Prediction Score [abstract]. 2012 ACR/ARHP Annual Meeting. Arthritis rheumatol. 2012;64 (suppl S10):S53.
3 Haxby Abbott J, Chapple C, Pinto D, . Exercise Therapy and/or Manual Therapy for Hip or Knee Osteoarthritis: 2-Year Follow-up of a Randomized Controlled Trial [abstract]. 2014 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2014;66 (suppl S10):S1266–7.
4 Lamas JR, Tornero-Esteban P, Garcia Fernández C, . A Double-Blind, Randomized, Placebo-Controlled Trial of Mesenchymal Stem Cells for the Treatment of Patients with Full-Thickness Rotator Cuff Tears [abstract]. 2015 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2015;67 (suppl 10):1411.26010937
5 Skou ST, Rasmussen S, Simonsen O, . Knee Confidence as It Relates to Self-reported and Objective Correlates of Knee Osteoarthritis: A Cross-sectional Study of 220 Patients. J Orthop Sports Phys Ther. 2015 Oct;45(10):765–71. doi: 10.2519/jospt.2015.5864. PMID: 26304646.26304646
6 White D, Neogi T, Rejeski WJ, . Can Knee Pain be Prevented through Diet and Exercise Among Those at High Risk? the Look Ahead Study [abstract]. 2014 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2014;66 (suppl S10):S1314–5.

## Not an intervention of interest – N = 95

1 Abou-Raya S, Abou-Raya A, Helmii M. Duloxetine for the management of pain in older adults with knee osteoarthritis: randomised placebo-controlled trial. Age Ageing. 2012 Sep;41(5):646–52. doi: 10.1093/ageing/afs072. PMID: 22743149.22743149
2 Alpayci M, Ozkan Y, Yazmalar L, . A randomized controlled trial on the efficacy of intermittent and continuous traction for patients with knee osteoarthritis. Clin Rehabil. 2013 Apr;27(4):347–54. doi: 10.1177/0269215512459062. PMID: 22960239.22960239
3 Anz AW, Hackel JG, Nilssen EC, . Application of Biologics in the Treatment of the Rotator Cuff, Meniscus, Cartilage, and Osteoarthritis. Journal of the American Academy of Orthopaedic Surgeons. 2014 Feb;22(2):68–79. 24486753
4 Arden NK, Reading IC, Jordan KM, . A randomised controlled trial of tidal irrigation vs corticosteroid injection in knee osteoarthritis: the KIVIS Study. Osteoarthritis Cartilage. 2008 Jun;16(6):733–9. doi: 10.1016/j.joca.2007.10.011. PMID: 18077189.18077189
5 Baltzer AWA, Moser C, Jansen SA, . Autologous conditioned serum (Orthokine) is an effective treatment for knee osteoarthritis. Osteoarthritis and Cartilage. 2009 Feb;17(2):152–60. 18674932
6 Baraf HS, Gloth FM, Barthel HR, . Safety and efficacy of topical diclofenac sodium gel for knee osteoarthritis in elderly and younger patients: pooled data from three randomized, double-blind, parallel-group, placebo-controlled, multicentre trials. Drugs Aging. 2011 Jan 1;28(1):27–40. doi: 10.2165/11584880-000000000-00000. PMID: 21174485.21174485
7 Barrett T, Franke R, Cheruvu N, . An assessment of the efficacy and tolerability of diclofenac sodium 2% topical solution for treating osteoarthritis of the knee. Journal of Pain. 2014 April;15(4 SUPPL. 1):S97.
8 Barthel HR, Haselwood D, Longley S, 3rd, . Randomized controlled trial of diclofenac sodium gel in knee osteoarthritis. Semin Arthritis Rheum. 2009 Dec;39(3):203–12. doi: 10.1016/j.semarthrit.2009.09.002. PMID: 19932833.19932833
9 Belcaro G, Dugall M, Luzzi R, . Meriva (R) plus Glucosamine versus Condroitin plus Glucosamine in patients with knee osteoarthritis: an observational study. European Review for Medical and Pharmacological Sciences. 2014 Dec;18(24):3959–63. 25555891
10 Bennell KL, Kyriakides M, Metcalf B, . Neuromuscular versus quadriceps strengthening exercise in patients with medial knee osteoarthritis and varus malalignment: a randomized controlled trial. Arthritis Rheumatol. 2014 Apr;66(4):950–9. doi: 10.1002/art.38317. PMID: 24757146.24757146
11 Bodick N, Lufkin J, Willwerth C, . An Intra-Articular, Extended-Release Formulation of Triamcinolone Acetonide Prolongs and Amplifies Analgesic Effect in Patients with Osteoarthritis of the Knee. Journal of Bone and Joint Surgery-American Volume. 2015 Jun;97A(11):877–88.
12 Chappell AS, Desaiah D, Liu-Seifert H, . A double-blind, randomized, placebo-controlled study of the efficacy and safety of duloxetine for the treatment of chronic pain due to osteoarthritis of the knee. Pain Pract. 2011 Jan–Feb;11(1):33–41. doi: 10.1111/j.1533-2500.2010.00401.x. PMID: 20602715.20602715
13 Chappell AS, Desaiah D, Liu-Seifert H, . A Double-blind, Randomized, Placebo-controlled Study of the Efficacy and Safety of Duloxetine for the Treatment of Chronic Pain Due to Osteoarthritis of the Knee. Pain Practice. 2011 Jan–Feb;11(1):33–41. 20602715
14 Chappell AS, Ossanna MJ, Liu-Seifert H, . Duloxetine, a centrally acting analgesic, in the treatment of patients with osteoarthritis knee pain: a 13-week, randomized, placebo-controlled trial. Pain. 2009 Dec;146(3):253–60. doi: 10.1016/j.pain.2009.06.024. PMID: 19625125.19625125
15 Chen LX, Mao JJ, Fernandes S, . Integrating acupuncture with exercise-based physical therapy for knee osteoarthritis: a randomized controlled trial. J Clin Rheumatol. 2013 Sep;19(6):308–16. doi: 10.1097/RHU.0b013e3182a21848. PMID: 23965480.23965480
16 Chen XY, Spaeth RB, Freeman SG, . The modulation effect of longitudinal acupuncture on resting state functional connectivity in knee osteoarthritis patients. Molecular Pain. 2015 Oct;11 25889478
17 Cheung RKH, Leung KK, Lee KC, . Sequential non-traumatic femoral shaft fractures in a patient on long-term alendronate. Hong Kong Medical Journal. 2007;13(6):485–9.18057440
18 Cho J, Kim T, Park Y, . Tissuegene-C (Invossa^™^) in patients with osteoarthritis: A phase II trials. Osteoarthritis and Cartilage. 2015 April;23 SUPPL. 2:A170.
19 Cho JJ, Kim TW, Park YM, . Tissuegene-C (InvossaTM) in patients with osteoarthritis: A phase II trials. Cytotherapy. 2015 June;17(6 SUPPL. 1):S84.
20 Conaghan PG, Dickson J, Bolten W, . A multicentre, randomized, placebo- and active-controlled trial comparing the efficacy and safety of topical ketoprofen in Transfersome gel (IDEA-033) with ketoprofen-free vehicle (TDT 064) and oral celecoxib for knee pain associated with osteoarthritis. Rheumatology (Oxford). 2013 Jul;52(7):1303–12. doi: 10.1093/rheumatology/ket133. PMID: 23542612.23542612
21 Crossley KM, Vicenzino B, Schache AG, . Targeted physiotherapy treatment for patellofemoral osteoarthritis: A randomised clinical trial. Osteoarthritis and cartilage; 2014. p. S431.
22 Davalillo CAT, Vasavilbaso CT, Alvarez JMN, . Clinical efficacy of intra-articular injections in knee osteoarthritis: A prospective randomized study comparing hyaluronic acid and betamethasone. Open Access Rheumatology: Research and Reviews; 2015. p. 9–18.27790040
23 De Campos GC, Rezende MU, Pailo AF, . Adding triamcinolone improves viscosupplementation: A randomized clinical trial knee. Clinical Orthopaedics and Related Research. 2013 February;471(2):613–20. (http://www.ncbi.nlm.nih.gov/pubmed/23100188) FULL TEXT LINK http://dx.doi.org/10.1007/s11999-012-2659-y.
24 Ding MH, Zhang H, Li Y. [A randomized controlled study on warming needle moxibustion for treatment of knee osteoarthritis]. Zhongguo zhen jiu [Chinese acupuncture & moxibustion]; 2009. p. 603–7.19947259
25 Dumais R, Benoit C, Dumais A, . Effect of regenerative injection therapy on function and pain in patients with knee osteoarthritis: a randomized crossover study. Pain Med. 2012 Aug;13(8):990–9. doi: 10.1111/j.1526-4637.2012.01422.x. PMID: 22759069.22759069
26 Erhan B, Gunduz B, Ustunel SH, . The Efficacy of Topical Glucosamine Sulfate-Chondroitin Sulfate in Knee Osteoarthritis Treated With Physical Therapy: A Randomized, Double-Blind, Placebo-Controlled Study. Turkiye Fiziksel Tip Ve Rehabilitasyon Dergisi-Turkish Journal of Physical Medicine and Rehabilitation. 2012 Sep;58(3):194–8.
27 Espinosa Cuervo G, Martinez Garcia MDC, Gonzalez Carmona B, . Efficacy of kots russian electroestimulation in quality of life, functional capacity, muscular force and equilibrium in knee osteoarthritis: Clinical trial. Physiotherapy (United Kingdom); 2011. p. eS319–eS20.
28 Fernandes NF, Malliah R, Stitik TP, . Herpes zoster following intra-articular corticosteroid injection. Acta Dermatovenerol Alp Pannonica Adriat. 2009 Mar;18(1):28–30. PMID: 19350185.19350185
29 Fioravanti A, Bellisai B, Iacoponi F, . Phytothermotherapy in osteoarthritis: a randomized controlled clinical trial. J Altern Complement Med. 2011 May;17(5):407–12. doi: 10.1089/acm.2010.0294. PMID: 21563963.21563963
30 Focht BC, Garver MJ, Devor ST, . Group-mediated physical activity promotion and mobility in sedentary patients with knee osteoarthritis: results from the IMPACT-pilot trial. Rehabil Res Pract. 2014 Oct;41(10):2068–77. doi: 10.1155/2014/861268 10.3899/jrheum.140054. PMID: 25179854.25179854
31 Fortin PR, Penrod JR, Clarke AE, . Timing of total joint replacement affects clinical outcomes among patients with osteoarthritis of the hip or knee. Arthritis Rheum. 2002 Dec;46(12):3327–30. doi: 10.1002/art.10631. PMID: 12483739.12483739
32 Foster NE, Thomas E, Barlas P, . Acupuncture as an adjunct to exercise based physiotherapy for osteoarthritis of the knee: randomised controlled trial. Bmj. 2007 Sep 1;335(7617):436. doi: 10.1136/bmj.39280.509803.BE. PMID: 17699546.17699546
33 Frakes EP, Risser RC, Ball TD, . Duloxetine added to oral nonsteroidal anti-inflammatory drugs for treatment of knee pain due to osteoarthritis: results of a randomized, double-blind, placebo-controlled trial. Curr Med Res Opin. 2011 Dec;27(12):2361–72. doi: 10.1185/03007995.2011.633502. PMID: 22017192.22017192
34 Garcia-Padilla S, Duarte-Vazquez MA, Gonzalez-Romero KE, . Effectiveness of intra-articular injections of sodium bicarbonate and calcium gluconate in the treatment of osteoarthritis of the knee: a randomized double-blind clinical trial. Bmc Musculoskeletal Disorders. 2015 May;16 25886129
35 Guler O, Mutlu S, Isyar M, . Comparison of short-term results of intraarticular platelet-rich plasma (PRP) and hyaluronic acid treatments in early-stage gonarthrosis patients. European Journal of Orthopaedic Surgery and Traumatology. 2015 2015;25(3):509–13. FULL TEXT LINK http://dx.doi.org/10.1007/s00590-014-1517-x.25085316
36 Ha CW, Cho JJ, Elmallah RK, . A Multicenter, Single-Blind, Phase IIa Clinical Trial to Evaluate the Efficacy and Safety of a Cell-Mediated Gene Therapy in Degenerative Knee Arthritis Patients. Hum Gene Ther Clin Dev. 2015 Jun;26(2):125–30. doi: 10.1089/humc.2014.145. PMID: 25760423.25760423
37 Hammad Y, Magid H, Sobhy M. Clinical and biochemical study of the comparative efficacy of topical versus oral glucosamine/chondroitin sulfate on osteoarthritis of the knee. Egyptian Rheumatologist; 2015. p. 85–91.
38 Henriksen M, Christensen R, Klokker L, . Evaluation of the benefit of corticosteroid injection before exercise therapy in patients with osteoarthritis of the knee: a randomized clinical trial. JAMA Intern Med. 2015 Jun;175(6):923–30. doi: 10.1001/jamainternmed.2015.0461. PMID: 25822572.25822572
39 Hochberg MC, Wohlreich M, Gaynor P, . Clinically relevant outcomes based on analysis of pooled data from 2 trials of duloxetine in patients with knee osteoarthritis. J Rheumatol. 2012 Feb;39(2):352–8. doi: 10.3899/jrheum.110307. PMID: 22133624.22133624
40 Horng HC, Kuo CP, Cherng CH, . The effects of collateral meridian therapy for knee osteoarthritis pain management: a pilot study. J Manipulative Physiol Ther. 2013 Jan;36(1):51–6. doi: 10.1016/j.jmpt.2012.12.003. PMID: 23380214.23380214
41 Housman L, Arden N, Schnitzer TJ, . Intra-articular hylastan versus steroid for knee osteoarthritis. Knee Surg Sports Traumatol Arthrosc. 2014 Jul;22(7):1684–92. doi: 10.1007/s00167-013-2438-7. PMID: 23417236.23417236
42 Itoh K, Hirota S, Katsumi Y, . Trigger point acupuncture for treatment of knee osteoarthritis--a preliminary RCT for a pragmatic trial. Acupunct Med. 2008 Mar;26(1):17–26. PMID: 18356795.18356795
43 Jevtic T, Mejdi Z, Vukomanovic J, . Application of methylprednisolone suspension by iontophoresis in patients with arthrosis of the knee. Serbian Journal of Experimental and Clinical Research. 2008 2008;9(1):13–7.
44 Jubb RW, Tukmachi ES, Jones PW, . A blinded randomised trial of acupuncture (manual and electroacupuncture) compared with a non-penetrating sham for the symptoms of osteoarthritis of the knee. Acupunct Med. 2008 Jun;26(2):69–78. PMID: 18591906.18591906
45 Kanzaki N, Saito K, Maeda A, . Effect of a dietary supplement containing glucosamine hydrochloride, chondroitin sulfate and quercetin glycosides on symptomatic knee osteoarthritis: a randomized, double-blind, placebo-controlled study. J Sci Food Agric. 2012 Mar 15;92(4):862–9. doi: 10.1002/jsfa.4660. PMID: 21969261.21969261
46 Karagulle M, Karagulle MZ, Karagulle O, . A 10-day course of SPA therapy is beneficial for people with severe knee osteoarthritis. A 24-week randomised, controlled pilot study. Clin Rheumatol. 2007 Dec;26(12):2063–71. doi: 10.1007/s10067-007-0618-x. PMID: 17431728.17431728
47 Kaya E, Kaplan C, Carli AB, . Effects of Balneotherapy and Physical Therapy on Sleep Quality in Patients With Osteoarthritis Aged 50 to 85 Years. Archives of Rheumatology. 2016;31(1):1–5. doi: 10.5606/ArchRheumatol.2016.4625. 29900973
48 Kivitz A, Fairfax M, Sheldon EA, . Comparison of the effectiveness and tolerability of lidocaine patch 5% versus celecoxib for osteoarthritis-related knee pain: post hoc analysis of a 12 week, prospective, randomized, active-controlled, open-label, parallel-group trial in adults. Clin Ther. 2008 Dec;30(12):2366–77. doi: 10.1016/j.clinthera.2008.12.015. PMID: 19167595.19167595
49 Kosuwon W, Sirichatiwapee W, Wisanuyotin T, . Efficacy of symptomatic control of knee osteoarthritis with 0.0125% of capsaicin versus placebo. J Med Assoc Thai. 2010 Oct;93(10):1188–95. PMID: 20973322.20973322
50 Lapshina S, Myasoutova L, Afanasyeva M, . Comparative effectiveness of local transdermal therapy with glyukozaminosulfatis (Hondroksid Maximum ) and injectable form of glyukozaminosulfatis (DONA) in patients with knee OA. Osteoporosis International. 2015 February;26(1 SUPPL. 1):S334–S5.
51 Lee B, Cho J, Kim T, . Tissuegene-C (TG-C), TGF-β1 transduced chondrocyte, improved clinical scores in patients with osteoarthritis: A phase 2B study. Molecular Therapy. 2014 June;22 SUPPL. 1:S292–S3.
52 Lev-Ari S, Miller E, Maimon Y, . Delayed effect of acupuncture treatment in OA of the knee: A blinded, randomized, controlled trial. Evidence based Complementary and Alternative Medicine. 2011;792975(410) FULL TEXT LINK http://dx.doi.org/10.1093/ecam/nen080.
53 Liu K, Tian LF. [Knee osteoarthritis treated with acupuncture at Neiguan (PC 6) and Taichong (LR 3)]. Zhongguo Zhen Jiu. 2013 Feb;33(2):105–8. PMID: 23620932.23620932
54 Liu MR, Li L, He ZW. [Efficacy observation on osteoarthritis of the knee treated with the ultrastructural acupotomy therapy at the counter-Ashi points]. [Chinese]. Zhongguo zhen jiu [Chinese acupuncture & moxibustion]; 2012. p. 621–4.22997793
55 Liu YS, Xue LG, Ma XJ, . Observation on pain release by long-round needle therapy in knee osteoarthritis related with meridian-sinews theory. Evidence-based Complementary and Alternative Medicine; 2013.
56 Magrans-Courtney T, Wilborn C, Rasmussen C, . Effects of diet type andFsupplementation of glucosamine, chondroitin, and MSM on body composition, functional status, and markers of health in women with knee osteoarthritis initiating a resistance-based exercise and weight loss program. J Int Soc Sports Nutr. 2011;8(1):8. doi: 10.1186/1550-2783-8-8. PMID: 21689421.21689421
57 Manheimer E, Lim B, Lao L, . Acupuncture for knee osteoarthritis--a randomised trial using a novel sham. Acupunct Med. 2006 Dec;24 Suppl:S7–14. PMID: 17308513.17308513
58 Mavrommatis CI, Argyra E, Vadalouka A, . Acupuncture as an adjunctive therapy to pharmacological treatment in patients with chronic pain due to osteoarthritis of the knee: a 3-armed, randomized, placebo-controlled trial. Pain. 2012 Aug;153(8):1720–6. doi: 10.1016/j.pain.2012.05.005. PMID: 22727499.22727499
59 Meng CR, Fan L, Fu WB, . Clinical research on abdominal acupuncture plus conventional acupuncture for knee osteoarthritis. J Tradit Chin Med. 2009 Dec;29(4):249–52. PMID: 20112481.20112481
60 Miller E, Maimon Y, Rosenblatt Y, . Delayed Effect of Acupuncture Treatment in OA of the Knee: A Blinded, Randomized, Controlled Trial. Evidence-Based Complementary and Alternative Medicine. 2011:1–5.
61 Miori R, Paolazzi G, Albertazzi R, . [Phytothermotherapy with fermenting alpine grass in knee osteoarthritis: mid-long term results]. Reumatismo. 2008 Oct–Dec;60(4):282–9. PMID: 19132153.19132153
62 Moller I, Cid M, Chetrit C, . Effect of a topical cream containing mucopolysaccharides on knee function and pain intensity of patients with osteoarthritis. Osteoarthritis and Cartilage. 2013 April;21 SUPPL. 1:S287.
63 Nejati P, Farzinmehr A, Moradi-Lakeh M. The effect of exercise therapy on knee osteoarthritis: a randomized clinical trial. Med J Islam Repub Iran. 2015;29:186. PMID: 26034739.26034739
64 Park SH, Park CY, Kim SK, . Safety and efficacy of piroxicam patches for treating knee osteoarthritis. Korean Journal of Medicine; 2008. p. 537–45.
65 Peniston JH, Gold MS, Wieman MS, . Long-term tolerability of topical diclofenac sodium 1% gel for osteoarthritis in seniors and patients with comorbidities. Clin Interv Aging. 2012;7:517–23. doi: 10.2147/cia.s35416. PMID: 23204844.23204844
66 Qiu L, Kan JW, Zheng X, . [Observation on the long-term efficacy of knee osteoarthritis treated with warm needling and rehabilitation training]. [Chinese]. Zhongguo zhen jiu [Chinese acupuncture & moxibustion]; 2013. p. 199–202.23713297
67 Rabago D, Kijowski R, Woods M, . Association between disease-specific quality of life and magnetic resonance imaging outcomes in a clinical trial of prolotherapy for knee osteoarthritis. Arch Phys Med Rehabil. 2013 Nov;94(11):2075–82. doi: 10.1016/j.apmr.2013.06.025. PMID: 23850615.23850615
68 Rabago D, Patterson JJ, Mundt M, . Dextrose prolotherapy for knee osteoarthritis: a randomized controlled trial. Ann Fam Med. 2013 May–Jun;11(3):229–37. doi: 10.1370/afm.1504. PMID: 23690322.23690322
69 Ren X, Yao C, Wu F, . Effectiveness of moxibustion treatment in quality of life in patients with knee osteoarthritis: A randomized, double-blinded, placebo-controlled trial. Evidence-based Complementary and Alternative Medicine; 2015.
70 Ren XM, Cao JJ, Shen XY, . [Knee osteoarthritis treated with moxibustion: a randomized controlled trial]. Zhongguo Zhen Jiu. 2011 Dec;31(12):1057–61. PMID: 22256633.22256633
71 Ren XM, Cao JJ, Shen XY, . Preliminary clinical randomized controlled trial on knee osteoarthritis treated with moxibustion. World Journal of Acupuncture - Moxibustion; 2012. p. 28–33.
72 Rossi MD, Eberle T, Roche M, . Delaying knee replacement and implications on early postoperative outcomes: a pilot study. Orthopedics. 2009 Dec;32(12):885. doi: 10.3928/01477447-20091020-06. PMID: 19968215.19968215
73 Rother M, Conaghan PG. A randomized, double-blind, phase III trial in moderate osteoarthritis knee pain comparing topical ketoprofen gel with ketoprofen-free gel. J Rheumatol. 2013 Oct;40(10):1742–8. doi: 10.3899/jrheum.130192. PMID: 23996292.23996292
74 Saleki M, Ahadi T, Razi M, . Comparison of the effects of acupuncture and isometric exercises on symptom of knee osteoarthritis. Int J Prev Med. 2013 Apr;4(Suppl 1):S73–7. PMID: 23717775.23717775
75 Scharf HP, Mansmann U, Streitberger K, . Acupuncture and knee osteoarthritis: a three-armed randomized trial. Ann Intern Med. 2006 Jul 4;145(1):12–20. PMID: 16818924.16818924
76 Schnitzer TJ, Pelletier JP, Haselwood DM, . Civamide cream 0.075% in patients with osteoarthritis of the knee: a 12-week randomized controlled clinical trial with a longterm extension. J Rheumatol. 2012 Mar;39(3):610–20. doi: 10.3899/jrheum.110192. PMID: 22089461.22089461
77 Schnitzer TJ, Pelletier J-P, Haselwood DM, . Civamide cream 0.075% in patients with osteoarthritis of the knee: a 12-week randomized controlled clinical trial with a longterm extension. Journal of Rheumatology 2012;39 (3)PMID: 108170486.
78 Selvan T, Rajiah K, Nainar MSM, . A Clinical Study on Glucosamine Sulfate versus Combination of Glucosamine Sulfate and NSAIDs in Mild to Moderate Knee Osteoarthritis. Scientific World Journal 2012:1–5.
79 Skou ST, Roos EM, Simonsen O, . The efficacy of non-surgical treatment on pain and sensitization in patients with knee osteoarthritis: a pre-defined ancillary analysis from a randomized controlled trial. Osteoarthritis Cartilage. 2015 Aug 1doi: 10.1016/j.joca.2015.07.013. PMID: 26241775.26241775
80 Spaeth RB, Camhi S, Hashmi JA, . A longitudinal study of the reliability of acupuncture deqi sensations in knee osteoarthritis. Evid Based Complement Alternat Med. 2013;2013:204259. doi: 10.1155/2013/204259. PMID: 23935656.23935656
81 Stutz-Doyle C. The effects of traditional strengthening exercises versus functional task training on pain, strength, and functional mobility in the 45–65 year old adult with knee osteoarthritis. Seton Hall University 2011 PMID: 109857766.
82 Suarez-Almazor ME, Looney C, Liu Y, . A randomized controlled trial of acupuncture for osteoarthritis of the knee: effects of patient-provider communication. Arthritis Care Res (Hoboken). 2010 Sep;62(9):1229–36. doi: 10.1002/acr.20225. PMID: 20506122.20506122
83 Sun K, Bao XM, Song YC, . [Clinical study on the treatment of knee osteoarthritis by acupuncture plus manipulative regulation of knee muscle]. Zhongguo Gu Shang. 2010 Dec;23(12):895–8. PMID: 21265192.21265192
84 Taechaarpornkul W, Suvapan D, Theppanom C, . Comparison of the effectiveness of six and two acupuncture point regimens in osteoarthritis of the knee: a randomised trial. Acupunct Med. 2009 Mar;27(1):3–8. doi: 10.1136/aim.2008.000067. PMID: 19369186.19369186
85 Tunay VB, Baltaci G, Atay AO. Hospital-based versus home-based proprioceptive and strengthening exercise programs in knee osteoarthritis. Acta Orthop Traumatol Turc. 2010;44(4):270–7. doi: 10.3944/aott.2010.2306. PMID: 21252603.21252603
86 Vas J, Mendez C, Perea-Milla E. Acupuncture versus Streitberger needle in knee osteoarthritis -- an RCT. Acupuncture Medicine; 2006. p. S15–s24.
87 Vermesan D, Prejbeanu R, Laitin S, . Arthroscopic debridement compared to intra-articular steroids in treating degenerative medial meniscal tears. Eur Rev Med Pharmacol Sci. 2013 Dec;17(23):3192–6. PMID: 24338461.24338461
88 Wang JG, He LJ. [Observation on the therapeutic effect of warming needle moxibustion on knee osteoarthritis]. Zhongguo zhen jiu [Chinese acupuncture & moxibustion]; 2007. p. 191–2.17432646
89 Weiner DK, Moore CG, Morone NE, . Efficacy of periosteal stimulation for chronic pain associated with advanced knee osteoarthritis: a randomized, controlled clinical trial. Clin Ther. 2013 Nov;35(11):1703–20.e5. doi: 10.1016/j.clinthera.2013.09.025. PMID: 24184053.24184053
90 Wi SY, Kang JH, Jang JH. Clinical Feasibility of Exercise Game for Depression Treatment in Older Women with Osteoarthritis: a Pilot Study. Journal of Physical Therapy Science. 2013 Feb;25(2):165–7.
91 Williamson OD, Schroer M, Ruff DD, . Onset of response with duloxetine treatment in patients with osteoarthritis knee pain and chronic low back pain: a post hoc analysis of placebo-controlled trials. Clin Ther. 2014 Apr 1;36(4):544–51. doi: 10.1016/j.clinthera.2014.02.009. PMID: 24650448.24650448
92 Wu ZH, Bao F. [Observation on therapeutic effects of electroacupuncture for the treatment of knee osteoarthritis]. Zhongguo gu shang [China journal of orthopaedics and traumatology]; 2008. p. 170–2.19105428
93 Yang XC, He SF, Wang RC, . [Observation on curative effect of thermal acupuncture needle muscular stimulation therapy for knee osteoarthritis patients]. Zhen Ci Yan Jiu. 2012 Jun;37(3):237–41. PMID: 22934397.22934397
94 Zane AJ, Huang J, Bettadahalli S, . Hyponatremia: A complication of intra-articular corticosteroid injection. Journal of General Internal Medicine. 2013 June;28 SUPPL. 1:S343.
95 Zhao L, Cheng K, Wang L, . Effectiveness of moxibustion treatment as adjunctive therapy in osteoarthritis of the knee: a randomized, double-blinded, placebo-controlled clinical trial. Arthritis Res Ther. 2014;16(3):R133. doi: 10.1007/s11999-014-3743-2 10.1186/ar4590. PMID: 24962039.24962039

## Specific interventions with a sample size less than 50 – N = 32

1 Aaboe J, Henriksen M, Bartholdy C, . The effect of quadriceps-strengthening exercise on quadriceps and knee biomichanics during walking in adults with knee osteoarthritis: A randomized controlled trial. Osteoarthritis and cartilage; 2014. p. S80–s1.
2 Anwer S, Alghadir A. Effect of isometric quadriceps exercise on muscle strength, pain, and function in patients with knee osteoarthritis: a randomized controlled study. J Phys Ther Sci. 2014 May;26(5):745–8. doi: 10.1589/jpts.26.745. PMID: 24926143.24926143
3 Armagan O, Yilmazer S, Calısir C, . Comparison of the symptomatic and chondroprotective effects of glucosamine sulphate and exercise treatments in patients with knee osteoarthritis. Journal of Back & Musculoskeletal Rehabilitation. 2015;28(2) .
4 Ay S, Koldas Dogan S, Evcik D. Is there an effective way to prescribe a home-based exercise program in patients with knee osteoarthritis? a randomized controlled study. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi; 2013. p. 1–6.
5 Bennell KL, Hunt MA, Wrigley TV, . Hip strengthening reduces symptoms but not knee load in people with medial knee osteoarthritis and varus malalignment: a randomised controlled trial. Osteoarthritis Cartilage. 2010 May;18(5):621–8. doi: 10.1016/j.joca.2010.01.010. PMID: 20175973.20175973
6 Chang TF, Liou TH, Chen CH, . Effects of elastic-band exercise on lower-extremity function among female patients with osteoarthritis of the knee. Disabil Rehabil. 2012;34(20):1727–35. doi: 10.3109/09638288.2012.660598. PMID: 22397710.22397710
7 Cherian JJ, Kapadia BH, Bhave A, . Use of Transcutaneous Electrical Nerve Stimulation Device in Early Osteoarthritis of the Knee. J Knee Surg. 2015 Aug;28(4):321–7. doi: 10.1055/s-0034-1389160. PMID: 25162407.25162407
8 Crossley KM, Vicenzino B, Lentzos J, . Exercise, education, manual-therapy and taping compared to education for patellofemoral osteoarthritis: a blinded, randomised clinical trial. Osteoarthritis Cartilage. 2015 Sep;23(9):1457–64. doi: 10.1016/j.joca.2015.04.024. PMID: 25960116.25960116
9 Durmus D, Alayli G, Aliyazicioglu Y, . Effects of glucosamine sulfate and exercise therapy on serum leptin levels in patients with knee osteoarthritis: preliminary results of randomized controlled clinical trial. Rheumatol Int. 2013 Mar;33(3):593–9. doi: 10.1007/s00296-012-2401-9. PMID: 22476244.22476244
10 Durmus D, Alayli G, Bayrak IK, . Assessment of the effect of glucosamine sulfate and exercise on knee cartilage using magnetic resonance imaging in patients with knee osteoarthritis: a randomized controlled clinical trial. J Back Musculoskelet Rehabil. 2012;25(4):275–84. doi: 10.3233/bmr-2012-0336. PMID: 23220811.23220811
11 Gallego-Ariza B, Mateos-Toset S, Cabrera-Martos I, . Impact of a supervised muscular training on perceived quality of sleep and health in a population with knee osteoarthritis. Sleep medicine; 2013. p. e63–e4.
12 Giordano N, Fioravanti A, Papakostas P, . The efficacy and tolerability of glucosamine sulfate in the treatment of knee osteoarthritis: A randomized, double-blind, placebo-controlled trial. Curr Ther Res Clin Exp. 2009 Jun;70(3):185–96. doi: 10.1016/j.curtheres.2009.05.004. PMID: 24683229.24683229
13 Haflah NHM, Jaarin K, Abdullah S, . Palm vitamin E and glucosamine sulphate in the treatment of osteoarthritis of the knee. Saudi Medical Journal. 2009 Nov;30(11):1432–8. 19882056
14 Heinonen A, Multanen J, Kujala U, . High-impact training to improve physical performance in postmenopausal women with early osteoarthritis. Physiotherapy (United Kingdom); 2011. p. eS470–eS1.
15 Henriksen M, Klokker L, Bartholdy C, . The effects of exercise therapy on knee joint biomechanics during walking in patients with knee osteoarthritis: Secondary outcome analyses from a randomized controlled trial. Osteoarthritis and cartilage; 2014. p. S44.
16 Hunt MA, Keefe FJ, Bryant C, . A physiotherapist-delivered, combined exercise and pain coping skills training intervention for individuals with knee osteoarthritis: a pilot study. Knee. 2013 Mar;20(2):106–12. doi: 10.1016/j.knee.2012.07.008. PMID: 22921688.22921688
17 Jorge RT, Souza MC, Chiari A, . Progressive resistance exercise in women with osteoarthritis of the knee: a randomized controlled trial. Clin Rehabil. 2015 Mar;29(3):234–43. doi: 10.1177/0269215514540920. PMID: 24994768.24994768
18 Kawasaki T, Kurosawa H, Ikeda H, . Additive effects of glucosamine or risedronate for the treatment of osteoarthritis of the knee combined with home exercise: a prospective randomized 18-month trial. J Bone Miner Metab. 2008;26(3):279–87. doi: 10.1007/s00774-007-0813-5. PMID: 18470670.18470670
19 Messier SP, Mihalko S, Loeser RF, . Glucosamine/chondroitin combined with exercise for the treatment of knee osteoarthritis: a preliminary study. Osteoarthritis Cartilage. 2007 Nov;15(11):1256–66. doi: 10.1016/j.joca.2007.04.016. PMID: 17561418.17561418
20 Petersen SG, Beyer N, Hansen M, . Nonsteroidal anti-inflammatory drug or glucosamine reduced pain and improved muscle strength with resistance training in a randomized controlled trial of knee osteoarthritis patients. Arch Phys Med Rehabil. 2011 Aug;92(8):1185–93. doi: 10.1016/j.apmr.2011.03.009. PMID: 21807137.21807137
21 Petersen SG, Beyer N, Hansen M, . Nonsteroidal Anti-Inflammatory Drug or Glucosamine Reduced Pain and Improved Muscle Strength With Resistance Training in a Randomized Controlled Trial of Knee Osteoarthritis Patients. Archives of Physical Medicine & Rehabilitation. 2011;92(8) .
22 Pietrosimone BG, Saliba SA, Hart JM, . Effects of transcutaneous electrical nerve stimulation and therapeutic exercise on quadriceps activation in people with tibiofemoral osteoarthritis. J Orthop Sports Phys Ther. 2011 Jan;41(1):4–12. doi: 10.2519/jospt.2011.3447. PMID: 21282869.21282869
23 Railhac JJ, Zaim M, Saurel AS, . Effect of 12 months treatment with chondroitin sulfate on cartilage volume in knee osteoarthritis patients: a randomized, double-blind, placebo-controlled pilot study using MRI. Clin Rheumatol. 2012 Sep;31(9):1347–57. doi: 10.1007/s10067-012-2022-4. PMID: 22729470.22729470
24 Sadeghi A, Jalili N, Asadi-Khiavi M. Low dose glucosamine and chondroitin sulfate use in knee osteoarthritis. Journal of Chemical and Pharmaceutical Research. 2014 2014;6(4):633–6.
25 Samuel Sundar Doss D, Rekha K, Prathap S. Effects of non weight bearing strength training for knee osteoarthritis. International Journal of Research in Pharmaceutical Sciences. 2014 30;5(3):188–92.
26 Samut G, Dincer F, Ozdemir O. The effect of isokinetic and aerobic exercises on serum interleukin-6 and tumor necrosis factor alpha levels, pain, and functional activity in patients with knee osteoarthritis. Mod Rheumatol. 2015 Nov;25(6):919–24. doi: 10.3109/14397595.2015.1038425. PMID: 25849853.25849853
27 Sayers SP, Gibson K, Cook CR. Effect of high-speed power training on muscle performance, function, and pain in older adults with knee osteoarthritis: a pilot investigation. Arthritis Care Res (Hoboken). 2012 Jan;64(1):46–53. doi: 10.1002/acr.20675. PMID: 22012877.22012877
28 Shahine EM, Elhadidi AS. Efficacy of glucosamine sulfate in lowering serum level of interleukin-1(beta) in symptomatic primary knee osteoarthritis: Clinical and laboratory study. Alexandria Journal of Medicine. 2014 June;50(2):159–63. FULL TEXT LINK http://dx.doi.org/10.1016/j.ajme.2014.01.006.
29 Sorour AS, Ayoub AS, Abd El Aziz EM. Effectiveness of acupressure versus isometric exercise on pain, stiffness, and physical function in knee osteoarthritis female patients. J Adv Res. 2014 Mar;5(2):193–200. doi: 10.1016/j.jare.2013.02.003. PMID: 25685487.25685487
30 Vincent KR, Hamilton AS, Lomonaco C, . Progressive enhanced eccentric or concentric resistance exercise training for knee osteoarthritis: Initial results on pain and function. PM and R; 2012. p. S188.
31 Wang TJ, Lee SC, Liang SY, . Comparing the efficacy of aquatic exercises and land-based exercises for patients with knee osteoarthritis. J Clin Nurs. 2011 Sep;20(17–18):2609–22. doi: 10.1111/j.1365-2702.2010.03675.x. PMID: 21539629.21539629
32 Zhang SL, Liu HQ, Xu XZ, . Effects of exercise therapy on knee joint function and synovial fluid cytokine levels in patients with knee osteoarthritis. Mol Med Rep. 2013 Jan;7(1):183–6. doi: 10.3892/mmr.2012.1168. PMID: 23135204.23135204

## Not an outcome of interest – N = 28

1 Anwer S, Alghadir A, Zafar H, . Effect of whole body vibration training on quadriceps muscle strength in individuals with knee osteoarthritis: a systematic review and meta-analysis. Physiotherapy. 2015 Oct 22doi: 10.1016/j.physio.2015.10.004. PMID: 26619822.26619822
2 Beckwee D, Bautmans I, Scheerlinck T, . Exercise in knee osteoarthritis - preliminary findings: Exercise-induced pain and health status differs between drop-outs and retainers. Exp Gerontol. 2015 Sep 12;72:29–37. doi: 10.1016/j.exger.2015.09.009. PMID: 26368538.26368538
3 Bove A, Smith K, Bise C, . What Is the Most Cost-Effective Physical Therapy Strategy to Treat Knee Osteoarthritis? [abstract]. 2015 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2015;67 (suppl 10):1001.
4 Burrows NJ, Booth J, Sturnieks DL, . Acute resistance exercise and pressure pain sensitivity in knee osteoarthritis: a randomised crossover trial. Osteoarthritis Cartilage. 2014 Mar;22(3):407–14. doi: 10.1016/j.joca.2013.12.023. PMID: 24418672.24418672
5 Christensen P, Bliddal H, Bartels E, . Long-term intervention with weight loss in patients with concomitant obesity and knee osteoarthritis: A randomized trial (the LIGHT study) (ClinicalTrials.gov Identifier: NCT00938808). Obesity reviews; 2014. p. 152.
6 Elboim-Gabyzon M, Rozen N, Laufer Y. The effect of electrical stimulation to the quadriceps muscle combined with group exercise on pain and function in knee osteoarthritis. Physiotherapy (United Kingdom); 2011. p. S3s08.
7 Englund M, Zhang F, Guermazi A, . The Effect of Arthroscopic Partial Meniscectomy in Patients with Osteoarthritis on Meniscal Body Extrusion [abstract]. Arthritis Rheumatol 2015;67 (suppl 10).
8 Gamache T, Price LL, Driban JB, . Education Effects on Outcome Expectations for Exercise in Adults with Knee Osteoarthritis [abstract]. 2014 ACR/ARHP Annual Meeting. Arthritis rheumatol. 2014;66 (suppl S10):S1249.
9 Henriksen M, Christensen R, Hunter DJ, . Structural changes in the knee during weight loss maintenance after a significant weight loss in obese patients with osteoarthritis: a report of secondary outcome analyses from a randomized controlled trial. Osteoarthritis Cartilage. 2014 May;22(5):639–46. doi: 10.1016/j.joca.2014.03.003. PMID: 24636948.24636948
10 Huang S, Sayre EC, Cibere J. Factors Associated with Physical Therapy Use in Osteoarthritis of the Knee: Results from a Population-Based Study. Arthritis Rheumatol. 2015;67(suppl 10).
11 Hunter DJ, Beavers DP, Eckstein F, . The Intensive Diet and Exercise for Arthritis (IDEA) trial: 18-month radiographic and MRI outcomes. Osteoarthritis Cartilage. 2015 Jul;23(7):1090–8. doi: 10.1016/j.joca.2015.03.034. PMID: 25887362.25887362
12 Kim YS, Choi YJ, Suh DS, . Mesenchymal stem cell implantation in osteoarthritic knees: is fibrin glue effective as a scaffold? Am J Sports Med. 2015 Jan;43(1):176–85. doi: 10.1177/0363546514554190. PMID: 25349263.25349263
13 Klokker L, Bandak E, Bartholdy C, . Pain in activity evaluation (PACE) in knee osteoarthritis-responsiveness and concurrent validity of tentative measures in a randomized controlled exercise study. Osteoarthritis and cartilage; 2014. p. S187.
14 Knoop J, Steultjens MP, Roorda LD, . Improvement in upper leg muscle strength underlies beneficial effects of exercise therapy in knee osteoarthritis: secondary analysis from a randomised controlled trial. Physiotherapy. 2015 Jun;101(2):171–7. doi: 10.1016/j.physio.2014.06.002. PMID: 25280604.25280604
15 Knoop J, van der Leeden M, Roorda LD, . Knee joint stabilization therapy in patients with osteoarthritis of the knee and knee instability: subgroup analyses in a randomized, controlled trial. J Rehabil Med. 2014 Jul;46(7):703–7. doi: 10.2340/16501977-1809. PMID: 24910399.24910399
16 Koli J, Multanen J, Kujala UM, . Effects of Exercise on Patellar Cartilage in Women with Mild Knee Osteoarthritis. Med Sci Sports Exerc. 2015 Sep;47(9):1767–74. doi: 10.1249/mss.0000000000000629. PMID: 25668399.25668399
17 Martel-Pelletier J, Roubille C, Abram F, . First-line analysis of the effects of treatment on progression of structural changes in knee osteoarthritis over 24 months: Data from the osteoarthritis initiative progression cohort. Annals of the Rheumatic Diseases. 2015 1;74(3):547–56. (http://www.ncbi.nlm.nih.gov/pubmed/24336337) FULL TEXT LINK http://dx.doi.org/10.1136/annrheumdis-2013-203906.
18 Meng CP, Katherine N, Leona Y, . Outcome Study of Non-operative Treatment for Knee Osteoarthritis in Middle-aged Patients With Reference to the Body Mass Index-A Randomised Prospective Study. Journal of Orthopaedics, Trauma and Rehabilitation; 2011. p. 17–20.
19 Monfort J, Escudero P, Orellana C, . Condroitin sulfate decreases chemokine levels and synovitis in knee osteoarthritis patients. Arthritis and Rheumatism. 2012 October;64 SUPPL. 10:S473.
20 Onat SS, Unsal Delialioglu S, Ucar D. Exercises in the Treatment of Elderly Patients with Knee Osteoarthritis: Factors Affecting the Efficiency of Patient Education. Turkish Journal of Geriatrics-Turk Geriatri Dergisi. 2013;16(2):166–71.
21 Pellegrini C, Song J, Chang RW, . Increasing Moderate-to-Vigorous Activity and Decreasing Sedentary Time Are Associated with 2-Year Weight Loss in Obese Persons with or at Risk for Knee Osteoarthritis [abstract]. 2015 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2015;67 (suppl 10):2274.25940781
22 Phillips K, Williams DA, Gammaitoni A, . Predicting Response to Osteoarthritis Treatment Based on Patient Reported Outcome Measures and Quantitative Sensory Testing [abstract]. 2015 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2015;67 (suppl 10):1433.
23 Rabago D, Fortney L, Kijowski R, . Clinical and magnetic resonance outcomes in a study of prolotherapy for knee osteoarthritis: Evidence for a potential mechanism of action. PM and R; 2013. p. S225.
24 Reid DA, McNair PJ. Effects of a six week lower limb stretching programme on range of motion, peak passive torque and stiffness in people and without osteoarthritis of the knee. New Zealand Journal of Physiotherapy 2011;39 (1).
25 Rezende MU, Farias FES, Silva CAC, . Analysis and correlation of physical therapy tests, pain, function and quality of life questionnaires in patients from parqve (project arthritis recovering quality of life by means of education). Osteoporosis international; 2015. p. S239–s40.
26 Sawitzke AD, Shi H, Finco MF, . The effect of glucosamine and/or chondroitin sulfate on the progression of knee osteoarthritis: a report from the glucosamine/chondroitin arthritis intervention trial. Arthritis Rheum. 2008 Oct;58(10):3183–91. doi: 10.1002/art.23973. PMID: 18821708.18821708
27 Selvan T, Rajiah K, Nainar MS, . A clinical study on glucosamine sulfate versus combination of glucosamine sulfate and NSAIDs in mild to moderate knee osteoarthritis. ScientificWorldJournal. 2012;2012:902676. doi: 10.1100/2012/902676. PMID: 22577354.22577354
28 Villadsen A, Overgaard S, Holsgaard-Larsen A, . Immediate efficacy of neuromuscular exercise in patients with severe osteoarthritis of the hip or knee: a secondary analysis from a randomized controlled trial. J Rheumatol. 2014 Jul;41(7):1385–94. doi: 10.3899/jrheum.130642. PMID: 24931956.24931956

## Study design – N = 85

1 National Board of Health, Denmark. Referenceprogram for knæartrose. Copenhagen National Board of Health, Denmark; 2007. Found at: http://www.sst.dk/publ/Publ2007/PLAN/SfR/Refprg_knaeartrose.pdf.
2 Ageberg E, Engstrom G, Gerhardsson de Verdier M, . Effect of leisure time physical activity on severe knee or hip osteoarthritis leading to total joint replacement: a population-based prospective cohort study. BMC Musculoskelet Disord. 2012;13:73. doi: 10.1186/1471-2474-13-73. PMID: 22595023.22595023
3 Al-Johani AH, Kachanathu SJ, Ramadan Hafez A, . Comparative study of hamstring and quadriceps strengthening treatments in the management of knee osteoarthritis. J Phys Ther Sci. 2014 Jun;26(6):817–20. doi: 10.1589/jpts.26.817. PMID: 25013274.25013274
4 Andia I, Maffulli N. Platelet-rich plasma for managing pain and inflammation in osteoarthritis. Nature Reviews Rheumatology. 2013 Dec;9(12):721–30. 24080861
5 Bar-Ziv Y, Debbi EM, Ran Y, . Long-Term Effects of AposTherapy in Patients with Osteoarthritis of the Knee: A Two-Year Followup. Arthritis. 2013;2013:689236. doi: 10.1155/2013/689236. PMID: 23533753.23533753
6 Beumer L, Wong JN, Warden SJ, . Effects of exercise and manual therapy on pain associated with hip osteoarthritis: a systematic review and meta-analysis. British Journal of Sports Medicine. 2016 Apr;50(8):458–U29. doi: 10.1136/bjsports-2015-095255. 26612846
7 Bressel E, Wing JE, Miller AI, . High-intensity interval training on an aquatic treadmill in adults with osteoarthritis: effect on pain, balance, function, and mobility. J Strength Cond Res. 2014 Aug;28(8):2088–96. doi: 10.1519/jsc.0000000000000258. PMID: 25057845.25057845
8 Brosseau L, . Efficacy of transcutaneous electrical nerve stimulation for osteoarthritis of the lower extremities: a meta-analysis. Physical Therapy Reviews. 2004;9(4):213–33.
9 Brouwer RW, van Raaij TM, Jakma TT, . Braces and orthoses for treating osteoarthritis of the knee. Cochrane Database of Systematic Reviews. 2015(3):N.PAG-N.PAG. doi: 10.1002/14651858.CD004020.pub3. PMID: 105838166. Language: English. Entry Date: 20101029. Revision Date: 20151007. Publication Type: Journal Article.
10 Brumini C, Natour J, Miura L, . Effectiveness of bracing in elderly with knee osteoartritis: A randomized controlled trial. Annals of the rheumatic diseases; 2015. p. 1311.25398374
11 Bruyere O, Cooper C, Pelletier JP, . A consensus statement on the European Society for Clinical and Economic Aspects of Osteoporosis and Osteoarthritis (ESCEO) algorithm for the management of knee osteoarthritis-From evidence-based medicine to the real-life setting. Semin Arthritis Rheum. 2016 Feb;45(4 Suppl):S3–11. doi: 10.1016/j.semarthrit.2015.11.010. PMID: 26806188.26806188
12 Carmona-Teres V, Lumillo-Gutierrez I, Jodar-Fernandez L, . Effectiveness and cost-effectiveness of a health coaching intervention to improve the lifestyle of patients with knee osteoarthritis: cluster randomized clinical trial. BMC Musculoskelet Disord. 2015;16:38. doi: 10.1186/s12891-015-0501-x. PMID: 25887078.25887078
13 Chang WD, Chen S, Lee CL, . The Effects of Tai Chi Chuan on Improving Mind-Body Health for Knee Osteoarthritis Patients: A Systematic Review and Meta-Analysis. Evid Based Complement Alternat Med. 2016;2016:1813979. doi: 10.1155/2016/1813979. PMID: 27635148.27635148
14 Cherian JJ, Harrison PE, Benjamin SA, . Do the Effects of Transcutaneous Electrical Nerve Stimulation on Knee Osteoarthritis Pain and Function Last? J Knee Surg. 2015 Nov 5doi: 10.1055/s-0035-1566735. PMID: 26540652.26540652
15 Cheung CK, Wyman J, Bronas U, . Is yoga better than aerobic/strengthening exercises for managing knee osteoarthritis in older adults? Osteoarthritis and Cartilage. 2016 April;24 SUPPL. 1:S484.
16 Coudeyre E, Jegu AG, Giustanini M, . Isokinetic muscle strengthening for knee osteoarthritis: A systematic review of randomized controlled trials with meta-analysis. Ann Phys Rehabil Med. 2016 Jun;59(3):207–15. doi: 10.1016/j.rehab.2016.01.013. PMID: 27079585.27079585
17 Dai Z, Liu HS, Wang SJ, . [Efficacy evaluation on knee osteoarthritis treated with acupuncture: non-randomized concurrent control trial]. Zhongguo Zhen Jiu. 2014 Apr;34(4):329–33. PMID: 24946628.24946628
18 Emadedin M, Ghorbani Liastani M, Fazeli R, . Long-Term Follow-up of Intra-articular Injection of Autologous Mesenchymal Stem Cells in Patients with Knee, Ankle, or Hip Osteoarthritis. Arch Iran Med. 2015 Jun;18(6):336–44. PMID: 26058927.26058927
19 Filardo G, Kon E, Pereira Ruiz MT, . Platelet-rich plasma intra-articular injections for cartilage degeneration and osteoarthritis: single- versus double-spinning approach. Knee Surg Sports Traumatol Arthrosc. 2012 Oct;20(10):2082–91. doi: 10.1007/s00167-011-1837-x. PMID: 22203046.22203046
20 Finger S, Paulos LE. Clinical and biomechanical evaluation of the unloading brace. J Knee Surg. 2002 Summer;15(3):155–8; discussion 9. PMID: 12152976.12152976
21 Fitzgerald GK, Hinman RS, Zeni J, Jr., . OARSI Clinical Trials Recommendations: Design and conduct of clinical trials of rehabilitation interventions for osteoarthritis. Osteoarthritis Cartilage. 2015 May;23(5):803–14. doi: 10.1016/j.joca.2015.03.013. PMID: 25952351.25952351
22 Forestier R, Erol Forestier FB, Francon A. Spa therapy and knee osteoarthritis: A systematic review. Ann Phys Rehabil Med. 2016 Jun;59(3):216–26. doi: 10.1016/j.rehab.2016.01.010. PMID: 26996955.26996955
23 Foster N, Nicholls E, Holden M, . Improving the effectiveness of exercise therapy for older adults with knee osteoarthritis: A pragmatic randomised controlled trial (the beep trial). Annals of the rheumatic diseases; 2015. p. 108.24107979
24 Fransen M, McConnell S. Exercise for osteoarthritis of the knee. Cochrane Database of Systematic Reviews. 2015(1):N.PAG-N.PAG. Language: English. Entry Date: 20111014. Revision Date: 20150711. Publication Type: Journal Article.
25 Ghasemi GA, Golkar A, Marandi SM. Effects of hata yoga on knee osteoarthritis. Int J Prev Med. 2013 Apr;4(Suppl 1):S133–8. PMID: 23717763.23717763
26 Golightly YM, Allen KD, Caine DJ. A comprehensive review of the effectiveness of different exercise programs for patients with osteoarthritis. Phys Sportsmed. 2012 Nov;40(4):52–65. doi: 10.3810/psm.2012.11.1988. PMID: 23306415.23306415
27 Gomes WF, Lacerda AC, Mendonca VA, . Effect of exercise on the plasma BDNF levels in elderly women with knee osteoarthritis. Rheumatol Int. 2014 Jun;34(6):841–6. doi: 10.1007/s00296-013-2786-0. PMID: 23739920.23739920
28 Grotle M. Traditional Chinese acupuncture was not superior to sham acupuncture for knee osteoarthritis but delivering treatment with high expectations of improvement was superior to delivering treatment with neutral expectations. J Physiother. 2011;57(1):56. doi: 10.1016/s1836-9553(11)70009-1. PMID: 21402332.21402332
29 Habib G, Zahran R, Najjar R, . The effect of intra-articular injection of Diprospan at the knee joint on the hypothalamic-pituitary-adrenal axis. Swiss Medical Weekly. 2015 May;145
30 Hayta E, Senel O, Hizmetli S, . Investigation of short-wave diathermy genotoxic effect in patients with knee osteoarthritis. Clinical and experimental rheumatology; 2014. p. S71–s2.24529335
31 Henriksen M, Hansen J, Klokker L, . Exercise versus analgesics for knee osteoarthritis pain: A meta-epidemiological study of cochrane systematic reviews. Osteoarthritis and cartilage; 2015. p. A172.
32 Henriksen M, Hansen JB, Klokker L, . Comparable effects of exercise and analgesics for pain secondary to knee osteoarthritis: a meta-analysis of trials included in Cochrane systematic reviews. J Comp Eff Res. 2016 Jul;5(4):417–31. doi: 10.2217/cer-2016-0007. PMID: 27346368.27346368
33 Hurley M, Walsh NE, Oliver S, . The Physical and Psychosocial Effects of Exercise on Chronic Hip and Knee Pain: A Cochrane Review with Meta-Analysis [abstract]. 2014 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2014;66 (suppl S10):S1016.
34 Ip D. Does addition of low-level laser therapy (LLLT) in conservative care of knee arthritis successfully postpone the need for joint replacement? Lasers Med Sci. 2015 Sep 29doi: 10.1007/s10103-015-1814-6. PMID: 26420240.26420240
35 Jaiswal PK, Bentley G, Carrington RWJ, . The adverse effect of elevated body mass index on outcome after autologous chondrocyte implantation. Journal of Bone and Joint Surgery-British Volume. 2012 Oct;94B(10):1377–81.
36 Jang SJ The application of platelet-rich plasma in early osteoarthritis of knee. Osteoarthritis and Cartilage. 2011 September;19 SUPPL. 1:S145.
37 Jones RK, Nester CJ, Richards JD, . A comparison of the biomechanical effects of valgus knee braces and lateral wedged insoles in patients with knee osteoarthritis. Gait Posture. 2013 Mar;37(3):368–72. doi: 10.1016/j.gaitpost.2012.08.002. PMID: 22920242.22920242
38 Jordan KM, Arden NK, Doherty M, . EULAR Recommendations 2003: an evidence based approach to the management of knee osteoarthritis: Report of a Task Force of the Standing Committee for International Clinical Studies Including Therapeutic Trials (ESCISIT). Ann Rheum Dis. 2003 Dec;62(12):1145–55. PMID: 14644851.14644851
39 Kanchanatawan W, Arirachakaran A, Chaijenkij K, . Short-term outcomes of platelet-rich plasma injection for treatment of osteoarthritis of the knee. Knee Surg Sports Traumatol Arthrosc. 2016 May;24(5):1665–77. doi: 10.1007/s00167-015-3784-4. PMID: 26387122.26387122
40 Kao MJ, Wu MP, Tsai MW, . The effectiveness of a self-management program on quality of life for knee osteoarthritis (OA) patients. Arch Gerontol Geriatr. 2012 Mar–Apr;54(2):317–24. doi: 10.1016/j.archger.2011.05.018. PMID: 21726907.21726907
41 Kim EJ, Lim CY, Lee EY, . Comparing the effects of individualized, standard, sham and no acupuncture in the treatment of knee osteoarthritis: a multicenter randomized controlled trial. Trials. 2013;14:129. doi: 10.1186/1745-6215-14-129. PMID: 23782709.23782709
42 Kim TH, Kim KH, Kang JW, . Moxibustion treatment for knee osteoarthritis: a multi-centre, non-blinded, randomised controlled trial on the effectiveness and safety of the moxibustion treatment versus usual care in knee osteoarthritis patients. PLoS One. 2014;9(7):e101973. doi: 10.1371/journal.pone.0101973. PMID: 25061882.25061882
43 Kim TH, Kim KH, Kang JW, . Moxibustion treatment for knee osteoarthritis: A multi-centre, non-blinded, randomised controlled trial. Integrative Medicine Research; 2015. p. 13.
44 Kim YS, Choi YJ, Koh YG Mesenchymal stem cell implantation in knee osteoarthritis: an assessment of the factors influencing clinical outcomes. Am J Sports Med. 2015 Sep;43(9):2293–301. doi: 10.1177/0363546515588317. PMID: 26113522.26113522
45 Komistek RD, Dennis DA, Northcut EJ, . An in vivo analysis of the effectiveness of the osteoarthritic knee brace during heel-strike of gait. J Arthroplasty. 1999 Sep;14(6):738–42. PMID: 10512447.10512447
46 Korkmaz M, Karaaslan F, Erdogan Y, . Efficacy of treatment with glucosamine sulfate in patients with knee effusion due to osteoarthritis. Pak J Med Sci. 2013 May;29(3):847–50. PMID: 24353641.24353641
47 Lau MC, Lam JK, Siu E, . Physiotherapist-designed aquatic exercise programme for community-dwelling elders with osteoarthritis of the knee: a Hong Kong pilot study. Hong Kong Med J. 2014 Feb;20(1):16–23. doi: 10.12809/hkmj133931. PMID: 24021934.24021934
48 Lee HY, Lee KJ. [Effects of Tai Chi exercise in elderly with knee osteoarthritis]. Taehan Kanho Hakhoe chi; 2008. p. 11–8.18323713
49 Li X, Wang XQ, Chen BL, . Whole-Body Vibration Exercise for Knee Osteoarthritis: A Systematic Review and Meta-Analysis (vol 2015, 758147, 2015). Evidence-Based Complementary and Alternative Medicine. 2015doi: 10.1155/2015/636435.
50 Lindenfeld TN, Hewett TE, Andriacchi TP Joint loading with valgus bracing in patients with varus gonarthrosis. Clin Orthop Relat Res. 1997 Nov(344):290–7. PMID: 9372780.9372780
51 Lu M, Su Y, Zhang Y, . Effectiveness of aquatic exercise for treatment of knee osteoarthritis: Systematic review and meta-analysis ORIGINAL (NON-ENGLISH) TITLE Wirksamkeit von Wassergymnastik bei Kniegelenksarthrose: Systematische Übersicht und Metaanalyse. Zeitschrift fur Rheumatologie. 2015 19;74(6):543–52. FULL TEXT LINK http://dx.doi.org/10.1007/s00393-014-1559-9.25691109
52 Maa SH, Sun MF, Wu CC The effectiveness of acupuncture on pain and mobility in patients with osteoarthritis of the knee: a pilot study. J Nurs Res. 2008 Jun;16(2):140–8. PMID: 18528820.18528820
53 Marcu RI, Traistaru R, Patru S, . Rehabilitation program improves functional status and quality of life in patients with knee osteoarthritis. Annals of the Rheumatic Diseases. 2015 June;74 SUPPL. 2:1192.
54 McAlindon TE, Driban JB, Henrotin Y, . OARSI Clinical Trials Recommendations: Design, conduct, and reporting of clinical trials for knee osteoarthritis. Osteoarthritis Cartilage. 2015 May;23(5):747–60. doi: 10.1016/j.joca.2015.03.005. PMID: 25952346.25952346
55 Meheux CJ, McCulloch PC, Lintner DM, . Efficacy of Intra-articular Platelet-Rich Plasma Injections in Knee Osteoarthritis: A Systematic Review. Arthroscopy - Journal of Arthroscopic and Related Surgery. 2016 1;32(3):495–505. FULL TEXT LINK http://dx.doi.org/10.1016/j.arthro.2015.08.005.26432430
56 Micca JL, Ruff D, Ahl J, . Safety and efficacy of duloxetine treatment in older and younger patients with osteoarthritis knee pain: a post hoc, subgroup analysis of two randomized, placebo-controlled trials. BMC Musculoskelet Disord. 2013;14:137. doi: 10.1186/1471-2474-14-137. PMID: 23590727.23590727
57 Mine K, Nakayama T, Milanese S, . The effectiveness of braces and orthoses for patients with knee osteoarthritis: A systematic review of Japanese-language randomised controlled trials. Prosthet Orthot Int. 2016 Apr 26doi: 10.1177/0309364616640926. PMID: 27117012.27117012
58 Moe RH, Fernandes L, Osteras N Daily use of a cane for two months reduced pain and improved function in patients with knee osteoarthritis. J Physiother. 2012;58(2):128. doi: 10.1016/s1836-9553(12)70094-2. PMID: 22613244.22613244
59 Nadaud MC, Komistek RD, Mahfouz MR, . In vivo three-dimensional determination of the effectiveness of the osteoarthritic knee brace: a multiple brace analysis. J Bone Joint Surg Am. 2005;87 Suppl 2:114–9. doi: 10.2106/JBJS.E.00482. PMID: 16326730.16326730
60 Nambi GS, Shah AA Additional effect of iyengar yoga and EMG biofeedback on pain and functional disability in chronic unilateral knee osteoarthritis. Int J Yoga. 2013 Jul;6(2):123–7. doi: 10.4103/0973-6131.113413. PMID: 23930031.23930031
61 Oiestad BE Multi-modal realignment treatment decreases pain in people with medial tibiofemoral osteoarthritis. J Physiother. 2012;58(4):272. doi: 10.1016/s1836-9553(12)70132-7. PMID: 23177233.23177233
62 Osiri M, . Transcutaneous electrical nerve stimulation for knee osteoarthritis (Review). 2009.
63 Pagani CH, Bohle C, Potthast W, . Short-term effects of a dedicated knee orthosis on knee adduction moment, pain, and function in patients with osteoarthritis. Arch Phys Med Rehabil. 2010 Dec;91(12):1936–41. doi: 10.1016/j.apmr.2010.09.003. PMID: 21112437.21112437
64 Park J, McCaffrey R, Newman D, . The Effect of Sit ‘N’ Fit Chair Yoga Among Community-Dwelling Older Adults With Osteoarthritis. Holistic Nursing Practice. 2014 Jul–Aug;28(4):247–57. 24919095
65 Peeler J, Christian M, Cooper J, . Managing Knee Osteoarthritis: The Effects of Body Weight Supported Physical Activity on Joint Pain, Function, and Thigh Muscle Strength. Clin J Sport Med. 2015 Nov;25(6):518–23. doi: 10.1097/jsm.0000000000000173. PMID: 25647537.25647537
66 Piyakhachornrot N, Aree-Ue S, Putwatana P, . Impact of an integrated health education and exercise program in middle-aged Thai adults with osteoarthritis of the knee. Orthop Nurs. 2011 Mar–Apr;30(2):134–42. doi: 10.1097/NOR.0b013e31821130bf. PMID: 21422897.21422897
67 Pollo FE Bracing and heel wedging for unicompartmental osteoarthritis of the knee. The American journal of knee surgery. 1997;11(1):47–50.
68 Rabago D, Mundt M, Zgierska A, . Hypertonic dextrose injection (prolotherapy) for knee osteoarthritis: Long term outcomes. Complement Ther Med. 2015 Jun;23(3):388–95. doi: 10.1016/j.ctim.2015.04.003. PMID: 26051574.26051574
69 Regnaux JP, Lefèvre-Colau MM, Trinquart L, . High-Intensity Versus Low-Intensity Physical Activity or Exercises in Patients with Hip or Knee Osteoarthritis: A Meta-Analysis [abstract]. 2015 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2015;67 (suppl 10):2414.
70 Rooij M, Leeden M, Cheung J, . Effectiveness of tailored exercise therapy in patients with knee osteoarthritis and comorbidity: A randomized controlled trial. Osteoarthritis and cartilage; 2016. p. S466–s7.
71 Rosa UH, Velasquez Tlapanco J, Lara Maya C, . Comparison of the effectiveness of isokinetic vs isometric therapeutic exercise in patients with osteoarthritis of knee. [Spanish]. Reumatologia clinica; 2012. p. 10–4.
72 Rutgers M, Creemers LB, Yang KGA, . Osteoarthritis treatment using autologous conditioned serum after placebo Patient considerations and clinical response in a non-randomized case series. Acta Orthopaedica. 2015 Feb;86(1):114–8. 25140983
73 Ryo T, Junya O, Nobuhiro K, . Does exercise therapy improve the health-related quality of life of people with knee osteoarthritis? A systematic review and meta-analysis of randomized controlled trials. Journal of Physical Therapy Science. 2015;27(10):3309–14. Language: English. Entry Date: 20160212. Revision Date: 20160212. Publication Type: Article. Journal Subset: Allied Health.26644699
74 Sanchez M, Anitua E, Azofra J, . Intra-articular injection of an autologous preparation rich in growth factors for the treatment of knee OA: a retrospective cohort study. Clin Exp Rheumatol. 2008 Sep–Oct;26(5):910–3. PMID: 19032827.19032827
75 Self BP, Greenwald RM, Pflaster DS A biomechanical analysis of a medial unloading brace for osteoarthritis in the knee. Arthritis Care Res. 2000 Aug;13(4):191–7. PMID: 14635273.14635273
76 Shainhouse J, Patrick J, Argoff C Open-label, open-ended study of the safety of diclofenac topical solution for management of osteoarthritis: Characterization of application-site adverse events. Osteoarthritis and Cartilage. 2011 September;19 SUPPL. 1:S231.
77 Shereif WI, Hassanin AA Comparison between Uses of Therapeutic Exercise and Heat Application on Relieve Pain, Stiffness and Improvement of Physical Function for Patient with Knee Osteoarthritis. Life Science Journal-Acta Zhengzhou University Overseas Edition. 2011;8(3):388–96.
78 Srivastava R, Avasthi V, Srivastava S, . Does yoga improve pain, stiffness and physical disability in knee osteoarthritis?-A randomize controlled clinical trial. Osteoarthritis and cartilage; 2015. p. A167.
79 Tanaka R, Ozawa J, Kito N, . Does exercise therapy improve health-related quality of life in people with knee osteoarthritis? a systematic review. Annals of the Rheumatic Diseases. 2015 June;74 SUPPL. 2:157–8.
80 Trombini-Souza F, Fuller R, Matias A, . Effectiveness of a long-term use of a minimalist footwear versus habitual shoe on pain, function and mechanical loads in knee osteoarthritis: A randomized controlled trial. BMC Musculoskeletal Disorders 2012;13 (121) MEDLINE PMID 2278857422788574 (http://www.ncbi.nlm.nih.gov/pubmed/22788574) FULL TEXT LINK http://dx.doi.org/10.1186/1471-2474-13-121.
81 Wallis JA, Webster KE, Levinger P, . A pre-operative group rehabilitation programme provided limited benefit for people with severe hip and knee osteoarthritis. Disabil Rehabil. 2014;36(24):2085–90. doi: 10.3109/09638288.2014.895428. PMID: 24597936.24597936
82 Watanabe S, Someya F Effect of Body Weight-supported Walking on Exercise Capacity and Walking Speed in Patients with Knee Osteoarthritis: A Randomized Controlled Trial. J Jpn Phys Ther Assoc. 2013;16(1):28–35. doi: 10.1298/jjpta.Vol16_004. PMID: 25792901.25792901
83 Yang SB, Eaton CB, McAlindon TE, . Effects of Glucosamine and Chondroitin Supplementation on Knee Osteoarthritis. Arthritis & Rheumatology. 2015 Mar;67(3):714–23. 25369761
84 Yu D, Xie HW, Zhang B, . [Observation on clinical effects of moxibustion stimulation of different sensitive status acupoints for knee osteoarthritis]. Zhen Ci Yan Jiu. 2013 Dec;38(6):497–501. PMID: 24579366.24579366
85 Zohra HF, Souad M, Mustapha R, . Exercise therapy for osteoarthritis of the knee: Two years follow up. Clinical and Experimental Rheumatology. 2014 2014;32(4 SUPPL. 83):S84.

## Study was included in a previous SR – N = 3

1 Baker K, Goggins J, Xie H, . A randomized crossover trial of a wedged insole for treatment of knee osteoarthritis. Arthritis and rheumatism; 2007. p. 1198–203.17393448
2 Bennell KL, Bowles KA, Payne C, . Effects of lateral wedge insoles on symptoms and structural disease progression in medial knee osteoarthritis: a 12-month randomised controlled trial. Osteoarthritis and cartilage; 2010. p. S11.
3 Kirkley A, Webster-Bogaert S, Litchfield R, . The effect of bracing on varus gonarthrosis. J Bone Joint Surg Am. 1999 Apr;81(4):539–48. PMID: 10225800.10225800

## Maximum followup is less than 30 days – N = 36

1 Ahsin S, Saleem S, Bhatti AM, . Clinical and endocrinological changes after electro-acupuncture treatment in patients with osteoarthritis of the knee. Pain. 2009 Dec 15;147(1–3):60–6. doi: 10.1016/j.pain.2009.08.004. PMID: 19766392.19766392
2 Altay F, Durmus D, Canturk F Effects of TENS on pain, disabiliy, quality of life and depression in patients with knee osteoarthritis. [Turkish]. Turkish Journal of Rheumatology; 2010. p. 116–21.
3 Anandkumar S, Sudarshan S, Nagpal P Efficacy of kinesio taping on isokinetic quadriceps torque in knee osteoarthritis: a double blinded randomized controlled study. Physiother Theory Pract. 2014 Aug;30(6):375–83. doi: 10.3109/09593985.2014.896963. PMID: 24617598.24617598
4 Basic-Kapidzic N, Imsirovic A, Music A Measurement of therapeutic effect of ultrasound on knee osteoarthritis; double blind study. Annals of the Rheumatic Disease; 2013.
5 Basu S, Palekar TJ, Balasaravanan R Comparative study of analgesic along with taping technique versus analgesic along with cryotherapy in unilateral patello-femoral osteoarthritis of knee joint. International Journal of Pharma and Bio Sciences. 2014 April/June;5(2):B361–B73.
6 Boyaci A, Tutoglu A, Boyaci N, . Comparison of the efficacy of ketoprofen phonophoresis, ultrasound, and short-wave diathermy in knee osteoarthritis. Rheumatol Int. 2013 Nov;33(11):2811–8. doi: 10.1007/s00296-013-2815-z. PMID: 23832291.23832291
7 Cheng G, Cheng W, Jiang YG. [Controlled observation of clinical efficacy on knee osteoarthritis treated with auricular electroacupuncture and the isolated moxibustion with Lingxian herbal paste]. Zhongguo zhen jiu = Chinese acupuncture & moxibustion; 2014. p. 230–4.24843960
8 Chiranthanut N, Hanprasertpong N Thai massage, and Thai herbal compress versus oral ibuprofen in symptomatic treatment of osteoarthritis of the knee: a randomized controlled trial. 2014;2014:490512. doi: 10.1155/2014/490512. PMID: 25254207.25254207
9 Cho HY, Kim EH, Kim J, . Kinesio taping improves pain, range of motion, and proprioception in older patients with knee osteoarthritis: a randomized controlled trial. Am J Phys Med Rehabil. 2015 Mar;94(3):192–200. doi: 10.1097/phm.0000000000000148. PMID: 25706053.25706053
10 Daskapan A, Anaforoglu B, Ozunlu Pekyavas N, . Comparison of mini-squats and straight leg raises in patients with knee osteoarthritis: A randomized controlled clinical trial. Turkish Journal of Rheumatology; 2013. p. 16–26.
11 Espejo Antunez L, Caro Puertolas B, Ibanez Burgos B, . Effects of mud therapy on perceived pain and quality of life related to health in patients with knee osteoarthritis. Reumatol Clin. 2013 May–Jun;9(3):156–60. doi: 10.1016/j.reuma.2012.09.005. PMID: 23357640.23357640
12 Fioravanti A, Giannitti C, Cheleschi S, . Circulating levels of adiponectin, resistin, and visfatin after mud-bath therapy in patients with bilateral knee osteoarthritis. Int J Biometeorol. 2015 Nov;59(11):1691–700. doi: 10.1007/s00484-015-0977-y. PMID: 25750093.25750093
13 Geler Kulcu D, Yanik B, Gulsen G, . Effect of neuromuscular electrical stimulation on pain and functional parameters in knee osteoarthritis. [Turkish]. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi; 2009. p. 111–5.
14 Gundog M, Atamaz F, Kanyilmaz S, . Interferential current therapy in patients with knee osteoarthritis: comparison of the effectiveness of different amplitude-modulated frequencies. Am J Phys Med Rehabil. 2012 Feb;91(2):107–13. doi: 10.1097/PHM.0b013e3182328687. PMID: 22019968.22019968
15 Habib G, Safia A The effect of intra-articular injection of betamethasone acetate/betamethasone sodium phosphate on blood glucose levels in controlled diabetic patients with symptomatic osteoarthritis of the knee. Clin Rheumatol. 2009 Jan;28(1):85–7. doi: 10.1007/s10067-008-1023-9. PMID: 18853221.18853221
16 Hanafy AF, Megeid Abdallah AAA Quadriceps strength, knee pain and functional performance with patellar taping in knee osteoarthritis. Journal of musculoskeletal research; 2014.
17 Hu QS, Zhang QR, Jia CS, . [Randomized controlled clinical trials of red-hot filiform needle puncturing for knee ostarthritis and inflammatory cytokines in knee articular fluid in senile knee ostarthritis patients]. Zhen Ci Yan Jiu. 2011 Apr;36(2):110–5. PMID: 21717778.21717778
18 Karner M, Brazkiewicz F, Remppis A, . Objectifying specific and nonspecific effects of acupuncture: a double-blinded randomised trial in osteoarthritis of the knee. Evid Based Complement Alternat Med. 2013;2013:427265. doi: 10.1155/2013/427265. PMID: 23365608.23365608
19 Kim MJ, Lee DH, Kim T, . Lower extremity exercise of knee osteoarthritis patients using portable assistive robot (HEXAR-KR40P). International Journal of Precision Engineering and Manufacturing. 2014 Dec;15(12):2617–22.
20 Kolen AF, de Nijs RN, Wagemakers FM, . Effects of spatially targeted transcutaneous electrical nerve stimulation using an electrode array that measures skin resistance on pain and mobility in patients with osteoarthritis in the knee: a randomized controlled trial. Pain. 2012 Feb;153(2):373–81. doi: 10.1016/j.pain.2011.10.033. PMID: 22119338.22119338
21 Liang YW, Tan YS, Yuan YQ Observation on the therapeutic effect of modified sparrow-pecking moxibustion for 60 cases of osteoarthritis of knee. World Journal of Acupuncture - Moxibustion; 2013. p. 55–7.
22 Lin MN, Li XH, Liang WN, . Needle-knife therapy improves the clinical symptoms of knee osteoarthritis by inhibiting the expression of inflammatory cytokines. Experimental and Therapeutic Medicine. 2014 Apr;7(4):835–42. 24669238
23 Navali AM, Sadat BE, Hajipour B, . Anew Shoe Decreases Pain and Fatigue in Ascending and Descending the stairs in patients with knee osteoarthritis. Life Science Journal-Acta Zhengzhou University Overseas Edition. 2012;9(4):2543–9.
24 Pavlovic AS, Djurasic LM The effect of low frequency pulsing electromagnetic field in treatment of patients with knee joint osteoarthritis. Acta Chir Iugosl. 2012;59(3):81–3. PMID: 23654012.23654012
25 Sahin-Onat S, Tasoglu O, Ozisler Z, . Balneotherapy in the treatment of knee osteoarthritis: A controlled study. Archives of Rheumatology; 2015. p. 292–7.
26 Sudhesh P Effect of taping and closed kinetic chain versus traditional approach in osteoarthritis knee. International Journal of Pharma and Bio Sciences; 2013. p. B1156–b65.
27 Toopchizadeh V, Javadi R, Sadat BE Therapeutic efficacy of dexamethasone phonophoresis on symptomatic knee osteoarthritis in elderly women. International Journal of Women’s Health and Reproduction Sciences. 2014 1;2(3):168–77. FULL TEXT LINK http://dx.doi.org/10.15296/ijwhr.2014.25.
28 Topp R, Brosky JA, Jr, Pieschel D The effect of either topical menthol or a placebo on functioning and knee pain among patients with knee OA. J Geriatr Phys Ther. 2013 Apr–Jun;36(2):92–9. doi: 10.1519/JPT.0b013e318268dde1. PMID: 22976810.22976810
29 Tosun A, Beyazova M, Meray J, . Efficacy of a Single Dose Transdermal Flurbiprofen Administration in Patients with Knee Osteoarthritis. Turkiye Klinikleri Tip Bilimleri Dergisi. 2010 Dec;30(6):1911–6.
30 Ulus Y, Tander B, Akyol Y, . Therapeutic ultrasound versus sham ultrasound for the management of patients with knee osteoarthritis: a randomized double-blind controlled clinical study. Int J Rheum Dis. 2012 Apr;15(2):197–206. doi: 10.1111/j.1756-185X.2012.01709.x. PMID: 22462424.22462424
31 van den Noort J, van der Esch M, Steultjens MP, . Influence of the instrumented force shoe on gait pattern in patients with osteoarthritis of the knee. Medical & Biological Engineering & Computing. 2011 Dec;49(12):1381–92. 21866409
32 Vance CG, Rakel BA, Blodgett NP, . Effects of transcutaneous electrical nerve stimulation on pain, pain sensitivity, and function in people with knee osteoarthritis: a randomized controlled trial. Phys Ther. 2012 Jul;92(7):898–910. doi: 10.2522/ptj.20110183. PMID: 22466027.22466027
33 Varadi G, Zhu Z, Blattler T, . Randomized clinical trial evaluating transdermal Ibuprofen for moderate to severe knee osteoarthritis. Pain Physician. 2013 Nov–Dec;16(6):E749–62. PMID: 24284856.24284856
34 Varadi G, Zhu Z, Blättler T, . Randomized clinical trial evaluating transdermal ibuprofen for moderate to severe knee osteoarthritis. Pain Physician. 2013;16(6):E749–E62.24284856
35 Wang YB, Huang XY, Song B, . Comparative study of drug intervention in treatment of rural middle-aged and elderly people with knee osteoarthritis in Fengxian District, Shanghai. African Journal of Pharmacy and Pharmacology. 2012 Jun;6(24):1741–5.
36 Zhang QR, Fu WB [Osteoarthritis of knee joint treated with acupuncture and moxibustion]. Zhongguo Zhen Jiu. 2010 May;30(5):375–8. PMID: 20518172.20518172

## Comparators not of interest – N = 70

1 Ali SS, Ahmed SI, Khan M, . Comparing the effects of manual therapy versus electrophysical agents in the management of knee osteoarthritis. Pak J Pharm Sci. 2014 Jul;27(4 Suppl):1103–6. PMID: 25016274.25016274
2 Allen KD, Bongiorni D, Bosworth HB, . Group Versus Individual Physical Therapy for Veterans With Knee Osteoarthritis: Results of a Randomized Clinical Trial. Phys Ther. 2015 Nov 19doi: 10.2522/ptj.20150194. PMID: 26586865.26586865
3 Angoorani H, Mazaherinezhad A, Marjomaki O, . Treatment of knee osteoarthritis with platelet-rich plasma in comparison with transcutaneous electrical nerve stimulation plus exercise: a randomized clinical trial. Med J Islam Repub Iran. 2015;29:223. PMID: 26478881.26478881
4 Ashraf A, Zarei F, Hadianfard MJ, . Comparison the effect of lateral wedge insole and acupuncture in medial compartment knee osteoarthritis: A randomized controlled trial. Knee. 2014 March;21(2):439–44. MEDLINE PMID 2446210824462108 (http://www.ncbi.nlm.nih.gov/pubmed/24462108) FULL TEXT LINK http://dx.doi.org/10.1016/j.knee.2013.12.002.
5 Brandao GDC, Korukian M, Brandao DDC, . Association of glucosamine sulphate and chondroitin sulphate for patients with osteoarthritis of the knee ORIGINAL (NON-ENGLISH) TITLE Associacao de sulfato de glicosamina e sulfato de condroitina para pacientes portadores de osteoartrose de joelho. Revista Brasileira de Medicina. 2009 November;66(11):405–8.
6 Bui B, Nguyen L Efficacy of PRP injection in treatment of primary knee OA. International Journal of Rheumatic Diseases. 2014 April;17 SUPPL. 1:35.
7 Byeon GJ, Kim KH Piriformis syndrome in knee osteoarthritis patients after wearing rocker bottom shoes. Korean J Pain. 2011 Jun;24(2):93–9. doi: 10.3344/kjp.2011.24.2.93. PMID: 21716617.21716617
8 Cerza F, Carni S, Carcangiu A, . Comparison between hyaluronic acid and platelet-rich plasma, intra-articular infiltration in the treatment of gonarthrosis. Am J Sports Med. 2012 Dec;40(12):2822–7. doi: 10.1177/0363546512461902. PMID: 23104611.23104611
9 Chen R, Chen M, Su T, . Heat-sensitive moxibustion in patients with osteoarthritis of the knee: a three-armed multicentre randomised active control trial. Acupunct Med. 2015 May 21doi: 10.1136/acupmed-2014-010740. PMID: 25998755.25998755
10 Chen WL, Hsu WC, Lin YJ, . Comparison of intra-articular hyaluronic acid injections with transcutaneous electric nerve stimulation for the management of knee osteoarthritis: a randomized controlled trial. Arch Phys Med Rehabil. 2013 Aug;94(8):1482–9. doi: 10.1016/j.apmr.2013.04.009. PMID: 23628378.23628378
11 Cheng Y, Wu K, Cheng Z, . [Randomized controlled study on the treatment of knee osteoarthritis with different acupuncture methods at different stages]. [Chinese]. Zhongguo zhen jiu [Chinese acupuncture & moxibustion]; 2013. p. 508–12.23967637
12 Cutovic M, Jovic S, Konstantinovic L, . [The effects of balneotherapy on knee osteoarthritis]. Med Pregl. 2006;59 Suppl 1:47–50. PMID: 17361596.17361596
13 Deng CL, Li J, Cao XW, . Therapeutic Effectiveness Evaluation on Shishi Manipulation for Knee Osteoarthritis. 2012 Ieee International Conference on Bioinformatics and Biomedicine Workshops. 2012.
14 Deng N, Ran QF, Jin T, . [Effect of stiletto needle intervention combined with massage on dysfunction and pain of knee-joints in patients with knee osteoarthrosis]. Zhen Ci Yan Jiu. 2012 Feb;37(1):59–63, 76. PMID: 22574571.22574571
15 Duivenvoorden T, van Raaij TM, Horemans HL, . Do laterally wedged insoles or valgus braces unload the medial compartment of the knee in patients with osteoarthritis? Clin Orthop Relat Res. 2015 Jan;473(1):265–74. doi: 10.1007/s11999-014-3947-5. PMID: 25267266.25267266
16 Eftekharsadat B, Babaei-Ghazani A, Habibzadeh A, . Efficacy of action potential simulation and interferential therapy in the rehabilitation of patients with knee osteoarthritis. Ther Adv Musculoskelet Dis. 2015 Jun;7(3):67–75. doi: 10.1177/1759720x15575724. PMID: 26029268.26029268
17 Eyigor S, Karapolat H, Ibisoglu U, . [Does transcutaneous electrical nerve stimulation or therapeutic ultrasound increase the effectiveness of exercise for knee osteoarthritis: a randomized controlled study]. Agri. 2008 Jan;20(1):32–40. PMID: 18338277.18338277
18 Fardellone P, Zaim M, Saurel AS, . Comparative efficacy and safety study of two chondroitin sulfate preparations from different origin (avian and bovine) in symptomatic osteoarthritis of the knee. Open Rheumatol J. 2013;7:1–12. doi: 10.2174/1874312901307010001. PMID: 23493263.23493263
19 Filardo G, Di Matteo B, Di Martino A, . Platelet-Rich Plasma Intra-articular Knee Injections Show No Superiority Versus Viscosupplementation: A Randomized Controlled Trial. Am J Sports Med. 2015 Jul;43(7):1575–82. doi: 10.1177/0363546515582027. PMID: 25952818.25952818
20 Filardo G, Kon E, Di Martino A, . Platelet-rich plasma vs hyaluronic acid to treat knee degenerative pathology: study design and preliminary results of a randomized controlled trial. BMC Musculoskelet Disord. 2012;13:229. doi: 10.1186/1471-2474-13-229. PMID: 23176112.23176112
21 Filardo G, Kon E, Pereira Ruiz MT, . Platelet-rich plasma intra-articular injections for cartilage degeneration and osteoarthritis: single- versus double-spinning approach. Knee Surg Sports Traumatol Arthrosc. 2012 Oct;20(10):2082–91. doi: 10.1007/s00167-011-1837-x. PMID: 22203046.22203046
22 Filardo G, Kon E, Ruiz MTP, . Platelet-rich plasma intra-articular injections for cartilage degeneration and osteoarthritis: single- versus double-spinning approach. Knee Surgery Sports Traumatology Arthroscopy. 2012 Oct;20(10):2078–87.
23 Forogh B, Mianehsaz E, Shoaee S, . Effect of single injection of Platelet-Rich Plasma in comparison with corticosteroid on knee osteoarthritis: a double-blind randomized clinical trial. J Sports Med Phys Fitness. 2015 Jul 14 PMID: 26173792.26173792
24 Forogh B, Mianehsaz E, Shoaee S, . Effect of single injection of platelet-rich plasma in comparison with corticosteroid on knee osteoarthritis: a double-blind randomized clinical trial. J Sports Med Phys Fitness. 2016 Jul–Aug;56(7–8):901–8. PMID: 26173792.26173792
25 Fu MY, Zhang ZL [Knee osteoarthritis treated with acupuncture at the points selected according to syndrome differentiation: a randomized controlled trial]. Zhongguo Zhen Jiu. 2011 Dec;31(12):1062–6. PMID: 22256634.22256634
26 Fu MY, Zhang ZL Knee osteoarthritis treated with acupuncture based on syndrome differentiation: A randomized controlled trial. World Journal of Acupuncture - Moxibustion. 2012 2012;22(3):11–7. FULL TEXT LINK http://dx.doi.org/10.1016/S1003-5257(12)60035-X.
27 Gharaibeh A Plasma rich in platelets versus hyaluronic acid and corticosteroids in the treatment of knee osteoarthritis. Osteoporosis International. 2015 February;26(1 SUPPL. 1):S282.
28 Gobbi A, Lad D, Karnatzikos G The effects of repeated intra-articular PRP injections on clinical outcomes of early osteoarthritis of the knee. Knee Surg Sports Traumatol Arthrosc. 2014 Apr 20doi: 10.1007/s00167-014-2987-4. PMID: 24748286.24748286
29 Gobbi A, Lad D, Karnatzikos G The effects of repeated intra-articular PRP injections on clinical outcomes of early osteoarthritis of the knee. Knee Surgery Sports Traumatology Arthroscopy. 2015 Aug;23(8):2170–7.
30 Gokmen F, Akbal A, Komurcu E, . Comparison of effects of combined physical therapy program and intra-articular treatment of hyaluronic acid on pain, balance and quality of life in patients with knee osteoarthritis ORIGINAL (NON-ENGLISH) TITLE Diz Osteoartritli Hastalarda Intraartikuler Hyaluronik Asit Tedavisi ile Kombine Fizik Tedavi Uygulamalarinin Anullri, Denge ve Yasam Kalitesi Uzerine Etkisinin Karsilastirilmasi. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi. 2013 April;59 SUPPL. 1:483.
31 Hammad YH, Magid HR, Sobhy MM Clinical and biochemical study of the comparative efficacy of topical versus oral glucosamine/chondroitin sulfate on osteoarthritis of the knee. Egyptian Rheumatologist. 2015 1;37(2):85–91. FULL TEXT LINK http://dx.doi.org/10.1016/j.ejr.2014.06.007.
32 Hashemi M, Jalili P, Mennati S, . The effects of prolotherapy with hypertonic dextrose versus prolozone (intraarticular ozone) in patients with knee osteoarthritis. Anesthesiology and Pain Medicine 2015;5 (5) FULL TEXT LINK http://dx.doi.org/10.5812/aapm.27585.
33 Hashemi SM, Madadi F, Razavi S, . Intra-articular hyaluronic acid injections Vs. dextrose prolotherapy in the treatment of osteoarthritic knee pain. Tehran University Medical Journal. 2012 May;70(2):119–25.
34 Hsieh RL, Lee WC Clinical effects of lateral wedge arch support insoles in knee osteoarthritis: A prospective double-blind randomized study. Medicine 2016;95 (27) FULL TEXT LINK http://dx.doi.org/10.1097/MD.0000000000003952.
35 Huang J, Zhang W, Lou BD, . Observation on clinical efficacy of tension-balance acupuncture therapy in treating knee osteoarthritis. World Journal of Acupuncture - Moxibustion; 2014. p. 42–6.
36 Jo CH, Lee YG, Shin WH, . Intra-articular injection of mesenchymal stem cells for the treatment of osteoarthritis of the knee: a proof-of-concept clinical trial. Stem Cells. 2014 May;32(5):1254–66. doi: 10.1002/stem.1634. PMID: 24449146.24449146
37 Kalpakcioglu BA, Cakmak B, Bahadir C Comparison of ultrasound and short wave diathermy therapy in knee osteoarthritis. [Turkish]. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi; 2006. p. 168–73.
38 Kulkarni C, Leena A, Lohit K, . A randomized comparative study of safety and efficacy of immediate release glucosamine HCL and glucosamine HCL sustained release formulation in the treatment of knee osteoarthritis: A proof of concept study. J Pharmacol Pharmacother. 2012 Jan;3(1):48–54. doi: 10.4103/0976-500x.92515. PMID: 22368417.22368417
39 Lee HY [Comparison of effects among Tai-Chi exercise, aquatic exercise, and a self-help program for patients with knee osteoarthritis]. Taehan Kanho Hakhoe chi; 2006. p. 571–80.16825841
40 Luksurapan W, Boonhong J Effects of phonophoresis of piroxicam and ultrasound on symptomatic knee osteoarthritis. Arch Phys Med Rehabil. 2013 Feb;94(2):250–5. doi: 10.1016/j.apmr.2012.09.025. PMID: 23063790.23063790
41 Lun V, Marsh A, Bray R, . Efficacy of Hip Strengthening Exercises Compared With Leg Strengthening Exercises on Knee Pain, Function, and Quality of Life in Patients With Knee Osteoarthritis. Clin J Sport Med. 2015 Nov;25(6):509–17. doi: 10.1097/jsm.0000000000000170. PMID: 25591130.25591130
42 Mascarin NC, Vancini RL, Andrade ML, . Effects of kinesiotherapy, ultrasound and electrotherapy in management of bilateral knee osteoarthritis: prospective clinical trial. BMC Musculoskelet Disord. 2012;13:182. doi: 10.1186/1471-2474-13-182. PMID: 22999098.22999098
43 Mehta K, Gala J, Bhasale S, . Comparison of glucosamine sulfate and a polyherbal supplement for the relief of osteoarthritis of the knee: A randomized controlled trial [ISRCTN25438351]. BMC Complementary and Alternative Medicine 2007;7doi: 10.1186/1472-6882-7-34.
44 Mei ZG, Cheng CG, Zheng JF Observations on curative effect of high-frequency electric sparkle and point-injection therapy on knee osteoarthritis. J Tradit Chin Med. 2011 Dec;31(4):311–5. PMID: 22462237.22462237
45 Melo Mde O, Pompeo KD, Brodt GA, . Effects of neuromuscular electrical stimulation and low-level laser therapy on the muscle architecture and functional capacity in elderly patients with knee osteoarthritis: a randomized controlled trial. Clin Rehabil. 2015 Jun;29(6):570–80. doi: 10.1177/0269215514552082. PMID: 25261425.25261425
46 Mirunalini R, Chandrasekaran M, Manimekalai K Efficacy of chondroitin sulfate with glucosamine versus diacerein in grade ii and iii osteoarthritis knee: A randomized comparative study. Asian Journal of Pharmaceutical and Clinical Research; 2015. p. 42–4.
47 Niazi NS, Niazi SNK, Niazi KNK, . Comparison of the effectiveness of knee braces and lateral wedge insole in the management of medial compartment knee osteoarthritis. Pakistan Journal of Medical and Health Sciences. 2014 January–March;8(1):37–40.
48 Ochiai S, Watanabe A, Oda H, . Effectiveness of thermotherapy using a heat and steam generating sheet for cartilage in knee osteoarthritis. J Phys Ther Sci. 2014 Feb;26(2):281–4. doi: 10.1589/jpts.26.281. PMID: 24648649.24648649
49 Odole AC, Ojo OD A Telephone-based Physiotherapy Intervention for Patients with Osteoarthritis of the Knee. Int J Telerehabil. 2013 Fall;5(2):11–20. doi: 10.5195/ijt.2013.6125. PMID: 25945214.25945214
50 Odole AC, Ojo OD Is telephysiotherapy an option for improved quality of life in patients with osteoarthritis of the knee? Int J Telemed Appl. 2014;2014:903816. doi: 10.1155/2014/903816. PMID: 24778645.24778645
51 Omori G, Watanabe H, Nawatax A, . Efficacy of topical nonsteroidal anti-inflammatory drug (nsaids) adhesive skin patch in quadriceps muscle exercise for knee osteoarthritis - A randomized controlled trial. Osteoarthritis and cartilage; 2013. p. S40.
52 Peungsuwan P, Sermcheep P, Harnmontree P, . The Effectiveness of Thai Exercise with Traditional Massage on the Pain, Walking Ability and QOL of Older People with Knee Osteoarthritis: A Randomized Controlled Trial in the Community. J Phys Ther Sci. 2014 Jan;26(1):139–44. doi: 10.1589/jpts.26.139. PMID: 24567694.24567694
53 Provenza JR, Shinjo SK, Silva JM, . Combined glucosamine and chondroitin sulfate, once or three times daily, provides clinically relevant analgesia in knee osteoarthritis. Clin Rheumatol. 2014 Aug 3doi: 10.1007/s10067-014-2757-1. PMID: 25085275.25085275
54 Provenza JR, Shinjo SK, Silva JM, . Combined glucosamine and chondroitin sulfate, once of three times daily, provide clinically relevant analgesia in knee osteoarthritis. Arthritis and Rheumatism. 2012 October;64 SUPPL. 10:S487.
55 Rabini A, Piazzini DB, Tancredi G, . Deep heating therapy via microwave diathermy relieves pain and improves physical function in patients with knee osteoarthritis: a double-blind randomized clinical trial. Eur J Phys Rehabil Med. 2012 Dec;48(4):549–59. PMID: 22820824.22820824
56 Raeissadat SA, Rayegani SM, Hassanabadi H, . Knee Osteoarthritis Injection Choices: Platelet- Rich Plasma (PRP) Versus Hyaluronic Acid (A one-year randomized clinical trial). Clin Med Insights Arthritis Musculoskelet Disord. 2015;8:1–8. doi: 10.4137/cmamd.s17894. PMID: 25624776.25624776
57 Rahimzadeh P, Imani F, Faiz SH, . Investigation the efficacy of intra-articular prolotherapy with erythropoietin and dextrose and intra-articular pulsed radiofrequency on pain level reduction and range of motion improvement in primary osteoarthritis of knee. J Res Med Sci. 2014 Aug;19(8):696–702. PMID: 25422652.25422652
58 Richards JD, Sanchez-Ballester J, Jones RK, . A comparison of knee braces during walking for the treatment of osteoarthritis of the medial compartment of the knee. J Bone Joint Surg Br. 2005 Jul;87(7):937–9. doi: 10.1302/0301-620X.87B7.16005. PMID: 15972906.15972906
59 Saleki M, Ahadi T, Razi M, . Comparison of the effects of acupuncture and physical modality on symptoms of knee osteoarthritis. [Persian]. Journal of Isfahan Medical School; 2012.
60 Sarsan A, Akkaya N, Ozgen M, . Comparing the efficacy of mature mud pack and hot pack treatments for knee osteoarthritis. J Back Musculoskelet Rehabil. 2012;25(3):193–9. doi: 10.3233/bmr-2012-0327. PMID: 22935858.22935858
61 Say F, Gurler D, Yener K, . Platelet-rich plasma injection is more effective than hyaluronic acid in the treatment of knee osteoarthritis. Acta Chir Orthop Traumatol Cech. 2013;80(4):278–83. PMID: 24119476.24119476
62 Say F, GÜRler D, Yener K, . Platelet-rich plasma injection is more effective than hyaluronic acid in the treatment of knee osteoarthritis. Acta Chirurgiae Orthopaedicae et Traumatologiae Cechoslovaca. 2013;80(4):278–83.24119476
63 Spakova T, Rosocha J, Lacko M, . Treatment of knee joint osteoarthritis with autologous platelet-rich plasma in comparison with hyaluronic acid. Am J Phys Med Rehabil. 2012 May;91(5):411–7. doi: 10.1097/PHM.0b013e3182aab72. PMID: 22513879.22513879
64 Spaková T, Rosocha J, Lacko M, . Treatment of knee joint osteoarthritis with autologous platelet-rich plasma in comparison with hyaluronic acid. American Journal of Physical Medicine and Rehabilitation. 2012;91(5):411–7. doi: 10.1097/PHM.0b013e3182aab72.22513879
65 Teslim OA, Adebowale AC, Ojoawo AO, . Comparative effects of pulsed and continuous short wave diathermy on pain and selected physiological parameters among subjects with chronic knee osteoarthritis. Technol Health Care. 2013;21(5):433–40. doi: 10.3233/thc-130744. PMID: 24004650.24004650
66 van Raaij TM, Reijman M, Brouwer RW, . Medial knee osteoarthritis treated by insoles or braces: a randomized trial. Clinical orthopaedics and related research; 2010. p. 1926–32.20177839
67 Vaquerizo V, Plasencia MA, Arribas I, . Comparison of intra-articular injections of plasma rich in growth factors (PRGF-Endoret) versus Durolane hyaluronic acid in the treatment of patients with symptomatic osteoarthritis: a randomized controlled trial. Arthroscopy. 2013 Oct;29(10):1635–43. doi: 10.1016/j.arthro.2013.07.264. PMID: 24075613.24075613
68 Vega A, Martin-Ferrero MA, Del Canto F, . Treatment of Knee Osteoarthritis With Allogeneic Bone Marrow Mesenchymal Stem Cells: A Randomized Controlled Trial. Transplantation. 2015 Mar 27doi: 10.1097/tp.0000000000000678. PMID: 25822648.25822648
69 Wang JL, Chai CH, Xu YM. [Clinical observations on the effect of Tuigua manipulation combined with quadriceps exercise for the treatment of degenerative gonarthritis]. Zhongguo gu shang [China journal of orthopaedics and traumatology]; 2008. p. 887–9.19146152
70 Wangroongsub Y, Tanavalee A, Wilairatana V, . Comparable clinical outcomes between glucosamine sulfate-potassium chloride and glucosamine sulfate sodium chloride in patients with mild and moderate knee osteoarthritis: a randomized, double-blind study. J Med Assoc Thai. 2010 Jul;93(7):805–11. PMID: 20649060.20649060

## No usable data – N = 80

1 Abbott JH, Fitzgerald G, Fritz JM, . Do manual therapy or booster sessions in addition to exercise therapy for knee osteoarthritis provide additional benefits? a randomized clinical trial. Osteoarthritis and cartilage; 2015. p. A385.
2 Abbott JH, Robertson MC, Chapple C, . Manual therapy, exercise therapy, or both, in addition to usual care, for osteoarthritis of the hip or knee: a randomized controlled trial. 1: clinical effectiveness. Osteoarthritis Cartilage. 2013 Apr;21(4):525–34. doi: 10.1016/j.joca.2012.12.014. PMID: 23313532.23313532
3 Alpayci M, Hiz O, Ediz L, . The effect of traction in the treatment of knee osteoarthritis: A prospective randomized controlled trial, Diz osteoartritinde traksiyon tedavisinin etkisi: Prospektif randomize kontrollu califlma. [Turkish, English]. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi; 2011. p. 259.
4 Barry HC Dextrose prolotherapy decreases pain and stiffness in knee degenerative joint disease. American Family Physician 2013;88 (9).
5 Bighea AC, Patru S, Marcu IR, . The effectiveness of combined exercises and therapeutic ultrasound to patients with knee osteoarthritis. Annals of the rheumatic diseases; 2013.
6 Birsan SD, Cioara F Study over phonophoresis with capsaicin in knee osteoarthritis. Osteoporosis International. 2014 April;25 SUPPL. 2:S413.
7 Bliddal H, Christensen P, Bartels EM, . Long-term intervention with weight loss in patients with concomitant obesity and knee osteoarthritis: A randomised trial (the light study). Annals of the rheumatic diseases; 2014.
8 Boyaci A, Tutotlu A, Boyaci N, . Comparison of the efficacy of ketoprofen phonophoresis, ultrasound and short-wave diathermy in knee osteoarthritis, Diz Osteoartritinde Ketoprofen Fonoforezi, Ultrason ve Kisa Dalga Diaterminin Etkinlitinin Karsilastirilmasi. [Turkish, English]. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi; 2013. p. 353.
9 Calis FA, Durmaz B, Baydar M, . The effectiveness of TENS, interferential current and short-wave diathermy on knee osteoarthritis: Multicenter, randomized, placebo controlled clinical study, Diz osteoartritinde TENS, interferansiyel akim ve kisa dalga diaterminin etkinliti: Cok merkezli, randomize, plasebo kontrollu klinik califlma. [Turkish, English]. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi; 2011. p. 141.
10 Callaghan M, Parkes MJ, Forsythe LM, . Beneficial effects of a brace for patellofemoral oa: Results of a randomised trial. Osteoarthritis and cartilage; 2013. p. S23.
11 Castgillo JR, Hochberg MC, Martel-Pelletier J, . Combined chondroitin sulfate and Glucosamine versus celecoxib for painful Knee osteoarthritis: Post-hoc analyses by Kellgren and Lawrence grade and C-reactive protein level from a randomized, double-blind, multicentre clinical trial. Clinical Therapeutics. 2015 August;37(8 SUPPL. 1):e122.
12 Cheung C, Wyman J, Resnick B Is yoga effective for knee osteoarthritis in older women? Osteoarthritis and cartilage; 2012. p. S280.
13 Christensen R, Leeds AR, Lohmander S, . Efficacy of dieting or exercise vs. control in obese knee osteoarthritis patients after a clinically significant weight loss: A pragmatic randomized controlled trial. Osteoarthritis and Cartilage. Conference: 2010 Osteoarthritis Research Society International, OARSI World Congress Brussels Belgium. Conference Start: 20100923 Conference End: 20100926. Conference Publication: (var.pagings); 2010. p. S143–s4.
14 Chung M, Wong JB, Chang S, . Nutraceutical Products and Pain or Non-Pain Medications Use in Patients with Knee Osteoarthritis [abstract]. 2014 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2014;66 (suppl S10):S110.
15 Cioara F, Birsan SD, Vicas L, . Balneary physical kinetic therapy effects over gonarthrosis symptoms. Osteoporosis International. 2014 April;25 SUPPL. 2:S409–S10.
16 Coleman S, Briffa NK, Carroll G, . An osteoarthritis of the knee self-management education program delivered by multidisciplinary health professionals; A randomised controlled trial. Physiotherapy (United Kingdom); 2011. p. eS1457.
17 Davis A, Palaganas M, Li L Support for Community-Based Programs for Managing Hip and Knee Osteoarthritis: Results of a Public Survey [abstract]. 2015 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2015;67 (suppl 10):1194.
18 Duivenvoorden T, Raaij T, Horemans H, . Do laterally wedged insoles and valgus knee braces really unload the medial compartment of the knee? Results of a RCT. Osteoarthritis and cartilage; 2014. p. S455–s6.
19 Farias FE, Silva CA, Cernigoy CH, . Analysis and correlation of physical therapy tests, pain, function and quality of life questionnaires in patients from parqve (project arhtritis recovering quality of life by means of education). Osteoarthritis and cartilage; 2015. p. A167.
20 Fary R, Carroll GJ, Briffa TG, . Is pulsed electrical stimulation a viable treatment option in managing pain from osteoarthritis of the knee? Physiotherapy (United Kingdom); 2011. p. eS325–eS6.
21 Filipovic K, Subin-Teodosijevic S, Zvekic-Svorcan J, . Symptomatic effect crystalline glucosamine sulfate osteoarthritis of the knee. Osteoporosis International. 2015 February;26(1 SUPPL. 1):S319.
22 Filipović K, Subin-Teodosijevic S, Zvekić-Svorcan J, . Symptomatic effect crystalline glucosamine sulfate osteoarthritis of the knee. Osteoporosis International. 2015 February;26(1 SUPPL. 1):S319.
23 Fitzgerald GK, Fritz J, Childs J, . Exercise, Manual Therapy, and Use of Booster Sessions in Physical Therapy for Knee OA: A Multi-Center Randomized Clinical Trial [abstract]. 2014 ACR/ARHP Annual Meeting. Arthritis rheumatol. 2014;66 (suppl S10):S393.
24 Forrester K, Taufiq F, Samuels J Comparison of Knee Osteoarthritis Treatment in the Non-Obese Versus Obese Populations Across Different Medical Specialties [abstract]. . Arthritis Rheumatol 2015;67(suppl 10).
25 Foster NE Management of primary care for people with knee osteoarthritis: The beep study (best evidence for exercise in knee pain). Annals of the rheumatic diseases; 2013.
26 Goldenstein-Schainberg C, Fuller R, Matias A, . Effectiveness of long-term use of minimalist footwear on pain and function in knee osteoarthritis. Osteoporosis international; 2013. p. S139.
27 Gomiero AB, Trevisani VM, Kayo AH, . Sensorimotor training versus resistance training in patients with knee osteoarthritis. Arthritis and rheumatism; 2011.
28 Gudbergsen H, Boesen M, Lohmander LS, . Weight loss is effective for symptomatic relief in obese subjects with knee osteoarthritis independently of joint damage severity assessed by high-field MRI and radiography. Osteoarthritis Cartilage. 2012 Jun;20(6):495–502. doi: 10.1016/j.joca.2012.02.639. PMID: 22401872.22401872
29 Henriksen M, Christensen R, Danneskiold-Samsoe B, . Changes in knee muscle strength and muscle mass after weight loss in obese patients with knee osteoarthritis: A prospective cohort study. Osteoarthritis and cartilage; 2011. p. S211.
30 Hochberg MC, Lao L, Langenberg P, . Efficacy and Safety of the Chinese Herbal Compound Hou-Lou-Xiao-Ling Dan in Patients with Osteoarthritis of the Knee: Results of a Phase II International Study [abstract]. 2012 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2012;64 (suppl S10):S112.
31 Hochberg MC, Peng L, Ahl J, . Duloxetine as treatment for knee pain in patients with osteoarthritis who regularly use nonsteroidal anti-inflammatory drugs (NSAIDS): A post hoc analysis of two randomized, placebo-controlled trials. Osteoarthritis and Cartilage. 2011 September;19 SUPPL. 1:S146–S7.
32 Huang H, Ologhobo T, Jin V, . The Effectiveness of Low-Impact Exercise Program on Musculoskeletal Health of Asian Older Adults [abstract]. 2015 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2015;67 (suppl 10):1193.25707478
33 Hurley M, Dickson K, Hauari H, . People’s Views, Beliefs and Experiences of Exercise for Chronic Hip and Knee Pain: Cochrane Review with Qualitative Synthesis. 2014 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2014;66 (suppl S10):S1017.
34 Hussein N, Saad M, El Sawey N Effect of combined balance and isotonic resistive exercises versus isotonic resistive exercise alone on proprioception and stabilizing reactions of quadriceps and hamstrings and functional capacity of knee osteoarthritis patients. 8th Mediterranean Congress of Physical and Rehabilitation Medicine. 2010:91–106.
35 Jeremic M Therapeutic effect viscosuplementa and local infiltration of corticosteroid in patients with knee osteoarthritis. Osteoporosis International. 2014 April;25 SUPPL. 2:S433.
36 Kaya Mutlu E, Razak Ozdincler A, Ercin E Comparison of two different mobilization techniques in the management of osteoarthritis of the knee: A randomized clinical trial. Osteoarthritis and cartilage; 2015. p. A391–a2.
37 Kilinc S, Kabayel DD, Ozdemir F, . Comparison of the effectiveness of isometric and isokinetic exercise in patients with osteoarthritis of knee, Gonartrozlu Hastalarda Izometrik ve Izokinetik Egzersizlerin Etkinlitinin Karsilastirilmasi. [Turkish, English]. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi; 2013. p. 344.
38 Knoop J, Leeden M, Roorda LD, . Importance of adherence in outcome of exercise therapy in patients with knee osteoarthritis. Osteoarthritis and cartilage; 2014. p. S458–s9.
39 Kon E, Filardo G, Di Martino A, . Platelet-rich plasma intra-articular injections versus visco-supplementation as a treatment for early osteoarthritis: A randomized double blind study. Journal of Orthopaedics and Traumatology. 2013 October;14(1 SUPPL. 1):S64–S5.
40 Kou U, Tohyama H, Chiba T, . Long-term effects of video-based home exercise on clinical and radiographic outcomes in subject with knee osteoarthritis: A two-year randomized controlled trial. Osteoarthritis and cartilage; 2013. p. S40.
41 Li LW, Harris RE, Murphy SL, . Feasibility of a Randomized Controlled Trial of Self-Administered Acupressure for Symptom Management in Older Adults with Knee Osteoarthritis. Journal of Alternative and Complementary Medicine. 2016 1;22(5):396–403. FULL TEXT LINK http://dx.doi.org/10.1089/acm.2015.0231.27031862
42 March L, Hunter D, Ward C, . A randomised placebo controlled pilot study of autologous non-expanded adipose-derived mesenchymal stem cells in the treatment of knee osteoarthritis. Internal Medicine Journal. 2013 May;43 SUPPL. 2:4–5.
43 Mathur S, Saracoglu M, Kuroda M, . Functional testing and pre-to post pain measure outcomes in chronic knee osteoarthritis pain with milnacipran: Interim analysis of a randomized, double-blind, placebo-controlled trial. Journal of Pain. 2013 April;14(4 SUPPL. 1):S66.
44 Mills KAG, Naylor JM, Eyles JP, . Examining the minimal important difference of patient-reported outcome measures for individuals with knee osteoarthritis: A model using the knee injury and osteoarthritis outcome score. Journal of Rheumatology. 2016 1;43(2):395–404. FULL TEXT LINK http://dx.doi.org/10.3899/jrheum.150398.26773118
45 Moen M, Weir A, Bakker E, . Efficacy of platelet-rich plasma injections in osteoarthritis of the knee: An updated systematic review and meta-analysis. Osteoarthritis and Cartilage. 2016 April;24 SUPPL. 1:S520–S1.
46 Multanen J, Hakkinen A, Kujala U, . The effects of bone exercise on knee pain, stiffness and function among women with mild knee osteoarthritis: Randomized, controlled trial. Physiotherapy (United Kingdom); 2011. p. eS852–eS3.
47 National Institute for Health and Care Excellence. Osteoarthritis: national clinical guideline for care and management in adults Royal College of Physicians. 2014.
48 Oida Y, Morozumi K, Nakamura N, . [Effectiveness of a community health service program using exercise intervention for elderly people with osteoarthritis of the knees: a randomized controlled trial]. [Nihon k?sh? eisei zasshi] Japanese journal of public health; 2008. p. 228–37.
49 Ozgen M, Mehmetotlu O, Armatan O Efficiency of local diclophenac treatment in knee osteoartritis, Diz osteoartritinde lokal diklofenak tedavisinin etkinliti. [Turkish, English]. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi; 2011. p. 299.
50 Paterson K, Nicholls M, Bates D Intra-articular injection of platelet-rich plasma in patients with knee osteoarthritis: A randomised controlled pilot study. Journal of Science and Medicine in Sport. 2013 December;16 SUPPL. 1:e90.
51 Peter WFH, Hurkmans E, van der Wees P, . Quality Indicators For Physical Therapy Management In Hip and Knee Osteoarthritis and Rheumatoid Arthritis [abstract]. 2013 ACR/ARHP Annual Meeting. 2013.
52 Povoroznyuk V, Grygorieva N, Unusova S, . Effectiveness of exercise therapy in combination with glucosamine and chondroitin treatment in postmenopausal women with knee osteoarthritis. European Journal of Pain Supplements. 2011 September;5(1):185.
53 Prieto-Alhambra D, Morros R Use of Drug Combinations in Patients with Osteoarthritis: A Population-Based Cohort Study [abstract]. 2012 ACR/ARHP Annual Meeting. Arthritis rheumatol 2012;64 (suppl S10):S117–8.
54 Rahela MI, Patru S, Bighea A, . Efficacy of physical exercice in patients with knee osteoarthritis. Annals of the Rheumatic Disease; 2013.
55 Reinhardt JD, Pu W, Yang L, . Effects of whole body vibration exercise associated with quadriceps resistance exercise on functioning and quality of life in patients with knee osteoarthritis: A randomized controlled trial. PM and R; 2014. p. S95–s6.
56 Rillo OL, Riera H, Espinosa-Morales R, . Panlar Consensus on Hand, Hip and Knee OA [abstract]. 2015 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2015;67 (suppl 10):1497.
57 Roper JA, Bressel E, Tillman MD Acute aquatic treadmill exercise improves gait and pain in people with knee osteoarthritis. Arch Phys Med Rehabil. 2013 Mar;94(3):419–25. doi: 10.1016/j.apmr.2012.10.027. PMID: 23131526.23131526
58 Saygi EK, Ozcan EE, Sanal C, . Effects of prolotherapy with 10% dextrose and oral glucosamine sulfate on the postural stability among the patients with knee osteoarthritis ORIGINAL (NON-ENGLISH) TITLE Diz Osteoartriti Tanili Hastalarda %10 Dekstroz Ile Proloterapi ve Glukozamin Sulfat Uygulamalarinin Postural Stabilite Uzerine Etkileri. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi. 2013 April;59 SUPPL. 1:251.
59 Schmidt S Uncontrolled clinical study of the efficacy of ambulant fasting in patients with osteoarthritis*. European Journal of Integrative Medicine. 2010 December;2(4):239.
60 Segal NA, Glass NA, Teran-Yengle P, . Intensive Gait Training for Older Adults with Symptomatic Knee Osteoarthritis. Am J Phys Med Rehabil. 2015 Oct;94(10 Suppl 1):848–58. doi: 10.1097/phm.0000000000000264. PMID: 25768068.25768068
61 Segal NA, Yack HJ, Glass NA, . Intensive gait training improves pain and mobility in older adults with symptomatic knee osteoarthritis. Journal of the American Geriatrics Society; 2010. p. S130.
62 Shakoor MA, Rahman MS, Azad AK, . Effects of isometric quadriceps muscle strengthening exercise on chronic osteoarthritis of the knee. Bangladesh Med Res Counc Bull. 2010 Apr;36(1):20–2. PMID: 21280554.21280554
63 Skou ST, Roos E, Simonsen O, . The combined efficacy of multimodal non-surgical treatment on pain and sensitization in patients with knee osteoarthritis not eligible for a total knee arthroplasty-an ancillary analysis from a randomized controlled trial. Osteoarthritis and Cartilage. 2015 April;23 SUPPL. 2:A34–A5.
64 Smith SR, Katz JN, Collins JE, . Cost-Effectiveness of Opioids for the Treatment of Knee Osteoarthritis: Impact of Chronic Opioid Use on Total Knee Arthroplasty Outcomes [abstract]. Arthritis Rheumatol 2015;67(suppl 10).
65 Sriram S, Ramesh R, Saravanan M, . Intra articular platelet rich plasma versus intra articular steroids versus viscosupplementation in the management of primary osteoarthritis of knee. International Journal of Rheumatic Diseases. 2015 September;18 SUPPL. 1:81–2.
66 Srivastava RN, Avasthi V, Srivastava SR, . Does yoga improve pain, stiffness and physical disability in knee osteoarthritis?-A randomize controlled clinical trial. Osteoarthritis and Cartilage. 2015 April;23 SUPPL. 2:A167.
67 Strebkova E, Solovyeva I, Sharapova E, . Evaluation of treatment efficacy of orlistat in obese women with knee osteoarthritis. Osteoporosis International. 2014 April;25 SUPPL. 2:S353.
68 Tetreault P, Baliki M, Vachon-Presseau E, . Cortical Reorganization after Duloxetine Treatment-Related Pain Decrease in Knee Osteoarthritis [abstract]. 2014 ACR/ARHP Annual Meeting. Arthritis rheumatol. 2014;66 (suppl S10):S410–1.
69 Tohyama H, Chiba T, Kou U, . Effects of video-based home exercise on clinical and radiographic outcomes in adults with knee osteoarthritis: A one-year randomized controlled trial. Osteoarthritis and cartilage; 2011. p. S37.
70 Villadsen A, Overgaard S, Christensen R, . Neuromuscular exercise (NEMEX-TJR) improves knee extension muscle power and chair stands ability in patients with severe knee osteoarthritis compared to controls: A randomized controlled trial. Osteoarthritis and cartilage; 2012. p. S266.
71 Wilder E, Lin J, Bomfim F, . Reduction of Treatment Needed for Knee Osteoarthritis after Bariatric Surgery [abstract]. 2015 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2015;67 (suppl 10):322.
72 Yamada E, Rodrigues PL, Almeida FR, . Effectiveness of transcutaneous electrical nerve stimulation, therapeutic exercise and the pursuit of the association of two techniques in knee osteoarthritis. Physiotherapy. 2011 June;(2011) 97 SUPPL. 1:eS1051–eS2.
73 Yang S, Eaton CB, McAlindon T, . Long-term effectiveness of glucosamine and chondroitin in treating knee osteoarthritis: An analysis with marginal structural modeling. Osteoarthritis and Cartilage. 2014 April;22 SUPPL. 1:S203.
74 Yavuz M, Ataotlu S, Ozsahin M Comparison of isokinetic exercise with treatments of laser and iontophoresis for patients with osteoarthritis of the knee, Diz osteoartriti olan hastalarda izokinetik egzersiz ile lazer ve iyontoforez tedavilerinin karflilafltirilmasi. [Turkish, English]. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi; 2011. p. 297.
75 Yesilyurt H, Tastekin N, Hakguder AH, . A comparison study of the clinical efficacy of ketoprophen phonophoresis and ultrasound therapy in primary knee osteoarthritis, Primer diz osteoartriinde ketoprofen fonoforezi ve ultrason tedavilerinin klinik etkinlitinin karflilafltirilmasi. [Turkish, English]. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi; 2011. p. 259.
76 Yildirim MA, Ucar D, Ones K, . Comparison of the duration of therapeutic ultrasound in patients with knee osteoarthritis. Annals of the rheumatic diseases; 2014.
77 Yildiz SK, Silte AD, Kaysin MY, . Effectiveness of ultrasound therapy in knee osteoarthritis, Diz Osteoartritli Hastalarda Ultrason Tedavisinin Etkinliti. [Turkish, English]. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi; 2013. p. 335.
78 Zeng C, Wei J, Lei GH Is chondroitin sulfate plus glucosamine superior to placebo in the treatment of knee osteoarthritis? Annals of the rheumatic diseases; 2015. p. e37.25749051
79 Zhang Y, Shen CL, Brismee JM, . Exploring the effects of self-managed acupressure on pain, function and osteoarthritis biomarkers among postmenopausal women with osteoarthritic knee pain: A feasibility study. Journal of alternative and complementary medicine (New York, N.Y.); 2013. p. A31.
80 Zhao L, Wu F, Wang L, . Effectiveness of moxibustion treatment as adjunctive therapy in osteoarthritis of the knee: A randomized controlled clinical trial. Journal of alternative and complementary medicine (New York, N.Y.); 2013. p. A6.

## Multi-component interventions – N = 27

1 Allen KD, Bongiorni D, Bosworth HB, . Randomized Clinical Trial of Group Vs. Individual Physical Therapy for Knee Osteoarthritis [abstract]. 2014;2014 ACR/ARHP Annual Meeting
2 Arazpour M, Bani MA, Maleki M, . Comparison of the efficacy of laterally wedged insoles and bespoke unloader knee orthoses in treating medial compartment knee osteoarthritis. Prosthet Orthot Int. 2013 Feb;37(1):50–7. doi: 10.1177/0309364612447094. PMID: 22864510.22864510
3 Arti HR, Azemi ME Comparing the effect of Glucosamine and Glucosamine With Alendronate in Symptomatic Relieve of Degenerative Knee Joint Disease: A Double- blind Randomized Clinical Trial Study. Jundishapur J Nat Pharm Prod. 2012 Summer;7(3):87–92. PMID: 24624161.24624161
4 Bennell K, Wrigley T, Kyriakides M, . Comparison of neuromuscular and quadriceps strengthening exercise in people with medial knee osteoarthritis and varus malalignment: Randomised controlled trial. Osteoarthritis and cartilage; 2013. p. S273–s4.
5 Bennell KL, Kyriakides M, Hodges PW, . Effects of two physiotherapy booster sessions on outcomes with home exercise in people with knee osteoarthritis: a randomized controlled trial. Arthritis Care Res (Hoboken). 2014 Nov;66(11):1680–7. doi: 10.1002/acr.22350. PMID: 24757032.24757032
6 Brito Sr NL, Rezende MU, Campos GC, . Analysis of anthropometric measurements and dietary intake in patients undergoing a multi-professional program osteoarthritis treatment (parqve-project arhtritis recovering quality of life by means of education). Osteoarthritis and cartilage; 2015. p. A386–a7.
7 Choi YL, Kim BK, Hwang YP, . Effects of isometric exercise using biofeedback on maximum voluntary isometric contraction, pain, and muscle thickness in patients with knee osteoarthritis. J Phys Ther Sci. 2015 Jan;27(1):149–53. doi: 10.1589/jpts.27.149. PMID: 25642061.25642061
8 Ebnezar J, Nagarathna R, Bali Y, . Effect of an integrated approach of yoga therapy on quality of life in osteoarthritis of the knee joint: A randomized control study. Int J Yoga. 2011 Jul;4(2):55–63. doi: 10.4103/0973-6131.85486. PMID: 22022123.22022123
9 Ebnezar J, Nagarathna R, Yogitha B, . Effect of integrated yoga therapy on pain, morning stiffness and anxiety in osteoarthritis of the knee joint: A randomized control study. Int J Yoga. 2012 Jan;5(1):28–36. doi: 10.4103/0973-6131.91708. PMID: 22346063.22346063
10 Ebnezar J, Nagarathna R, Yogitha B, . Effects of an integrated approach of hatha yoga therapy on functional disability, pain, and flexibility in osteoarthritis of the knee joint: a randomized controlled study. J Altern Complement Med. 2012 May;18(5):463–72. doi: 10.1089/acm.2010.0320. PMID: 22537508.22537508
11 Espejo Antúnez L, Cardero Durán M, Caro Puértolas B, . [Effects of exercise on the function and quality of life in the institutionalised elderly diagnosed with gonarthrosis]. Revista española de geriatría y gerontología; 2012. p. 262–5.22592162
12 Fazaa A, Souabni L, Ben Abdelghani K, . Comparison of the clinical effectiveness of thermal cure and rehabilitation in knee osteoarthritis. A randomized therapeutic trial. Ann Phys Rehabil Med. 2014 Dec;57(9–10):561–9. doi: 10.1016/j.rehab.2014.09.007. PMID: 25447748.25447748
13 Hunter D, Gross KD, McCree P, . Realignment treatment for medial tibiofemoral osteoarthritis: randomised trial. Ann Rheum Dis. 2012 Oct;71(10):1658–65. doi: 10.1136/annrheumdis-2011-200728. PMID: 22377805.22377805
14 Kocaman O, Koyuncu H, Dinc A, . The comparison of the effects of electrical stimulation and exercise in the treatment of knee osteoarthritis. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi; 2008. p. 54–8.
15 Kudo M, Watanabe K, Otsubo H, . Analysis of effectiveness of therapeutic exercise for knee osteoarthritis and possible factors affecting outcome. J Orthop Sci. 2013 Nov;18(6):932–9. doi: 10.1007/s00776-013-0443-9. PMID: 24085378.24085378
16 Massari F, De Carvalho VA, Da Silva CR Efficacy and safety of the association of glucosamine sulfate and chondroitin sulfate in the treatment of symptomatic knee osteoarthritis ORIGINAL (NON-ENGLISH) TITLE Eficacia e seguranca da associacao de sulfato de glucosamina e sulfato de condroitina no tratamento sintomatico da osteoartrite de joelho. Revista Brasileira de Medicina. 2014;71:6–7.
17 Matei D, Bighea A, Patru S, . The place of kinetotherapy in rehabilitation program of knee osteoarthritis patients. Osteoporosis International. 2014 April;25 SUPPL. 2:S279.
18 Müller-Rath R, Cho HY, Siebert CH, . [Clinical and gait analytical investigation of valgus knee bracing in therapy for medial degenerative joint disease of the knee]. Zeitschrift für Orthopädie und Unfallchirurgie; 2011. p. 160–5.20391324
19 Nunez M, Nunez E, Segur JM, . The effect of an educational program to improve health-related quality of life in patients with osteoarthritis on waiting list for total knee replacement: a randomized study. Osteoarthritis Cartilage. 2006 Mar;14(3):279–85. doi: 10.1016/j.joca.2005.10.002. PMID: 16309929.16309929
20 Rafiaee M, Karimi MT The effects of various kinds of lateral wedge insoles on performance of individuals with knee joint osteoarthritis. Int J Prev Med. 2012 Oct;3(10):693–8. PMID: 23112895.23112895
21 Salli A, Ugurlu H, Emlik D Comparison of the effectiveness of concentric, combined concentric-eccentric and isometric exercises on symptoms and functional capacity in patients with knee osteoarthritis. [Turkish]. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi; 2006. p. 61–7.
22 Saraboon Y, Aree-Ue S, Maruo SJ The Effect of Multifactorial Intervention Programs on Health Behavior and Symptom Control Among Community-Dwelling Overweight Older Adults With Knee Osteoarthritis. Orthop Nurs. 2015 Sep–Oct;34(5):296–308. doi: 10.1097/nor.0000000000000180. PMID: 26375841.26375841
23 Shirokova LY, Noskov SM, Abrosimova EB, . [Effect of local therapy of autolgous platelet-enriched plasma on pain syndrome in patients with knee osteoarthritis]. Klinicheskaia meditsina. 2012;90(10):48–52.
24 Skou ST, Rasmussen S, Laursen MB, . The efficacy of 12 weeks non-surgical treatment for patients not eligible for total knee replacement: a randomized controlled trial with 1-year follow-up. Osteoarthritis Cartilage. 2015 Sep;23(9):1465–75. doi: 10.1016/j.joca.2015.04.021. PMID: 25937024.25937024
25 Tefner IK, Gaal R, Koroknai A, . The effect of Neydharting mud-pack therapy on knee osteoarthritis: a randomized, controlled, double-blind follow-up pilot study. Rheumatol Int. 2013 Oct;33(10):2569–76. doi: 10.1007/s00296-013-2776-2. PMID: 23689969.23689969
26 Wu SF, Kao MJ, Wu MP, . Effects of an osteoarthritis self-management programme. J Adv Nurs. 2011 Jul;67(7):1491–501. doi: 10.1111/j.1365-2648.2010.05603.x. PMID: 21375573.21375573
27 Zotkin EG, Kharitonova TV, Shkireeva S [Clinical use of chondroitin sulfate in patients with osteoarthritis in geriatric practice]. Adv Gerontol. 2014;27(2):366–75. PMID: 25306673.25306673

## Duplicate or duplicate data – N = 39

1 Atukorala I, Makovey J, Lawler L, . Is there a dose response relationship between weight loss and symptom improvement in persons with symptomatic knee osteoarthritis? Osteoarthritis and Cartilage. 2014 April;22 SUPPL. 1:S50–S1.
2 Bennell K, Ahamed Y, Bryant C, . Physiotherapist-delivered exercise and pain coping skills training is more effective than either intervention alone in knee osteoarthritis. Journal of science and medicine in sport; 2013. p. e91.
3 Bennell KL, Ahamed Y, Bryant C, . Physiotherapist-delivered exercise and pain coping skills training is more effective than either intervention alone in knee osteoarthritis. Osteoarthritis and cartilage; 2014. p. S192–s3.
4 Bennell KL, Ahamed Y, Jull G, . Physical Therapist-Delivered Pain Coping Skills Training and Exercise for Knee Osteoarthritis: Randomized Controlled Trial. Arthritis Care Res (Hoboken). 2016 May;68(5):590–602. doi: 10.1002/acr.22744. PMID: 26417720.26417720
5 Bove A, Smith K, Bise C, . What Is the Most Cost-Effective Physical Therapy Strategy to Treat Knee Osteoarthritis? [abstract]. Arthritis Rheumatol 2015;67(suppl 10).
6 Bruyere O, Pavelka K, Rovati LC, . Total joint replacement after glucosamine sulphate treatment in knee osteoarthritis: results of a mean 8-year observation of patients from two previous 3-year, randomised, placebo-controlled trials. Osteoarthritis and Cartilage. 2008;16(2):254–60. doi: 10.1016/j.joca.2007.06.011.17681803
7 Cho Sr JJ, Kim TW, Park YM, . Tissuegene-C (TG-C) in patients with osteoarthritis: A phase iib clinical study. Osteoarthritis and Cartilage. 2013 April;21 SUPPL. 1:S147.
8 Crossley K, Vicenzino B, Pandy M, . A randomised clinical trial of targeted physiotherapy for patellofemoral osteoarthritis. Journal of science and medicine in sport; 2012. p. S245.
9 Douidi-Hamimed FZ, Mekaouche M, Derdour S, . Functional and clinical outcome after self-management in people with knee osteoarthritis. Annals of Physical and Rehabilitation Medicine. 2013 October;56 SUPPL. 1:e362.
10 Felson DT, Parkes MJ, Gait AD, . A randomised trial of a brace for patellofemoral osteoarthritis targeting knee pain and bone marrow lesions. Arthritis and rheumatism; 2013. p. S717.
11 Fransen M, Agaliotis M Glucosamine and chondroitin for knee osteoarthritis: a double-blind randomised placebo-controlled clinical trial evaluating single and combination regimens. 2015 May;74(5):851–8. doi: 10.1136/annrheumdis-2013-203954. PMID: 24395557.24395557
12 Fransen M, Agaliotis M, Nairn L, . Glucosamine and chondroitin for knee osteoarthritis: A double-blind randomised placebo-controlled clinical trial evaluating single and combination regimens. Annals of the rheumatic diseases; 2015. p. 851–8.24395557
13 Fransen M, Agaliotis M, Nairn L, . Glucosamine and chondroitin for knee osteoarthritis: A double blind randomised controlled clinical trial evaluating single and combination regimens. Osteoarthritis and Cartilage. 2014 April;22 SUPPL. 1:S457.
14 Henriksen M, Klokker L, Graven-Nielsen T, . Exercise Therapy Reduces Pain Sensitivity In Patients With Knee Osteoarthritis: A Randomized Controlled Trial [abstract]. 2013 ACR/ARHP Annual Meeting. Arthritis Rheumatol. 2013;65 (suppl S10):S775.
15 Hochberg M, Martel-Pelletier J, Monfort J, . Combined chondroitin sulfate and glucosamine is comparable to celecoxib for painful knee osteoarthritis. Results from a multicenter, randomized, double-blind, phase IV non-inferiority trial. Arthritis and Rheumatology. 2014 October;66 SUPPL. 10:S971.
16 Hochberg MC, Martel-Pelletier J, Monfort J, . Combined chondroitin sulfate and glucosamine for painful knee osteoarthritis: a multicentre, randomised, double-blind, non-inferiority trial versus celecoxib. Ann Rheum Dis. 2016 Jan;75(1):37–44. doi: 10.1136/annrheumdis-2014-206792. PMID: 25589511.25589511
17 Hochberg MC, Martel-Pelletier J, Monfort J, . Multicentric osteoarthritis intervention study with sysadoa (MOVES): Effects of combined glucosamine hydrochloride and chondroitin sulfate vs celecoxib for painful knee osteoarthritis. Basic and Clinical Pharmacology and Toxicology. 2014 September;115 SUPPL. 2:25.
18 Jain A, Patel S, Aggarwal S, . Autologous platelet derived growth factors as a treatment modality in early osteoarthritis knee-a prospective randomized control trial. Vox Sanguinis. 2012 July;103 SUPPL. 1:61.
19 Knoop J, Dekker J, Dan Der Leeden M, . Knee joint stabilization therapy in patients with osteoarthritis of the knee: A randomized, controlled trial. Arthritis and rheumatism; 2012. p. S116.
20 Lee B, Cho J, Kim T, . Tissuegene-C (TG-C) improved clinical scores in patients with osteoarthritis: A phase 2b study. Osteoarthritis and Cartilage. 2014 April;22 SUPPL. 1:S194.
21 Matias A, Trombini-Souza F, Yokota M, . Long-term effect of a flexible minimalist shoe on algofunctional, analgesic medication intake and gait kinematic in elderly women with knee osteoarthritis. Osteoarthritis and cartilage; 2014. p. S198.
22 Micca JL, Risser RC, Ahl J, . The efficacy and safety of duloxetine treatment in older patients with osteoarthritis knee pain: A post hoc, subgroup analysis of data from 2 placebo-controlled trials. Arthritis and Rheumatism. 2011;63(10):2011–11.
23 Nelson F, Zvirbulis R, Pilla AA Non-invasive electromagnetic field therapy produces rapid and substantial pain reduction in early knee osteoarthritis: A randomized double-blind pilot study. Osteoarthritis and Cartilage. 2012 April;20 SUPPL. 1:S174.
24 Peniston JH, Gold MS, Alwine LK An open-label, long-term safety and tolerability trial of diclofenac sodium 1% gel in patients with knee osteoarthritis. Phys Sportsmed. 2011 Sep;39(3):31–8. doi: 10.3810/psm.2011.09.1918. PMID: 22030938.22030938
25 Provenza JR, Shinjo SK, Silva JM, . Combined glucosamine and chondroitin sulfate, once or three times daily, provides clinically relevant analgesia in knee osteoarthritis. Clin Rheumatol. 2015 Aug;34(8):1455–62. doi: 10.1007/s10067-014-2757-1. PMID: 25085275.25085275
26 Rabago DP, Miller DJ, Zgierska AE, . Dextrose prolotherapy for knee osteoarthritis: Results of a randomized controlled trial. Osteoarthritis and cartilage; 2011. p. S142–s3.
27 Raynauld JP, Martel-Pelletier J, Dorais M, . Prediction of total knee replacement in a 6-month multicentre clinical trila with chondroitin sulfate in knee osteoarthritis: Results from a 4-year observation. Osteoarthritis and Cartilage. 2012 April;20 SUPPL. 1:S175.
28 Reginster J, Tajana E Single oral dose of (1200 MG) sachet of chondroitin 4&6 sulfate (CS4&6-chondrosulf(registered trademark)) relieves pain and improves function. Results of a double blind study, versus placebo and an active treatment in knee OA patients. Osteoarthritis and Cartilage. 2011 September;19 SUPPL. 1:S226–S7.
29 Sattari S, Ashraf A Comparison of the effects of 3-point valgus knee support and lateral wedge insoles in medial compartment knee osteoarthritis. Iranian Red Crescent Medical Journal. 2011 2011;13(9):581–4.
30 Segal N, Glass N, Teran-Yengle P, . Intensive Gait Training for Older Adults with Symptomatic Knee Osteoarthritis. American journal of physical medicine & rehabilitation/Association of Academic Physiatrists; 2015. p. 848–58.
31 Snyder-Mackler L Lateral wedge insoles worn for 12 months provided no symptomatic or structural benefit for people with medial knee osteoarthritis. Journal of Physiotherapy. 2011 September;57(3):195.21843837
32 Sung-Bum JU, Gi Duck P, Sang-Soo KIM Effects of proprioceptive circuit exercise on knee joint pain and muscle function in patients with knee osteoarthritis. Journal of Physical Therapy Science. 2015;27(8):2439–41. PMID: 109081584. Language: English. Entry Date: 20151013. Revision Date: 20151013. Publication Type: Article.26357422
33 Teixeira PE, Piva SR, Fitzgerald GK Effects of impairment-based exercise on performance of specific self-reported functional tasks in individuals with knee osteoarthritis. Phys Ther. 2011 Dec;91(12):1752–65. doi: 10.2522/ptj.20100269. PMID: 22003157.22003157
34 Tsai PF, Chang JY, Beck C, . A supplemental report to a randomized cluster trial of a 20-week Sun-style Tai Chi for osteoarthritic knee pain in elders with cognitive impairment. Complementary Therapies in Medicine. 2015 Aug;23(4):570–6. 26275650
35 Vincent KR, Montero C, Vincent HK Progressive enhanced eccentric or concentric resistance exercise training for knee osteoarthritis. Osteoarthritis and cartilage; 2013. p. S275–s6.
36 Wang C, Schmid C, Iversen MD, . Comparative Effectiveness of Tai Chi Versus Physical Therapy in Treating Knee Osteoarthritis: A Randomized, Single-Blind Trial [abstract]. Arthritis Rheumatol 2015;67(suppl 10).
37 Wang C, Schmid CH, Iversen MD, . Comparative Effectiveness of Tai Chi Versus Physical Therapy for Knee Osteoarthritis: A Randomized Trial. Ann Intern Med. 2016 Jul 19;165(2):77–86. doi: 10.7326/m15-2143. PMID: 27183035.27183035
38 Wang P, Yang L, Li H, . Effects of whole-body vibration training with quadriceps strengthening exercise on functioning and gait parameters in patients with medial compartment knee osteoarthritis: A randomised controlled preliminary study. Physiotherapy (United Kingdom); 2016. p. 86–92.
39 Yildiz S, Özkan F, Akta I, . The effectiveness of ultrasound treatment for the management of knee osteoarthritis: a randomized, placebo-controlled, double-blind study. Turkish journal of medical sciences; 2015. p. 1187–91.26775369