# Appendix A Search Strategy

## SEARCHES RUN IN JULY/AUGUST 2015 [For Surveillance]

### DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 1/1/2006–7/10/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

### GLUCOSAMINE:

“osteoarthritis, knee”[MH] OR (“osteoarthritis”[MH] AND (knee[tiab] OR knees[tiab])) OR (osteoarthritis*[tiab] AND (knee[tiab] OR knees[tiab])) OR (“osteoarthritis”[MH] AND (patellofemoral[tiab] OR patello-femoral[tiab])

AND

Glucosamine[MH] OR “Chondroitin”[MH] OR glucosamine OR acetylglucosamine OR “n-acetylglucosamine” OR “n-acetyl-d-glucosamine” OR chondroitin

### NEW THERAPIES:

“osteoarthritis, knee”[MH] OR (“osteoarthritis”[MH] AND (knee[tiab] OR knees[tiab])) OR (osteoarthritis*[tiab] AND (knee[tiab] OR knees[tiab])) OR (“osteoarthritis”[MH] AND (patellofemoral[tiab] OR patello-femoral[tiab])

AND

monovisc OR duloxetine* OR cymbalta OR selective serotonin* OR ssnri OR milnacipran OR savella OR venlafaxine OR effexor OR desvenlafaxine OR pristiq OR “il-1” OR interleukin* OR anakinra OR canakinumab OR “platelet rich plasma” OR “platelet-rich plasma” OR PRP OR “nerve growth factor” OR fibroblast growth OR shoe wedge* OR capsaicin

### MANUALLY SEARCHED ENDNOTE TO FILTER ABOVE RESULTS FOR THE FOLLOWING TERMS REPRESENTING STUDY DESIGNS:

Comparative

Evaluation

Follow-up

Follow up

Prospective

Placebo

Clinical trial

Mask

Single-blind

Double-blind

Blind

Random

RCT

Research design

Control

Volunteer

Systematic review

Meta-analy*

Meta analy*

Metaanaly*

Database or Data base

Case series (for Arthroscopy only)

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

Embase – 1/1/2006–7/21/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

### GLUCOSAMINE:

‘knee osteoarthritis’/exp OR ‘knee osteoarthritis’ OR (‘osteoarthritis’/exp OR osteoarthritis AND (‘knee’/exp OR knee OR knees OR patellofemoral OR ‘patello femoral’))

AND

‘chondroitin’ OR ‘chondroitin’/exp OR chondroitin OR ‘glucosamine’ OR ‘glucosamine’/exp OR glucosamine OR ‘acetylglucosamine’ OR ‘acetylglucosamine’/exp OR acetylglucosamine OR ‘n-acetylglucosamine’/exp OR ‘n-acetylglucosamine’ OR ‘n-acetyl-d-glucosamine’/exp OR ‘n-acetyl-d-glucosamine’

AND

Human/de

### NEW THERAPIES:

‘knee osteoarthritis’/exp OR ‘knee osteoarthritis’ OR (‘osteoarthritis’/exp OR osteoarthritis AND (‘knee’/exp OR knee OR knees OR patellofemoral OR ‘patello femoral’))

AND

‘monovisc’ OR ‘monovisc’/exp OR monovisc OR duloxetine* OR ‘cymbalta’ OR ‘cymbalta’/exp OR cymbalta OR (selective AND serotonin*) OR ‘ssnri’ OR ‘ssnri’/exp OR ssnri OR ‘milnacipran’ OR ‘milnacipran’/exp OR milnacipran OR ‘savella’ OR ‘savella’/exp OR savella OR ‘venlafaxine’ OR ‘venlafaxine’/exp OR venlafaxine OR ‘effexor’ OR ‘effexor’/exp OR effexor OR ‘desvenlafaxine’ OR ‘desvenlafaxine’/exp OR desvenlafaxine OR ‘pristiq’ OR ‘pristiq’/exp OR pristiq OR ‘il-1’/exp OR ‘il-1’ OR interleukin* OR ‘anakinra’ OR ‘anakinra’/exp OR anakinra OR ‘canakinumab’ OR ‘canakinumab’/exp OR canakinumab OR ‘platelet rich plasma’/exp OR ‘platelet rich plasma’ OR ‘platelet-rich plasma’/exp OR ‘platelet-rich plasma’ OR ‘prp’ OR ‘prp’/exp OR prp OR ‘nerve growth factor’/exp OR ‘nerve growth factor’ OR ((‘fibroblast’ OR ‘fibroblast’/exp OR fibroblast) AND (‘growth’ OR ‘growth’/exp OR growth)) OR ((‘shoe’ OR ‘shoe’/exp OR shoe) AND wedge*) OR capsaicin*

AND

Human/de

### MANUALLY SEARCHED ENDNOTE TO FILTER ABOVE RESULTS FOR THE FOLLOWING TERMS REPRESENTING STUDY DESIGNS:

Comparative

Follow-up

Follow up

Prospective

Placebo

Trial

Mask

Single-blind

Double-blind

Blind

Random

RCT

Research design

Control

Volunteer

Systematic review

Meta-analy*

Meta analy*

Database or Data base

Case series (for Arthroscopy only)

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

Cochrane Databases of Systematic Reviews, Other Reviews, CENTRAL, Methods, Technology Assessment, Economic Evaluations – 1/1/2006–8/3/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

### GLUCOSAMINE:

osteoarthritis and (knee or knees or patellofemoral or patello-femoral):ti,ab,kw

AND

glucosamine or acetylglucosamine or “n-acetylglucosamine” or “n-acetyl-d-glucosamine” or chondroitin:ti,ab,kw

### NEW THERAPIES:

osteoarthritis and (knee or knees or patellofemoral or patello-femoral):ti,ab,kw

AND

monovisc or duloxetine* or cymbalta or selective serotonin* or ssnri or milnacipran or savella or venlafaxine or effexor or desvenlafaxine or pristiq or “il-1” or interleukin* or anakinra or canakinumab or “platelet rich plasma” or “platelet-rich plasma” or PRP or “nerve growth factor” or fibroblast growth or shoe wedge* or capsaicin:ti,ab,kw

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

International Pharmaceutical Abstracts – 1/1/2006–8/4/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

### GLUCOSAMINE:

ab(osteoarthritis and (knee or knees or patellofemoral or patello-femoral)) OR ti(osteoarthritis and (knee or knees or patellofemoral or patello-femoral)) OR su(osteoarthritis and (knee or knees or patellofemoral or patello-femoral))

AND

ab(glucosamine or acetylglucosamine or “n-acetylglucosamine” or “n-acetyl-d-glucosamine” or chondroitin) OR ti(glucosamine or acetylglucosamine or “n-acetylglucosamine” or “n-acetyl-d-glucosamine” or chondroitin) OR su(glucosamine or acetylglucosamine or “n-acetylglucosamine” or “n-acetyl-d-glucosamine” or chondroitin)

### NEW THERAPIES:

ab(osteoarthritis and (knee or knees or patellofemoral or patello-femoral)) OR ti(osteoarthritis and (knee or knees or patellofemoral or patello-femoral)) OR su(osteoarthritis and (knee or knees or patellofemoral or patello-femoral))

AND

ab(monovisc or duloxetine* or cymbalta or selective serotonin* or ssnri or milnacipran or savella or venlafaxine or effexor or desvenlafaxine or pristiq or “il-1” or interleukin* or anakinra or canakinumab or “platelet rich plasma” or “platelet-rich plasma” or PRP or “nerve growth factor” or fibroblast growth or shoe wedge* or capsaicin) OR ti(monovisc or duloxetine* or cymbalta or selective serotonin* or ssnri or milnacipran or savella or venlafaxine or effexor or desvenlafaxine or pristiq or “il-1” or interleukin* or anakinra or canakinumab or “platelet rich plasma” or “platelet-rich plasma” or PRP or “nerve growth factor” or fibroblast growth or shoe wedge* or capsaicin) OR su(monovisc or duloxetine* or cymbalta or selective serotonin* or ssnri or milnacipran or savella or venlafaxine or effexor or desvenlafaxine or pristiq or “il-1” or interleukin* or anakinra or canakinumab or “platelet rich plasma” or “platelet-rich plasma” or PRP or “nerve growth factor” or fibroblast growth or shoe wedge* or capsaicin)

## UPDATES RUN IN NOVEMBER/DECEMBER 2015 for the report

### DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 6/1/2015–11/4/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

### GLUCOSAMINE:

“osteoarthritis, knee”[MH] OR (“osteoarthritis”[MH] AND (knee[tiab] OR knees[tiab])) OR (osteoarthritis*[tiab] AND (knee[tiab] OR knees[tiab])) OR (“osteoarthritis”[MH] AND (patellofemoral[tiab] OR patello-femoral[tiab]))

AND

Glucosamine[MH] OR “Chondroitin”[MH] OR glucosamine OR acetylglucosamine OR “n-acetylglucosamine” OR “n-acetyl-d-glucosamine” OR chondroitin

### NEW THERAPIES:

### DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 6/1/2015–12/2/2015

“osteoarthritis, knee”[MH] OR (“osteoarthritis”[MH] AND (knee[tiab] OR knees[tiab])) OR (osteoarthritis*[tiab] AND (knee[tiab] OR knees[tiab])) OR (“osteoarthritis”[MH] AND (patellofemoral[tiab] OR patello-femoral[tiab]))

AND

duloxetine* OR cymbalta OR selective serotonin* OR ssnri OR milnacipran OR savella OR venlafaxine OR effexor OR desvenlafaxine OR pristiq OR “il-1” OR interleukin* OR anakinra OR canakinumab OR “platelet rich plasma” OR “platelet-rich plasma” OR PRP OR “nerve growth factor” OR fibroblast growth OR shoe wedge* OR capsaicin

### ADDITIONAL THERAPIES:

### DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed - 1/1/2006–12/11/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

“osteoarthritis, knee”[MH] OR (“osteoarthritis”[MH] AND (knee[tiab] OR knees[tiab])) OR (osteoarthritis*[tiab] AND (knee[tiab] OR knees[tiab])) OR (“osteoarthritis”[MH] AND (patellofemoral[tiab] OR patello-femoral[tiab])) OR (“osteoarthritis”[tiab] AND (patellofemoral[tiab] OR patello-femoral[tiab])

AND

acupuncture[tiab] OR acupuncture[ot] OR braces OR orthotic* OR orthosis OR orthoses OR stem cell* OR physical therapy OR exercis* OR herbal supplement* OR transdermal OR topical analgesic* OR analgesic cream* OR prolotherap* OR weight loss OR losing weight OR diet OR dieting OR weight reduc* OR cell-based therap* OR “Acupuncture Therapy”[Mesh] OR “Orthotic Devices”[Mesh] OR “Stem Cells”[Mesh] OR “Physical Therapy Modalities”[Mesh] OR “Exercise Movement Techniques”[Mesh] OR “Exercise Therapy”[Mesh] OR “Transdermal Patch”[Mesh] OR “Weight Loss”[Mesh] OR “Diet, Reducing”[Mesh] OR “Weight Reduction Programs”[Mesh] OR (dietary supplements[mh] AND (plants, medicinal[mh] OR plant extracts[mh])) OR (administration, topical[mh] AND analgesics[mh])

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

Embase – 1/1/2015–11/5/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

### GLUCOSAMINE:

‘knee osteoarthritis’/exp OR ‘knee osteoarthritis’ OR (‘osteoarthritis’ OR ‘osteoarthritis’/exp OR osteoarthritis AND (‘knee’ OR ‘knee’/exp OR knee OR knees OR patellofemoral OR ‘patello femoral’)) AND [english]/lim AND [humans]/lim AND [2015–2015]/py

AND

‘chondroitin’ OR ‘chondroitin’/exp OR chondroitin OR ‘glucosamine’ OR ‘glucosamine’/exp OR glucosamine OR ‘acetylglucosamine’ OR ‘acetylglucosamine’/exp OR acetylglucosamine OR ‘n-acetylglucosamine’/exp OR ‘n-acetylglucosamine’ OR ‘n-acetyl-d-glucosamine’/exp OR ‘n-acetyl-d-glucosamine’

### NEW THERAPIES:

### DATABASE SEARCHED & TIME PERIOD COVERED:

Embase – 1/1/2015–11/5/2015

‘knee osteoarthritis’/exp OR ‘knee osteoarthritis’ OR (‘osteoarthritis’ OR ‘osteoarthritis’/exp OR osteoarthritis AND (‘knee’ OR ‘knee’/exp OR knee OR knees OR patellofemoral OR ‘patello femoral’))

AND

duloxetine* OR ‘cymbalta’ OR ‘cymbalta’/exp OR cymbalta OR (selective AND serotonin*) OR ‘ssnri’ OR ‘ssnri’/exp OR ssnri OR ‘milnacipran’ OR ‘milnacipran’/exp OR milnacipran OR ‘savella’ OR ‘savella’/exp OR savella OR ‘venlafaxine’ OR ‘venlafaxine’/exp OR venlafaxine OR ‘effexor’ OR ‘effexor’/exp OR effexor OR ‘desvenlafaxine’ OR ‘desvenlafaxine’/exp OR desvenlafaxine OR ‘pristiq’ OR ‘pristiq’/exp OR pristiq OR ‘il-1’/exp OR ‘il-1’ OR interleukin* OR ‘anakinra’ OR ‘anakinra’/exp OR anakinra OR ‘canakinumab’ OR ‘canakinumab’/exp OR canakinumab OR ‘platelet rich plasma’/exp OR ‘platelet rich plasma’ OR ‘platelet-rich plasma’/exp OR ‘platelet-rich plasma’ OR ‘prp’ OR ‘prp’/exp OR prp OR ‘nerve growth factor’/exp OR ‘nerve growth factor’ OR (‘fibroblast’ OR ‘fibroblast’/exp OR fibroblast AND (‘growth’ OR ‘growth’/exp OR growth)) OR (‘shoe’ OR ‘shoe’/exp OR shoe AND wedge*) OR capsaicin*

AND

Human

### ADDITIONAL THERAPIES:

### DATABASE SEARCHED & TIME PERIOD COVERED:

Embase - 1/1/2006–12/11/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

‘knee osteoarthritis’/exp OR ‘knee osteoarthritis’ OR ‘osteoarthritis’ OR ‘osteoarthritis’/exp OR osteoarthritis AND (‘knee’ OR ‘knee’/exp OR knee OR knees OR patellofemoral OR ‘patello femoral’)

AND

‘acupuncture’ OR ‘acupuncture’/exp OR acupuncture OR ‘braces’ OR ‘braces’/exp OR braces OR orthotic* OR ‘orthosis’ OR ‘orthosis’/exp OR orthosis OR ‘orthoses’ OR ‘orthoses’/exp OR orthoses OR (stem AND cell*) OR (physical AND (‘therapy’ OR ‘therapy’/exp OR therapy)) OR exercis* OR herbal AND supplement* OR ‘transdermal’ OR ‘transdermal’/exp OR transdermal OR (‘topical’ OR ‘topical’/exp OR topical AND analgesic*) OR (‘analgesic’ OR ‘analgesic’/exp OR analgesic AND cream*) OR prolotherap* OR (‘weight’ OR ‘weight’/exp OR weight AND (loss OR losing) OR ‘diet’ OR ‘diet’/exp OR diet OR ‘dieting’ OR ‘dieting’/exp OR dieting OR (‘weight’ OR ‘weight’/exp OR weight AND reduc*) OR ‘(cell based’ AND therap*)

AND

Humans

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

Cochrane – 1/1/2015–11/5/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

### GLUCOSAMINE:

osteoarthritis and (knee or knees or patellofemoral or patello-femoral):ti,ab,kw (Word variations have been searched)

AND

glucosamine or acetylglucosamine or “n-acetylglucosamine” or “n-acetyl-d-glucosamine” or chondroitin:ti,ab,kw (Word variations have been searched)

### NEW THERAPIES:

### DATABASE SEARCHED & TIME PERIOD COVERED:

Cochrane – 1/1/2015–12/2/2015

### SEARCH STRATEGY:

osteoarthritis and (knee or knees or patellofemoral or patello-femoral):ti,ab,kw Publication Year from 2015 to 2015 (Word variations have been searched)

AND

duloxetine* or cymbalta or selective serotonin* or ssnri or milnacipran or savella or venlafaxine or effexor or desvenlafaxine or pristiq or “il-1” or interleukin* or anakinra or canakinumab or “platelet rich plasma” or “platelet-rich plasma” or PRP or “nerve growth factor” or fibroblast growth or shoe wedge* or capsaicin:ti,ab,kw (Word variations have been searched)

### ADDITIONAL THERAPIES:

### DATABASE SEARCHED & TIME PERIOD COVERED:

Cochrane - 1/1/2006–12/11/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

osteoarthritis and (knee or knees or patellofemoral or patello-femoral):ti,ab,kw (Word variations have been searched)

AND

acupuncture or braces or orthotic* or orthosis or orthoses or “stem cell” or “stem cells” or “physical therapy” or exercis* or “herbal supplement” or “herbal supplements” or transdermal or “topical analgesic” or “topical analgesics” or “analgesic cream” or “analgesic creams” or prolotherap* or weight or diet or dieting or “cell-based therapy” or “cell-based therapies” 143386

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

CINAHL – 1/1/2006–11/12/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

### GLUCOSAMINE:

TI ( osteoarthritis AND (knee or knees or patellofemoral or patello-femoral) ) OR AB ( osteoarthritis AND (knee or knees or patellofemoral or patello-femoral) ) OR SU ( osteoarthritis AND (knee or knees or patellofemoral or patello-femoral) )

AND

TI ( glucosamine or acetylglucosamine or “n-acetylglucosamine” or “n-acetyl-d-glucosamine” or chondroitin ) OR AB ( glucosamine or acetylglucosamine or “n-acetylglucosamine” or “n-acetyl-d-glucosamine” or chondroitin ) OR SU ( glucosamine or acetylglucosamine or “n-acetylglucosamine” or “n-acetyl-d-glucosamine” or chondroitin

### NEW THERAPIES:

### DATABASE SEARCHED & TIME PERIOD COVERED:

CINAHL – 1/1/2006–12/2/2015

### SEARCH STRATEGY:

TI ( osteoarthritis AND (knee or knees or patellofemoral or patello-femoral ) OR AB ( osteoarthritis AND (knee or knees or patellofemoral or patello-femoral ) OR SU ( osteoarthritis AND (knee or knees or patellofemoral or patello-femoral )

AND

TI ( duloxetine* or cymbalta or selective serotonin* or ssnri or milnacipran or savella or venlafaxine or effexor or desvenlafaxine or pristiq or “il-1” or interleukin* or anakinra or canakinumab or “platelet rich plasma” or “platelet-rich plasma” or PRP or “nerve growth factor” or fibroblast growth or shoe wedge* or capsaicin ) OR AB ( duloxetine* or cymbalta or selective serotonin* or ssnri or milnacipran or savella or venlafaxine or effexor or desvenlafaxine or pristiq or “il-1” or interleukin* or anakinra or canakinumab or “platelet rich plasma” or “platelet-rich plasma” or PRP or “nerve growth factor” or fibroblast growth or shoe wedge* or capsaicin ) OR SU ( duloxetine* or cymbalta or selective serotonin* or ssnri or milnacipran or savella or venlafaxine or effexor or desvenlafaxine or pristiq or “il-1” or interleukin* or anakinra or canakinumab or “platelet rich plasma” or “platelet-rich plasma” or PRP or “nerve growth factor” or fibroblast growth or shoe wedge* or capsaicin )

### ADDITIONAL THERAPIES:

### DATABASE SEARCHED & TIME PERIOD COVERED:

CINAHL - 1/1/2006–12/4/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

TI ( osteoarthritis and (knee or knees or patellofemoral or patello-femoral) ) OR AB ( osteoarthritis and (knee or knees or patellofemoral or patello-femoral) ) OR SU ( osteoarthritis and (knee or knees or patellofemoral or patello-femoral)

AND

TI ( acupuncture or braces or orthotic* or orthosis or orthoses or “stem cell” or “stem cells” or “physical therapy” or exercis* or “herbal supplement” or “herbal supplements” or transdermal or “topical analgesic” or “topical analgesics” or “analgesic cream” or “analgesic creams” or prolotherap* or weight or diet or dieting or “cell-based therapy” or “cell-based therapies” ) OR AB ( acupuncture or braces or orthotic* or orthosis or orthoses or “stem cell” or “stem cells” or “physical therapy” or exercis* or “herbal supplement” or “herbal supplements” or transdermal or “topical analgesic” or “topical analgesics” or “analgesic cream” or “analgesic creams” or prolotherap* or weight or diet or dieting or “cell-based therapy” or “cell-based therapies” ) OR SU ( acupuncture or braces or orthotic* or orthosis or orthoses or “stem cell” or “stem cells” or “physical therapy” or exercis* or “herbal supplement” or “herbal supplements” or transdermal or “topical analgesic” or “topical analgesics” or “analgesic cream” or “analgesic creams” or prolotherap* or weight or diet or dieting or “cell-based therapy” or “cell-based therapies”)

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science – Indexes=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, CCR-EXPANDED, IC 1/1/2006–12/2/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

### GLUCOSAMINE:

TOPIC: (osteoarthritis and (knee or knees or patellofemoral or patello-femoral)

AND

TOPIC: (glucosamine or acetylglucosamine or “n-acetylglucosamine” or “n-acetyl-d-glucosamine” or chondroitin)

### NEW THERAPIES:

### DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science – Indexes=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, CCR-EXPANDED, IC 1/1/2006–12/2/2015

### SEARCH STRATEGY:

TS=(osteoarthritis and (knee or knees or patellofemoral or patello-femoral)

AND

TS=(duloxetine* or cymbalta or selective serotonin* or ssnri or milnacipran or savella or venlafaxine or effexor or desvenlafaxine or pristiq or “il-1” or interleukin* or anakinra or canakinumab or “platelet rich plasma” or “platelet-rich plasma” or PRP or “nerve growth factor” or fibroblast growth or shoe wedge* or capsaicin)

### ADDITIONAL THERAPIES:

### DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science Indexes=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, ESCI, CCR-EXPANDED, IC - 1/1/2006–12/14/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

ts=(osteoarthritis) AND ts=(knee or knees or patellofemoral or patello-femoral)

AND

ts=(acupuncture or braces or orthotic* or orthosis or orthoses or “stem cell” or “stem cells” or “physical therapy” or exercis* or “herbal supplement” or “herbal supplements” or transdermal or “topical analgesic” or “topical analgesics” or “analgesic cream” or “analgesic creams” or prolotherap* or weight or diet or dieting or “cell-based therapy” or “cell-based therapies”)

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

Scopus - 1/1/2006–11/6/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

### GLUCOSAMINE:

TITLE-ABS-KEY ( osteoarthritis AND ( knee OR knees OR patellofemoral OR patello-femoral ) )

AND

TITLE-ABS-KEY ( glucosamine OR acetylglucosamine OR “n-acetylglucosamine” OR “n-acetyl-d-glucosamine” OR chondroitin ) )

AND

SUBJAREA ( mult OR agri OR bioc OR immu OR neur OR phar OR mult OR medi OR nurs OR vete OR dent OR heal OR mult OR arts OR busi OR deci OR econ OR psyc OR soci )

### NEW THERAPIES

### DATABASE SEARCHED & TIME PERIOD COVERED:

Scopus - 1/1/2006–12/2/2015

### SEARCH STRATEGY:

TITLE-ABS-KEY ( osteoarthritis AND ( knee OR knees OR patellofemoral OR patello-femoral ) )

AND

SUBJAREA ( mult OR agri OR bioc OR immu OR neur OR phar OR mult OR medi OR nurs OR vete OR dent OR heal OR mult OR arts OR busi OR deci OR econ OR psyc OR soci )

AND

TITLE-ABS-KEY ( duloxetine* OR cymbalta OR selective serotonin* OR ssnri OR milnacipran OR savella OR venlafaxine OR effexor OR desvenlafaxine OR pristiq OR “il-1” OR interleukin* OR anakinra OR canakinumab OR “platelet rich plasma” OR “platelet-rich plasma” OR prp OR ( “nerve growth factor” OR fibroblast growth OR shoe wedge* OR capsaicin )

AND

SUBJAREA ( mult OR agri OR bioc OR immu OR neur OR phar OR mult OR medi OR nurs OR vete OR dent OR heal OR mult OR arts OR busi OR deci OR econ OR psyc OR soci )

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

International Pharmaceutical Abstracts - 6/29/2015–11/18/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGY:

ab(osteoarthritis AND (knee OR knees OR patellofemoral OR patello-femoral)) OR ti(osteoarthritis AND (knee OR knees OR patellofemoral OR patello-femoral)) OR su(osteoarthritis AND (knee OR knees OR patellofemoral OR patello-femoral))

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

AMED (Allied & Complementary Medicine) - 6/29/2015–11/18/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

### GLUCOSAMINE:

ab(osteoarthritis AND (knee OR knees OR patellofemoral OR patello-femoral)) OR ti(osteoarthritis AND (knee OR knees OR patellofemoral OR patello-femoral)) OR su(osteoarthritis AND (knee OR knees OR patellofemoral OR patello-femoral))

AND

ab(glucosamine OR acetylglucosamine OR “n-acetylglucosamine” OR “n-acetyl-d-glucosamine” OR chondroitin) OR ti(glucosamine OR acetylglucosamine OR “n-acetylglucosamine” OR “n-acetyl-d-glucosamine” OR chondroitin) OR su(glucosamine OR acetylglucosamine OR “n-acetylglucosamine” OR “n-acetyl-d-glucosamine” OR chondroitin)

### NEW THERAPIES:

### DATABASE SEARCHED & TIME PERIOD COVERED:

AMED (Allied & Complementary Medicine) - 6/29/2015–11/18/2015

### SEARCH STRATEGY:

ab(osteoarthritis AND (knee OR knees OR patellofemoral OR patello-femoral)) OR ti(osteoarthritis AND (knee OR knees OR patellofemoral OR patello-femoral)) OR su(osteoarthritis AND (knee OR knees OR patellofemoral OR patello-femoral)

AND

ab(duloxetine* or cymbalta or selective serotonin* or ssnri or milnacipran or savella or venlafaxine or effexor or desvenlafaxine or pristiq or “il-1” or interleukin* or anakinra or canakinumab or “platelet rich plasma” or “platelet-rich plasma” or PRP or “nerve growth factor” or fibroblast growth or shoe wedge* or capsaicin) OR ti(duloxetine* or cymbalta or selective serotonin* or ssnri or milnacipran or savella or venlafaxine or effexor or desvenlafaxine or pristiq or “il-1” or interleukin* or anakinra or canakinumab or “platelet rich plasma” or “platelet-rich plasma” or PRP or “nerve growth factor” or fibroblast growth or shoe wedge* or capsaicin) OR su(duloxetine* or cymbalta or selective serotonin* or ssnri or milnacipran or savella or venlafaxine or effexor or desvenlafaxine or pristiq or “il-1” or interleukin* or anakinra or canakinumab or “platelet rich plasma” or “platelet-rich plasma” or PRP or “nerve growth factor” or fibroblast growth or shoe wedge* or capsaicin)

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

ClinicalTrials.gov – 1/1/2006–11/10/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

### GLUCOSAMINE:

KEYWORD :knee OR knees OR patellofemoral OR patello-femoral

AND

CONDITION:osteoarthritis

AND

INTERVENTION: glucosamine OR acetylglucosamine OR “n-acetylglucosamine” OR “n-acetyl-d-glucosamine” OR chondroitin

### NEW THERAPIES:

KEYWORD:knee OR knees OR patellofemoral OR patello-femoral

AND

CONDITION:osteoarthritis

AND

INTERVENTION:duloxetine OR cymbalta OR selective serotonin OR ssnri OR milnacipran OR savella OR venlafaxine OR effexor OR desvenlafaxine OR pristiq OR “il-1” OR interleukin OR anakinra OR canakinumab OR “platelet rich plasma” OR “platelet-rich plasma” OR PRP OR “nerve growth factor” OR fibroblast growth OR shoe wedge OR shoe wedges OR capsaicin

### ADDITIONAL THERAPIES:

### DATABASE SEARCHED & TIME PERIOD COVERED:

ClinicalTrials.gov - 1/1/2006–12/21/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

KEYWORD: knee OR knees OR patellofemoral OR patello-femoral

CONDITION: osteoarthritis

INTERVENTION: acupuncture OR stem cell OR stem cells OR physical therapy OR diet OR diets OR nutrition OR nutritional OR weight OR obese OR obesity OR dietary supplements OR transdermal OR patch OR plant OR plants OR exercise OR exercising OR topical analgesic OR topical analgesics OR analgesic cream OR analgesic creams OR brace OR braces OR orthotic OR orthotics OR orthosis OR orthoses OR herbal supplement OR herbal supplements OR prolotherapy or prolotherapies OR prolotherapeutic OR cell-based

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

PEDRO - 1/1/2006–12/11/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGIES:

Abstract & Title: Osteoarthritis

AND

Abstract & Title: knee

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

WHO International Clinical Trials Registry - 1/1/2006–12/15/2015

### LANGUAGE:

English OR Non-English with English Abstract

### SEARCH STRATEGY:

CONDITION: Osteoarthritis AND knee

## UPDATE SEARCHES IN SEPTEMBER 2016 FOR THE REPORT:

### DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 1/1/2015–9/20/2016

### LANGUAGE:

English and Non-English with English abstracts

### TOPIC 1 – GLUCOSAMINE:

### SEARCH STRATEGY:

“osteoarthritis, knee”[MH] OR (“osteoarthritis”[MH] AND (knee[tiab] OR knees[tiab])) OR (osteoarthritis*[tiab] AND (knee[tiab] OR knees[tiab])) OR (“osteoarthritis”[MH] AND (patellofemoral[tiab] OR patello-femoral[tiab]))

AND

Glucosamine[MH] OR “Chondroitin”[MH] OR glucosamine OR acetylglucosamine OR “n-acetylglucosamine” OR “n-acetyl-d-glucosamine” OR chondroitin

### TOPIC 2 – ADDITIONAL THERAPIES

### SEARCH STRATEGY:

### SEARCH STRATEGY:

“osteoarthritis, knee”[MH] OR (“osteoarthritis”[MH] AND (knee[tiab] OR knees[tiab])) OR (osteoarthritis*[tiab] AND (knee[tiab] OR knees[tiab])) OR (“osteoarthritis”[MH] AND (patellofemoral[tiab] OR patello-femoral[tiab]))

AND

braces OR orthotic* OR orthosis OR orthoses OR stem cell* OR physical therapy OR exercis* OR weight loss OR losing weight OR diet OR dieting OR weight reduc* OR cell-based therap* OR “Orthotic Devices”[Mesh] OR “Stem Cells”[Mesh] OR “Physical Therapy Modalities”[Mesh] OR “Exercise Movement Techniques”[Mesh] OR “Exercise Therapy”[Mesh] OR “Weight Loss”[Mesh] OR “Diet, Reducing”[Mesh] OR “Weight Reduction Programs”[Mesh] OR dietary supplements[mh] OR (administration, topical[mh] AND analgesics[mh])

### TOPIC 3 – NEW THERAPIES

### SEARCH STRATEGY:

“osteoarthritis, knee”[MH] OR (“osteoarthritis”[MH] AND (knee[tiab] OR knees[tiab])) OR (osteoarthritis*[tiab] AND (knee[tiab] OR knees[tiab])) OR (“osteoarthritis”[MH] AND (patellofemoral[tiab] OR patello-femoral[tiab]))

AND

“platelet rich plasma” OR “platelet-rich plasma” OR PRP OR fibroblast growth OR shoe wedge*

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

Embase – 1/1/2015–9/20/2016

### LANGUAGE:

English and Non-English with English abstracts

### TOPIC 1 – GLUCOSAMINE:

### SEARCH STRATEGY:

‘knee osteoarthritis’/exp OR ‘knee osteoarthritis’ OR ((‘osteoarthritis’ OR ‘osteoarthritis’/exp OR osteoarthritis) AND (‘knee’ OR ‘knee’/exp OR knee OR knees OR patellofemoral OR ‘patello femoral’))

AND

‘chondroitin’ OR ‘chondroitin’/exp OR chondroitin OR ‘glucosamine’ OR ‘glucosamine’/exp OR glucosamine OR ‘acetylglucosamine’ OR ‘acetylglucosamine’/exp OR acetylglucosamine OR ‘n-acetylglucosamine’/exp OR ‘n-acetylglucosamine’ OR ‘n-acetyl-d-glucosamine’/exp OR ‘n-acetyl-d-glucosamine’

AND

[humans]/lim

### TOPIC 2 – ADDITIONAL THERAPIES

### SEARCH STRATEGY:

‘knee osteoarthritis’/exp OR ‘knee osteoarthritis’ OR ((‘osteoarthritis’ OR ‘osteoarthritis’/exp OR osteoarthritis) AND (‘knee’ OR ‘knee’/exp OR knee OR knees OR patellofemoral OR ‘patello femoral’))

AND

‘braces’ OR ‘braces’/exp OR braces OR orthotic* OR ‘orthosis’ OR ‘orthosis’/exp OR orthosis OR ‘orthoses’ OR ‘orthoses’/exp OR orthoses OR (stem AND cell*) OR (physical AND (‘therapy’ OR ‘therapy’/exp OR therapy)) OR exercis* OR supplement* OR prolotherap* OR (‘weight’ OR ‘weight’/exp OR weight AND (loss OR losing)) OR ‘diet’ OR ‘diet’/exp OR diet OR ‘dieting’ OR ‘dieting’/exp OR dieting OR (‘weight’ OR ‘weight’/exp OR weight AND reduc*) OR (‘cell based’ AND therap*)

AND

[humans]/lim

### TOPIC 3 – NEW THERAPIES

### SEARCH STRATEGY:

‘knee osteoarthritis’/exp OR ‘knee osteoarthritis’ OR ((‘osteoarthritis’ OR ‘osteoarthritis’/exp OR osteoarthritis) AND (‘knee’ OR ‘knee’/exp OR knee OR knees OR patellofemoral OR ‘patello femoral’))

AND

‘platelet rich plasma’/exp OR ‘platelet rich plasma’ OR ‘platelet-rich plasma’/exp OR ‘platelet-rich plasma’ OR ‘prp’ OR ‘prp’/exp OR prp OR (‘fibroblast’ OR ‘fibroblast’/exp OR (fibroblast AND (‘growth’ OR ‘growth’/exp OR growth)) OR ((‘shoe’ OR ‘shoe’/exp OR shoe) AND wedge*)

AND

[humans]/lim

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

Cochrane – 1/1/2015–9/20/2016

### LANGUAGE:

English and Non-English with English abstracts

### TOPIC 1 – GLUCOSAMINE:

### SEARCH STRATEGY:

osteoarthritis and (knee or knees or patellofemoral or patello-femoral):ti,ab,kw

AND

glucosamine or acetylglucosamine or “n-acetylglucosamine” or “n-acetyl-d-glucosamine” or chondroitin:ti,ab,kw

### TOPIC 2 – ADDITIONAL THERAPIES

### SEARCH STRATEGY:

osteoarthritis and (knee or knees or patellofemoral or patello-femoral):ti,ab,kw

AND

braces or orthotic* or orthosis or orthoses or “stem cell” or “stem cells” or “physical therapy” or exercis* or prolotherap* or weight or diet or dieting or “cell-based therapy” or “cell-based therapies”:ti,ab,kw

### TOPIC 3 – NEW THERAPIES

### SEARCH STRATEGY:

osteoarthritis and (knee or knees or patellofemoral or patello-femoral):ti,ab,kw

AND

“platelet rich plasma” or “platelet-rich plasma” or PRP or fibroblast growth or shoe wedge*:ti,ab,kw

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

CINAHL – 1/1/2015–9/20/2016

### LANGUAGE:

English and Non-English with English abstracts

### TOPIC 1 – GLUCOSAMINE:

### SEARCH STRATEGY:

TI ( osteoarthritis AND (knee or knees or patellofemoral or patello-femoral )) OR AB ( osteoarthritis AND (knee or knees or patellofemoral or patello-femoral )) OR MW ( osteoarthritis AND (knee or knees or patellofemoral or patello-femoral) )

AND

TI ( glucosamine or acetylglucosamine or “n-acetylglucosamine” or “n-acetyl-d-glucosamine” or chondroitin ) OR AB ( glucosamine or acetylglucosamine or “n-acetylglucosamine” or “n-acetyl-d-glucosamine” or chondroitin ) OR MW ( glucosamine or acetylglucosamine or “n-acetylglucosamine” or “n-acetyl-d-glucosamine” or chondroitin )

### TOPIC 2 – ADDITIONAL THERAPIES

### SEARCH STRATEGY:

TI ( osteoarthritis AND (knee or knees or patellofemoral or patello-femoral )) OR AB ( osteoarthritis AND (knee or knees or patellofemoral or patello-femoral )) OR MW ( osteoarthritis AND (knee or knees or patellofemoral or patello-femoral) )

AND

TI ( braces or orthotic* or orthosis or orthoses or “stem cell” or “stem cells” or “physical therapy” or exercis* or weight or diet or dieting or “cell-based therapy” or “cell-based therapies” ) OR AB ( braces or orthotic* or orthosis or orthoses or “stem cell” or “stem cells” or “physical therapy” or exercis* or weight or diet or dieting or “cell-based therapy” or “cell-based therapies” ) OR MW (( braces or orthotic* or orthosis or orthoses or “stem cell” or “stem cells” or “physical therapy” or exercis* or weight or diet or dieting or “cell-based therapy” or “cell-based therapies” )

### TOPIC 3 – NEW THERAPIES

### SEARCH STRATEGY:

TI ( osteoarthritis AND (knee or knees or patellofemoral or patello-femoral )) OR AB ( osteoarthritis AND (knee or knees or patellofemoral or patello-femoral )) OR MW ( osteoarthritis AND (knee or knees or patellofemoral or patello-femoral) )

AND

TI ( platelet rich plasma” or “platelet-rich plasma” or PRP OR fibroblast growth or shoe wedge* ) OR AB ( “platelet rich plasma” or “platelet-rich plasma” or PRP OR fibroblast growth or shoe wedge* ) OR MW (“platelet rich plasma” or “platelet-rich plasma” or PRP OR fibroblast growth or shoe wedge* )

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science – 1/1/2015–9/20/2016

### LANGUAGE:

English and Non-English with English abstracts

### TOPIC 1 – GLUCOSAMINE:

### SEARCH STRATEGY:

TS=(osteoarthritis and (knee or knees or patellofemoral or patello-femoral))

AND

TS=(glucosamine or acetylglucosamine or “n-acetylglucosamine” or “n-acetyl-d-glucosamine” or chondroitin)

### TOPIC 2 – ADDITIONAL THERAPIES

### SEARCH STRATEGY:

TS=(osteoarthritis and (knee or knees or patellofemoral or patello-femoral))

AND

ts=(braces or orthotic* or orthosis or orthoses or “stem cell” or “stem cells” or “physical therapy” or exercis* or prolotherap* or weight or diet or dieting or “cell-based therapy” or “cell-based therapies”)

### TOPIC 3 – NEW THERAPIES

### SEARCH STRATEGY:

TS=(osteoarthritis and (knee or knees or patellofemoral or patello-femoral))

AND

ts=(“platelet rich plasma” or “platelet-rich plasma” or PRP or fibroblast growth or shoe wedge*)

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

Scopus – 1/1/2015–9/20/2016

### LANGUAGE:

English and Non-English with English abstracts

### TOPIC 1 – GLUCOSAMINE:

### SEARCH STRATEGY:

TITLE-ABS-KEY ( osteoarthritis AND ( knee OR knees OR patellofemoral OR patello-femoral ) )

AND

TITLE-ABS-KEY ( glucosamine OR acetylglucosamine OR “n-acetylglucosamine” OR “n-acetyl-d-glucosamine” OR chondroitin)

### TOPIC 2 – ADDITIONAL THERAPIES

### SEARCH STRATEGY:

TITLE-ABS-KEY ( osteoarthritis AND ( knee OR knees OR patellofemoral OR patello-femoral ) )

AND

TITLE-ABS-KEY ( braces OR orthotic* OR orthosis OR orthoses OR “stem cell” OR “stem cells” OR “physical therapy” OR exercis* OR weight OR diet OR dieting OR “cell-based therapy” OR “cell-based therapies”)

### TOPIC 3 – NEW THERAPIES

### SEARCH STRATEGY:

TITLE-ABS-KEY ( osteoarthritis AND ( knee OR knees OR patellofemoral OR patello-femoral ) )

AND

TITLE-ABS-KEY ( “platelet rich plasma” OR “platelet-rich plasma” OR prp OR fibroblast growth OR shoe wedge* )

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

International Pharmaceutical Abstracts – 1/1/2015–9/20/2016

### LANGUAGE:

English and Non-English with English abstracts

### SEARCH STRATEGY:

ab(osteoarthritis AND (knee OR knees OR patellofemoral OR patello-femoral)) OR ti(osteoarthritis AND (knee OR knees OR patellofemoral OR patello-femoral)) OR su(osteoarthritis AND (knee OR knees OR patellofemoral OR patello-femoral))

Include medical synonyms

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

AMED – 1/1/2015–9/20/2016

### LANGUAGE:

English and Non-English with English abstracts

### SEARCH STRATEGY:

ab(osteoarthritis AND (knee OR knees OR patellofemoral OR patello-femoral)) OR ti(osteoarthritis AND (knee OR knees OR patellofemoral OR patello-femoral)) OR su(osteoarthritis AND (knee OR knees OR patellofemoral OR patello-femoral))

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

ClinicalTrials.gov – 1/1/2015–9/20/2016

### LANGUAGE:

English and Non-English with English abstracts

### TOPIC 1 – GLUCOSAMINE:

### SEARCH STRATEGY:

knee OR knees OR patellofemoral OR patello-femoral | osteoarthritis | glucosamine OR acetylglucosamine OR “n-acetylglucosamine” OR “n-acetyl-d-glucosamine” OR chondroitin | Studies received from 01/01/2015 to 09/20/2016

### TOPIC 3 – NEW THERAPIES:

knee OR knees OR patellofemoral OR patello-femoral | osteoarthritis | “platelet rich plasma” OR “platelet-rich plasma” OR PRP OR fibroblast growth OR shoe wedge OR shoe wedges | Studies received from 01/01/2015 to 09/20/2016

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

PEDRO – 1/1/2015–9/20/2016

### LANGUAGE:

English and Non-English with English abstracts

### SEARCH STRATEGY:

ABSTRACT & TITLE: osteoarthritis AND knee*

=========================================================================

### DATABASE SEARCHED & TIME PERIOD COVERED:

World Health Organization ICTR – 1/1/2015–9/20/2016

### LANGUAGE:

English and Non-English with English abstracts

### SEARCH STRATEGY:

TITLE: Knee

CONDITION: Osteoarthritis

DATE OF REGISTRATION – BETWEEN 2015–2016