# Abbreviations/Acronyms

AAOS: American Academy of Orthopaedic Surgeons
ACR: American College of Rheumatology
ADL: Activities of Daily Living
AHRQ: Agency for Healthcare Research and Quality
BWM: behavioral weight management
CI: confidence intervals
EPC: Evidence-based Practice Center
FDA: Food and Drug Administration
HRQoL: Health-related Quality of Life
K-L: Kellgren-Lawrence
MCID: minimum clinically important difference
MCII: minimum clinically important improvement;
MD: mean difference
MRI: Magnetic resonance imaging
N/A: not applicable
NMES: neuromuscular electrical stimulation
N/R: not reported
NRS: Numeric Rating Scale
PCST: pain coping skills training
PEMF: Pulsed Electromagnetic Field Therapy
PICOT: Participants, interventions, comparators, outcomes, timing
PRP: Platelet-rich Plasma
QoL: quality of life
RCT: randomized controlled trial
RoB: risk of bias
SF: short form
SMD: standardized mean difference
SoE: strength of evidence
ST: strength training
TENS: transcutaneous electrical nerve stimulation
TUG: timed up and go
U/S: Ultrasound
VAS: visual analog scale
WBV: whole-body vibration
WOMAC: Western Ontario and McMaster Universities Osteoarthritis Index