# References and Included Studies

(Note: There is a separate set of references at the end of Appendix G whose reference numbers are different from those in the text of the report.)

1 American Cancer Society (ACS). Cancer facts and figures 2003. Atlanta, GA. American Cancer Society (ACS). 2003. Available at: http://www.cancer.org/docroot/STT/stt_0.asp.
2 American Cancer Society (ACS). Cancer facts & figures 2009. Atlanta, GA. American Cancer Society (ACS). 2009. Available at: http://www.cancer.org/downloads/STT/500809web.pdf.
3 National Cancer Institute. Surveillance Epidemiology and End Results. SEER stat fact sheets—cancer of the breast. Available at: http://seer.cancer.gov/statfacts/html/breast_print.html. Accessed February 5, 2007.
4 Feuer EJ, Wun LM. DEVCAN: probability of developing or dying of cancer software, version 4.1. Available at: http://canques.seer.cancer.gov/cgi-bin/cq_submit?dir-devcan1999&db=1&rpt=TAB&sel=. Accessed May 28 2002.
5 Levine P, Simsir A, Cangiarella J. Management issues in breast lesions diagnosed by fine-needle aspiration and percutaneous core breast biopsy. Am J Clin Pathol. Jun. 2006;125(Suppl):S124-S134. PMID: 16830962. [pmid: 16830962].
6 American Cancer Society (ACS). Cancer facts & figures 2008. Atlanta, GA. American Cancer Society (ACS). 2008. Available at: http://www.cancer.org/downloads/STT/2008CAFFfinalsecured.pdf.
7 U.S. Preventive Services Task Force (USPSTF). Screening for breast cancer: recommendations and rationale. Washington, DC. Agency for Healthcare Research and Quality. February. 2002. AHRQ Publication No. 02–507A. Available at: http://www.ahrq.gov/clinic/3rduspstf/breastcancer.
8 Humphrey LL, Helfand M, Chan BK, et al. Breast cancer screening: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Sep. 3. 2002;137(5 Part 1):347-367. PMID: 12204020. [pmid: 12204020].
9 Rosato FE, Rosato EL. Bland KI, Copeland EM 3rd, editors. Examination techniques: roles of the physician and patient in evaluating breast diseases. The breast: comprehensive management of benign and malignant diseases. 2. Philadelphia, PA. W.B. Saunders Company. 1998;1:615-623.
10 U.S. Preventive Services Task Force. Screening for breast cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. Nov. 17. 2009;151(10):716-726. W236. PMID: 19920272. [pmid: 19920272].
11 Liberman L, Menell JH. Breast imaging reporting and data system (BI-RADS). Radiol Clin North Am. May. 2002;40(3):409-430. PMID: 12117184. [pmid: 12117184].
12 Diagnostic and Interventional Radiology Department. Mammography. Omaha, NE. Creighton University School of Medicine. Available at: http://radiology.creighton.edu/mammo.html.
13 Obenauer S, Hermann KP, Grabbe E. Applications and literature review of the BI-RADS classification. Eur Radiol. May. 2005;15(5):1027-1036. PMID: 15856253. [pmid: 15856253].
14 Wallis M, Tardivon A, Helbich T, et al. Guidelines from the European Society of Breast Imaging for diagnostic interventional breast procedures. Eur Radiol. Feb. 2007;17(2):581-588. PMID: 17013595. [pmid: 17013595].
15 Lacquement MA, Mitchell D, Hollingsworth AB. Positive predictive value of the Breast Imaging Reporting and Data System. J Am Coll Surg. Jul. 1999;189(1):34-40. PMID: 10401738. [pmid: 10401738].
16 Rakha EA, Ellis IO. An overview of assessment of prognostic and predictive factors in breast cancer needle core biopsy specimens. J Clin Pathol. Dec. 2007;60(12):1300-1306. PMID: 17630399. [pmid: 17630399].
17 American Cancer Society (ACS). Detailed guide: breast cancer. How is breast cancer staged?. Available at: http://www.cancer.org/docroot/CRI/content/CRI_2_4_3X_How_is_breast_cancer_staged_5.asp. Accessed May 25, 2007.
18 NCCN clinical practice guidelines in oncology: breast cancer V.2.2007. Jenkintown, PA. National Comprehensive Cancer Network (NCCN). 2007. Mar. 28.
19 Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making. Apr–Jun. 1991;11(2):88-94. PMID: 1907710. [pmid: 1907710].
20 Deeks JJ. Egger M, Smith GD, Altman DG, editors. Systematic reviews of evaluations of diagnostic and screening tests. Systematic reviews in health care: meta-analysis in context. 2. London, England. BMJ Books. 2001:248-282.
21 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. Sep. 15. 1999;282(11):1061-1066. PMID: 10493205. [pmid: 10493205].
22 Moher D, Pham B, Klassen TP, et al. What contributions do languages other than English make on the results of meta-analyses?. J Clin Epidemiol. Sep. 2000;53(9):964-972. PMID: 11004423. [pmid: 11004423].
23 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. Feb. 2002;31(1):115-123. PMID: 11914306. [pmid: 11914306].
24 Chalmers I, Adams M, Dickersin K, et al. A cohort study of summary reports of controlled trials. JAMA. Mar. 9. 1990;263(10):1401-1405. PMID: 2304219. [pmid: 2304219].
25 Neinstein LS. A review of Society for Adolescent Medicine abstracts and Journal of Adolescent Health Care articles. J Adolesc Health Care. Mar. 1987;8(2):198-203. PMID: 3818406. [pmid: 3818406].
26 Dundar Y, Dodd S, WIlliamson P, et al. Case study of the comparison of data from conference abstracts and full-text articles in health technology assessment of rapidly evolving technologies: does it make a difference?. Int J Technol Assess Health Care. Jul. 2006;22(3):288-294. [pmid: 16984055].
27 De Bellefeuille C, Morrison CA, Tannock IF. The fate of abstracts submitted to a cancer meeting: factors which influence presentation and subsequent publication. Ann Oncol. Mar. 1992;3(3):187-191. PMID: 1586615. [pmid: 1586615].
28 Scherer RW, Langenberg P. Full publication of results initially presented in abstracts. Cochrane Library [Cochrane methodology review]. Oxford. Update Software. 2001;(Issue 2). Available at: http://www.cochrane.org/index.htm. Accessed April 23, 2001.
29 Marx WF, Cloft HJ, Do HM, et al. The fate of neuroradiologic abstracts presented at national meetings in 1993: rate of subsequent publication in peer-reviewed, indexed journals. AJNR Am J Neuroradiol. Jun–Jul. 1999;20(6):1173-1177. PMID: 10445467. [pmid: 10445467].
30 Yentis SM, Campbell FA, Lerman J. Publication of abstracts presented at anaesthesia meetings. Can J Anaesth. Jul. 1993;40(7):632-634. PMID: 8403137. [pmid: 8403137].
31 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3(1):25. PMID: 14606960. [pmid: 14606960].
32 Treadwell JR, Tregear SJ, Reston JT, et al. A system for rating the stability and strength of medical evidence. BMC Med Res Methodol. 2006;6:52. PMID: 17052350. [pmid: 17052350].
33 Rakha EA, El-Sayed ME, Reed J, et al. Screen-detected breast lesions with malignant needle core biopsy diagnoses and no malignancy identified in subsequent surgical excision specimens (potential false-positive diagnosis). Eur J Cancer. May. 2009;45(7):1162-1167. PMID: 19121932. [pmid: 19121932].
34 Harbord RM, Deeks JJ, Egger M, et al. A unification of models for meta-analysis of diagnostic accuracy studies. Biostatistics. Apr. 2007;8(2):239-251. PMID: 16698768. [pmid: 16698768].
35 STATA statistics/data analysis. MP parallel edition. College Station (TX). StataCorp. 1984-2007. Single user Stata for Windows. Available at: http://www.stata.com.
36 Zamora J, Abraira V, Muriel A, et al. Meta-DiSc: a software for meta-analysis of test accuracy data. BMC Med Res Methodol. 2006;6:31. PMID: 16836745. [pmid: 16836745].
37 Borenstein M, Hedges L, Higgins J, et al. Comprehensive meta-analysis. Version 2. Englewood (NJ). Biostat. 2005. Available at: http://www.meta-analysis.com/pages/about_us.html.
38 Deeks J, Macaskill P, Irwig L. Detecting publication bias in systematic reviews of diagnostic test accuracy [abstract O-009]. Cochrane Collaboration [database online]. Oxford (UK). Cochrane Collaboration. 2004. Available at: http://www.cochrane.org/colloquia/abstracts/ottawa/O-009.htm. Accessed May 25, 2005.
39 Deeks J, Macaskill P, Irwig L. By how much does publication bias affect the results of systematic reviews of diagnostic test accuracy? (abstract O-010). Cochrane Collaboration [database online]. Oxford (UK). Cochrane Collaboration. 2004. Available at: http://www.cochrane.org/colloquia/abstracts/ottawa/O-010.htm. Accessed May 25, 2005.
40 Antley CM, Mooney EE, Layfield LJ. A comparison of accuracy rates between open biopsy, cutting-needle biopsy, and fine-needle aspiration biopsy of the breast: A 3-year experience. Breast J. 1998;4(1):3-8.
41 Meyer JE, Kopans DB. Analysis of mammographically obvious carcinomas of the breast with benign results upon initial biopsy. Surg Gynecol Obstet. Oct. 1981;153(4):570-572. PMID: 6269239. [pmid: 6269239].
42 Patchefsky AS, Potok J, Hoch WS, et al. Increased detection of occult breast carcinoma after more thorough histologic examination of breast biopsies. Am J Clin Pathol. Dec. 1973;60(6):799-804. PMID: 4357121. [pmid: 4357121].
43 Grady D, Hodgkins ML, Goodson WH 3rd. The lumpy breast. West J Med. Aug. 1988;149(2):226-229. PMID: 3073579. [pmid: 3073579].
44 Wong TE, Hisham AN. Core needle biopsy of palpable breast lump: the influence of needle size. Med J Malaysia. Aug. 2003;58(3):399-404. PMID: 14750380. [pmid: 14750380].
45 Scopa CD, Koukouras D, Spiliotis J, et al. Comparison of fine needle aspiration and Tru-Cut biopsy of palpable mammary lesions. Cancer Detect Prev. 1996;20(6):620-624. PMID: 8939348. [pmid: 8939348].
46 McMahon AJ, Lutfy AM, Matthew A, et al. Needle core biopsy of the breast with a spring-loaded device. Br J Surg. Oct. 1992;79(10):1042-1045. PMID: 1422715. [pmid: 1422715].
47 Barreto V, Hamed H, Griffiths AB, et al. Automatic needle biopsy in the diagnosis of early breast cancer. Eur J Surg Oncol. Jun. 1991;17(3):237-239. PMID: 2044776. [pmid: 2044776].
48 Cusick JD, Dotan J, Jaecks RD, et al. The role of Tru-Cut needle biopsy in the diagnosis of carcinoma of the breast. Surg Gynecol Obstet. May. 1990;170(5):407-410. PMID: 2183373. [pmid: 2183373].
49 Youk JH, Kim EK, Kim MJ, et al. Sonographically guided 14-gauge core needle biopsy of breast masses: a review of 2420 cases with long-term follow-up. AJR Am J Roentgenol. Jan. 2008;190(1):202-207. PMID: 18094312. [pmid: 18094312].
50 de Lucena CE, Dos Santos JL Junior, de Lima Resende CA, et al. Ultrasound-guided core needle biopsy of breast masses: How many cores are necessary to diagnose cancer?. J Clin Ultrasound. Sep. 2007;35(7):363-366. PMID: 17663457. [pmid: 17663457].
51 Bolivar AV, Alonso-Bartolome P, Garcia EO, et al. Ultrasound-guided core needle biopsy of non-palpable breast lesions: a prospective analysis in 204 cases. Acta Radiol. Nov. 2005;46(7):690-695. PMID: 16372687. [pmid: 16372687].
52 Crystal P, Koretz M, Shcharynsky S, et al. Accuracy of sonographically guided 14-gauge core-needle biopsy: Results of 715 consecutive breast biopsies with at least two-year follow-up of benign lesions. J Clin Ultrasound. Feb. 2005;33(2):47-52. PMID: 15674836. [pmid: 15674836].
53 Sauer G, Deissler H, Strunz K, et al. Ultrasound-guided large-core needle biopsies of breast lesions: Analysis of 962 cases to determine the number of samples for reliable tumour classification. Br J Cancer. Jan. 31. 2005;92(2):231-235. PMID: 15611793. [pmid: 15611793].
54 Delle Chiaie L, Terinde R. Three-dimensional ultrasound-validated large-core needle biopsy: is it a reliable method for the histological assessment of breast lesions. Ultrasound Obstet Gynecol. Apr. 2004;23(4):393-397. PMID: 15065192. [pmid: 15065192].
55 Fishman JE, Milikowski C, Ramsinghani R, et al. US-guided core-needle biopsy of the breast: How many specimens are necessary?. Radiology. Mar. 1. 2003;226(3):779-782. PMID: 12601206. [pmid: 12601206].
56 Philpotts LE, Hooley RJ, Lee CH. Comparison of automated versus vacuum-assisted biopsy methods for sonographically guided core biopsy of the breast. AJR Am J Roentgenol. Feb. 2003;180(2):347-351. PMID: 12540431. [pmid: 12540431].
57 Smith DN, Rosenfield Darling ML, et al. The utility of ultrasonographically guided large-core needle biopsy: results from 500 consecutive breast biopsies. J Ultrasound Med. Jan. 2001;20(1):43-49. PMID: 11149527. [pmid: 11149527].
58 Wunderbaldinger P, Helbich TH, Partik B, et al. First experience with a new dedicated ultrasound system for computer-guided large-core breast biopsy. Eur Radiol. 2001;11(12):2460-2464. PMID: 11734940. [pmid: 11734940].
59 Yeow KM, Lo YF, Wang CS, et al. Ultrasound-guided core needle biopsy as an initial diagnostic test for palpable breast masses. J Vasc Interv Radiol. Nov. 2001;12(11):1313-1317. PMID: 11698631. [pmid: 11698631].
60 Liberman L, Feng TL, Dershaw DD, et al. US-guided core breast biopsy: use and cost-effectiveness. Radiology. Sep. 1998;208(3):717-723. PMID: 9722851. [pmid: 9722851].
61 Schulz-Wendtland R, Kramer S, Lang N, et al. Ultrasonic guided microbiopsy in mammary diagnosis: indications, technique and results. Anticancer Res. May–Jun. 1998;18(3C):2145-2146. PMID: 9703772. [pmid: 9703772].
62 Khattar SC, Torp-Pedersen S, Horn T, et al. Ultrasound-guided biopsy of palpable breast masses. Eur J Ultrasound. 1997;6(1):1-7.
63 Parker SH, Jobe WE, Dennis MA, et al. US-guided automated large-core breast biopsy. Radiology. May. 1993;187(2):507-511. PMID: 8475299. [pmid: 8475299].
64 Schueller G, Jaromi S, Ponhold L, et al. US-guided 14-gauge core-needle breast biopsy: results of a validation study in 1352 cases. Radiology. Aug. 2008;248(2):406-413. PMID: 18641246. [pmid: 18641246].
65 Peters N, Hoorntje L, Mali W, et al. Diagnostic performance of stereotactic large core needle biopsy for nonpalpable breast lesions in routine clinical practice. Int J Cancer. Jan. 15. 2008;122(2):468-471. PMID: 17935136. [pmid: 17935136].
66 Koskela AK, Sudan M, Berg MH, et al. Add-on device for stereotactic core-needle breast biopsy: How many biopsy specimens are needed for a reliable diagnosis?. Radiology. Sep. 2005;236(3):801-809. PMID: 16020555. [pmid: 16020555].
67 Han BK, Choe YH, Ko YH, et al. Stereotactic core-needle biopsy of non-mass calcifications: outcome and accuracy at long-term follow-up. Korean J Radiol. Oct–Dec. 2003;4(4):217-223. PMID: 14726638. [pmid: 14726638].
68 Verkooijen HM. Core Biopsy After Radiological Localisation (COBRA) Study Group. Diagnostic accuracy of stereotactic large-core needle biopsy for nonpalpable breast disease: results of a multicenter prospective study with 95% surgical confirmation. Int J Cancer. Jun. 20. 2002;99(6):853-859. PMID: 12115488. [pmid: 12115488].
69 Becker L, Taves D, McCurdy L, et al. Stereotactic core biopsy of breast microcalcifications: comparison of film versus digital mammography, both using an add-on unit. AJR Am J Roentgenol. Dec. 2001;177(6):1451-1457. PMID: 11717106. [pmid: 11717106].
70 Brenner RJ, Bassett LW, Fajardo LL, et al. Stereotactic core-needle breast biopsy: a multi-institutional prospective trial. Radiology. Mar. 2001;218(3):866-872. PMID: 11230668. [pmid: 11230668].
71 Dahlstrom JE, Jain S. Histological correlation of mammographically detected microcalcifications in stereotactic core biopsies. Pathology. 2001;33(4):444-448. PMID: 11827410. [pmid: 11827410].
72 Levin MF, Papoff WJ, Doan L, et al. Stereotaxic percutaneous core biopsy versus surgical biopsy of nonpalpable breast lesions using a standard mammographic table with an add-on device. Can Assoc Radiol J. 2001;52(1):29-32. PMID: 11247262. [pmid: 11247262].
73 Kirwan SE, Denton ER, Nash RM, et al. Multiple 14G stereotactic core biopsies in the diagnosis of mammographically detected stellate lesions of the breast. Clin Radiol. Oct. 2000;55(10):763-766. PMID: 11052877. [pmid: 11052877].
74 Ward SE, Taves DH, McCurdy LI. Stereotaxic core needle biopsy of breast microcalcifications obtained using a standard mammography table with an add-on unit. Can Assoc Radiol J. Feb. 2000;51(1):10-15. PMID: 10711288. [pmid: 10711288].
75 Jackman RJ, Nowels KW, Rodriguez-Soto J, et al. Stereotactic, automated, large-core needle biopsy of nonpalpable breast lesions: false-negative and histologic underestimation rates after long-term follow-up. Radiology. Mar. 1999;210(3):799-805. PMID: 10207484. [pmid: 10207484].
76 Soo MS, Ghate S, Delong D. Stereotactic biopsy of noncalcified breast lesions: utility of vacuum-assisted technique compared to multipass automated gun technique. Clin Imaging. Nov–Dec. 1999;23(6):347-352. PMID: 10899415. [pmid: 10899415].
77 Doyle AJ, Collins JP, Forkert CD. Decubitus stereotactic core biopsy of the breast: technique and experience. AJR Am J Roentgenol. Mar. 1999;172(3):688-690. PMID: 10063861. [pmid: 10063861].
78 Vega Bolivar A, Ortega Garcia E, Garijo Ayensa F. Stereotaxic core needle aspiration biopsy with multiple passes in nonpalpable breast lesions. Acta Radiol. Jul. 1998;39(4):389-394. PMID: 9685825. [pmid: 9685825].
79 Whitman GJ, Kopans DB, McCarthy KA, et al. Coaxial core needle biopsy under mammographic guidance: indications and applications. AJR Am J Roentgenol. 1998;171(1):67-70. PMID: 9648766. [pmid: 9648766].
80 Zannis VJ, Aliano KM. The evolving practice pattern of the breast surgeon with disappearance of open biopsy for nonpalpable lesions. Am J Surg. Dec. 1998;176(6):525-528. PMID: 9926783. [pmid: 9926783].
81 Bauer RL, Sung J, Eckhert KH Jr, et al. Comparison of histologic diagnosis between stereotactic core needle biopsy and open surgical biopsy. Ann Surg Oncol. Jun. 1997;4(4):316-320. PMID: 9181231. [pmid: 9181231].
82 Liberman L, Dershaw DD, Glassman JR, et al. Analysis of cancers not diagnosed at stereotactic core breast biopsy. Radiology. Apr. 1997;203(1):151-157. PMID: 9122384. [pmid: 9122384].
83 Pitre B, Baron PL, Baron LF, et al. Stereotactic core biopsy of the breast: Results of one-year follow-up of 101 patients. Am Surg. 1997;63(12):1124-1127. PMID: 9393264. [pmid: 9393264].
84 Sutton S, Dahlstrom JE, Jain S. Stereotactic large-gauge core biopsy: its role in the diagnosis of non-palpable mammographic abnormalities presenting to a screening service. Australas Radiol. May. 1997;41(2):103-108. PMID: 9153803. [pmid: 9153803].
85 Walker TM. Impalpable breast lesions: Stereotactic core biopsy with an ‘add-on’ unit. Breast. Jun. 1997;6(3):126-131.
86 Frazee RC, Roberts JW, Symmonds RE, et al. Open versus stereotactic breast biopsy. Am J Surg. Nov. 1996;172(5):491-493. 494. 495. PMID: 8942551. [pmid: 8942551].
87 Fuhrman G, Cederbom G, Champagne J, et al. Stereotactic core needle breast biopsy is an accurate diagnostic technique to assess nonpalpable mammographic abnormalities. J La State Med Soc. Apr. 1996;148(4):167-170. PMID: 8935619. [pmid: 8935619].
88 Head JF, Haynes AE, Elliott MC, et al. Stereotaxic localization and core needle biopsy of nonpalpable breast lesions: two-year follow-up of a prospective study. Am Surg. Dec. 1996;62(12):1018-1023. PMID: 8955240. [pmid: 8955240].
89 Mainiero MB, Philpotts LE, Lee CH, et al. Stereotaxic core needle biopsy of breast microcalcifications: correlation of target accuracy and diagnosis with lesion size. Radiology. Mar. 1996;198(3):665-669. PMID: 8628852. [pmid: 8628852].
90 Meyer JE, Christian RL, Lester SC, et al. Evaluation of nonpalpable solid breast masses with stereotaxic large- needle core biopsy using a dedicated unit. AJR Am J Roentgenol. 1996;167(1):179-182. [pmid: 8659367].
91 Pettine S, Place R, Babu S, et al. Stereotactic breast biopsy is accurate, minimally invasive, and cost effective. Am J Surg. May. 1996;171(5):474-476. PMID: 8651388. [pmid: 8651388].
92 Rosenblatt R, Fineberg SA, Sparano JA, et al. Stereotactic core needle biopsy of multiple sites in the breast: efficacy and effect on patient care. Radiology. Oct. 1996;201(1):67-70. PMID: 8816522. [pmid: 8816522].
93 Cross MJ, Evans WP, Peters GN, et al. Stereotactic breast biopsy as an alternative to open excisional biopsy. Ann Surg Oncol. May. 1995;2(3):195-200. PMID: 7641014. [pmid: 7641014].
94 Gisvold JJ, Goellner JR, Grant CS, et al. Breast biopsy: a comparative study of stereotaxically guided core and excisional techniques. AJR Am J Roentgenol. Apr. 1994;162(4):815-820. PMID: 8140997. [pmid: 8140997].
95 Smyth AT, Cederbom GJ. Core biopsy of breast lesions. J La State Med Soc. Nov. 1994;146(11):499-501. PMID: 7806950. [pmid: 7806950].
96 Elvecrog EL, Lechner MC, Nelson MT. Nonpalpable breast lesions: correlation of stereotaxic large-core needle biopsy and surgical biopsy results. Radiology. Aug. 1993;188(2):453-455. PMID: 8327696. [pmid: 8327696].
97 Parker SH, Lovin JD, Jobe WE, et al. Stereotactic breast biopsy with a biopsy gun. Radiology. Sep. 1990;176(3):741-747. PMID: 2167501. [pmid: 2167501].
98 Vag T, Pfleiderer SO, Bottcher J, et al. Ultrasound-guided breast biopsy using a 10-gauge self-contained vacuum-assisted device. Eur Radiol. Dec. 2007;17(12):3100-3102. PMID: 17639409. [pmid: 17639409].
99 Wu YK, Huang YM, Chou AS, et al. Management of breast fibroadenomas by ultrasound-guided vacuum-assisted biopsy - Three years experience. Tzu Chi Med J. Dec. 2005;17(6):405-408, 52.
100 Alonso-Bartolome P, Vega-Bolivar A, Torres-Tabanera M, et al. Sonographically guided 11-G directional vacuum-assisted breast biopsy as an alternative to surgical excision: utility and cost study in probably benign lesions. Acta Radiol. Jul. 2004;45(4):390-396. PMID: 15323390. [pmid: 15323390].
101 March DE, Coughlin BF, Barham RB, et al. Breast masses: Removal of all US evidence during biopsy by using a handheld vacuum-assisted device— Initial experience. Radiology. May. 1. 2003;227(2):549-555. PMID: 12676972. [pmid: 12676972].
102 Johnson AT, Henry-Tillman RS, Smith LF, et al. Percutaneous excisional breast biopsy. Am J Surg. Dec. 2002;184(6):550-554. discussion 554. PMID: 12488164. [pmid: 12488164].
103 Perez-Fuentes JA, Longobardi IR, Acosta VF, et al. Sonographically guided directional vacuum-assisted breast biopsy: preliminary experience in Venezuela. AJR Am J Roentgenol. Dec. 2001;177(6):1459-1463. PMID: 11717107. [pmid: 11717107].
104 Tonegutti M, Girardi V. Stereotactic vacuum-assisted breast biopsy in 268 nonpalpable lesions. Radiol Med. Feb. 2008;113(1):65-75. PMID: 18338128. [pmid: 18338128].
105 Uematsu T, Yuen S, Kasami M, et al. Dynamic contrast-enhanced MR imaging in screening detected microcalcification lesions of the breast: is there any value?. Breast Cancer Res Treat. Jul. 2007;103(3):269-281. PMID: 17063274. [pmid: 17063274].
106 Chapellier C, Balu-Maestro C, Amoretti N, et al. Vacuum-assisted breast biopsies: Experience at the Antoine Lacassagne Cancer Center (Nice, France). Clin Imaging. Mar. 2006;30(2):99-107. PMID: 16500540. [pmid: 16500540].
107 Dhillon MS, Bradley SA, England DW. Mammotome biopsy: Impact on preoperative diagnosis rate. Clin Radiol. Mar. 2006;61(3):276-281. PMID: 16488210. [pmid: 16488210].
108 Weber WP, Zanetti R, Langer I, et al. Mammotome: Less invasive than ABBI with similar accuracy for early breast cancer detection. World J Surg. Apr. 2005;29(4):495-499. PMID: 15770379. [pmid: 15770379].
109 Kubota K, Gomi N, Wakita T, et al. Magnetic resonance imaging of the metal clip in a breast: safety and its availability as a negative marker. Breast Cancer. 2004;11(1):55-59. PMID: 14718794. [pmid: 14718794].
110 Lomoschitz FM, Helbich TH, Rudas M, et al. Stereotactic 11-gauge vacuum-assisted breast biopsy: influence of number of specimens on diagnostic accuracy. Radiology. Sep. 2004;232(3):897-903. PMID: 15273332. [pmid: 15273332].
111 Ambrogetti D, Bianchi S, Ciatto S. Accuracy of percutaneous core biopsy of isolated breast microcalcifications identified by mammography. Experience with a vacuum-assisted large-core biopsy device. Radiol Med. Oct. 2003;106(4):313-319. PMID: 14612823. [pmid: 14612823].
112 Apesteguia L, Mellado M, Saenz J, et al. Vacuum-assisted breast biopsy on digital stereotaxic table of nonpalpable lesions non-recognisable by ultrasonography. Eur Radiol. Mar. 2002;12(3):638-645. PMID: 11870480. [pmid: 11870480].
113 Georgian-Smith D, D’Orsi C, Morris E, et al. Stereotactic biopsy of the breast using an upright unit, a vacuum-suction needle, and a lateral arm-support system. AJR Am J Roentgenol. Apr. 2002;178(4):1017-1024. Available at: http://www.ajronline.org. PMID: 11906893.
114 Liberman L, Kaplan JB, Morris EA, et al. To excise or to sample the mammographic target: what is the goal of stereotactic 11-gauge vacuum-assisted breast biopsy. AJR Am J Roentgenol. Sep. 2002;179(3):679-683. PMID: 12185043. [pmid: 12185043].
115 Meloni GB, Becchere MP, Soro D, et al. Percutaneous vacuum-assisted core breast biopsy with upright stereotactic equipment. Indications, limitations and results. Acta Radiol. Nov. 2002;43(6):575-578. PMID: 12485254. [pmid: 12485254].
116 Morris EA, Liberman L, Trevisan SG, et al. Histologic heterogeneity of masses at percutaneous breast biopsy. Breast J. Jul–Aug. 2002;8(4):187-191. PMID: 12100109. [pmid: 12100109].
117 Pfarl G, Helbich TH, Riedl CC, et al. Stereotactic 11-gauge vacuum-assisted breast biopsy: a validation study. AJR Am J Roentgenol. Dec. 2002;179(6):1503-1507. PMID: 12438044. [pmid: 12438044].
118 Cangiarella J, Waisman J, Symmans WF, et al. Mammotome core biopsy for mammary microcalcification: analysis of 160 biopsies from 142 women with surgical and radiologic followup. Cancer. Jan. 1. 2001;91(1):173-177. PMID: 11148574. [pmid: 11148574].
119 Lai JT, Burrowes P, MacGregor JH. Diagnostic accuracy of a stereotaxically guided vacuum-assisted large-core breast biopsy program in Canada. Can Assoc Radiol J. Aug. 2001;52(4):223-227. PMID: 11512293. [pmid: 11512293].
120 Beck RM, Gotz L, Heywang-Kobrunner SH. Stereotaxic vacuum core breast biopsy—experience of 560 patients. Swiss Surg. 2000;6(3):108-110. PMID: 10894010. [pmid: 10894010].
121 Heywang-Kobrunner SH, Schaumloffel U, Viehweg P, et al. Minimally invasive stereotaxic vacuum core breast biopsy. Eur Radiol. 1998;8(3):377-385. PMID: 9510569. [pmid: 9510569].
122 Sim LS, Kei PL. Upright stereotactic vacuum-assisted needle biopsy of suspicious breast microcalcifications. J Med Imaging Radiat Oncol. Aug. 2008;52(4):358-364. PMID: 18811759. [pmid: 18811759].
123 Jackman RJ, Marzoni FA Jr, Rosenberg J. False-negative diagnoses at stereotactic vacuum-assisted needle breast biopsy: long-term follow-up of 1,280 lesions and review of the literature. AJR Am J Roentgenol. Feb. 2009;192(2):341-351. PMID: 19155393. [pmid: 19155393].
124 Pfleiderer SOR, Reichenbach JR, Azhari T, et al. A manipulator system for 14-gauge large core breast biopsies inside a high-field whole-body MR scanner. J Magn Reson Imaging. Apr. 1. 2003;17(4):493-498. [pmid: 12655591].
125 Puglisi F, Pertoldi B, Ramello M, et al. Diagnostic accuracy of perforated compression grid approach for mammographically guided core needle biopsy of breast lesions. Cancer Lett. Nov. 15. 1999;146(2):181-188. PMID: 10656624. [pmid: 10656624].
126 Ciatto S, Houssami N, Ambrogetti D, et al. Accuracy and underestimation of malignancy of breast core needle biopsy: the Florence experience of over 4000 consecutive biopsies. Breast Cancer Res Treat. Mar. 2007;101(3):291-297. PMID: 16823506. [pmid: 16823506].
127 Cipolla C, Fricano S, Vieni S, et al. Validity of needle core biopsy in the histological characterisation of mammary lesions. Breast. Feb. 2006;15(1):76-80. PMID: 16473738. [pmid: 16473738].
128 Dillon MF, Hill AD, Quinn CM, et al. The accuracy of ultrasound, stereotactic, and clinical core biopsies in the diagnosis of breast cancer, with an analysis of false-negative cases. Ann Surg. Nov. 2005;242(5):701-707. PMID: 16244544. [pmid: 16244544].
129 Fajardo LL, Pisano ED, Caudry DJ, et al. Radiologist Investigators of the Radiologic Diagnostic Oncology Group V. Stereotactic and sonographic large-core biopsy of nonpalpable breast lesions: results of the Radiologic Diagnostic Oncology Group V study. Acad Radiol. Mar. 2004;11(3):293-308. PMID: 15035520. [pmid: 15035520].
130 Abdsaleh S, Azavedo E, Lindgren PG. Semiautomatic core biopsy. A modified biopsy technique in breast diseases. Acta Radiol. Jan. 2003;44(1):47-51. PMID: 12630998. [pmid: 12630998].
131 Kirshenbaum KJ, Voruganti T, Overbeeke C, et al. Stereotactic core needle biopsy of nonpalpable breast lesions using a conventional mammography unit with an add-on device. AJR Am J Roentgenol. Aug. 2003;181(2):527-331. PMID: 12876040. [pmid: 12876040].
132 Jackman RJ, Lamm RL. Stereotactic histologic biopsy in breasts with implants. Radiology. Jan. 2002;222(1):157-164. PMID: 11756720. [pmid: 11756720].
133 Margolin FR, Leung JW, Jacobs RP, et al. Percutaneous imaging-guided core breast biopsy: 5 years’ experience in a community hospital. AJR Am J Roentgenol. Sep. 2001;177(3):559-564. PMID: 11517047. [pmid: 11517047].
134 White RR, Halperin TJ, Olson JA Jr, et al. Impact of core-needle breast biopsy on the surgical management of mammographic abnormalities. Ann Surg. Jun. 2001;233(6):769-777. PMID: 11371735. [pmid: 11371735].
135 Latosinsky S, Cornell D, Bear HD, et al. Evaluation of stereotactic core needle biopsy (SCNB) of the breast at a single institution. Breast Cancer Res Treat. Apr. 2000;60(3):277-283. PMID: 10930116. [pmid: 10930116].
136 Liberman L, Ernberg LA, Heerdt A, et al. Palpable breast masses: is there a role for percutaneous imaging-guided core biopsy. AJR Am J Roentgenol. Sep. 2000;175(3):779-787. PMID: 10954467. [pmid: 10954467].
137 Makoske T, Preletz R, Riley L, et al. Long-term outcomes of stereotactic breast biopsies. Am Surg. 2000;66(12):1104-1109. [pmid: 11149580].
138 Welle GJ, Clark M, Loos S, et al. Stereotactic breast biopsy: recumbent biopsy using add-on upright equipment. AJR Am J Roentgenol. Jul. 2000;175(1):59-63. PMID: 10882246. [pmid: 10882246].
139 Meyer JE, Smith DN, Lester SC, et al. Large-core needle biopsy of nonpalpable breast lesions. JAMA. May. 5. 1999;281(17):1638-1641. PMID: 10235159. [pmid: 10235159].
140 Caruso ML, Gabrieli G, Marzullo G, et al. Core Biopsy as Alternative to Fine-Needle Aspiration Biopsy in Diagnosis of Breast Tumors. Oncologist. 1998;3(1):45-49. PMID: 10388083. [pmid: 10388083].
141 Fuhrman GM, Cederbom GJ, Bolton JS, et al. Image-guided core-needle breast biopsy is an accurate technique to evaluate patients with nonpalpable imaging abnormalities. Ann Surg. Jun. 1998;227(6):932-939. PMID: 9637557. [pmid: 9637557].
142 Ioffe OB, Berg WA, Silverberg SG, et al. Mammographic-histopathologic correlation of large-core needle biopsies of the breast. Mod Pathol. Aug. 1998;11(8):721-727. PMID: 9720499. [pmid: 9720499].
143 Britton PD, Flower CD, Freeman AH, et al. Changing to core biopsy in an NHS breast screening unit. Clin Radiol. Oct. 1997;52(10):764-767. PMID: 9366536. [pmid: 9366536].
144 Helbich TH, Mayr W, Schick S, et al. Coaxial technique: approach to breast core biopsies. Radiology. Jun. 1997;203(3):684-690. PMID: 9169689. [pmid: 9169689].
145 Stolier AJ. Stereotactic breast biopsy: A surgical series. J Am Coll Surg. 1997;185(3):224-228. PMID: 9291397. [pmid: 9291397].
146 Nguyen M, McCombs MM, Ghandehari S, et al. An update on core needle biopsy for radiologically detected breast lesions. Cancer. Dec. 1. 1996;78(11):2340-2345. PMID: 8941004. [pmid: 8941004].
147 Doyle AJ, Murray KA, Nelson EW, et al. Selective use of image-guided large-core needle biopsy of the breast: accuracy and cost-effectiveness. AJR Am J Roentgenol. Aug. 1995;165(2):281-284. PMID: 7618540. [pmid: 7618540].
148 Burbank F, Kaye K, Belville J, et al. Image-guided automated core biopsies of the breast, chest, abdomen, and pelvis. Radiology. Apr. 1994;191(1):165-171. PMID: 8134564. [pmid: 8134564].
149 Parker SH, Burbank F, Jackman RJ, et al. Percutaneous large-core breast biopsy: a multi-institutional study. Radiology. Nov. 1994;193(2):359-364. PMID: 7972743. [pmid: 7972743].
150 Helbich TH, Rudas M, Bohm G, et al. Randomized in vitro and in vivo evaluation of different biopsy needles and devices for breast biopsy. Clin Radiol. 1999;54(1):56-62. PMID: 9915512. [pmid: 9915512].
151 Hamed H, De Freitas R Jr, Rasbridge S, et al. A prospective randomized study of two gauges of biopty-cut needle in diagnosis of early breast cancer. Breast. 1995;4(2):135-136.
152 Vitug AF, Newman LA. Complications in breast surgery. Surg Clin North Am. Apr. 2007;87(2):431-451. PMID: 17498536. [pmid: 17498536].
153 Rissanen TJ, Makarainen HP, Mattila SI, et al. Wire localized biopsy of breast lesions: a review of 425 cases found in screening or clinical mammography. Clin Radiol. Jan. 1993;47(1):14-22. PMID: 8428412. [pmid: 8428412].
154 Diaz LK, Wiley EL, Venta LA. Are malignant cells displaced by large-gauge needle core biopsy of the breast. AJR Am J Roentgenol. Nov. 1999;173(5):1303-1313. PMID: 10541110. [pmid: 10541110].
155 Chao C, Torosian MH, Boraas MC, et al. Local recurrence of breast cancer in the stereotactic core needle biopsy site: case reports and review of the literature. Breast J. Mar–Apr. 2001;7(2):124-127. PMID: 11328321. [pmid: 11328321].
156 Youngson BJ, Cranor M, Rosen PP. Epithelial displacement in surgical breast specimens following needling procedures. Am J Surg Pathol. Sep. 1994;18(9):896-903. PMID: 8067510. [pmid: 8067510].
157 Harter LP, Curtis JS, Ponto G, et al. Malignant seeding of the needle track during stereotaxic core needle breast biopsy. Radiology. Dec. 1992;185(3):713-714. PMID: 1343569. [pmid: 1343569].
158 Michalopoulos NV, Zagouri F, Sergentanis TN, et al. Needle tract seeding after vacuum-assisted breast biopsy. Acta Radiol. Apr. 2008;49(3):267-270. PMID: 18365811. [pmid: 18365811].
159 Uematsu T, Kasami M. Risk of needle tract seeding of breast cancer: cytological results derived from core wash material. Breast Cancer Res Treat. Jul. 2008;110(1):51-55. PMID: 17674195. [pmid: 17674195].
160 Hoorntje LE, Schipper MEI, Kaya A, et al. Tumour cell displacement after 14G breast biopsy. Eur J Surg Oncol. Jun. 2004;30(5):520-525. [pmid: 15135480].
161 Stolier A, Skinner J, Levine EA. A prospective study of seeding of the skin after core biopsy of the breast. Am J Surg. Aug. 2000;180(2):104-107. PMID: 11044522. [pmid: 11044522].
162 Liberman L, Vuolo M, Dershaw DD, et al. Epithelial displacement after stereotactic 11-gauge directional vacuum-assisted breast biopsy. AJR Am J Roentgenol. Mar. 1999;172(3):677-681. PMID: 10063859. [pmid: 10063859].
163 Youngson BJ, Liberman L, Rosen PP. Displacement of carcinomatous epithelium in surgical breast specimens following stereotaxic core biopsy. Am J Clin Pathol. May. 1995;103(5):598-602. PMID: 7741106. [pmid: 7741106].
164 Uriburu JL, Vuoto HD, Cogorno L, et al. Local recurrence of breast cancer after skin-sparing mastectomy following core needle biopsy: Case reports and review of the literature. Breast J. May. 2006;12(3):194-198. PMID: 16684314. [pmid: 16684314].
165 Fitzal F, Sporn EP, Draxler W, et al. Preoperative core needle biopsy does not increase local recurrence rate in breast cancer patients. Breast Cancer Res Treat. May. 2006;97(1):9-15. PMID: 16502019. [pmid: 16502019].
166 Chen AM, Haffty BG, Lee CH. Local recurrence of breast cancer after breast conservation therapy in patients examined by means of stereotactic core-needle biopsy. Radiology. Dec. 2002;225(3):707-712. PMID: 12461249. [pmid: 12461249].
167 Knight R, Horiuchi K, Parker SH, et al. Risk of needle-track seeding after diagnostic image-guided core needle biopsy in breast cancer. J Soc Laparoendosc Surg. Jul–Sep. 2002;6(3):207-209. PMID: 12166757.
168 King TA, Hayes DH, Cederbom GJ, et al. Biopsy technique has no impact on local recurrence after breast-conserving therapy. Breast J. Jan–Feb. 2001;7(1):19-24. PMID: 11348411. [pmid: 11348411].
169 Newman EL, Kahn A, Diehl KM, et al. Does the method of biopsy affect the incidence of sentinel lymph node metastases?. Breast J. Jan. 2006;12(1):53-57. PMID: 16409587. [pmid: 16409587].
170 Hansen NM, Ye X, Grube BJ, et al. Manipulation of the primary breast tumor and the incidence of sentinel node metastases from invasive breast cancer. Arch Surg. Jun. 2004;139(6):634-640. [pmid: 15197090].
171 Peters-Engl C, Konstantiniuk P, Tausch C, et al. The impact of preoperative breast biopsy on the risk of sentinel lymph node metastases: Analysis of 2502 cases from the Austrian sentinel node biopsy study group. Br J Cancer. Nov. 15. 2004;91(10):1782-1786. [pmid: 15477859].
172 Bleiweiss IJ, Nagi CS, Jaffer S. Axillary sentinel lymph nodes can be falsely positive due to iatrogenic displacement and transport of benign epithelial cells in patients with breast carcinoma. J Clin Oncol. May. 1. 2006;24(13):2013-2018. [pmid: 16606970].
173 Hatmaker AR, Donahue RM, Tarpley JL, et al. Cost-effective use of breast biopsy techniques in a Veterans health care system. Am J Surg. Nov. 2006;192(5):e37-e41. PMID: 17071179. [pmid: 17071179].
174 Soo MS, Kliewer MA, Ghate S, et al. Stereotactic breast biopsy of noncalcified lesions: A cost-minimization analysis comparing 14-gauge multipass automated core biopsy to 14- and 11-gauge vacuum-assisted biopsy. Clin Imaging. Jan. 2005;29(1):26-33. [pmid: 15859015].
175 Golub RM, Bennett CL, Stinson T, et al. Cost minimization study of image-guided core biopsy versus surgical excisional biopsy for women with abnormal mammograms. J Clin Oncol. 2004;22(12):2430-2437. [pmid: 15197205].
176 Launders JH. ECRI Institute, Plymouth Meeting. PA. CER Breast Biopsy Project. August. 12. 2008.
177 Liberman L, Latrenta LR, Dershaw DD, et al. Impact of core biopsy on the surgical management of impalpable breast cancer. AJR Am J Roentgenol. 1997;168(2):495-499. [pmid: 9016234].
178 Duchesne N, Parker SH, Lechner MC, et al. Multicenter evaluation of a new ultrasound-guided biopsy device: Improved ergonomics, sampling and rebiopsy rates. Breast J. Jan–Feb. 2007;13(1):36-43. PMID: 17214791. [pmid: 17214791].
179 Hui JY, Chan LK, Chan RL, et al. Prone table stereotactic breast biopsy. Hong Kong Med J. Dec. 2002;8(6):447-451. PMID: 12459602. [pmid: 12459602].
180 Geller BM, Oppenheimer RG, Mickey RM, et al. Patient perceptions of breast biopsy procedures for screen-detected lesions. Am J Obstet Gynecol. Apr. 2004;190(4):1063-1069. PMID: 15118643. [pmid: 15118643].
181 Chun K, Velanovich V. Patient-perceived cosmesis and satisfaction after breast biopsy: Comparison of stereotactic incisional, excisional, and wire-localized biopsy techniques. Surgery. 2002;131(5):497-501. PMID: 12019401. [pmid: 12019401].
182 Collins LC, Connolly JL, Page DL, et al. Diagnostic agreement in the evaluation of image-guided breast core needle biopsies: results from a randomized clinical trial. Am J Surg Pathol. Jan. 2004;28(1):126-131. PMID: 14707874. [pmid: 14707874].
183 Gukas ID, Nwana EJ, Ihezue CH, et al. Tru-cut biopsy of palpable breast lesions: a practical option for pre-operative diagnosis in developing countries. Cent Afr J Med. May. 2000;46(5):127-130. PMID: 11210334. [pmid: 11210334].
184 Deurloo EE, Gilhuijs KGA, Schultze Kool LJ, et al. Displacement of breast tissue and needle deviations during stereotactic procedures. Invest Radiol. 2001;36(6):347-353. [pmid: 11410756].
185 Verkooijen HM, Borel Rinkes IH, Peeters PH, et al. Impact of stereotactic large-core needle biopsy on diagnosis and surgical treatment of non-palpable breast cancer. Eur J Surg Oncol. 2001;27(3):244-249. [pmid: 11393185].
186 Williams AB, Roberts JV, Michell MJ, et al. Prone stereotactic breast core biopsy: The impact on surgical management of nonpalpable breast cancers. Breast. Feb. 1999;8(1):12-15.
187 Mainiero MB, Gareen IF, Bird CE, et al. Preferential use of sonographically guided biopsy to minimize patient discomfort and procedure time in a percutaneous image-guided breast biopsy program. J Ultrasound Med. Nov. 2002;21(11):1221-1226. PMID: 12418763. [pmid: 12418763].
188 Wunderbaldinger P, Wolf G, Turetschek K, et al. Comparison of sitting versus prone position for stereotactic large-core breast biopsy in surgically proven lesions. AJR Am J Roentgenol. 2002;178(5):1221-1225. PMID: 11959735. [pmid: 11959735].
189 Chen SC, Yang HR, Hwang TL, et al. Intraoperative ultrasonographically guided excisional biopsy or vacuum-assisted core needle biopsy for nonpalpable breast lesions. Ann Surg. Nov. 2003;238(5):738-742. PMID: 14578737. [pmid: 14578737].
190 Orel SG, Rosen M, Mies C, et al. MR imaging-guided 9-gauge vacuum-assisted core-neddle breast biopsy: Initial experience. Radiology. Jan. 2006;238(1):54-61. PMID: 16304093. [pmid: 16304093].
191 Shin S, Schneider HB, Cole FJ Jr, et al. Follow-up recommendations for benign breast biopsies. Breast J. Sep. 2006;12(5):413-417. [pmid: 16958957].
192 Fine RE, Whitworth PW, Kim JA, et al. Low-risk palpable breast masses removed using a vacuum-assisted hand-held device. Am J Surg. Oct. 2003;186(4):362-367. PMID: 14553851. [pmid: 14553851].
193 Krainick-Strobel U, Huber B, Majer I, et al. Complete extirpation of benign breast lesions with an ultrasound-guided vacuum biopsy system. Ultrasound Obstet Gynecol. Mar. 2007;29(3):342-346. [pmid: 17167817].
194 Wong TT, Cheung PS, Ma MK, et al. Experience of stereotactic breast biopsy using the vacuum-assisted core needle biopsy device and the advanced breast biopsy instrumentation system in Hong Kong women. Asian J Surg. Jan. 2005;28(1):18-23. [pmid: 15691792].
195 Kettritz U, Rotter K, Schreer I, et al. Stereotactic vacuum-assisted breast biopsy in 2874 patients: a multicenter study. Cancer. Jan. 15. 2004;100(2):245-251. PMID: 14716757. [pmid: 14716757].
196 Mariotti C, Feliciotti F, Baldarelli M, et al. Digital stereotactic biopsies for nonpalpable breast lesion. Surg Endosc. Jun. 2003;17(6):911-917. PMID: 12632135. [pmid: 12632135].
197 Schneider E, Rohling KW, Schnall MD, et al. An apparatus for MR-guided breast lesion localization and core biopsy: Design and preliminary results. J Magn Reson Imaging. 2001;14(3):243-253. [pmid: 11536401].
198 Holloway CMB, Saskin R, Brackstone M, et al. Variation in the use of percutaneous biopsy for diagnosis of breast abnormalities in Ontario. Ann Surg Oncol. Oct. 2007;14(10):2932-2939. [pmid: 17619931].
199 Hoffmann J. Analysis of surgical and diagnostic quality at a specialist breast unit. Breast. Aug. 2006;15(4):490-497. [pmid: 16343904].
200 Lehman CD, DePeri ER, Peacock S, et al. Clinical experience with MRI-guided vacuum-assisted breast biopsy. AJR Am J Roentgenol. Jun. 2005;184(6):1782-1787. PMID: 15908530. [pmid: 15908530].
201 Liberman L, Holland AE, Marjan D, et al. Underestimation of atypical ductal hyperplasia at MRI-guided 9-gauge vacuum-assisted breast biopsy. AJR Am J Roentgenol. Mar. 2007;188(3):684-690. PMID: 17312054. [pmid: 17312054].
202 Popiela TJ, Tabor J, Nowak W, et al. Detectability of pre-clinical breast pathologies in own experience. Pol Przegl Chir. 2002;74(1):36-43.
203 Liberman L, Morris EA, Dershaw DD, et al. Fast MRI-guided vacuum-assisted breast biopsy: initial experience. AJR Am J Roentgenol. Nov. 2003;181(5):1283-1293. PMID: 14573421. [pmid: 14573421].
204 Perlet C, Heywang-Kobrunner SH, Heinig A, et al. Magnetic resonance-guided, vacuum-assisted breast biopsy: Results from a European multicenter study of 538 lesions. Cancer. Mar. 1. 2006;106(5):982-990. PMID: 16456807. [pmid: 16456807].
205 Diebold T, Hahn T, Solbach C, et al. Evaluation of the stereotactic 8G vacuum-assisted breast biopsy in the histologic evaluation of suspicious mammography findings (BI-RADS IV). Invest Radiol. Jul. 2005;40(7):465-471. PMID: 15973139. [pmid: 15973139].
206 Bloomston M, D’Angelo P, Galliano D, et al. One hundred consecutive advanced breast biopsy instrumentation procedures: complications, costs, and outcome. Ann Surg Oncol. Mar. 1999;6(2):195-199. PMID: 10082046. [pmid: 10082046].
207 Rotenberg L, Verhille R, Schulz-Wendtland R, et al. Multicenter clinical experience with large core soft tissue biopsy without vacuum assistance. Eur J Cancer Prev. Dec. 2004;13(6):491-498. PMID: 15548942. [pmid: 15548942].
208 Janes RH, Bouton MS. Initial 300 consecutive stereotactic core-needle breast biopsies by a surgical group. Am J Surg. Dec. 1994;168(6):533-536. discussion 536–537. PMID: 7977991. [pmid: 7977991].
209 Uematsu T, Kasami M, Uchida Y, et al. Ultrasonographically guided 18-gauge automated core needle breast biopsy with post-fire needle position verification (PNPV). Breast Cancer. 2007;14(2):219-228. PMID: 17485909. [pmid: 17485909].
210 Viehweg P, Bernerth T, Kiechle M, et al. MR-guided intervention in women with a family history of breast cancer. Eur J Radiol. Jan. 2006;57(1):81-89. PMID: 16364583. [pmid: 16364583].
211 Florentine BD, Cobb CJ, Frankel K, et al. Core needle biopsy: A useful adjunct to fine-needle aspiration in select patients with palpable breast lesions. Cancer. Feb. 25. 1997;81(1):33-39. [pmid: 9100539].
212 Howisey RL, Acheson MB, Rowbotham RK, et al. A comparison of Medicare reimbursement and results for various imaging-guided breast biopsy techniques. Am J Surg. May. 1997;173(5):395-398. PMID: 9168074. [pmid: 9168074].
213 Burbank F. Stereotactic breast biopsy of atypical ductal hyperplasia and ductal carcinoma in situ lesions: Improved accuracy with directional, vacuum-assisted biopsy. Radiology. Mar. 1997;202(3):843-847. [pmid: 9051043].
214 Yim JH, Barton P, Weber B, et al. Mammographically detected breast cancer. Benefits of stereotactic core versus wire localization biopsy. Ann Surg. Jun. 1996;223(6):688-697. discussion 697–670. PMID: 8645042. [pmid: 8645042].
215 Strong JW, Worsham GF, Austin RM, et al. Stereotactic core biopsy of nonpalpable breast lesions. J S C Med Assoc. Dec. 1995;91(12):489-496. PMID: 8587312. [pmid: 8587312].
216 Morrow M, Venta L, Stinson T, et al. Prospective comparison of stereotactic core biopsy and surgical excision as diagnostic procedures for breast cancer patients. Ann Surg. Apr. 2001;233(4):537-541. PMID: 11303136. [pmid: 11303136].
217 Liberman L, Gougoutas CA, Zakowski MF, et al. Calcifications highly suggestive of malignancy: comparison of breast biopsy methods. AJR Am J Roentgenol. Jul. 2001;177(1):165-172. PMID: 11418420. [pmid: 11418420].
218 Altomare V, Guerriero G, Giacomelli L, et al. Management of nonpalpable breast lesions in a modern functional breast unit. Breast Cancer Res Treat. Sep. 2005;93(1):85-89. PMID: 16184463. [pmid: 16184463].
219 Carmon M, Rivkin L, Abu-Dalo R, et al. Increased mammographic screening and use of percutaneous image-guided core biopsy in non-palpable breast cancer: Impact on surgical treatment. Isr Med Assoc J. Jun. 2004;6(6):326-328. PMID: 15214456. [pmid: 15214456].
220 Lind DS, Minter R, Steinbach B, et al. Stereotactic core biopsy reduces the reexcision rate and the cost of mammographically detected cancer. J Surg Res. Jul. 15. 1998;78(1):23-26. [pmid: 9733612].
221 Smith DN, Christian R, Meyer JE. Large-core needle biopsy of nonpalpable breast cancers. The impact on subsequent surgical excisions. Arch Surg. Mar. 1997;132(3):256-259. discussion 260. PMID: 9125023. [pmid: 9125023].
222 Elliott RL, Haynes AE, Bolin JA, et al. Stereotaxic needle localization and biopsy of occult breast lesions: first year’s experience. Am Surg. Feb. 1992;58(2):126-131. PMID: 1550304. [pmid: 1550304].
223 Liberman L, Dershaw DD, Rosen PP, et al. Stereotaxic core biopsy of impalpable spiculated breast masses. AJR Am J Roentgenol. 1995;165(3):551-554. [pmid: 7645467].
224 Pijnappel RM, Peeters PH, van den Donk M, et al. Diagnostic strategies in non-palpable breast lesions. Eur J Cancer. Mar. 2002;38(4):550-555. PMID: 11872348. [pmid: 11872348].
225 Al-Sobhi SS, Helvie MA, Pass HA, et al. Extent of lumpectomy for breast cancer after diagnosis by stereotactic core versus wire localization biopsy. Ann Surg Oncol. Jun. 1999;6(4):330-335. [pmid: 10379852].
226 Johnson JM, Dalton RR, Landercasper J, et al. Image-guided or needle-localized open biopsy of mammographic malignant-appearing microcalcifications?. J Am Coll Surg. 1998;187(6):604-609. PMID: 9849733. [pmid: 9849733].
227 Kaufman CS, Delbecq R, Jacobson L. Excising the reexcision: stereotactic core-needle biopsy decreases need for reexcision of breast cancer. World J Surg. Oct. 1998;22(10):1023-1027. PMID: 9747160. [pmid: 9747160].
228 Fenoglio ME, Gallagher JQ, Joy N, et al. Stereotactic core breast biopsy versus needle localization breast biopsy—The effect of initial diagnostic modality on surgical therapy in patients with breast cancer. Minim Invasive Ther Allied Technol. Jun. 1997;6(3):225-227.
229 Whitten TM, Wallace TW, Bird RE, et al. Image-guided core biopsy has advantages over needle localization biopsy for the diagnosis of nonpalpable breast cancer. Am Surg. Dec. 1997;63(12):1072-1077. discussion 1077–1078. PMID: 9393255. [pmid: 9393255].
230 Friese CR, Neville BA, Edge SB, et al. Breast biopsy patterns and outcomes in Surveillance, Epidemiology, and End Results-Medicare data. Cancer. Feb. 15. 2009;115(4):716-724. PMID: 19152430. [pmid: 19152430].
231 Handy RB, Fajardo LL, Innis CA, et al. Patient perceptions of stereotaxic large-core breast biopsy. Acad Radiol. Dec. 1996;3(12):1007-1011. PMID: 9017015. [pmid: 9017015].
232 Helbich TH, Rudas M, Haitel A, et al. Evaluation of needle size for breast biopsy: Comparison of 14-, 16-, and 18-gauge biopsy needles. AJR Am J Roentgenol. Jul. 1998;171(1):59-63. PMID: 9648764. [pmid: 9648764].
233 Killebrew LK, Oneson RH. Comparison of the diagnostic accuracy of a vacuum-assisted percutaneous intact specimen sampling device to a vacuum-assisted core needle sampling device for breast biopsy: Initial experience. Breast J. Jul. 2006;12(4):302-308. PMID: 16848839. [pmid: 16848839].
234 Verkooijen HM, Peeters PH, Buskens E, et al. Diagnostic accuracy of large-core needle biopsy for nonpalpable breast disease: a meta-analysis. Br J Cancer. Mar. 2000;82(5):1017-1021. PMID: 10737383. [pmid: 10737383].
235 Fahrbach K, Sledge I, Cella C, et al. A comparison of the accuracy of two minimally invasive breast biopsy methods: a systematic literature review and meta-analysis. Arch Gynecol Obstet. May. 2006;274(2):63-73. PMID: 16598478. [pmid: 16598478].
236 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. PMID: 17302989. [pmid: 17302989].
237 Troxel DB. Medicolegal aspects of error in pathology. Arch Pathol Lab Med. May. 2006;130(5):617-619. PMID: 16683874. [pmid: 16683874].