# Glossary of Selected Terms

Atypical ductal hyperplasia: A condition in which the cells that line the milk ducts of the breast experience abnormal growth. The lesion itself is not malignant but may sometimes contain foci of malignant cells and women with ADH have an elevated risk of developing a malignant lesion.
Automated biopsy gun: A device used to obtain core-needle samples. The device is pressed against the tissue at the appropriate location and angle and then the needle is “fired” into the tissue. After confirming the core-needle has sampled the appropriate tissue the needle is withdrawn and the tissue sample ejected from the needle into a sampling container. Some units use a coaxial needle. With a coaxial needle, a cannula (hollow tube) is advanced into the tissue until in contact with the area to be sampled, and then the sampling needle is “fired” through the cannula and into the lesion.
Ductal carcinoma in situ: A carcinoma of the milk ducts of the breast that is confined within the duct.
High-risk lesion: Any of a number of different types of non-cancerous lesions of the breast that have been observed to sometimes contain foci of malignant cells, and women diagnosed with these types of lesions have an elevated risk of developing a malignant lesion. Some common types of high-risk lesions include atypical ductal hyperplasia (ADH), radial scars, papillary lesions, atypical lobular hyperplasia (ALH), and lobular carcinoma in situ (LCIS).
Microcalcification: A tiny deposit of calcium visible as a bright spot on a mammogram. Tight clusters of microcalcifications may be a sign of a malignant lesion.
Negative likelihood ratio: A measure of the ability of the diagnostic test to accurately “rule out” disease. The smaller the negative likelihood ratio is, the more accurate the test is.
Palpable lesion: A breast lesion that can be felt by manual manipulation.
Sensitivity: Sensitivity is the proportion of people with the disease who have a positive test for the disease. A test with high sensitivity will rarely misclassify people with the disease as not having the disease (the test has a low rate of false-negatives).
Stereotactic guidance: X-rays are taken from multiple locations in order to accurately identify the exact location of the lesion to be sampled. After using the images to determine where to sample, the needle is inserted. Further x-ray images are usually taken to confirm the needle has penetrated the lesion.
Ultrasound guidance: High-frequency sound waves are used to visualize the exact location of the lesion to be sampled. After using the images to determine where to sample, the needle is inserted. Images can be taken continuously during needle insertion to guide and confirm the needle has penetrated the lesion.
Vacuum-assisted: After insertion of a hollow biopsy needle a vacuum can be applied to pull tissue into the needle.
Underestimation rate: The percentage of lesions that were diagnosed on core-needle biopsy as lesion types of lesser concern than the final diagnosis. For example, a lesion diagnosed as ADH on core-needle biopsy that is diagnosed as malignant on open biopsy was “underestimated” by the core-needle biopsy.