# Introduction

## Background

### Breast Cancer

Breast cancer is the second most common malignancy of women.1 The American Cancer Society estimates that in the U.S. in 2009, 67,280 women will have been diagnosed with new cases of in situ cancer, 192,370 women will have been newly diagnosed as having invasive breast cancer, and there will be 40,170 deaths due to this disease.2 In the general population, the cumulative risk of being diagnosed with breast cancer by age 70 is estimated to be 6% (lifetime risk of 13%).3,4

Ductal carcinoma, including ductal carcinoma in situ (DCIS), is the most common malignancy of the breast. It arises within the ducts of the breast. DCIS is early breast cancer confined to the inside of the ductal system, and invasive (also called infiltrating) ductal carcinoma is a later stage that has broken through the walls of the ducts and invaded nearby tissues. Lobular carcinoma is similar to ductal carcinoma, first arising in the terminal ducts of the lobules and then invading through the walls of the ducts and into nearby tissues. Atypical lobular hyperplasia (ALH) and lobular carcinoma in situ (LCIS) are caused by abnormal cellular proliferation within the terminal ducts of the lobules. The two conditions are distinguished primarily by the degree to which the ducts are filled by cells, and some pathologists have suggested the use of the term lobular neoplasia to describe a continuum of disease from ALH to LCIS.5 LCIS is not usually detectable by routine clinical exam or mammograms; it is, however, occasionally detected as an incidental finding at the time a breast biopsy is performed for other reasons. Women diagnosed with ALH or LCIS are at elevated risk of developing an invasive carcinoma in the future.

Other types of benign breast abnormalities that have been linked to an elevated risk of invasive carcinoma or a finding of associated invasive carcinoma upon excision are atypical ductal hyperplasia (ADH), papillary lesions, and radial scars.5

### Breast Biopsy

Breast cancer is usually first detected by feeling a lump on physical examination (either self-examination or an exam conducted by a health practitioner) or by observing an abnormality during x-ray screening mammography. Survival rates depend on the stage of disease at diagnosis. At stage 0 (carcinoma in situ) the five-year survival rate is close to 100%. The five-year survival rate for women with stage IV (cancer that has spread beyond the breast) is only 27%.6 These observations suggest that breast cancer mortality rates can be significantly reduced by identifying cancers at earlier stages. Because early breast cancer is asymptomatic, the only way to detect it is through population-wide screening. Mammography is a widely accepted method for breast cancer screening.7,8

Mammography uses x-rays to examine the breast for clusters of microcalcifications, circumscribed and dense masses, masses with indistinct margins, architectural distortion compared with the contralateral breast, or other abnormal structures. Currently, most professional organizations recommend that all women older than fifty years of age receive an annual or biennial mammogram.6,9 Some professional organizations recommend that routine breast cancer screening begin earlier, at age 40, although x-ray mammography screening is less effective in younger women.7 Most experts believe that regular x-ray mammographic screening of all women who are between the age of 50 and 70 can reduce mortality from breast cancer.6–8 The United States Preventive Services Task Force (USPSTF) recommends screening mammography every 2 years for women aged 50 to 74.^10^

The American College of Radiology has created a standardized system for reporting the results of mammography, the Breast Imaging Reporting and Data System (BI-RADS^®^).11–13 There are seven categories of assessment and recommendation:

- 0 Need additional imaging evaluation and/or prior mammograms for comparison
- 1 Negative
- 2 Benign finding
- 3 Probably benign finding. Initial short interval follow-up suggested
- 4 Suspicious abnormality. Biopsy should be considered.
- 5 Highly suggestive of malignancy. Appropriate action should be taken.
- 6 Known biopsy-proven malignancy. Appropriate action should be taken.

After identification of a possible abnormality on screening mammographyor physical examination, women typically undergo additional imaging studies (e.g., diagnostic mammography, ultrasound, possibly magnetic resonance imaging (MRI)) and a physical examination. If these studies suggest the abnormality may be malignant, a biopsy of the suspicious area may be recommended. Biopsy material may be obtained by fine-needle aspiration, core-needle biopsy, or open surgical procedures. The combination of physical examination, imaging studies, and fine-needle aspirationis sometimes referred to as the “triple assessment.”14 Fine-needle aspiration is not the topic of this report and is not discussed further.

Open surgical biopsy involves removing a sample of tissue from the suspicious area through an open incision. To aid in location of a non-palpable lesion, it may be marked with a wire, dye, or carbon particles using an imaging method (e.g., mammography, ultrasound, MRI) to guide placement of the marker. The biopsy procedure may be performed under general anesthesia, sedation plus local anesthesia, or local anesthesia only. The surgeon may attempt to remove the entire lesion during the biopsy procedure (excisional biopsy) if the lesion is fairly small. After removing the tissue sample, the incision is closed with sutures.

Open surgical biopsy is the reference standard for evaluating a suspicious breast lesion because it is thought to be very accurate in diagnosing these lesions. However, it is a surgical procedure that, like all surgeries, places the patient at risk of experiencing morbidities and, in rare cases, mortality. Lacquement et al. examined a series of 668 women who underwent biopsy, and reported that only 23% of these women were diagnosed with breast cancer after biopsy.15 Exposing large numbers of women who do not have cancer to invasive surgical procedures may be considered an undesirable medical practice. A less invasive method for evaluation of suspicious breast lesions would be preferable if it were sufficiently accurate.

A core-needle biopsy is a procedure that involves removing small samples of breast tissue through a hollow core needle inserted through the skin. Basic core-needle biopsy uses a special 11-, 14-, or 16-gauge needle (the smaller the gauge the larger the diameter of the needle). The suspicious lesion may be located by palpation or by imaging (e.g., stereotactic mammography, ultrasound, MRI). The procedure is usually performed under local anesthesia. Multiple core-needle samples may be taken from the suspicious area.

A variant on core-needle biopsy is vacuum-assisted biopsy. After locating the suspicious area by stereotactic mammography, ultrasound, or MRI, the probe of the device is inserted into the suspicious area. The device uses vacuum suction to help remove tissue samples. Multiple samples may be taken from the suspicious area. Some vacuum-assisted devices, unlike traditional core-needle biopsy devices, can collect multiple samples while only needing to be inserted through the skin once.

Another variant on core-needle biopsy is large core breast biopsy. Large core breast biopsy is intended to be a minimally invasive method of removing a fairly large sample of breast tissue, or even to remove an entire small lesion. After locating the suspicious area by stereotactic mammography a wire is inserted to mark the location. The device then removes a large core of breast tissue through a cannula. Sutures are required to close the skin at the entry site. There were no large core biopsy devices commercially available in the United States at the time this report was prepared.

Initial biopsy of any breast abnormality has a primary goal of making a diagnosis of the abnormality as benign or malignant. Generally, only malignant lesions require invasive follow-up procedures such as surgical excision or lymph node evaluation. As discussed above, the majority of women who are sent for breast biopsy do not have malignant lesions and do not require follow-up surgery. Thus an accurate initial core-needle biopsy would allow women with benign findings to avoid an open surgical procedure. If the core-needle biopsy suggests the lesion is malignant, lymph node exploration and lesion excision to clear margins could be performed during a subsequent open procedure. Women who are diagnosed with malignant lesions by open biopsy are often subjected to additional follow-up surgical procedures to ensure the lesion has been completely removed and, in some cases, for lymph node evaluation. Therefore, an accurate method of performing core-needle biopsies may enable many women to avoid surgery altogether and reduce the number of surgical procedures women with malignancies must undergo.

### Prognostic and Predictive Factors

Pathological prognostic and predictive factors are used in clinical practice to guide treatment planning. One of the major concerns about core-needle biopsy techniques is under-sampling of important areas of the lesion. If important areas are missed, the pathology report may be misleading. Categories of prognostic and predictive factors include tumor type, histological grade, and immunophenotype of the tumor. These categories are briefly discussed below.

Tumor typing is evaluation of type of the tumor, e.g., DCIS, infiltrating ductal carcinoma, medullary carcinoma, infiltrating lobular carcinoma, tubular carcinoma, mucinous carcinoma, inflammatory breast cancer, or other. Tumor typing of mixed-type tumors by core-needle biopsy may be incorrect due to the inability of needle biopsy to sample all parts of the tumor.

Histological grade is used to describe invasive tumors and other breast abnormalities. The grade is based on how closely cells in the sample tissue resemble normal breast tissue. Different grading systems are in use, but in general the higher the grade, the more abnormal the tissue structure and cells. Interpretation of grade from core-needle biopsy material has been reported to commonly underestimate the grade by one level as compared to surgical specimens.16 Rakh a and Ellis have suggested that the discrepancy is often due to the fact that core-needle samples are generally taken from the interior of the tumor and surgical specimens for grading are usually taken from the periphery of the tumor, where the most active growth is occuring.16

Immunophenotype of the tumor refers to determining the status of certain biomarkers. The presence of estrogen receptors, progesterone receptors, and HER-2 overexpression are important features of tumor biology that need to be incorporated into treatment decisions. For example, estrogen receptor positive tumors may be effectively treated with hormone-blocking medications such as tamoxifen, and tumors that over-express HER-2 may be treated with trastuzumab (Herceptin) or lapatinib (Tykerb). Core-needle specimens can be utilized in tests to determine the immunophenotype of the tumor.

### Staging

Final treatment decisions are based on the stage of the tumor. Breast cancer is most commonly staged with the American Joint Committee on Cancer (AJCC) TNM system.17 The “T” stands for tumor, and is assigned a number from 0 to 4 to describe the size and local spread of the primary tumor, determined by imaging studies such as mammography, MRI, and CT scanning. The ‘N” stands for lymph nodes, and is assigned a number from 0 to 3 to indicate whether the cancer has spread to the lymph nodes and to how many lymph nodes, determined by sentinel lymph node biopsy or axillary lymph node dissection. The “M” stands for distant metastasis, and is assigned either 0 or 1 to indicate whether the cancer has spread to distant locations, determined by imaging studies such as CT scanning and bone scintigraphy.18 Breast cancer stage may also be expressed as a number from 0 to IV, where stage 0 is ductal carcinoma in situ (DCIS) and stage IV is metastatic cancer.17,18

### Negative Surgical Excision after After Core-Needle Biopsy

Sometimes a core-needle biopsy specimen suggests that a tumor is present, and thus an open surgical procedure is per formed, only to find no tumor present. Many experts suggest that in these cases the core-needle biopsy procedure removed the entire tumor.16 This may be the case. It is also possible that the pathology report for either procedure was incorrect, or that the open procedure missed the lesion.

### Choice of Biopsy Method

Medical indications may direct the preference for one type of procedure over another. For example, the size and location of the lesion, imaging characteristics of the lesion, and likelihood of eventual surgical excision could be important to the choice of method. However, other factors such as patient preferences, access, and practice and referral patterns also influence decisions about which procedure should be performed.

The large number of possible methods of performing breast biopsy can be bewildering to patients and healthcare providers alike. Which method should one choose? Is a particular method clearly superior, or does the method of choice depend upon individual patient or lesion characteristics? We have performed a systematic review intended to evaluate the accuracy of different methods of performing breast biopsy, and to explore what factor(s) may impact the accuracy and possible harms of different methods of performing breast biopsy.

### Conceptual Framework

The analytical framework (Figure 1) demonstrates the links between patients, tests, interventions, and outcomes. The numbers on the diagram refer to the Key Questions (see next section) and their placement in Figure 1 exhibits the many links separating the Key Questions from the patient-oriented outcomes. Fryback and Thornbury have proposed a six-level model of assessing diagnostic efficacy.19 Level 1 is analytic validity; level 2 is diagnostic accuracy; level 3 is diagnostic thinking; level 4 is impact on choice of treatment; level 5 is patient-important outcomes; and level 6 is societal impact. Demonstration of efficacy at each lower level is logically necessary, but not sufficient, to assure efficacy at higher levels. This systematic review is primarily concerned with Level 2, the diagnostic accuracy of various methods of performing breast biopsies.

Figure 1 Analytical framework

The numbers in the figure depict where the three Key Questions addressed in this report are located within the flow of the analytical framework.

Figure 1 demonstrates the links between patients, tests, interventions, and outcomes for patients referred for biopsy after detection of a breast abnormality. The patient is referred for biopsy after detection of a breast abnormality. Question 1 deals with the accuracy of core-needle compared to open biopsy for diagnosis/classification of the breast abnormality. Diagnosis/classification is followed by either treatment, followup or return to screening. These interventions may lead to a change in clinical decisions, which may be followed by treatment and further testing. Outcomes of these interventions or tests include response to treatment, clear surgical margins and cosmetic results, survival and quality of life. The Figure illustrates that the outcomes examined in this report, namely, accuracy of the biopsy methods, are separated from the patient-oriented outcomes by several intervening steps. Question 2 deals with adverse events related to biopsy. Question 3 deals with a variety of factors that might influence choice of biopsy type.

We have expanded the section of the analytical framework that is relevant to the questions addressed in this systematic review in a patient flow diagram (Figure 2). The numbers on the diagram refer to the Key Questions (see next section). We have simplified the diagram for clarity by combining all types of core-needle procedures together into one pathway.

Figure 2 Patient flow diagram

The numbers in the figure depict where the three Key Questions addressed in this report are located within the patient flow diagram.

*If initial core-needle biopsy indicates malignancy but surgical excision is negative for malignancy, many would assume that the initial biopsy removed the lesion rather than to label it a false positive. Patients may then undergo close surveillance or further treatment.

Figure 2 is a patient flow diagram depicting the steps following the decisions to perform a biopsy and to perform either surgical biopsy or core needle biopsy. If the abnormality on initial biopsy is malignant, surgical excision is performed and the initial biopsy results are interpreted in light of the findings. Further treatment and screening would follow. If the initial biopsy indicates that the abnormality is benign, the patient returns to routine screening. Interpretation of the initial biopsy would be based on the results of screening and clinical follow up. A false negative on the initial biopsy would result in a delay of diagnosis of malignancy.

### Diagnostic Test Characteristics

No diagnostic test is perfect. Studies of test performance compare test results on a group of individuals, some of whom have the disease and some of whom do not. Each individual undergoes the experimental test as well as a second reference test to determine “true” disease status. The relationship between the diagnostic test results and disease status is described using diagnostic test characteristics. It is important that the reference test is very accurate in measuring “true” disease status, or else the performance of the experimental diagnostic test will be poorly estimated.

#### Sensitivity and Specificity

The results of the experimental and reference standard test and their relationship are commonly presented as two-by-two (2×2) tables (see Table 1). From the 2×2 table, sensitivity and specificity are readily calculated:

Sensitivity = TP / ( TP + FN ) Specificity = TN / ( FP + TN )

Table 1 Example of a 2×2 table

| | Disease
| | Present | Absent
Test Results | Positive | True positives (TP) | False positives (FP)
Test Results | Negative | False negatives (FN) | True negatives (TN)

Sensitivity and specificity are properties of a test that are useful when deciding whether to use a test. Sensitivity is the proportion of people with the disease who have a positive test for the disease. A test with high sensitivity will rarely misclassify people with the disease as not having the disease (the test has a low rate of false-negatives). Specificity is the proportion of people without the disease who have a negative test. A test with high specificity will rarely misclassify people without the disease as diseased (a low rate of false-positives).

#### Predictive Values and Likelihood Ratios

To make sense of a diagnostic investigation, a clinician needs to be able to make an inference regarding the probability that a patient has the disease in question according to the result obtained from the test. Sensitivity and specificity do not directly provide this information. The predictive values and likelihood ratios can also b e directly calculated from a 2×2 table:

Positive predictive value = TP / ( TP + FP ) Negative predictive value = TN / ( FN + TN ) Positive likelihood ratio = ( TP / ( TP + FN ) ) / ( FP / (FP + TN) ) Negative likelihood ratio = ( FN / ( TP + FN ) ) / ( TN / (FP + TN) )

The positive predictive value of a test is the probability of a patient having the disease following a positive test result. The negative predictive value is the probability of a patient not having the disease following a negative test result. Predictive values describe the probabilities that positive or negative results are correct for an individual patient. However, predictive values depend on the prevalence of disease in the population. A study that enrolled a patient population with a disease prevalence of 70% may report a positive predictive value of 80%. If a clinician tests a patient from a population with a disease prevalence of 70%, and the test comes back positive, the clinician knows the patient has an 80% chance of having the disease in question. However, if the patient comes from a population with a disease prevalence of 20%, the clinician cannot apply the results of the study directly to this patient.

Because sensitivity and specificity are difficult to directly apply to clinical situations, and predictive values vary markedly as a function of disease prevalence (i.e., may be different for each patient subpopulation) a combined measure of diagnostic performance, the likelihood ratio, is a clinically useful diagnostic test performance measure. Negative likelihood ratios measure the ability of the test to accurately “rule out” disease, and positive likelihood ratios measure the ability of the test to accurately detect disease.

Likelihood ratios are independent of prevalence and therefore can be directly applied in the clinic to update an individual’s estimated chances of disease according to their test result. Likelihood ratios can be used in Bayes’ theorem to calculate post-test odds of having a disease from the pre-test suspicion of the patient’s odds of having that disease. Clinicians may be familiar with simple nomograms that allow a direct visualization of post-test chances of disease given a positive or negative test result, without the need to go through the tedious calculations of Bayes’ theorem; see, for example, Figure 3 or the interactive form of the nomogram provided by the Center for Evidence-based Medicine at http://www.cebm.net.

Figure 3 Example of a nomogram

Figure 3 depicts a nomogram using the negative likelihood ratio of 0.04 for ultrasound-guided vacuum-assisted biopsy. A typical woman with a mammogram described as BI-RADS 4 pre-biopsy has an approximate 30% probability of having a malignant tumor. If this woman has a "benign" finding on her core-needle biopsy, her post-biopsy probability of having a malignant tumor is approximately 2%.

In Figure 3 a nomogram using the negative likelihood ratio for ultrasound-guided vacuum-assisted biopsy is shown. A typical woman with a mammogram described as BI-RADS 4 pre-biopsy has an approximate 30% probability of having a malignant tumor. The dotted blue line in the nomogram can be drawn with a straight-edge from 30% on the left side of the figure, through the negative likelihood ratio of 0.04, and continue in a straight line to the right side of the figure to 2%, indicating that if this woman has a “benign” finding on her core-needle biopsy her post-biopsy probability of having a malignant tumor is approximately 2%.

## Scope and Key Questions

This systematic review was commissioned by the Agency for Healthcare Research and Quality (AHRQ) to address the following Key Questions:

1. In women with a [underlined: palpable] or [underlined: non-palpable] breast abnormality, what is the accuracy of different types of core-needle breast biopsy compared with open biopsy for diagnosis? (The primary outcomes for determination of accuracy are missed cancers [the false negative rate, or sensitivity] and the underestimation rate).

1a. What factors associated with the [underlined: patient] and her [underlined: breast abnormality] influence the accuracy of different types of core-needle breast biopsy compared with open biopsy for diagnosis of a breast abnormality?

Patient and lesion-associated factors include, but may not be limited to:

Age, characteristics of lesion on mammography or other imaging, breast density, tissue type(s) and architecture of breast lesion, location of breast lesion, or other patient clinical health issues that may affect biopsy (i.e., clotting disorder).

1b. What factors associated with the [underlined: procedure] itself influence the accuracy of different types of core-needle breast biopsy compared with open biopsy for diagnosis of a breast abnormality?

Procedure-related factors include, but may not be limited to:

Equipment used, gauge of core-needle needle used, number of cores, area/amount of specimen obtained, use of vacuum, specific device used, and use of imaging guidance (e.g., MRI, US, stereotactic techniques).

1c. What [underlined: clinician and facility] factors influence the accuracy of core-needle breast biopsy compared with open biopsy for diagnosis of a breast abnormality?

Clinician and facility factors include, but may not be limited to:

Training and experience of clinicians performing the diagnostic procedure and interpreting breast specimen (e.g., specialized breast team, pathologist), annual volume of each procedure performed at facility, geographic location (where in country/world), practice setting (e.g., group, solo), facility setting (e.g., office, ambulatory surgical center, hospital)

2. In women with a [underlined: palpable] or [underlined: non-palpable] breast abnormality, what are the harms associated with core-needle breast biopsy compared to the open biopsy technique in the diagnosis of breast cancer? (The primary outcomes for determination of harms are inconclusive findings and the re-biopsy rate, dissemination of cancerous cells along needle track, complications, patient centered outcomes including satisfaction, quality of life metrics, time to recover, use of pain medications and subsequent false positive and false negative rate on mammography.)

2a. What factors associated with the [underlined: patient] and her [underlined: breast abnormality] influence the harms of core-needle breast biopsy compared with the open biopsy technique in the diagnosis of a breast abnormality?

Patient and lesion-associated factors include, but may not be limited to:

Age, characteristics of lesion on mammography or other imaging, breast density, tissue type(s) and architecture of breast lesion, location of breast lesion, or other patient clinical health issues that may affect biopsy (i.e., clotting disorder).

2b. What factors associated with the [underlined: procedure] itself influence the harms of core -needle breast biopsy compared with the open biopsy technique in the diagnosis of a breast abnormality?

Procedure-related factors include, but may not be limited to:

Equipment used, gauge of core-needle needle used, number of core samples, area/amount of specimen obtained, use of vacuum, specific device used, and use of imaging guidance (e.g., MRI, US, stereotactic techniques).

2c. What [underlined: clinician and facility] factors influence the harms of core-needle breast biopsy compared with the open biopsy technique for diagnosis of a breast abnormality?

Clinician and facility factors include, but may not be limited to:

Training and experience of clinicians performing the diagnostic procedure and interpreting breast specimen (e.g., specialized breast team, pathologist), annual volume of each procedure performed at facility, geographic location (where in country/world), practice setting (e.g., group, solo), facility setting (e.g., office, ambulatory surgical center, hospital)

3. How do open biopsy and various core-needle techniques differ in terms of patient preference, availability, costs, availability of qualified pathologist interpretations, and other factors that may influence choice of particular technique?

This report focuses on the use of core-needle biopsies to evaluate suspected cancer confined to the breast. Fine-needle aspiration is outside the scope of this report. Other uses of biopsy for diagnosing and managing breast cancer, or any other issue not mentioned in the Key Questions, are outside the scope of this report.