# Grading the Strength of Evidence

Ideally, the body of evidence to support a conclusion would be strong. Often, however, the evidence suffers from various limitations concerning the possible risk of bias in available studies, small numbers of studies and patients, and/or inconsistent effects. These limitations often mean that the strength of the evidence is only moderate, weak, or even insufficient to permit any conclusion. In order to gauge the impact of these possible limitations, we applied a formal rating system that conforms with the CER Methods Guide Manual recommendations on grading the strength of evidence.

The strength of evidence supporting each major conclusion was graded as High, Moderate, Low, or Insufficient. The grade was developed by considering four important domains: the quality (risk of potential bias) of the evidence base, the size of the evidence base, the consistency (agreement across studies) of the findings, and the robustness of the findings (as determined by sensitivity analysis). The grading system moves stepwise to consider each important domain. These steps are described below.

## Step 1 What is the quality of individual studies?

We used an internal validity rating scale for diagnostic studies to grade the internal validity of the evidence base. This scale is based on a modification of the QUADAS instrument.595 Each question in the instrument addresses an aspect of study design or conduct that can help to protect against bias. Each question can be answered “yes”, “no”, or “not reported,” and each is phrased such that an answer of “yes” indicates that the study reported a protection against bias on that aspect. A summary score was computed with each “yes” given a +1, each “no” a −1, and each “not reported” a zero. As all of the factors captured by the questions on the quality instrument were thought to be of equal importance for this topic, no weighting was utilized in computing the summary score. This summary score was then normalized to a scale from 0 to 10, with the lower the score the greater the risk that the study was affected by biases.

## Step 2 What is the overall quality of evidence?

To evaluate the overall quality of the evidence base for each conclusion, we computed the median quality score of the studies contributing to that conclusion. We used the median because it is the appropriate measure of central tendency to represent the “typical” quality score, and is less sensitive to outliers than the mean. An evidence base with a median score higher than 8.4 was considered to be of high quality; an evidence base with a median score 8.4 or less but greater than 6.7 was considered to be of moderate quality; an evidence base with a median score 6.7 or less but greater than 5.0 was considered to be of low quality; and an evidence base with a median score less than 5.0 was considered to be of insufficient quality. The quality rating was considered to be the “baseline” grade of strength of evidence.

## Step 3 Is the evidence base large enough to be informative?

For this Step, we first count the number of included studies. If there are fewer than three studies, the evidence grade is automatically set to Insufficient. Next, we determined whether the precision of the evidence base was sufficient to permit a conclusion. Precision is to a large degree dependent on the size of the evidence base-in general, as the evidence base increases in size the confidence interval around the summary effect becomes tighter due to the increase in statistical power. If the effect is statistically or clinically significant we conclude the data are informative. For diagnostic test evaluations, we consider the precision of the primary measures of diagnostic test accuracy, sensitivity and specificity. If the confidence interval bounds are within 20% of the point estimate for these measures we conclude the data are informative. Other measures of diagnostic test accuracy, such as likelihood ratios and predictive values, are calculated from the same analysis and data used to calculate sensitivity and specificity and therefore are not rated separately. If the data are not sufficiently precise, we down-grade the evidence rating by one level, for example, a rating of High from Step 2 would be down-graded to Moderate.

## Step 4 Are data consistent?

Consistency refers to the extent to which the study findings are similar. Quantitative consistency can be tested with the Higgins and Thompson’s I^2^ statistic. For this report, we considered an evidence base to be quantitatively consistent when I^2^<50%. The evidence base is considered to be qualitatively consistent when the studies all report the same qualitative conclusion. If the data are not sufficiently consistent, we down-grade the evidence rating by one level, for example, a rating of High from Steps 2 and 4 would be down-graded to Moderate.

## Step 5 Are data robust?

In this step we determine whether the data are robust to minor alterations of the data. What types of robustness tests should be performed may vary. For example, if some data were imputed, the analysis should be re-done using reasonable variations in the value(s) of the imputed data. Other robustness tests may include removing one study at a time from the analysis, or performing cumulative meta-analyses. We considered findings to not be robust only if a robustness analysis significantly altered the conclusion (e.g., a statistically significant finding becomes non-significant as studies are added to the evidence base, or the point estimate changed by more 20% after removal of any single study from the analysis). If the data are not sufficiently robust, we down-grade the evidence rating by one level, for example, a rating of High from Steps 2, 4, and 5 would be down-graded to Moderate.

In addition to the conclusions about diagnostic accuracy, we also rated the strength of evidence for one conclusion about a patient-oriented outcome, surgeries avoided. The method of rating patient-oriented outcomes is similar to, but not identical to, the method of rating the conclusions about diagnostic accuracy. In addition to the four important domains used for rating conclusions about diagnostic accuracy we also considered the domain Strength of Association (magnitude of the size of the effect). If the size of the effect was determined to be very small, we down-graded the rating of the strength of evidence by one level; and if the size of effect was determined to be very large we up-graded the strength of evidence by one level.

## References

1 Bukhari MH, Akhtar ZM. Comparison of accuracy of diagnostic modalities for evaluation of breast cancer with review of literature. Diagn Cytopathol. Jun. 2009;37(6):416-424. PMID: 19217034. [pmid: 19217034].
2 Eliahou R, Sella T, Allweis T, et al. Magnetic resonance-guided interventional procedures of the breast: initial experience. Isr Med Assoc J. May. 2009;11(5):275-279. PMID: 19637504. [pmid: 19637504].
3 Peters NH, Meeuwis C, Bakker CJ, et al. Feasibility of MRI-guided large-core-needle biopsy of suspiscious breast lesions at 3 T. Eur Radiol. Jul. 2009;19(7):1639-1644. PMID: 19214520. [pmid: 19214520].
4 Salem C, Sakr R, Chopier J, et al. Accuracy of stereotactic vacuum-assisted breast biopsy with a 10-gauge hand-held system. Breast. Jun. 2009;18(3):178-182. PMID: 19364652. [pmid: 19364652].
5 Tozaki M, Yamashiro N, Suzuki T, et al. MR-guided vacuum-assisted breast biopsy: is it an essential technique?. Breast Cancer. 2009;16(2):121-125. PMID: 18807122. [pmid: 18807122].
6 Bernik SF, Troob S, Ying BL, et al. Papillary lesions of the breast diagnosed by core needle biopsy: 71 cases with surgical follow-up. Am J Surg. Apr. 2008;197(4):473-478. PMID: 18723154. [pmid: 18723154].
7 Brem RF, Lechner MC, Jackman RJ, et al. Lobular neoplasia at percutaneous breast biopsy: variables associated with carcinoma at surgical excision. AJR Am J Roentgenol. Mar. 2008;190(3):637-641. PMID: 18287433. [pmid: 18287433].
8 Carder PJ, Khan T, Burrows P, et al. Large volume “mammotome” biopsy may reduce the need for diagnostic surgery in papillary lesions of the breast. J Clin Pathol. Aug. 2008;61(8):928-933. PMID: 18495791. [pmid: 18495791].
9 Cheung KL, Wong AW, Parker H, et al. Pathological features of primary breast cancer in the elderly based on needle core biopsies-A large series from a single centre. Crit Rev Oncol Hematol. Sep. 2008;67(3):263-267. [pmid: 18524618].
10 Choo KS, Kwak HS, Tae Bae Y, et al. The value of a combination of wire localization and ultrasound-guided vacuum-assisted breast biopsy for clustered microcalcifications. Breast. Dec. 1. 2008;17(6):611-616. PMID: 18653339. [pmid: 18653339].
11 Doren E, Hulvat M, Norton J, et al. Predicting cancer on excision of atypical ductal hyperplasia. Am J Surg. Mar. 2008;195(3):358-362. [pmid: 18206849].
12 Eby PR, Ochsner JE, Demartini WB, et al. Is surgical excision necessary for focal atypical ductal hyperplasia found at stereotactic vacuum-assisted breast biopsy. Ann Surg Oncol. Nov. 2008;15(11):3232-3238. PMID: 18696163. [pmid: 18696163].
13 Eun YK, Bae YA, Kim MJ, et al. Factors affecting the efficacy of ultrasound- guided vacuum-assisted percutaneous excision for removal of benign breast lesions. J Ultrasound Med. Jan. 2008;27(1):65-73. [pmid: 18096732].
14 Forgeard C, Benchaib M, Guerin N, et al. Is surgical biopsy mandatory in case of atypical ductal hyperplasia on 11-gauge core needle biopsy? A retrospective study of 300 patients. Am J Surg. Sep. 2008;196(3):339-345. PMID: 18585676. [pmid: 18585676].
15 Hahn M, Okamgba S, Scheler P, et al. Vacuum-assisted breast biopsy: a comparison of 11-gauge and 8-gauge needles in benign breast disease. World J Surg Oncol. May. 19. 2008;6(1):51. PMID: 18489771. [pmid: 18489771].
16 Hauth EA, Jaeger HJ, Lubnau J, et al. MR-guided vacuum-assisted breast biopsy with a handheld biopsy system: Clinical experience and results in postinterventional MR mammography after 24 h. Eur Radiol. Jan. 2008;18(1):168-176. PMID: 17609959. [pmid: 17609959].
17 He Q, Fan X, Guan Y, et al. Percutaneous excisional biopsy of impalpable breast lesions under ultrasound visualization. Breast. Dec. 2008;17(6):666-670. PMID: 18835778. [pmid: 18835778].
18 Hertl K, Marolt-Music M, Kocijancic I, et al. Haematomas After Percutaneus Vacuum-Assisted Breast Biopsy. Ultraschall Med. Feb. 2009;30(1):33-36. PMID: 18773386. [pmid: 18773386].
19 Hemmer JM, Kelder JC, van Heesewijk HP. Stereotactic large-core needle breast biopsy: Analysis of pain and discomfort related to the biopsy procedure. Eur Radiol. Feb. 2008;18(2):351-354. PMID: 17909818. [pmid: 17909818].
20 Hukkinen K, Kivisaari L, Heikkila PS, et al. Unsuccessful preoperative biopsies, fine needle aspiration cytology or core needle biopsy, lead to increased costs in the diagnostic workup in breast cancer. Acta Oncol. 2008;47(6):1037-1045. PMID: 18607862. [pmid: 18607862].
21 Hwang H, Barke LD, Mendelson EB, et al. Atypical lobular hyperplasia and classic lobular carcinoma in situ in core biopsy specimens: Routine excision is not necessary. Mod Pathol. Oct. 2008;21(10):1208-1216. [pmid: 18660792].
22 Jang M, Cho N, Moon WK, et al. Underestimation of atypical ductal hyperplasia at sonographically guided core biopsy of the breast. AJR Am J Roentgenol. Nov. 2008;191(5):1347-1351. PMID: 18941067. [pmid: 18941067].
23 Ji HY, Kim EK, Min JK, et al. Sonographically guided 14-gauge core needle biopsy of breast masses: A review of 2,420 cases with long-term follow-up. AJR Am J Roentgenol. Jan. 2008;190(1):202-207. [pmid: 18094312].
24 Youk JH, Kim EK, Kim MJ, et al. Sonographically guided 14-gauge core needle biopsy of breast masses: a review of 2,420 cases with long-term follow-up. AJR Am J Roentgenol. Jan. 2008;190(1):202-207. PMID: 18094312. [pmid: 18094312].
25 Kil WH, Cho EY, Kim JH, et al. Is surgical excision necessary in benign papillary lesions initially diagnosed at core biopsy?. Breast. Jun. 2008;17(3):258-262. PMID: 18054232. [pmid: 18054232].
26 Kim MJ, Kim E-K, Park SY, et al. Imaging-histologic discordance at sonographically guided percutaneous biopsy of breast lesions. Eur J Radiol. Jan. 2008;65(1):163-169. [pmid: 17466478].
27 Kim MJ, Kim EK, Kwak JY, et al. Nonmalignant papillary lesions of the breast at US-guided directional vacuum-assisted removal: A preliminary report. Eur Radiol. 2008;18(9):1774-1783. [pmid: 18446345].
28 Kumaroswamy V, Liston J, Shaaban AM. Vacuum assisted stereotactic guided mammotome biopsies in the management of screen detected microcalcifications: experience of a large breast screening centre. J Clin Pathol. Jun. 2008;61(6):766-769. PMID: 18326021. [pmid: 18326021].
29 Lee JM, Kaplan JB, Murray MP, et al. Complete excision of the MRI target lesion at MRI-guided vacuum-assisted biopsy of breast cancer. AJR Am J Roentgenol. Oct. 2008;191(4):1198-1202. PMID: 18806165. [pmid: 18806165].
30 Londero V, Zuiani C, Linda A, et al. Lobular neoplasia: Core needle breast biopsy underestimation of malignancy in relation to radiologic and pathologic features. Breast. Dec. 1. 2008;17(6):623-630. PMID: 18619840. [pmid: 18619840].
31 Mahoney MC. Initial clinical experience with a new MRI vacuum-assisted breast biopsy device. J Magn Reson Imaging. Oct. 2008;28(4):900-905. PMID: 18821610. [pmid: 18821610].
32 Menon S, Porter GJ, Evans AJ, et al. The significance of lobular neoplasia on needle core biopsy of the breast. Virchows Arch. May. 2008;452(5):473-479. PMID: 18389278. [pmid: 18389278].
33 Michalopoulos NV, Zagouri F, Sergentanis TN, et al. Needle tract seeding after vacuum-assisted breast biopsy. Acta Radiol. Apr. 2008;49(3):267-270. PMID: 18365811. [pmid: 18365811].
34 Perretta T, Pistolese CA, Bolacchi F, et al. MR imaging-guided 10-gauge vacuum-assisted breast biopsy: histological characterisation. Radiol Med. Sep. 2008;113(6):830-840. PMID: 18633687. [pmid: 18633687].
35 Peter D, Grunhagen J, Wenke R, et al. False-negative results after stereotactically guided vacuum biopsy. Eur Radiol. Jan. 2008;18(1):177-182. PMID: 17637996. [pmid: 17637996].
36 Resetkova E, Edelweiss M, Albarracin CT, et al. Management of radial sclerosing lesions of the breast diagnosed using percutaneous vacuum-assisted core needle biopsy: recommendations for excision based on seven years’ of experience at a single institution. Breast Cancer Res Treat. 2008. Jul. 15. Epub ahead of print. PMID: 18626769.
37 Rizzo M, Lund MJ, Oprea G, et al. Surgical follow-up and clinical presentation of 142 breast papillary lesions diagnosed by ultrasound-guided core-needle biopsy. Ann Surg Oncol. Apr. 2008;15(4):1040-1047. PMID: 18204989. [pmid: 18204989].
38 Salem C, Sakr R, Chopier J, et al. Pain and complications of directional vacuum-assisted stereotactic biopsy: Comparison of the Mammotome and Vacora techniques. Eur J Radiol. 2008. Aug. 26. Epub ahead of print. PMID: 18755562.
39 Shin HJ, Kim HH, Kim SM, et al. Papillary lesions of the breast diagnosed at percutaneous sonographically guided biopsy: comparison of sonographic features and biopsy methods. AJR Am J Roentgenol. Mar. 2008;190(3):630-636. PMID: 18287432. [pmid: 18287432].
40 Sigal-Zafrani B, Muller K, El Khoury C, et al. Vacuum-assisted large-core needle biopsy (VLNB) improves the management of patients with breast microcalcifications - Analysis of 1009 cases. Eur J Surg Oncol. Apr. 2008;34(4):377-381. [pmid: 17604937].
41 Skandarajah AR, Field L, Yuen Larn Mou A, et al. Benign papilloma on core biopsy requires surgical excision. Ann Surg Oncol. Aug. 2008;15(8):2272-2277. PMID: 18473143. [pmid: 18473143].
42 Smetherman D, Dydynski P, Jackson P. Effect of breast core needle biopsy technique on detection of lobular intraepithelial neoplasia. Ochsner J. Sep. 2007;7(3):121-124.
43 Sohn VY, Arthurs ZM, Kim FS, et al. Lobular neoplasia: Is surgical excision warranted?. Am Surg. Feb. 2008;74(2):172-177. PMID: 18306873. [pmid: 18306873].
44 Somerville P, Seifert PJ, Destounis SV, et al. Anticoagulation and bleeding risk after core needle biopsy. AJR Am J Roentgenol. Oct. 2008;191(4):1194-1197. PMID: 18806164. [pmid: 18806164].
45 Tagaya N, Nakagawa A, Ishikawa Y, et al. Experience with ultrasonographically guided vacuum-assisted resection of benign breast tumors. Clin Radiol. Apr. 26. 2008;63(4):396-400. [pmid: 18325359].
46 Taourel P, Hoa D, Chaveron C, et al. Stereotactic vacuum biopsy of calcifications with a handheld portable biopsy system: A validation study. Eur Radiol. Jul. 2008;18(7):1319-1325. [pmid: 18351352].
47 Tozaki M, Yamashiro N, Suzuki T, et al. MR-guided vacuum-assisted breast biopsy: is it an essential technique. Breast Cancer. 2008. Sep. 20. Epub ahead of print. PMID: 18807122.
48 Tseng HS, Chen YL, Chen ST, et al. The management of papillary lesion of the breast by core needle biopsy. Eur J Surg Oncol. Jan. 2009;35(1):21-24. PMID: 18640002. [pmid: 18640002].
49 Zagouri F, Sergentanis TN, Gounaris A, et al. Pain in different methods of breast biopsy: Emphasis on vacuum-assisted breast biopsy. Breast. Feb. 2008;17(1):71-75. [pmid: 17869106].
50 Zografos G, Zagouri F, Sergentanis TN, et al. Vacuum-assisted breast biopsy in nonpalpable solid breast lesions without microcalcifications: the Greek experience. Diagn Interv Radiol. Sep. 2008;14(3):127-130. PMID: 18814132. [pmid: 18814132].
51 Zografos GC, Zagouri F, Sergentanis TN, et al. Minimizing underestimation rate of microcalcifications excised via vacuum-assisted breast biopsy: a blind study. Breast Cancer Res Treat. May. 2008;109(2):397-402. PMID: 17653855. [pmid: 17653855].
52 Zografos GC, Zagouri F, Sergentanis TN, et al. Pain during vacuum-assisted breast biopsy: Are there any predictors. Breast. Dec. 2008;17(6):592-595. Epub 2008 Jul 26. PMID: 18657974. [pmid: 18657974].
53 Andreu FJ, Saez A, Sentis M, et al. Breast core biopsy reporting categories—An internal validation in a series of 3054 consecutive lesions. Breast. Feb. 2007;16(1):94-101. PMID: 16982194. [pmid: 16982194].
54 Arora N, Hill C, Hoda SA, et al. Clinicopathologic features of papillary lesions on core needle biopsy of the breast predictive of malignancy. Am J Surg. Oct. 2007;194(4):444-449. PMID: 17826053. [pmid: 17826053].
55 Ashkenazi I, Ferrer K, Sekosan M, et al. Papillary lesions of the breast discovered on percutaneous large core and vacuum-assisted biopsies: reliability of clinical and pathological parameters in identifying benign lesions. Am J Surg. Aug. 2007;194(2):183-188. PMID: 17618801. [pmid: 17618801].
56 Bode MK, Rissanen T, Apaja-Sarkkinen M. Ultrasonography and core needle biopsy in the differential diagnosis of fibroadenoma and tumor phyllodes. Acta Radiol. Sep. 2007;48(7):708-713. PMID: 17728999. [pmid: 17728999].
57 Cassano E, Urban LA, Pizzamiglio M, et al. Ultrasound-guided vacuum-assisted core breast biopsy: experience with 406 cases. Breast Cancer Res Treat. Mar. 2007;102(1):103-110. PMID: 16838109. [pmid: 16838109].
58 Ciatto S, Houssami N. Breast imaging and needle biopsy in women with clinically evident breast cancer: does combined imaging change overall diagnostic sensitivity?. Breast. Aug. 2007;16(4):382-386. PMID: 17350262. [pmid: 17350262].
59 Dillon MF, McDermott EW, Hill AD, et al. Predictive value of breast lesions of “uncertain malignant potential” and “suspicious for malignancy” determined by needle core biopsy. Ann Surg Oncol. Feb. 2007;14(2):704-711. [pmid: 17151788].
60 Douglas-Jones AG, Denson JL, Cox AC, et al. Radial scar lesions of the breast diagnosed by needle core biopsy: analysis of cases containing occult malignancy. J Clin Pathol. Mar. 2007;60(3):295-298. PMID: 16731590. [pmid: 16731590].
61 Duchesne N, Parker SH, Lechner MC, et al. Multicenter evaluation of a new ultrasound-guided biopsy device: Improved ergonomics, sampling and rebiopsy rates. Breast J. Jan-Feb. 2007;13(1):36-43. PMID: 17214791. [pmid: 17214791].
62 Duijm LEM, Groenewoud JH, Roumen RMH, et al. A decade of breast cancer screening in the Netherlands: Trends in the preoperative diagnosis of breast cancer. Breast Cancer Res Treat. Nov. 2007;106(1):113-119. [pmid: 17219049].
63 Easley S, Abdul-Karim FW, Klein N, et al. Segregation of radiographic calcifications in stereotactic core biopsies of breast: Is it necessary?. Breast J. Sep. 2007;13(5):486-489. [pmid: 17760670].
64 Esserman LE, Lamea L, Tanev S, et al. Should the extent of lobular neoplasia on core biopsy influence the decision for excision?. Breast J. Jan. 2007;13(1):55-61. [pmid: 17214794].
65 Foxcroft LM, Evans EB, Porter AJ. Difficulties in the pre-operative diagnosis of phyllodes tumours of the breast: a study of 84 cases. Breast. Feb. 2007;16(1):27-37. PMID: 16876413. [pmid: 16876413].
66 Garg S, Mohan H, Bal A, et al. A comparative analysis of core needle biopsy and fine-needle aspiration cytology in the evaluation of palpable and mammographically detected suspicious breast lesions. Diagn Cytopathol. Nov. 2007;35(11):681-689. PMID: 17924407. [pmid: 17924407].
67 Holloway CMB, Saskin R, Brackstone M, et al. Variation in the use of percutaneous biopsy for diagnosis of breast abnormalities in Ontario. Ann Surg Oncol. Oct. 2007;14(10):2932-2939. [pmid: 17619931].
68 Houssami N, Ciatto S, Bilous M, et al. Borderline breast core needle histology: Predictive values for malignancy in lesions of uncertain malignant potential (B3). Br J Cancer. Apr. 23. 2007;96(8):1253-1257. [pmid: 17438578].
69 Karabakhtsian RG, Johnson R, Sumkin J, et al. The clinical significance of lobular neoplasia on breast core biopsy. Am J Surg Pathol. May. 2007;31(5):717-723. PMID: 17460455. [pmid: 17460455].
70 Kikuchi M, Tsunoda-Shimizu H, Kawasaki T, et al. Indications for stereotactically-guided vacuum-assisted breast biopsy for patients with category 3 microcalcifications. Breast Cancer. 2007;14(3):285-291. PMID: 17690506. [pmid: 17690506].
71 Kim MJ, Kim EK, Lee JY, et al. Breast lesions with imaging-histologic discordance during US-guided 14G automated core biopsy: can the directional vacuum-assisted removal replace the surgical excision? Initial findings. Eur Radiol. Sep. 2007;17(9):2376-2383. PMID: 17361422. [pmid: 17361422].
72 Ko ES, Cho N, Cha JH, et al. Sonographically-guided 14-gauge core needle biopsy for papillary lesions of the breast. Korean J Radiol. May-Jun. 2007;8(3):206-211. PMID: 17554187. [pmid: 17554187].
73 Krainick-Strobel U, Huber B, Majer I, et al. Complete extirpation of benign breast lesions with an ultrasound-guided vacuum biopsy system. Ultrasound Obstet Gynecol. Mar. 2007;29(3):342-346. [pmid: 17167817].
74 Kumaraswamy V, Carder PJ. Examination of breast needle core biopsy specimens performed for screen-detected microcalcification. J Clin Pathol. Jun. 2007;60(6):681-684. PMID: 16882700. [pmid: 16882700].
75 Kunju LP, Kleer CG. Significance of flat epithelial atypia on mammotome core needle biopsy: should it be excised?. Hum Pathol. Jan. 2007;38(1):35-41. [pmid: 17095049].
76 Lavoue V, Graesslin O, Classe JM, et al. Management of lobular neoplasia diagnosed by core needle biopsy: study of 52 biopsies with follow-up surgical excision. Breast. Oct. 2007;16(5):533-539. PMID: 17629481. [pmid: 17629481].
77 Lee JM, Kaplan JB, Murray MP, et al. Underestimation of DCIS at MRI-guided vacuum-assisted breast biopsy. AJR Am J Roentgenol. Aug. 2007;189(2):468-474. PMID: 17646475. [pmid: 17646475].
78 Lee J-M, Kaplan JB, Murray MP, et al. Imaging-histologic discordance at MRI-guided 9-gauge vacuum-assisted breast biopsy. AJR Am J Roentgenol. Oct. 2007;189(4):852-859. [pmid: 17885056].
79 Leikola J, Heikkila P, Pamilo M, et al. Predicting invasion in patients with DCIS in the preoperative percutaneous biopsy. Acta Oncol. 2007;46(6):798-802. [pmid: 17653903].
80 Liberman L, Holland AE, Marjan D, et al. Underestimation of atypical ductal hyperplasia at MRI-guided 9-gauge vacuum-assisted breast biopsy. AJR Am J Roentgenol. Mar. 2007;188(3):684-690. PMID: 17312054. [pmid: 17312054].
81 Londero V, Zuiani C, Furlan A, et al. Role of ultrasound and sonographically guided core biopsy in the diagnostic evaluation of ductal carcinoma in situ (DCIS) of the breast. Radiol Med. Sep. 2007;112(6):863-876. [pmid: 17891529].
82 Lourenco AP, Mainiero MB, Lazarus E, et al. Stereotactic breast biopsy: Comparison of histologic underestimation rates with 11- and 9-gauge vacuum-assisted breast biopsy. AJR Am J Roentgenol. Nov. 2007;189(5):W275-W279. PMID: 17954625. [pmid: 17954625].
83 Luczynska E, Skotnicki P, Kocurek A, et al. Vacuum mammotomy under ultrasound guidance. Pol Przegl Radiol. Jul. 2007;72(3):15-18.
84 Martel M, Barron-Rodriguez P, Tolgay Ocal I, et al. Flat DIN 1 (flat epithelial atypia) on core needle biopsy: 63 Cases identified retrospectively among 1,751 core biopsies performed over an 8-year period (1992–1999). Virchows Arch. Nov. 2007;451(5):883-891. [pmid: 17786469].
85 Mathew J, Crawford DJ, Lwin M, et al. Ultrasound-guided, vacuum-assisted excision in the diagnosis and treatment of clinically benign breast lesions. Ann R Coll Surg Engl. Jul. 2007;89(5):494-496. PMID: 17688722. [pmid: 17688722].
86 Mendel JB, Long M, Slanetz PJ. CT-guided core needle biopsy of breast lesions visible only on MRI. AJR Am J Roentgenol. Jul. 2007;189(1):152-154. PMID: 17579165. [pmid: 17579165].
87 Murta De Lucena CE, Dos Santos JL Jr, De Lima Resende CA, et al. Ultrasound-guided core needle biopsy of breast masses: How many cores are necessary to diagnose cancer?. J Clin Ultrasound. Sep. 2007;35(7):363-366. [pmid: 17663457].
88 Nakano S, Sakamoto H, Ohtsuka M, et al. Evaluation and indications of ultrasound-guided vacuum-assisted core needle breast biopsy. Breast Cancer. 2007;14(3):292-296. PMID: 17690507. [pmid: 17690507].
89 Popiela TJ, Herman-Sucharska I, Kleinrok K, et al. Core breast biopsy under MR control - Preliminary results. Pol Przegl Radiol. Apr. 2007;72(2):15-24.
90 Povoski SP, Jimenez RE. A comprehensive evaluation of the 8-gauge vacuum-assisted Mammotome system for ultrasound-guided diagnostic biopsy and selective excision of breast lesions. World J Surg Oncol. 2007;5. Article 83.
91 Rutstein LA, Johnson RR, Poller WR, et al. Predictors of residual invasive disease after core needle biopsy diagnosis of ductal carcinoma in situ. Breast J. May-Jun. 2007;13(3):251-257. PMID: 17461899. [pmid: 17461899].
92 Schaefer FK, Eden I, Schaefer PJ, et al. Factors associated with one step surgery in case of non-palpable breast cancer. Eur J Radiol. Dec. 2007;64(3):426-431. [pmid: 17386990].
93 Smitt MC, Horst K. Association of clinical and pathologic variables with lumpectomy surgical margin status after preoperative diagnosis or excisional biopsy of invasive breast cancer. Ann Surg Oncol. Mar. 2007;14(3):1040-1044. PMID: 17203329. [pmid: 17203329].
94 Sohn V, Arthurs Z, Herbert G, et al. Atypical ductal hyperplasia: Improved accuracy with the 11-gauge vacuum-assisted versus the 14-gauge core biopsy needle. Ann Surg Oncol. Sep. 2007;14(9):2497-2501. PMID: 17564749. [pmid: 17564749].
95 Sydnor MK, Wilson JD, Hijaz TA, et al. Underestimation of the presence of breast carcinoma in papillary lesions initially diagnosed at core-needle biopsy. Radiology. Jan. 2007;242(1):58-62. PMID: 17090707. [pmid: 17090707].
96 Uematsu T, Kasami M. Risk of needle tract seeding of breast cancer: cytological results derived from core wash material. Breast Cancer Res Treat. Jul. 2008;110(1):51-55. PMID: 17674195. [pmid: 17674195].
97 Uematsu T, Kasami M, Uchida Y, et al. Ultrasonographically guided 18-gauge automated core needle breast biopsy with post-fire needle position verification (PNPV). Breast Cancer. 2007;14(2):219-228. PMID: 17485909. [pmid: 17485909].
98 Usami S, Moriya T, Amari M, et al. Reliability of prognostic factors in breast carcinoma determined by core needle biopsy. Jpn J Clin Oncol. Apr. 2007;37(4):250-255. [pmid: 17485439].
99 Zagouri F, Sergentanis TN, Nonni A, et al. Vacuum-assisted breast biopsy: The value and limitations of cores with microcalcifications. Pathol Res Pract. Aug. 30. 2007;203(8):563-566. [pmid: 17611039].
100 Zografos GC, Zagouri F, Sergentanis TN, et al. Is zero underestimation feasible? Extended Vacuum-assisted breast biopsy in solid lesions—A blind study. World J Surg Oncol. May. 14. 2007;5. Article Number:53.
101 Zuiani C, Mazzarella F, Londero V, et al. Stereotactic vacuum-assisted breast biopsy: results, follow-up and correlation with radiological suspicion. Radiol Med. Mar. 2007;112(2):304-317. PMID: 17361368. [pmid: 17361368].
102 Al-Attar MA, Michell MJ, Ralleigh G, et al. The impact of image guided needle biopsy on the outcome of mammographically detected indeterminate microcalcification. Breast. Oct. 2006;15(5):635-639. PMID: 16488148. [pmid: 16488148].
103 Becker L, Trop I, David J, et al. Management of radial scars found at percutaneous breast biopsy. Can Assoc Radiol J. Apr. 2006;57(2):72-78. PMID: 16944680. [pmid: 16944680].
104 Bedei L, Falcini F, Sanna PA, et al. Atypical ductal hyperplasia of the breast: The controversial management of a borderline lesion: Experience of 47 cases diagnosed at vacuum-assisted biopsy. Breast. Apr. 2006;15(2):196-202. PMID: 16055333. [pmid: 16055333].
105 Chrzan R, Rudnicka L, Popiela T Jr, et al. The problems with histopathological verification of breast microcalcification clusters in the stereotactic mammotome biopsy specimens. Pol J Pathol. 2006;57(3):133-135. [pmid: 17219739].
106 Cox D, Bradley S, England D. The significance of mammotome core biopsy specimens without radiographically identifiable microcalcification and their influence on surgical management-A retrospective review with histological correlation. Breast. Apr. 2006;15(2):210-218. PMID: 16081287. [pmid: 16081287].
107 Dillon MF, McDermott EW, Quinn CM, et al. Predictors of invasive disease in breast cancer when core biopsy demonstrates DCIS only. J Surg Oncol. Jun. 1. 2006;93(7):559-563. [pmid: 16705731].
108 Dillon MF, Quinn CM, McDermott EW, et al. Needle core biopsy in the diagnosis of phyllodes neoplasm. Surgery. Nov. 2006;140(5):779-784. PMID: 17084721. [pmid: 17084721].
109 Fine RE, Staren ED. Percutaneous radiofrequency-assisted excision of fibroadenomas. Am J Surg. 2006;192(4):545-547. PMID: 16978972. [pmid: 16978972].
110 Fitzal F, Sporn EP, Draxler W, et al. Preoperative core needle biopsy does not increase local recurrence rate in breast cancer patients. Breast Cancer Res Treat. May. 2006;97(1):9-15. PMID: 16502019. [pmid: 16502019].
111 Gebauer B, Bostanjoglo M, Moesta KT, et al. Magnetic resonance-guided biopsy of suspicious breast lesions with a handheld vacuum biopsy device. Acta Radiol. Nov. 2006;47(9):907-913. PMID: 17077039. [pmid: 17077039].
112 Ghate SV, Rosen EL, Soo MS, et al. MRI-guided vacuum-assisted breast biopsy with a handheld portable biopsy system. AJR Am J Roentgenol. Jun. 2006;186(6):1733-1736. PMID: 16714667. [pmid: 16714667].
113 Govindarajulu S, Narreddy S, Shere MH, et al. Preoperative mammotome biopsy of ducts beneath the nipple areola complex. Eur J Surg Oncol. May. 2006;32(4):410-412. PMID: 16516432. [pmid: 16516432].
114 Hanley C, Kessaram R. Quality of diagnosis and surgical management of breast lesions in a community hospital: room for improvement?. Can J Surg. Jun. 2006;49(3):185-192. PMID: 16749979. [pmid: 16749979].
115 Hoffmann J. Analysis of surgical and diagnostic quality at a specialist breast unit. Breast. Aug. 2006;15(4):490-497. [pmid: 16343904].
116 Huo L, Sneige N, Hunt KK, et al. Predictors of invasion in patients with core-needle biopsy-diagnosed ductal carcinoma in situ and recommendations for a selective approach to sentinel lymph node biopsy in ductal carcinoma in situ. Cancer. Oct. 15. 2006;107(8):1760-1768. PMID: 16977650. [pmid: 16977650].
117 Jackman RJ, Rodriguez-Soto J. Breast microcalcifications: retrieval failure at prone stereotactic core and vacuum breast biopsy--frequency, causes, and outcome. Radiology. Apr. 2006;239(1):61-70. PMID: 16567483. [pmid: 16567483].
118 Jensen A, Rank F, Dyreborg U, et al. Performance of combined clinical mammography and needle biopsy: a nationwide study from Denmark. APMIS. Dec. 2006;114(12):884-892. PMID: 17207089. [pmid: 17207089].
119 Kamer E, Unalp HR, Akguner T, et al. Thick-needle vacuum-assisted biopsy technique for inflammatory breast carcinoma diagnosis. Acta Cir Bras. Nov. 2006;21(6):422-424. [pmid: 17160256].
120 Killebrew LK, Oneson RH. Comparison of the diagnostic accuracy of a vacuum-assisted percutaneous intact specimen sampling device to a vacuum-assisted core needle sampling device for breast biopsy: Initial experience. Breast J. Jul. 2006;12(4):302-308. PMID: 16848839. [pmid: 16848839].
121 Koskela A, Berg M, Sudah M, et al. Learning curve for add-on stereotactic core needle breast biopsy. Acta Radiol. Jun. 2006;47(5):454-460. PMID: 16796305. [pmid: 16796305].
122 Lam WW, Chu WC, Tse GM, et al. Role of fine needle aspiration and tru cut biopsy in diagnosis of mucinous carcinoma of breast--from a radiologist’s perspective. Clin Imaging. Jan-Feb. 2006;30(1):6-10. PMID: 16377477. [pmid: 16377477].
123 Lannin DR, Ponn T, Andrejeva L, et al. Should all breast cancers be diagnosed by needle biopsy?. Am J Surg. Oct. 2006;192(4):450-454. PMID: 16978947. [pmid: 16978947].
124 Liberman L, Tornos C, Huzjan R, et al. Is surgical excision warranted after benign, concordant diagnosis of papilloma at percutaneous breast biopsy?. AJR Am J Roentgenol. May. 2006;186(5):1328-1334. PMID: 16632727. [pmid: 16632727].
125 Lieske B, Ravichandran D, Wright D. Role of fine-needle aspiration cytology and core biopsy in the preoperative diagnosis of screen-detected breast carcinoma. Br J Cancer. Jul. 3. 2006;95(1):62-66. [pmid: 16755293].
126 Lim CN, Ho BC, Bay BH, et al. Nuclear morphometry in columnar cell lesions of the breast: is it useful?. J Clin Pathol. Dec. 2006;59(12):1283-1286. PMID: 16603646. [pmid: 16603646].
127 Lopez-Medina A, Cintora E, Mugica B, et al. Radial scars diagnosed at stereotactic core-needle biopsy: Surgical biopsy findings. Eur Radiol. Aug. 2006;16(8):1803-1810. PMID: 16708220. [pmid: 16708220].
128 Margenthaler JA, Duke D, Monsees BS, et al. Correlation between core biopsy and excisional biopsy in breast high-risk lesions. Am J Surg. Oct. 2006;192(4):534-537. PMID: 16978969. [pmid: 16978969].
129 Mercado CL, Hamele-Bena D, Oken SM, et al. Papillary lesions of the breast at percutaneous core-needle biopsy. Radiology. Mar. 2006;238(3):801-808. PMID: 16424237. [pmid: 16424237].
130 Newman EL, Kahn A, Diehl KM, et al. Does the method of biopsy affect the incidence of sentinel lymph node metastases?. Breast J. Jan. 2006;12(1):53-57. PMID: 16409587. [pmid: 16409587].
131 Orel SG, Rosen M, Mies C, et al. MR imaging-guided 9-gauge vacuum-assisted core-neddle breast biopsy: Initial experience. Radiology. Jan. 2006;238(1):54-61. PMID: 16304093. [pmid: 16304093].
132 Perlet C, Heywang-Kobrunner SH, Heinig A, et al. Magnetic resonance-guided, vacuum-assisted breast biopsy: Results from a European multicenter study of 538 lesions. Cancer. Mar. 1. 2006;106(5):982-990. PMID: 16456807. [pmid: 16456807].
133 Popiela TJ, Tabor J, Chrzan R, Posiadlo-Kleinrok B, Urbanik A. Mammotome biopsy in the diagnostic management of non-palpable breast pathologies. Pol Przegl Radiol. Jul. 2006;71(3):48-56.
134 Renshaw AA, Gould EW. Comparison of disagreement and amendment rates by tissue type and diagnosis: identifying cases for directed blinded review. Am J Clin Pathol. Nov. 2006;126(5):736-739. PMID: 17050070. [pmid: 17050070].
135 Renshaw AA, Derhagopian RP, Martinez P, et al. Lobular neoplasia in breast core needle biopsy specimens is associated with a low risk of ductal carcinoma in situ or invasive carcinoma on subsequent excision. Am J Clin Pathol. Aug. 2006;126(2):310-313. PMID: 16891208. [pmid: 16891208].
136 Senn Bahls E, Dupont Lampert V, Oelschlegel C, et al. Multitarget stereotactic core-needle breast biopsy (MSBB)-an effective and safe diagnostic intervention for non-palpable breast lesions: A large prospective single institution study. Breast. Jun. 2006;15(3):339-346. [pmid: 16488609].
137 Shin S, Schneider HB, Cole Jr FJ, et al. Follow-up recommendations for benign breast biopsies. Breast J. Sep. 2006;12(5):413-417. [pmid: 16958957].
138 Sie A, Bryan DC, Gaines V, et al. Multicenter evaluation of the breast lesion excision system, a percutaneous, vacuum-assisted, intact-specimen breast biopsy device. Cancer. Sep. 1. 2006;107(5):945-949. PMID: 16874817. [pmid: 16874817].
139 Uriburu JL, Vuoto HD, Cogorno L, et al. Local recurrence of breast cancer after skin-sparing mastectomy following core needle biopsy: Case reports and review of the literature. Breast J. May. 2006;12(3):194-198. PMID: 16684314. [pmid: 16684314].
140 Valdes EK, Tartter PI, Genelus-Dominique E, et al. Significance of papillary lesions at percutaneous breast biopsy. Ann Surg Oncol. Apr. 2006;13(4):480-482. [pmid: 16474908].
141 Vargas HI, Vargas MP, Gonzalez K, et al. Percutaneous excisional biopsy of palpable breast masses under ultrasound visualization. Breast J. Sep. 2006;12(Suppl 2):S218-S222. PMID: 16959005. [pmid: 16959005].
142 Viehweg P, Bernerth T, Kiechle M, et al. MR-guided intervention in women with a family history of breast cancer. Eur J Radiol. Jan. 2006;57(1):81-89. PMID: 16364583. [pmid: 16364583].
143 Wu YC, Chen DR, Kuo SJ. Personal experience of ultrasound-guided 14-gauge core biopsy of breast tumor. Eur J Surg Oncol. Sep. 2006;32(7):715-718. PMID: 16769196. [pmid: 16769196].
144 Yazici B, Sever AR, Mills P, et al. Scar formation after stereotactic vacuum-assisted core biopsy of benign breast lesions. Clin Radiol. Jul. 2006;61(7):619-624. PMID: 16784949. [pmid: 16784949].
145 Altomare V, Guerriero G, Giacomelli L, et al. Management of nonpalpable breast lesions in a modern functional breast unit. Breast Cancer Res Treat. Sep. 2005;93(1):85-89. PMID: 16184463. [pmid: 16184463].
146 Badoual C, Maruani A, Ghorra C, et al. Pathological prognostic factors of invasive breast carcinoma in ultrasound-guided large core biopsies - Correlation with subsequent surgical excisions. Breast. Feb. 2005;14(1):22-27. PMID: 15695077. [pmid: 15695077].
147 Bonifacino A, Petrocelli V, Pisani T, et al. Accuracy rates of US-guided vacuum-assisted breast biopsy. Anticancer Res. May. 2005;25(3 C):2465-2470. PMID: 16080477. [pmid: 16080477].
148 Brem RF, Tran K, Rapelyea J, et al. Percutaneous biopsy of papillary lesions of the breast: Accuracy of pathologic diagnosis. J Womens Imaging. Dec. 2005;7(4):157-162.
149 Caines JS, Schaller GH, Iles SE, et al. Ten years of breast screening in the Nova Scotia Breast Screening Program, 1991–2001. Experience: Use of an adaptable stereotactic device in the diagnosis of screening-detected abnormalities. Can Assoc Radiol J. Apr. 2005;56(2):82-93. [pmid: 15957275].
150 Cho N, Moon WK, Cha JH, et al. Sonographically guided core biopsy of the breast: comparison of 14-gauge automated gun and 11-gauge directional vacuum-assisted biopsy methods. Korean J Radiol. Apr-Jun. 2005;6(2):102-109. PMID: 15968149. [pmid: 15968149].
151 Costantini R, Sardellone A, Marino C, et al. Vacuum-assisted core biopsy (mammotome) for the diagnosis of non-palpable breast lesions: Four-year experience in an Italian center. Tumori. Jul. 2005;91(4):351-354. PMID: 16277103. [pmid: 16277103].
152 Diebold T, Hahn T, Solbach C, et al. Evaluation of the stereotactic 8G vacuum-assisted breast biopsy in the histologic evaluation of suspicious mammography findings (BI-RADS IV). Invest Radiol. Jul. 2005;40(7):465-471. PMID: 15973139. [pmid: 15973139].
153 Doridot V, Meunier M, El Khoury C, et al. Stereotactic radioguided surgery by siteSelect for subclinical mammographic lesions. Ann Surg Oncol. Feb. 2005;12(2):181-188. PMID: 15827800. [pmid: 15827800].
154 Doyle JM, O’Doherty A, Coffey L, et al. Can the radiologist accurately predict the adequacy of sampling when performing ultrasound-guided core biopsy of BI-RADS category 4 and 5 lesions detected on screening mammography?. Clin Radiol. Sep. 2005;60(9):999-1005. PMID: 16124982. [pmid: 16124982].
155 Elsheikh TM, Silverman JF. Follow-up surgical excision is indicated when breast core needle biopsies show atypical lobular hyperplasia or lobular carcinoma in situ: a correlative study of 33 patients with review of the literature. Am J Surg Pathol. Apr. 2005;29(4):534-543. PMID: 15767810. [pmid: 15767810].
156 Gambos EC, Godinez J, Poppiti RJ Jr. Significance of extent of lobular neoplasia on breast core biopsy. J Womens Imaging. Dec. 2005;7(4):150-156.
157 Grady I, Gorsuch H, Wilburn-Bailey S. Ultrasound-guided, vacuum-assisted, percutaneous excision of breast lesions: an accurate technique in the diagnosis of atypical ductal hyperplasia. J Am Coll Surg. Jul. 2005;201(1):14-17. PMID: 15978438. [pmid: 15978438].
158 Hanna WC, Demyttenaere SV, Ferri LE, et al. The use of stereotactic excisional biopsy in the management of invasive breast cancer. World J Surg. Nov. 2005;29(11):1490-1494. PMID: 16240063. [pmid: 16240063].
159 Homesh NA, Issa MA, El-Sofiani HA. The diagnostic accuracy of fine needle aspiration cytology versus core needle biopsy for palpable breast lump(s). Saudi Med J. Jan. 2005;26(1):42-46. PMID: 15756351. [pmid: 15756351].
160 Lehman CD, DePeri ER, Peacock S, et al. Clinical experience with MRI-guided vacuum-assisted breast biopsy. AJR Am J Roentgenol. Jun. 2005;184(6):1782-1787. PMID: 15908530. [pmid: 15908530].
161 Monticciolo DL. Histologic grading at breast core needle biopsy: Comparison with results from the excised breast specimen. Breast J. Jan. 2005;11(1):9-14. PMID: 15647072. [pmid: 15647072].
162 Pilgrim S, Ravichandran D. Fine needle aspiration cytology as an adjunct to core biopsy in the assessment of symptomatic breast carcinoma. Breast. Oct. 2005;14(5):411-414. [pmid: 16216746].
163 Qazi D-E-S, Mohayuddin N. Role of fine needle aspiration cytology and core biopsy in the diagnosis of breast lumps. J Postgrad Med Inst. Jan. 2005;19(1):67-70.
164 Riedl CC, Pfarl G, Memarsadeghi M, et al. Lesion miss rates and false-negative rates for 1115 consecutive cases of stereotactically guided needle-localized open breast biopsy with long-term follow-up. Radiology. Dec. 2005;237(3):847-853. PMID: 16237133. [pmid: 16237133].
165 Rulli A, Lauro A, Bisacci C, et al. Non-palpable breast lesion-biopsy by ABBI system: A diagnostic tool. Chirurgia. Aug. 2005;18(4):175-179.
166 Satchithananda K, Fernando RA, Ralleigh G, et al. An audit of pain/discomfort experienced during image-guided breast biopsy procedures. Breast J. Nov-Dec. 2005;11(6):398-402. PMID: 16297083. [pmid: 16297083].
167 Schneider J, Lucas R, Tejerina A. Predicting complete removal of impalpable breast carcinomas using stereotactic radiologically guided surgery. Br J Surg. May. 2005;92(5):563-564. PMID: 15739212. [pmid: 15739212].
168 Soo MS, Kliewer MA, Ghate S, et al. Stereotactic breast biopsy of noncalcified lesions: A cost-minimization analysis comparing 14-gauge multipass automated core biopsy to 14- and 11-gauge vacuum-assisted biopsy. Clin Imaging. Jan. 2005;29(1):26-33. [pmid: 15859015].
169 Wahner-Roedler DL, Whaley DH, Brandt KR, et al. Vacuum-assisted breast biopsy device (Mammotome) malfunction simulating microcalcifications. Breast J. Nov. 2005;11(6):474-475. [pmid: 16297098].
170 Wiratkapun C, Wibulpholprasert B, Wongwaisayawan S, et al. Nondiagnostic core needle biopsy of the breast under imaging guidance: result of rebiopsy. J Med Assoc Thai. Mar. 2005;88(3):350-357. PMID: 15962643. [pmid: 15962643].
171 Wong TT, Cheung PS, Ma MK, et al. Experience of stereotactic breast biopsy using the vacuum-assisted core needle biopsy device and the advanced breast biopsy instrumentation system in Hong Kong women. Asian J Surg. Jan. 2005;28(1):18-23. [pmid: 15691792].
172 You JK, Kim EK, Kwak JY, et al. Focal fibrosis of the breast diagnosed by a sonographically guided core biopsy of nonpalpable lesions: imaging findings and clinical relevance. J Ultrasound Med. Oct. 2005;24(10):1377-1384. PMID: 16179621. [pmid: 16179621].
173 Zuiani C, Londero V, Bestagno A, et al. Proliferative high-risk lesions of the breast: Contribution and limits of US-guided core biopsy. Radiol Med. Nov. 2005;110(5–6):589-602. PMID: 16437044. [pmid: 16437044].
174 Agoff SN, Lawton TJ. Papillary lesions of the breast with and without atypical ductal hyperplasia: Can we accurately predict benign behavior from core needle biopsy. Am J Clin Pathol. Sep. 2004;122(3):440-443. [pmid: 15362376].
175 Arpino G, Allred DC, Mohsin SK, et al. Lobular neoplasia on core-needle biopsy--clinical significance. Cancer. Jul. 15. 2004;101(2):242-250. PMID: 15241819. [pmid: 15241819].
176 Carmon M, Rivkin L, Abu-Dalo R, et al. Increased mammographic screening and use of percutaneous image-guided core biopsy in non-palpable breast cancer: Impact on surgical treatment. Isr Med Assoc J. Jun. 2004;6(6):326-328. PMID: 15214456. [pmid: 15214456].
177 Chagpar AB, Martin RCG II, Hagendoorn LJ, et al. Lumpectomy margins are affected by tumor size and histologic subtype but not by biopsy technique. Am J Surg. Oct. 2004;188(4 Spec issue):399-402. [pmid: 15474434].
178 Chen X, Lehman CD, Dee KE. MRI-guided breast biopsy: clinical experience with 14-gauge stainless steel core biopsy needle. AJR Am J Roentgenol. Apr. 2004;182(4):1075-1080. PMID: 15039191. [pmid: 15039191].
179 Collins LC, Connolly JL, Page DL, et al. Diagnostic agreement in the evaluation of image-guided breast core needle biopsies: results from a randomized clinical trial. Am J Surg Pathol. Jan. 2004;28(1):126-131. PMID: 14707874. [pmid: 14707874].
180 Docktor BJ, MacGregor JH, Burrowes PW. Ultrasonographic findings 6 months after 11-gauge vacuum-assisted large-core breast biopsy. Can Assoc Radiol J. Jun. 2004;55(3):151-156. PMID: 15237775. [pmid: 15237775].
181 Foster MC, Helvie MA, Gregory NE, et al. Lobular carcinoma in situ or atypical lobular hyperplasia at core-needle biopsy: is excisional biopsy necessary?. Radiology. Jun. 2004;231(3):813-819. PMID: 15105449. [pmid: 15105449].
182 Gan FY, Wettlaufer JR, Lundell AL. Breast imaging in a military setting: a comparison with civilian breast imaging. Mil Med. May. 2004;169(5):361-367. PMID: 15186000. [pmid: 15186000].
183 Geller BM, Oppenheimer RG, Mickey RM, et al. Patient perceptions of breast biopsy procedures for screen-detected lesions. Am J Obstet Gynecol. Apr. 2004;190(4):1063-1069. PMID: 15118643. [pmid: 15118643].
184 Gendler LS, Feldman SM, Balassanian R, et al. Association of breast cancer with papillary lesions identified at percutaneous image-guided breast biopsy. Am J Surg. Oct. 2004;188(4):365-370. PMID: 15474427. [pmid: 15474427].
185 Georgian-Smith D, Kricun B, et al. The mammary hamartoma: appreciation of additional imaging characteristics. J Ultrasound Med. Oct. 2004;23(10):1267-1273. PMID: 15448315. [pmid: 15448315].
186 Golshan M, Fung BB, Wiley E, et al. Prediction of breast cancer size by ultrasound, mammography and core biopsy. Breast. Aug. 2004;13(4):265-271. PMID: 15325659. [pmid: 15325659].
187 Golub RM, Bennett CL, Stinson T, et al. Cost minimization study of image-guided core biopsy versus surgical excisional biopsy for women with abnormal mammograms. J Clin Oncol. 2004;22(12):2430-2437. [pmid: 15197205].
188 Hansen NM, Ye X, Grube BJ, et al. Manipulation of the primary breast tumor and the incidence of sentinel node metastases from invasive breast cancer. Arch Surg. Jun. 2004;139(6):634-640. [pmid: 15197090].
189 Hoorntje LE, Peeters PH, Mali WP, et al. Is stereotactic large-core needle biopsy beneficial prior to surgical treatment in BI-RADS 5 lesions?. Breast Cancer Res Treat. Jul. 2004;86(2):165-170. PMID: 15319568. [pmid: 15319568].
190 Hoorntje LE, Schipper MEI, et al. Tumour cell displacement after 14G breast biopsy. Eur J Surg Oncol. Jun. 2004;30(5):520-525. [pmid: 15135480].
191 Ivan D, Selinko V, Sahin AA, et al. Accuracy of core needle biopsy diagnosis in assessing papillary breast lesions: histologic predictors of malignancy. Mod Pathol. Feb. 2004;17(2):165-171. PMID: 14631369. [pmid: 14631369].
192 Margolin FR, Kaufman L, Jacobs RP, et al. Stereotactic core breast biopsy of malignant calcifications: Diagnostic yield of cores with and cores without calcifications on specimen radiographs. Radiology. Oct. 2004;233(1):251-254. PMID: 15333764. [pmid: 15333764].
193 Mendez A, Cabanillas F, Echenique M, et al. Evaluation of Breast Imaging Reporting and Data System Category 3 mammograms and the use of stereotactic vacuum-assisted breast biopsy in a nonacademic community practice. Cancer. Feb. 15. 2004;100(4):710-714. PMID: 14770425. [pmid: 14770425].
194 O’Leary R, Hawkins K, Beazley JCS, et al. Agreement between preoperative core needle biopsy and postoperative invasive breast cancer histopathology is not dependent on the amount of clinical material obtained. J Clin Pathol. Feb. 2004;57(2):193-195. [pmid: 14747449].
195 Peters-Engl C, Konstantiniuk P, Tausch C, et al. The impact of preoperative breast biopsy on the risk of sentinel lymph node metastases: Analysis of 2502 cases from the Austrian sentinel node biopsy study group. Br J Cancer. Nov. 15. 2004;91(10):1782-1786. [pmid: 15477859].
196 Piana De Andrade V, Gobbi H. Accuracy of typing and grading invasive mammary carcinomas on core needle biopsy compared with the excisional specimen. Virchows Arch. Dec. 2004;445(6):597-602. [pmid: 15480766].
197 Pijnappel RM, van den Donk M, Holland R, et al. Diagnostic accuracy for different strategies of image-guided breast intervention in cases of nonpalpable breast lesions. Br J Cancer. Feb. 9. 2004;90(3):595-600. PMID: 14760370. [pmid: 14760370].
198 Renshaw AA. Minimal (< or =0.1 cm) invasive carcinoma in breast core needle biopsies. Incidence, sampling, associated findings, and follow-up. Arch Pathol Lab Med. Sep. 2004;128(9):996-999. PMID: 15335264. [pmid: 15335264].
199 Renshaw AA, Derhagopian RP, Tizol-Blanco DM, et al. Papillomas and atypical papillomas in breast core needle biopsy specimens: Risk of carcinoma in subsequent excision. Am J Clin Pathol. Aug. 2004;122(2):217-221. [pmid: 15323138].
200 Rotenberg L, Verhille R, Schulz-Wendtland R, et al. Multicenter clinical experience with large core soft tissue biopsy without vacuum assistance. Eur J Cancer Prev. Dec. 2004;13(6):491-498. PMID: 15548942. [pmid: 15548942].
201 Agarwal T, Patel B, Rajan P, et al. Core biopsy versus FNAC for palpable breast cancers. Is image guidance necessary?. Eur J Cancer. Jan. 2003;39(1):52-56. PMID: 12504658. [pmid: 12504658].
202 Baez E, Huber A, Vetter M, et al. Minimal invasive complete excision of benign breast tumors using a three-dimensional ultrasound-guided mammotome vacuum device. Ultrasound Obstet Gynecol. Mar. 2003;21(3):267-272. PMID: 12666222. [pmid: 12666222].
203 Bauer VP, Ditkoff BA, Schnabel F, et al. The management of lobular neoplasia identified on percutaneous core breast biopsy. Breast J. Jan. 2003;9(1):4-9. PMID: 12558663. [pmid: 12558663].
204 Berg WA, Campassi CI, Ioffe OB. Cystic lesions of the breast: sonographic-pathologic correlation. Radiology. Apr. 2003;227(1):183-191. PMID: 12668745. [pmid: 12668745].
205 Bonnett M, Wallis T, Rossmann M, et al. Histopathologic analysis of atypical lesions in image-guided core breast biopsies. Mod Pathol. Feb. 1. 2003;16(2):154-160. PMID: 12591968. [pmid: 12591968].
206 Brenner RJ, Jackman RJ, Parker SH, et al. Percutaneous core needle biopsy of radial scars of the breast: when is excision necessary?. AJR Am J Roentgenol. Jul. 2003;181(1):275. author reply 275. PMID: 12388495.
207 Carder PJ, Liston JC. Will the spectrum of lesions prompting a “B3” breast core biopsy increase the benign biopsy rate?. J Clin Pathol. Feb. 2003;56(2):133-138. PMID: 12560393. [pmid: 12560393].
208 Cawson JN, Malara F, Kavanagh A, et al. Fourteen-gauge needle core biopsy of mammographically evident radial scars: Is excision necessary?. Cancer. Jan. 15. 2003;97(2):345-351. PMID: 12518358. [pmid: 12518358].
209 Charles M, Edge SB, Winston JS, et al. Effect of stereotactic core needle biopsy on pathologic measurement of tumor size of T1 invasive breast carcinomas presenting as mammographic masses. Cancer. May. 1. 2003;97(9):2137-2141. [pmid: 12712464].
210 Chen SC, Yang HR, Hwang TL, et al. Intraoperative ultrasonographically guided excisional biopsy or vacuum-assisted core needle biopsy for nonpalpable breast lesions. Ann Surg. Nov. 2003;238(5):738-742. PMID: 14578737. [pmid: 14578737].
211 Corn CC. Review of 125 SiteSelect stereotactic large-core breast biopsy procedures. Breast J. May-Jun. 2003;9(3):147-152. PMID: 12752621. [pmid: 12752621].
212 Crisi GM, Mandavilli S, Cronin E, et al. Invasive mammary carcinoma after immediate and short-term follow-up for lobular neoplasia on core biopsy. Am J Surg Pathol. Mar. 1. 2003;27(3):325-333. [pmid: 12604888].
213 Crowe JP Jr, Rim A, Patrick RJ, et al. Does core needle breast biopsy accurately reflect breast pathology?. Surgery. Oct. 2003;134(4):523-528. [pmid: 14605609].
214 Dennison G, Anand R, Makar SH, et al. A prospective study of the use of fine-needle aspiration cytology and core biopsy in the diagnosis of breast cancer. Breast J. Nov. 2003;9(6):491-493. PMID: 14616944. [pmid: 14616944].
215 Dmytrasz K, Tartter PI, Mizrachy H, et al. The significance of atypical lobular hyperplasia at percutaneous breast biopsy. Breast J. Jan. 2003;9(1):10-12. [pmid: 12558664].
216 Farshid G, Rush G. The use of fine-needle aspiration cytology and core biopsy in the assessment of highly suspicious mammographic microcalcifications: analysis of outcome for 182 lesions detected in the setting of a population-based breast cancer screening program. Cancer Cytol. Dec. 25. 2003;99(6):357-364. PMID: 14681944.
217 Fine RE, Whitworth PW, Kim JA, et al. Low-risk palpable breast masses removed using a vacuum-assisted hand-held device. Am J Surg. Oct. 2003;186(4):362-367. PMID: 14553851. [pmid: 14553851].
218 Fures R, Bukovic D, Lez C, et al. Large-gauge needle biopsy in diagnosing malignant breast neoplasia. Coll Antropol. Jun. 2003;27(1):259-262. PMID: 12974154. [pmid: 12974154].
219 Harris GC, Denley HE, Pinder SE, et al. Correlation of histologic prognostic factors in core biopsies and therapeutic excisions of invasive breast carcinoma. Am J Surg Pathol. Jan. 1. 2003;27(1):11-15. [pmid: 12502923].
220 Hoorntje LE, Schipper MEI, Peeters PHM, et al. The finding of invasive cancer after a preoperative diagnosis of ductal carcinoma-in-situ: Causes of ductal carcinoma-in-situ underestimates with stereotactic 14-gauge needle biopsy. Ann Surg Oncol. 2003;10(7):748-753. [pmid: 12900365].
221 Jackman RJ, Marzoni FA Jr. Stereotactic histologic biopsy with patients prone: technical feasibility in 98% of mammographically detected lesions. AJR Am J Roentgenol. Mar. 2003;180(3):785-794. PMID: 12591697. [pmid: 12591697].
222 Kneeshaw PJ, Turnbull LW, Smith A, et al. Dynamic contrast enhanced magnetic resonance imaging aids the surgical management of invasive lobular breast cancer. Eur J Surg Oncol. Feb. 2003;29(1):32-37. PMID: 12559074. [pmid: 12559074].
223 Komenaka IK, El-Tamer M, Pile-Spellman E, et al. Core needle biopsy as a diagnostic tool to differentiate phyllodes tumor from fibroadenoma. Arch Surg. Sep. 1. 2003;138(9):987-990. [pmid: 12963656].
224 Lee AHS, Denley HE, Pinder SE, et al. Excision biopsy findings of patients with breast needle core biopsies reported as suspicious of malignancy (B4) or lesion of uncertain malignant potential (B3). Histopathology. Apr. 1. 2003;42(4):331-336. [pmid: 12653944].
225 Leifland K, Lagerstedt U, Svane G. Comparison of stereotactic fine needle aspiration cytology and core needle biopsy in 522 non-palpable breast lesions. Acta Radiol. Jul. 2003;44(4):387-391. PMID: 12846688. [pmid: 12846688].
226 Leifland K, Lundquist H, Lagerstedt U, et al. Comparison of preoperative simultaneous stereotactic fine needle aspiration biopsy and stereotactic core needle biopsy in ductal carcinoma in situ of the breast. Acta Radiol. Mar. 2003;44(2):213-217. PMID: 12694110. [pmid: 12694110].
227 Liberman L, Morris EA, Dershaw DD, et al. Fast MRI-guided vacuum-assisted breast biopsy: initial experience. AJR Am J Roentgenol. Nov. 2003;181(5):1283-1293. PMID: 14573421. [pmid: 14573421].
228 Mariotti C, Feliciotti F, Baldarelli M, et al. Digital stereotactic biopsies for nonpalpable breast lesion. Surg Endosc. Jun. 2003;17(6):911-917. PMID: 12632135. [pmid: 12632135].
229 Masood S, Loya A, Khalbuss W. Is core needle biopsy superior to fine-needle aspiration biopsy in the diagnosis of papillary breast lesions?. Diagn Cytopathol. Jun. 2003;28(6):329-334. PMID: 12768640. [pmid: 12768640].
230 Middleton LP, Grant S, Stephens T, et al. Lobular carcinoma in situ diagnosed by core needle biopsy: When should it be excised?. Mod Pathol. Feb. 1. 2003;16(2):120-129. PMID: 12591964. [pmid: 12591964].
231 Miller KL, Marks LB, Barrier RC Jr, et al. Increased sectioning of pathologic specimens with ductal carcinoma in situ of the breast: are there clinical consequences?. Clin Breast Cancer. Aug. 2003;4(3):198-202. PMID: 14499013. [pmid: 14499013].
232 Puglisi F, Zuiani C, Bazzocchi M, et al. Role of mammography, ultrasound and large core biopsy in the diagnostic evaluation of papillary breast lesions. Oncology. 2003;65(4):311-315. PMID: 14707450. [pmid: 14707450].
233 Shah VI, Raju U, Chitale D, et al. False-negative core needle biopsies of the breast: An analysis of clinical, radiologic, and pathologic findings in 27 consecutive cases of missed breast cancer. Cancer. Apr. 15. 2003;97(8):1824-1831. PMID: 12673707. [pmid: 12673707].
234 Sneige N, Lim SC, Whitman GJ, et al. Atypical ductal hyperplasia diagnosis by directional vacuum-assisted stereotactic biopsy of breast microcalcifications. Considerations for surgical excision. Am J Clin Pathol. Feb. 2003;119(2):248-253. PMID: 12579995. [pmid: 12579995].
235 Sperber F, Blank A, Metser U, et al. Diagnosis and treatment of breast fibroadenomas by ultrasound-guided vacuum-assisted biopsy. Arch Surg. Jul. 2003;138(7):796-800. PMID: 12860764. [pmid: 12860764].
236 Tsang FHF, Lo JJ, Wong JLN, et al. Application of image-guided biopsy for impalpable breast lesions in Chinese women. ANZ J Surg. Jan. 2003;73(1–2):23-25. [pmid: 12534733].
237 Verkooijen HM, Peterse JL, Schipper MEI, et al. Interobserver variability between general and expert pathologists during the histopathological assessment of large-core needle and open biopsies of non-palpable breast lesions. Eur J Cancer. Oct. 2003;39(15):2187-2191. [pmid: 14522377].
238 Winchester DJ, Bernstein JR, Jeske JM, et al. Upstaging of atypical ductal hyperplasia after vacuum-assisted 11-gauge stereotactic core needle biopsy. Arch Surg. Jun. 2003;138(6):619-22. discussion 622–623. PMID: 12799332. [pmid: 12799332].
239 Witt A, Yavuz D, Walchetseder C, et al. Preoperative core needle biopsy as an independent risk factor for wound infection after breast surgery. Obstet Gynecol. Apr. 1. 2003;101(4):745-750. PMID: 12681880. [pmid: 12681880].
240 Yeh I-T, Dimitrov D, Otto P, et al. Pathologic review of atypical hyperplasia identified by image-guided breast needle core biopsy: Correlation with excision specimen. Arch Pathol Lab Med. Jan. 2003;127(1):49-54. [pmid: 12521366].
241 Zhao L, Freimanis R, Bergman S, et al. Biopsy needle technique and the accuracy of diagnosis of atypical ductal hyperplasia for mammographic abnormalities. Am Surg. Sep. 2003;69(9):757-762. discussion 762. PMID: 14509322. [pmid: 14509322].
242 Acheson MB, Patton RG, Howisey RL, et al. Three- to six-year followup for 379 benign image-guided large-core needle biopsies of nonpalpable breast abnormalities. J Am Coll Surg. Oct. 2002;195(4):462-466. PMID: 12375750. [pmid: 12375750].
243 Bonnett M, Wallis T, Rossmann M, et al. Histologic and radiographic analysis of ductal carcinoma in situ diagnosed using stereotactic incisional core breast biopsy. Mod Pathol. 2002;15(2):95-101. [pmid: 11850537].
244 Chen AM, Haffty BG, Lee CH. Local recurrence of breast cancer after breast conservation therapy in patients examined by means of stereotactic core-needle biopsy. Radiology. Dec. 2002;225(3):707-712. PMID: 12461249. [pmid: 12461249].
245 Chun K, Velanovich V. Patient-perceived cosmesis and satisfaction after breast biopsy: Comparison of stereotactic incisional, excisional, and wire-localized biopsy techniques. Surgery. 2002;131(5):497-501. PMID: 12019401. [pmid: 12019401].
246 Fine RE, Boyd BA, Whitworth PW, et al. Percutaneous removal of benign breast masses using a vacuum-assisted hand-held device with ultrasound. Am J Surg. Oct. 1. 2002;184(4):332-336. PMID: 12383895. [pmid: 12383895].
247 Gal-Gombos EC, Esserman LE, Recine MA, et al. Large-needle core biopsy in atypical intraductal epithelial hyperplasia including immunohistochemical expression of high molecular weight cytokeratin: analysis of results of a single institution. Breast J. Sep-Oct. 2002;8(5):269-274. PMID: 12199753. [pmid: 12199753].
248 Giardina C, Guerrieri AM, Ingravallo G, et al. [Mammary stereotaxic core-biopsy by Mammotome: An alternative to frozen section examination]. Pathologica. Aug. 2002;94(4):182-189. (Ita). [pmid: 12325416].
249 Haj M, Kniaz D, Eitan A, et al. Three years of experience with advanced breast biopsy instrumentation (ABBI). Breast J. Sep. 2002;8(5):275-280. PMID: 12199754. [pmid: 12199754].
250 Harvey JM, Sterrett GF, Frost FA. Atypical ductal hyperplasia and atypia of uncertain significance in core biopsies from mammographically detected lesions: correlation with excision diagnosis. Pathology. Oct. 2002;34(5):410-416. PMID: 12408338. [pmid: 12408338].
251 Hoorntje LE, Peeters PHM, Borel Rinkes IHM, et al. Stereotactic large core needle biopsy for all nonpalpable breast lesions?. Breast Cancer Res Treat. 2002;73(2):177-182. [pmid: 12088119].
252 Hui JY, Chan LK, Chan RL, et al. Prone table stereotactic breast biopsy. Hong Kong Med J. Dec. 2002;8(6):447-451. PMID: 12459602. [pmid: 12459602].
253 Insausti LP, Alberro JA, Regueira FM, et al. An experience with the Advanced Breast Biopsy Instrumentation (ABBI) system in the management of non-palpable breast lesions. Eur Radiol. Jul. 1. 2002;12(7):1703-1710. [pmid: 12111061].
254 Jackman RJ, Birdwell RL, Ikeda DM. Atypical ductal hyperplasia: can some lesions be defined as probably benign after stereotactic 11-gauge vacuum-assisted biopsy, eliminating the recommendation for surgical excision. Radiology. Aug. 2002;224(2):548-554. PMID: 12147855. [pmid: 12147855].
255 Jan WA, Zada N, Samieullah, et al. Comparison of FNAC and core biopsy for evaluating breast lumps. Med Forum Mon. Dec. 1. 2002;13(12):26-28.
256 Knight R, Horiuchi K, Parker SH, et al. Risk of needle-track seeding after diagnostic image-guided core needle biopsy in breast cancer. J Soc Laparoendosc Surg. Jul-Sep. 2002;6(3):207-209. PMID: 12166757.
257 Liberman L, Goodstine SL, Dershaw DD, et al. One operation after percutaneous diagnosis of nonpalpable breast cancer: Frequency and associated factors. AJR Am J Roentgenol. 2002;178(3):673-679. PMID: 11856696. [pmid: 11856696].
258 Lifrange E, Dondelinger RF, Foidart JM, et al. Percutaneous stereotactic en bloc excision of nonpalpable breast carcinoma: A step in the direction of supraconservative surgery. Breast. Dec. 2002;11(6):501-508. [pmid: 14965717].
259 Mainiero MB, Gareen IF, Bird CE, et al. Preferential use of sonographically guided biopsy to minimize patient discomfort and procedure time in a percutaneous image-guided breast biopsy program. J Ultrasound Med. Nov. 2002;21(11):1221-1226. PMID: 12418763. [pmid: 12418763].
260 McKee MD, Cropp MD, Hyland A, et al. Provider case volume and outcome in the evaluation and treatment of patients with mammogram-detected breast carcinoma. Cancer. Aug. 15. 2002;95(4):704-712. [pmid: 12209712].
261 Perlet C, Schneider P, Amaya B, et al. MR-Guided vacuum biopsy of 206 contrast-enhancing breast lesions. Rofo Fortschr Geb Rontgenstr Neuen Bildgeb Verfahr. Jan. 2002;174(1):88-95. PMID: 11793291. [pmid: 11793291].
262 Pijnappel RM, Peeters PH, van den Donk M, et al. Diagnostic strategies in non-palpable breast lesions. Eur J Cancer. Mar. 2002;38(4):550-555. PMID: 11872348. [pmid: 11872348].
263 Popiela TJ, Tabor J, Nowak W, et al. Detectability of pre-clinical breast pathologies in own experience. Pol Przegl Chir. 2002;74(1):36-43.
264 Rao A, Parker S, Ratzer E, et al. Atypical ductal hyperplasia of the breast diagnosed by 11-gauge directional vacuum-assisted biopsy. Am J Surg. Dec. 2002;184(6):534-537. discussion 537. PMID: 12488158. [pmid: 12488158].
265 Renshaw AA. Can mucinous lesions of the breast be reliably diagnosed by core needle biopsy?. Am J Clin Pathol. 2002;118(1):82-84. PMID: 12109860. [pmid: 12109860].
266 Renshaw AA, Cartagena N, Derhagopian RP, et al. Lobular neoplasia in breast core needle biopsy specimens is not associated with an increased risk of ductal carcinoma in situ or invasive carcinoma. Am J Clin Pathol. 2002;117(5):797-799. [pmid: 12090431].
267 Rosen EL, Bentley RC, Baker JA, et al. Imaging-guided core needle biopsy of papillary lesions of the breast. AJR Am J Roentgenol. Nov. 2002;179(5):1185-1192. PMID: 12388496. [pmid: 12388496].
268 Schneider JP, Schulz T, Horn LC, et al. MR-guided percutaneous core biopsy of small breast lesions: first experience with a vertically open 0.5T scanner. J Magn Reson Imaging. Apr. 2002;15(4):374-385. PMID: 11948826. [pmid: 11948826].
269 Shin SJ, Rosen PP. Excisional biopsy should be performed if lobular carcinoma in situ is seen on needle core biopsy. Arch Pathol Lab Med. 2002;126(6):697-701. [pmid: 12033958].
270 Smyczek-Gargya B, Krainick U, Muller-Schimpfle M, et al. Large-core needle biopsy for diagnosis and treatment of breast lesions. Arch Gynecol Obstet. Aug. 2002;266(4):198-200. PMID: 12192478. [pmid: 12192478].
271 Soo MS, Baker JA, Rosen EL, et al. Sonographically guided biopsy of suspicious microcalcifications of the breast: A pilot study. AJR Am J Roentgenol. 2002;178(4):1007-1015. PMID: 11906892. [pmid: 11906892].
272 Tan SM, Behranwala KA, Trott PA, et al. A retrospective study comparing the individual modalities of triple assessment in the pre-operative diagnosis of invasive lobular breast carcinoma. Eur J Surg Oncol. Apr. 2002;28(3):203-208. PMID: 11944950. [pmid: 11944950].
273 Tse GM, Law BK, Ma TK, et al. Hamartoma of the breast: a clinicopathological review. J Clin Pathol. Dec. 2002;55(12):951-954. PMID: 12461066. [pmid: 12461066].
274 Verkooijen HM, Peeters PHM. Diagnostic accuracy of stereotactic large-core needle biopsy for nonpalpable breast disease: Results of a multicenter prospective study with 95% surgical confirmation. Int J Cancer. Jun. 20. 2002;99(6):853-859. [pmid: 12115488].
275 Verkooijen HM, Buskens E, Peeters PH, et al. Diagnosing non-palpable breast disease: short-term impact on quality of life of large-core needle biopsy versus open breast biopsy. Surg Oncol. May. 2002;10(4):177-181. PMID: 12020672. [pmid: 12020672].
276 Watermann DO, Einert A, Ehritt-Braun C, et al. Experience with the Advanced Breast Biopsy Instrumentation (ABBI) System. Anticancer Res. Sep. 2002;22(5):3067-3070. [pmid: 12530044].
277 Wunderbaldinger P, Wolf G, Turetschek K, et al. Comparison of sitting versus prone position for stereotactic large-core breast biopsy in surgically proven lesions. AJR Am J Roentgenol. 2002;178(5):1221-1225. PMID: 11959735. [pmid: 11959735].
278 Bagnall MJC, Evans AJ, Wilson ARM, et al. Predicting invasion in mammographically detected microcalcification. Clin Radiol. Oct. 2001;56(10):828-832. [pmid: 11895299].
279 Berg WA, Arnoldus CL, Teferra E, et al. Biopsy of amorphous breast calcifications: Pathologic outcome and yield at stereotactic biopsy. Radiology. 2001;221(2):495-503. PMID: 11687695. [pmid: 11687695].
280 Berg WA, Mrose HE, Ioffe OB. Atypical lobular hyperplasia or lobular carcinoma in situ at core-needle breast biopsy. Radiology. 2001;218(2):503-509. PMID: 11161169. [pmid: 11161169].
281 Brem RF, Schoonjans JM, Goodman SN, et al. Nonpalpable breast cancer: Percutaneous diagnosis with 11- and 8-gauge stereotactic vacuum-assisted biopsy devices. Radiology. Jun. 2001;219(3):793-796. [pmid: 11376271].
282 Chao C, Torosian MH, Boraas MC, et al. Local recurrence of breast cancer in the stereotactic core needle biopsy site: case reports and review of the literature. Breast J. Mar-Apr. 2001;7(2):124-127. PMID: 11328321. [pmid: 11328321].
283 Clarke D, Sudhakaran N, Gateley CA. Replace fine needle aspiration cytology with automated core biopsy in the triple assessment of breast cancer. Ann R Coll Surg Engl. Mar. 2001;83(2):110-112. PMID: 11320918. [pmid: 11320918].
284 Daniel BL, Birdwell RL, Butts K, et al. Freehand iMRI-guided large-gauge core needle biopsy: A new minimally invasive technique for diagnosis of enhancing breast lesions. J Magn Reson Imaging. Jun. 2001;13(6):896-902. [pmid: 11382950].
285 Deurloo EE, Gilhuijs KGA, Schultze Kool LJ, et al. Displacement of breast tissue and needle deviations during stereotactic procedures. Invest Radiol. 2001;36(6):347-353. [pmid: 11410756].
286 Ely KA, Carter BA, Jensen RA, et al. Core biopsy of the breast with atypical ductal hyperplasia: a probabilistic approach to reporting. Am J Surg Pathol. Aug. 2001;25(8):1017-1021. PMID: 11474285. [pmid: 11474285].
287 Fine RE, Israel PZ, Walker LC, et al. A prospective study of the removal rate of imaged breast lesions by an 11-gauge vacuum-assisted biopsy probe system. Am J Surg. Oct. 2001;182(4):335-340. PMID: 11720666. [pmid: 11720666].
288 Grimes MM, Karageorge LS, Hogge JP. Does exhaustive search for microcalcifications improve diagnostic yield in stereotactic core needle breast biopsies?. Mod Pathol. 2001;14(4):350-353. PMID: 11301352. [pmid: 11301352].
289 Hung WK, Lam HS, Lau Y, et al. Diagnostic accuracy of vacuum-assisted biopsy device for image-detected breast lesions. Aust N Z J Surg. Aug. 2001;71(8):457-460. PMID: 11504288.
290 Ibrahim AEK, Bateman AC, Theaker JM, et al. The role and histological classification of needle core biopsy in comparison with fine needle aspiration cytology in the preoperative assessment of impalpable breast lesions. J Clin Pathol. 2001;54(2):121-125. [pmid: 11215280].
291 Jackman RJ, Burbank F, Parker SH, et al. Stereotactic breast biopsy of nonpalpable lesions: Determinants of ductal carcinoma in situ underestimation rates. Radiology. 2001;218(2):497-502. [pmid: 11161168].
292 Jacobs IA, Chevinsky AH, Diehl W, et al. Advanced breast biopsy instrumentataion (ABBI) and management of nonpalpable breast abnormalities: A community hospital experience. Breast. 2001;10(5):421-426. [pmid: 14965618].
293 Joshi M, Duva-Frissora A, Padmanabhan R, et al. Atypical ductal hyperplasia in stereotactic breast biopsies: enhanced accuracy of diagnosis with the mammotome. Breast J. Jul-Aug. 2001;7(4):207-213. PMID: 11678796. [pmid: 11678796].
294 Kaufman HJ, Witherspoon LE, Gwin JL Jr, et al. Stereotactic breast biopsy: a study of first core samples. Am Surg. Jun. 2001;67(6):572-575. discussion 575–576. PMID: 11409806. [pmid: 11409806].
295 King TA, Hayes DH, Cederbom GJ, et al. Biopsy technique has no impact on local recurrence after breast-conserving therapy. Breast J. Jan-Feb. 2001;7(1):19-24. PMID: 11348411. [pmid: 11348411].
296 Kuhl CK, Morakkabati N, Leutner CC, et al. MR imaging--guided large-core (14-gauge) needle biopsy of small lesions visible at breast MR imaging alone. Radiology. Jul. 2001;220(1):31-39. PMID: 11425969. [pmid: 11425969].
297 Liberman L, Benton CL, Dershaw DD, et al. Learning curve for stereotactic breast biopsy: how many cases are enough?. AJR Am J Roentgenol. Mar. 2001;176(3):721-727. PMID: 11222213. [pmid: 11222213].
298 Liberman L, Gougoutas CA, Zakowski MF, et al. Calcifications highly suggestive of malignancy: comparison of breast biopsy methods. AJR Am J Roentgenol. Jul. 2001;177(1):165-172. PMID: 11418420. [pmid: 11418420].
299 Lifrange E, Dondelinger RF, Fridman V, et al. En bloc excision of nonpalpable breast lesions using the advanced breast biopsy instrumentation system: An alternative to needle guided surgery?. Eur Radiol. 2001;11(5):796-801. PMID: 11372610. [pmid: 11372610].
300 Maganini RO, Klem DA, Huston BJ, et al. Upgrade rate of core biopsy-determined atypical ductal hyperplasia by open excisional biopsy. Am J Surg. Oct. 2001;182(4):355-358. PMID: 11720670. [pmid: 11720670].
301 Marti WR, Zuber M, Oertli D, et al. Advanced breast biopsy instrumentation for the evaluation of impalpable lesions: A reliable diagnostic tool with little therapeutic potential. Eur J Surg. 2001;167(1):15-18. [pmid: 11213814].
302 Meloni GB, Dessol S, Becchere MP, et al. Ultrasound-guided mammotome vacuum biopsy for the diagnosis of impalpable breast lesions. Ultrasound Obstet Gynecol. 2001;18(5):520-524. [pmid: 11844176].
303 Mendez I, Andreu FJ, Saez E, et al. Ductal carcinoma in situ and atypical ductal hyperplasia of the breast diagnosed at stereotactic core biopsy. Breast J. 2001;7(1):14-18. PMID: 11348410. [pmid: 11348410].
304 Mercado CL, Hamele-Bena D, Singer C, et al. Papillary lesions of the breast: evaluation with stereotactic directional vacuum-assisted biopsy. Radiology. Dec. 2001;221(3):650-655. PMID: 11719659. [pmid: 11719659].
305 Morrow M, Venta L, Stinson T, et al. Prospective comparison of stereotactic core biopsy and surgical excision as diagnostic procedures for breast cancer patients. Ann Surg. Apr. 2001;233(4):537-541. PMID: 11303136. [pmid: 11303136].
306 O’Driscoll D, Britton P, Bobrow L, et al. Lobular carcinoma in situ on core biopsy - What is the clinical significance?. Clin Radiol. Mar. 1. 2001;56(3):216-220. [pmid: 11247699].
307 Parker SH, Klaus AJ, McWey PJ, et al. Sonographically guided directional vacuum-assisted breast biopsy using a handheld device. AJR Am J Roentgenol. Aug. 2001;177(2):405-408. PMID: 11461871. [pmid: 11461871].
308 Parker SJ, Wheaton M, Wallis MG, et al. Why should diagnostic benign breast biopsies weight less than twenty grams?. Ann R Coll Surg Engl. Mar. 2001;83(2):113-116. PMID: 11320919. [pmid: 11320919].
309 Renshaw AA. Adequate histologic sampling of breast core needle biopsies. Arch Pathol Lab Med. 2001;125(8):1055-1057. [pmid: 11473457].
310 Renshaw AA, Cartagena N, Schenkman RH, et al. Atypical ductal hyperplasia in breast core needle biopsies. Correlation of size of the lesion, complete removal of the lesion, and the incidence of carcinoma in follow-up biopsies. Am J Clin Pathol. Jul. 2001;116(1):92-96. PMID: 11447758. [pmid: 11447758].
311 Saarenmaa I, Salminen T, Geiger U, et al. Validity of radiological examinations of patients with breast cancer in different age groups in a population based study. Breast. 2001;10(1):78-81. [pmid: 14965565].
312 Schneider E, Rohling KW, Schnall MD, et al. An apparatus for MR-guided breast lesion localization and core biopsy: Design and preliminary results. J Magn Reson Imaging. 2001;14(3):243-253. [pmid: 11536401].
313 Schoonjans JM, Brem RF. Fourteen-gauge ultrasonographically guided large-core needle biopsy of breast masses. J Ultrasound Med. 2001;20(9):967-972. PMID: 11549157. [pmid: 11549157].
314 Shannon J, Douglas-Jones AG, Dallimore NS. Conversion to core biopsy in preoperative diagnosis of breast lesions: is it justified by results?. J Clin Pathol. Oct. 2001;54(10):762-765. PMID: 11577122. [pmid: 11577122].
315 Sklair-Levy M, Samuels TH, Catzavelos C, et al. Stromal fibrosis of the breast. AJR Am J Roentgenol. 2001;177(3):573-577. PMID: 11517049. [pmid: 11517049].
316 Smith LF, Henry-Tillman R, Mancino AT, et al. Magnetic resonance imaging-guided core needle biopsy and needle localized excision of occult breast lesions. Am J Surg. Oct. 2001;182(4):414-418. PMID: 11720683. [pmid: 11720683].
317 Sun W, Li A, Abreo F, et al. Comparison of fine-needle aspiration cytology and core biopsy for diagnosis of breast cancer. Diagn Cytopathol. 2001;24(6):421-425. PMID: 11391825. [pmid: 11391825].
318 Verkooijen HM, Borel Rinkes IH, Peeters PH, et al. Impact of stereotactic large-core needle biopsy on diagnosis and surgical treatment of nonpalpable breast cancer. Eur J Surg Oncol. Apr. 2001;27(3):244-249. PMID: 11393185. [pmid: 11393185].
319 Westenend PJ, Sever AR, Beekman-de Volder HJC, et al. A comparison of aspiration cytology and core needle biopsy in the evaluation of breast lesions. Cancer. 2001;93(2):146-150. [pmid: 11309781].
320 Adrales G, Turk P, Wallace T, et al. Is surgical excision necessary for atypical ductal hyperplasia of the breast diagnosed by Mammotome?. Am J Surg. Oct. 2000;180(4):313-315. PMID: 11113443. [pmid: 11113443].
321 Bagnall MJ, Evans AJ, Wilson AR, et al. When have mammographic calcifications been adequately sampled at needle core biopsy?. Clin Radiol. Jul. 2000;55(7):548-553. PMID: 10924380. [pmid: 10924380].
322 Burns RP, Brown JP, Roe SM, et al. Stereotactic core-needle breast biopsy by surgeons: Minimum 2-year follow-up of benign lesions. Ann Surg. 2000;232(4):542-548. [pmid: 10998652].
323 Darling ML, Smith DN, Lester SC, et al. Atypical ductal hyperplasia and ductal carcinoma in situ as revealed by large-core needle breast biopsy: results of surgical excision. AJR Am J Roentgenol. Nov. 2000;175(5):1341-1346. PMID: 11044038. [pmid: 11044038].
324 Cangiarella JF, Waisman J, Weg N, et al. The use of stereotaxic core biopsy and stereotaxic aspiration biopsy as diagnostic tools in the evaluation of mammary calcification. Breast J. 2000;6(6):366-372. [pmid: 11348394].
325 Cangiarella J, Gross J, Symmans WF, et al. The incidence of positive margins with breast conserving therapy following mammotome biopsy for microcalcification. J Surg Oncol. Aug. 2000;74(4):263-266. PMID: 10962457. [pmid: 10962457].
326 Gukas ID, Nwana EJ, Ihezue CH, et al. Tru-cut biopsy of palpable breast lesions: a practical option for pre-operative diagnosis in developing countries. Cent Afr J Med. May. 2000;46(5):127-130. PMID: 11210334. [pmid: 11210334].
327 Hatada T, Ishii H, Ichii S, et al. Diagnostic value of ultrasound-guided fine-needle aspiration biopsy; core-needle biopsy; and evaluation of combined use in the diagnosis of breast lesions. J Am Coll Surg. Mar. 2000;190(3):299-303. PMID: 10703854. [pmid: 10703854].
328 Lamm RL, Jackman RJ. Mammographic abnormalities caused by percutaneous stereotactic biopsy of histologically benign lesions evident on follow-up mammograms. AJR Am J Roentgenol. Mar. 2000;174(3):753-756. PMID: 10701620. [pmid: 10701620].
329 Lee CH, Carter D, Philpotts LE, et al. Ductal carcinoma in situ diagnosed with stereotactic core needle biopsy: can invasion be predicted?. Radiology. Nov. 2000;217(2):466-470. PMID: 11058647. [pmid: 11058647].
330 Liberman L, Drotman M, Morris EA, et al. Imaging-histologic discordance at percutaneous breast biopsy: an indicator of missed cancer. Cancer. Dec. 15. 2000;89(12):2538-2546. [pmid: 11135213].
331 Melotti MK, Berg WA. Core needle breast biopsy in patients undergoing anticoagulation therapy: preliminary results. AJR Am J Roentgenol. Jan. 2000;174(1):245-249. PMID: 10628487. [pmid: 10628487].
332 Mok PM, Keepin Y. Stereotactic breast biopsies for lesions discovered on routine mammography: experience at the North Shore Hospital. N Z Med J. Jul. 14. 2000;113(1113):273-274. PMID: 10935565. [pmid: 10935565].
333 Moritz JD, Mertens C, Westerhof JP, et al. Role of high magnification specimen radiography in surgical and core biopsies of the breast. Br J Radiol. 2000;73(875):1170-1177. [pmid: 11144794].
334 Nisbet AP, Borthwick-Clarke A, Scott N. 11-gauge vacuum assisted directional biopsy of breast calcifications, using upright stereotactic guidance. Eur J Radiol. Dec. 2000;36(3):144-146. [pmid: 11091014].
335 O’hea BJ, Tornos C. Mild ductal atypia after large-core needle biopsy of the breast: is surgical excision always necessary?. Surgery. Oct. 2000;128(4):738-743. PMID: 11015109. [pmid: 11015109].
336 Philpotts LE, Lee CH, Horvath LJ, et al. Underestimation of breast cancer with II-gauge vacuum suction biopsy. AJR Am J Roentgenol. Oct. 2000;175(4):1047-1050. PMID: 11000162. [pmid: 11000162].
337 Philpotts LE, Shaheen NA, Jain KS, et al. Uncommon high-risk lesions of the breast diagnosed at stereotactic core-needle biopsy: Clinical importance. Radiology. 2000;216(3):831-837. PMID: 10966718. [pmid: 10966718].
338 Portincasa G, Lucci E, Navarra GG, et al. Initial experience with breast biopsy utilizing the Advanced Breast Biopsy Instrumentation (ABBI). J Surg Oncol. 2000;74(3):201-203. [pmid: 10951417].
339 Schwartzberg BS, Goates JJ, Keeler SA, et al. Use of advanced breast biopsy instrumentation while performing stereotactic breast biopsies: review of 150 consecutive biopsies. J Am Coll Surg. Jul. 2000;191(1):9-15. PMID: 10898178. [pmid: 10898178].
340 Simon JR, Kalbhen CL, Cooper RA, et al. Accuracy and complication rates of US guided vacuum-assisted core breast biopsy: Initial results. Radiology. Jun. 2000;215(3):694-697. PMID: 10831686. [pmid: 10831686].
341 Sneige N, Tulbah A. Accuracy of cytologic diagnoses made from touch imprints of image-guided needle biopsy specimens of nonpalpable breast abnormalities. Diagn Cytopathol. Jul. 2000;23(1):29-34. PMID: 10907929. [pmid: 10907929].
342 Stolier A, Skinner J, Levine EA. A prospective study of seeding of the skin after core biopsy of the breast. Am J Surg. Aug. 2000;180(2):104-107. PMID: 11044522. [pmid: 11044522].
343 Teh WL, Wilson ARM, Evans AJ, et al. Ultrasound guided core biopsy of suspicious mammographic calcifications using high frequency and power doppler ultrasound. Clin Radiol. 2000;55(5):390-394. [pmid: 10816407].
344 Whitlock JPL, Evans AJ, Burrell HC, et al. Digital imaging improves upright stereotactic core biopsy of mammographic microcalcifications. Clin Radiol. 2000;55(5):374-377. [pmid: 10816404].
345 Yang J-H, Lee S-D, Nam S-J. Diagnostic utility of ABBI (Advanced Breast Biopsy Instrumentation) for nonpalpable breast lesions in Korea. Breast J. 2000;6(4):257-262. [pmid: 11348375].
346 Al-Sobhi SS, Helvie MA, Pass HA, et al. Extent of lumpectomy for breast cancer after diagnosis by stereotactic core versus wire localization biopsy. Ann Surg Oncol. Jun. 1999;6(4):330-335. [pmid: 10379852].
347 Baker JA, Soo MS, Mengoni P. Sonographically guided percutaneous interventions of the breast using a steerable ultrasound beam. AJR Am J Roentgenol. Jan. 1999;172(1):157-159. [pmid: 9888759].
348 Bloomston M, D’Angelo P, Galliano D, et al. One hundred consecutive advanced breast biopsy instrumentation procedures: complications, costs, and outcome. Ann Surg Oncol. Mar. 1999;6(2):195-199. PMID: 10082046. [pmid: 10082046].
349 Bokran W, Reynolds HE, Lazaridis CL, et al. Stereotactic biopsy of ductal carcinoma in situ of the breast using an II-gauge vacuum-assisted device: Persistent underestimation of disease. AJR Am J Roentgenol. Jul. 1999;173(1):227-229. [pmid: 10397131].
350 Brem RF, Behrndt VS, Sanow L, et al. Atypical ductal hyperplasia: Histologic underestimation of carcinoma in tissue harvested from impalpable breast lesions using 11-gauge stereotactically guided directional vacuum-assisted biopsy. AJR Am J Roentgenol. May. 1999;172(5):1405-1407. [pmid: 10227526].
351 Britton PD, McCann J. Needle biopsy in the NHS breast screening programme 1996/97: How much and how accurate?. Breast. Feb. 1999;8(1):5-11.
352 Damascelli B, Frigerio LF, Patelli G, et al. Stereotactic breast biopsy: En bloc excision of microcalcifications with a large-bore cannula device. AJR Am J Roentgenol. Oct. 1999;173(4):895-900. [pmid: 10511143].
353 Deschryver K, Radford DM, Schuh ME. Pathology of large-caliber stereotactic biopsies in nonpalpable breast lesions. Semin Diagn Pathol. Aug. 1999;16(3):224-234. PMID: 10490199. [pmid: 10490199].
354 Diaz LK, Wiley EL, Venta LA. Are malignant cells displaced by large-gauge needle core biopsy of the breast. AJR Am J Roentgenol. Nov. 1999;173(5):1303-1313. PMID: 10541110. [pmid: 10541110].
355 DiPiro PJ, Meyer JE, Denison CM, et al. Image-guided core breast biopsy of ductal carcinoma in situ presenting as a non-calcified abnormality. Eur J Radiol. Jun. 1999;30(3):231-236. PMID: 10452723. [pmid: 10452723].
356 El-Tamer M, Axiotis C, Kim E, et al. Accurate prediction of the amount of in situ tumor in palpable breast cancers by core needle biopsy: Implications for neoadjuvant therapy. Ann Surg Oncol. Jul. 1999;6(5):461-466. [pmid: 10458684].
357 Evans AJ, Whitlock JP, Burrell HC, et al. A comparison of 14 and 12 gauge needles for core biopsy of suspicious mammographic calcification. Br J Radiol. 1999;72:1152-1154. [pmid: 10703470].
358 Ferzli GS, Puza T, VanVorst-Bilotti S, et al. Breast biopsies with ABBI: Experience with 183 attempted biopsies. Breast J. 1999;5(1):26-28. [pmid: 11348252].
359 Fraser Symmans W, Weg N, Gross J, et al. A prospective comparison of stereotaxic fine-needle aspiration versus stereotaxic core needle biopsy for the diagnosis of mammographic abnormalities. Cancer. 1999;85(5):1119-1132. [pmid: 10091797].
360 Gajdos C, Levy M, Herman Z, et al. Complete removal of nonpalpable breast malignancies with a stereotactic percutaneous vacuum-assisted biopsy instrument. J Am Coll Surg. Sep. 1999;189(3):237-240. PMID: 10472922. [pmid: 10472922].
361 Gentry CL, Henry CA. Stereotactic percutaneous breast biopsy: A comparative analysis between surgeon and radiologist. Breast J. 1999;5(2):101-104. [pmid: 11348267].
362 Gray RE, Benson GW, Lustig DD. Stereotactic breast biopsy: experience in a community setting. J Miss State Med Assoc. Jan. 1999;40(1):3-7. PMID: 9919043. [pmid: 9919043].
363 Harlow SP, Krag DN, Ames SE, et al. Intraoperative ultrasound localization to guide surgical excision of nonpalpable breast carcinoma. J Am Coll Surg. Sep. 1999;189(3):241-246. [pmid: 10472923].
364 Harvey SC, Denison CM, Lester SC, et al. Fibrous nodules found at large-core needle biopsy of the breast: Imaging features. Radiology. May. 1999;211(2):535-540. PMID: 10228539. [pmid: 10228539].
365 Johnson JM, Dalton RR, Wester SM, et al. Histological correlation of microcalcifications in breast biopsy specimens. Arch Surg. Jul. 1999;134(7):712-716. PMID: 10401820. [pmid: 10401820].
366 Klem D, Jacobs HK, Jorgensen R, et al. Stereotactic breast biopsy in a community hospital setting. Am Surg. Aug. 1999;65(8):737-740. discussion 740–741. PMID: 10432083. [pmid: 10432083].
367 LaRaja RD, Saber AA, Sickles A. Early experience in the use of the advanced breast biopsy instrumentation: A report of one hundred twenty-seven patients. Surgery. 1999;125(4):380-384. PMID: 10216528. [pmid: 10216528].
368 Liberman L, Bracero N, Vuolo MA, et al. Percutaneous large-core biopsy of papillary breast lesions. AJR Am J Roentgenol. Feb. 1999;172(2):331-337. [pmid: 9930777].
369 Liberman L, Sama M, Susnik B, et al. Lobular carcinoma in situ at percutaneous breast biopsy: Surgical biopsy findings. AJR Am J Roentgenol. Aug. 1999;173(2):291-299. PMID: 10430122. [pmid: 10430122].
370 Liberman L, Vuolo M, Dershaw DD, et al. Epithelial displacement after stereotactic 11-gauge directional vacuum-assisted breast biopsy. AJR Am J Roentgenol. Mar. 1999;172(3):677-681. PMID: 10063859. [pmid: 10063859].
371 Matthews BD, Williams GB. Initial experience with the advanced breast biopsy instrumentation system. Am J Surg. Feb. 1999;177(2):97-101. PMID: 10204548. [pmid: 10204548].
372 Mitnick JS, Gianutsos R, Pollack AH, et al. Tubular carcinoma of the breast: sensitivity of diagnostic techniques and correlation with histopathology. AJR Am J Roentgenol. Feb. 1999;172(2):319-323. PMID: 9930775. [pmid: 9930775].
373 Philpotts LE, Shaheen NA, Carter D, et al. Comparison of rebiopsy rates after stereotactic core needle biopsy of the breast with 11-gauge vacuum suction probe versus 14-gauge needle and automatic gun. AJR Am J Roentgenol. Mar. 1999;172(3):683-687. PMID: 10063860. [pmid: 10063860].
374 Rebner M, Chesbrough R, Gregory N. Initial experience with the advanced breast biopsy instrumentation device. AJR Am J Roentgenol. Jul. 1999;173(1):221-226. [pmid: 10397130].
375 Rich PM, Michell MJ, Humphreys S, et al. Stereotactic 14G core biopsy of non-palpable breast cancer: What is the relationship between the number of core samples taken and the sensitivity for detection of malignancy?. Clin Radiol. Jun. 1999;54(6):384-389. [pmid: 10406340].
376 Rosen EL, Soo MS, Bentley RC. Focal fibrosis: A common breast lesion diagnosed at imaging-guided core biopsy. AJR Am J Roentgenol. Dec. 1999;173(6):1657-1662. PMID: 10584816. [pmid: 10584816].
377 Roth WD, von Smitten K, Heikkila P, et al. Automated stereotactic core needle biopsy of microcalcifications with correlation to surgical biopsy. Acta Radiol. Jul. 1999;40(4):390-393. PMID: 10394866. [pmid: 10394866].
378 Sharifi S, Peterson MK, Baum JK, et al. Assessment of pathologic prognostic factors in breast core needle biopsies. Mod Pathol. Oct. 1999;12(10):941-945. [pmid: 10530557].
379 Sheth D, Wesen CA, Schroder D, et al. The Advanced Breast Biopsy Instrumentation (ABBI) experience at a community hospital. Am Surg. Aug. 1999;65(8):726-730. [pmid: 10432081].
380 Shin HJC, Sneige N, Staerkel GA. Utility of punch biopsy for lesions that are hard to aspirate by conventional fine-needle aspiration. Cancer. Jun. 25. 1999;87(3):149-154. [pmid: 10385446].
381 Staren ED, O’Neill TP. Ultrasound-guided needle biopsy of the breast. Surgery. 1999;126(4):629-635. PMID: 10520908. [pmid: 10520908].
382 Tran DQ, Wilkerson DK, Namm J, et al. Needle-localized breast biopsy for mammographic abnormalities: A community hospital experience. Am Surg. Mar. 1999;65(3):283-288. PMID: 10075310. [pmid: 10075310].
383 Velanovich V, Lewis FR Jr, Nathanson SD, et al. Comparison of mammographically guided breast biopsy techniques. Ann Surg. May. 1999;229(5):625-630. discussion 630–633. PMID: 10235520. [pmid: 10235520].
384 Williams AB, Roberts JV, Michell MJ, et al. Prone stereotactic breast core biopsy: The impact on surgical management of nonpalpable breast cancers. Breast. Feb. 1999;8(1):12-15.
385 Won B, Reynolds HE, Lazaridis CL, et al. Stereotactic biopsy of ductal carcinoma in situ of the breast using an 11-gauge vacuum-assisted device: persistent underestimation of disease. AJR Am J Roentgenol. Jul. 1999;173(1):227-229. PMID: 10397131. [pmid: 10397131].
386 Yong WS, Chia KH, Poh WT, et al. A comparison of trucut biopsy with fine needle aspiration cytology in the diagnosis of breast cancer. Singapore Med J. Sep. 1999;40(9):587-589. PMID: 10628249. [pmid: 10628249].
387 Andreu FJ, Sentis M, Castaner E, et al. The impact of stereotactic large-core needle biopsy in the treatment of patients with nonpalpable breast lesions: a study of diagnostic accuracy in 510 consecutive cases. Eur Radiol. 1998;8(8):1468-1474. PMID: 9853239. [pmid: 9853239].
388 Antley CM, Mooney EE, Layfield LJ. A comparison of accuracy rates between open biopsy, cutting-needle biopsy, and fine-needle aspiration biopsy of the breast: A 3-year experience. Breast J. 1998;4(1):3-8.
389 Bleznak AD, Magaram D. Surgical biopsy techniques for mammographically detected abnormalities. Breast J. 1998;4(6):426-429.
390 Damascelli B, Frigerio LF, Lanocita R, et al. Stereotactic excisional breast biopsy performed by interventional radiologists using the advanced breast biopsy instrumentation system. Br J Radiol. Oct. 1998;71(850):1003-1011. PMID: 10211058. [pmid: 10211058].
391 Doyle AJ, King AR, Miller MV, et al. Implementation of image-guided large-core needle biopsy of the breast on a limited budget. Australas Radiol. 1998;42(3):199-203. [pmid: 9727241].
392 Goodman KA, Birdwell RL, Ikeda DM. Compliance with recommended follow-up after percutaneous breast core biopsy. AJR Am J Roentgenol. 1998;170(1):89-93. [pmid: 9423606].
393 Helbich TH, Rudas M, Haitel A, et al. Evaluation of needle size for breast biopsy: Comparison of 14-, 16-, and 18-gauge biopsy needles. AJR Am J Roentgenol. Jul. 1998;171(1):59-63. PMID: 9648764. [pmid: 9648764].
394 Jackman RJ, Marzoni FA Jr, Nowels KW. Percutaneous removal of benign mammographic lesions: Comparison of automated large-core and directional vacuum-assisted stereotactic biopsy techniques. AJR Am J Roentgenol. Nov. 1998;171(5):1325-1330. [pmid: 9798873].
395 Johnson JM, Dalton RR, Landercasper J, et al. Image-guided or needle-localized open biopsy of mammographic malignant- appearing microcalcifications?. J Am Coll Surg. 1998;187(6):604-609. PMID: 9849733. [pmid: 9849733].
396 Kaufman CS, Delbecq R, Jacobson L. Excising the reexcision: stereotactic core-needle biopsy decreases need for reexcision of breast cancer. World J Surg. Oct. 1998;22(10):1023-1027. PMID: 9747160. [pmid: 9747160].
397 Kelley WE Jr, Bailey R, Bertelsen C, et al. Stereotactic automated surgical biopsy using the ABBI biopsy device: A multicenter study. Breast J. 1998;4(5):302-306.
398 King TA, Cederbom GJ, Champaign JL, et al. A core breast biopsy diagnosis of invasive carcinoma allows for definitive surgical treatment planning. Am J Surg. Dec. 1998;176(6):497-501. PMID: 9926778. [pmid: 9926778].
399 Liberman L, Dershaw DD, Rosen PP, et al. Percutaneous removal of malignant mammographic lesions of stereotactic vaccum-assisted biopsy. Radiology. Mar. 1998;206(3):711-715. PMID: 9494489. [pmid: 9494489].
400 Liberman L, Smolkin JH, Dershaw DD, et al. Calcification retrieval at stereotactic, 11-gauge, directional, vacuum- assisted breast biopsy. Radiology. Jul. 1998;208(1):251-260. PMID: 9646821. [pmid: 9646821].
401 Lin PH, Clyde JC, Bates DM, et al. Accuracy of stereotactic core-needle breast biopsy in atypical ductal hyperplasia. Am J Surg. May. 1998;175(5):380-382. PMID: 9600282. [pmid: 9600282].
402 Lind DS, Minter R, Steinbach B, et al. Stereotactic core biopsy reduces the reexcision rate and the cost of mammographically detected cancer. J Surg Res. Jul. 15. 1998;78(1):23-26. [pmid: 9733612].
403 Meyer JE, Smith DN, Lester SC, et al. Large-needle core biopsy: Nonmalignant breast abnormalities evaluated with surgical excision or repeat core biopsy. Radiology. Mar. 1998;206(3):717-720. [pmid: 9494490].
404 Mitnick JS, Gianutsos R, Pollack AH, et al. Comparative value of mammography, fine-needle aspiration biopsy, and core biopsy in the diagnosis of invasive lobular carcinoma. Breast J. 1998;4(2):75-83.
405 Seoudi H, Mortier J, Basile R, et al. Stereotactic core needle biopsy of nonpalpable breast lesions: Initial experience with a promising technique. Arch Surg. Apr. 1998;133(4):366-372. PMID: 9565115. [pmid: 9565115].
406 Slanetz PJ, Giardino AA, McCarthy KA, et al. Previous breast biopsy for benign disease rarely complicates or alters interpretation on screening mammography. AJR Am J Roentgenol. Jul. 1998;170(6):1539-1541. [pmid: 9609170].
407 Soo MS, Walsh R, Patton J. Prone table stereotactic breast biopsy: Facilitating biopsy of posterior lesions using the arm-through-the-hole technique. AJR Am J Roentgenol. Sep. 1998;171(3):615-617. [pmid: 9725284].
408 Woodcock NP, Glaves I, Morgan DR, et al. Ultrasound-guided Tru-cut biopsy of the breast. Ann R Coll Surg Engl. 1998;80(4):253-256. PMID: 9771224. [pmid: 9771224].
409 Zardawi IM. Fine needle aspiration cytology vs. Core biopsy in a rural setting. Acta Cytol. 1998;42(4):883-887. PMID: 9684572. [pmid: 9684572].
410 Zonderland HM, Hermans J, Van De Vijver MJ, et al. Triple diagnostic approach versus ultrasound-guided 18 gauge core biopsy in suspicious breast masses. Breast. Jun. 1998;7(3):168-172.
411 Acheson MB, Patton RG, Howisey RL, et al. Histologic correlation of image-guided core biopsy with excisional biopsy of nonpalpable breast lesions. Arch Surg. Aug. 1997;132(8):815-818. discussion 819–821. PMID: 9267263. [pmid: 9267263].
412 Anania G, Bazzocchi M, Di Loreto C, et al. Percutaneous large core needle biopsy versus surgical biopsy in the diagnosis of breast lesions. Int Surg. Jan. 1997;82(1):52-55. PMID: 9189803. [pmid: 9189803].
413 Burbank F. Stereotactic breast biopsy of atypical ductal hyperplasia and ductal carcinoma in situ lesions: Improved accuracy with directional, vacuum- assisted biopsy. Radiology. Mar. 1997;202(3):843-847. [pmid: 9051043].
414 Burbank F. Stereotactic breast biopsy: comparison of 14- and 11-gauge Mammotome probe performance and complication rates. Am Surg. Nov. 1997;63(11):988-995. PMID: 9358788. [pmid: 9358788].
415 Burbank F. Mammographic findings after 14-gauge automated needle and 14-gauge directional, vacuum-assisted stereotactic breast biopsies. Radiology. Jul. 1997;204(1):153-156. PMID: 9205238. [pmid: 9205238].
416 Cerwenka H, Hoff M, Rosanelli G, et al. Experience with a high speed biopsy gun in breast cancer diagnosis. Eur J Surg Oncol. 1997;23(3):206-207. PMID: 9236891. [pmid: 9236891].
417 D’Angelo PC, Galliano DE, Rosemurgy AS. Stereotactic excisional breast biopsies utilizing the advanced breast biopsy instrumentation system. Am J Surg. Sep. 1997;174(3):297-302. PMID: 9324141. [pmid: 9324141].
418 Devia A, Murray KA, Nelson EW. Stereotactic core needle biopsy and the workup of mammographic breast lesions. Arch Surg. May. 1997;132(5):512-515. discussion 515–517. PMID: 9161394. [pmid: 9161394].
419 Fenoglio ME, Gallagher JQ, Joy N, et al. Stereotactic core breast biopsy versus needle localization breast biopsy—The effect of initial diagnostic modality on surgical therapy in patients with breast cancer. Minim Invasive Ther Allied Technol. Jun. 1997;6(3):225-227.
420 Ferzli GS, Hurwitz JB, Puza T, et al. Advanced breast biopsy instrumentation: A critique. J Am Coll Surg. 1997;185(2):145-151. [pmid: 9249081].
421 Florentine BD, Cobb CJ, Frankel K, et al. Core needle biopsy: A useful adjunct to fine-needle aspiration in select patients with palpable breast lesions. Cancer. Feb. 25. 1997;81(1):33-39. [pmid: 9100539].
422 Gadzala DE, Cederbom GJ, Bolton JS, et al. Appropriate management of atypical ductal hyperplasia diagnosed by stereotactic core needle breast biopsy. Ann Surg Oncol. Jun. 1997;4(4):283-286. PMID: 9181225. [pmid: 9181225].
423 Hirst C, Davis N. Core biopsy for microcalcifications in the breast. Aust N Z J Surg. 1997;67(6):320-324. [pmid: 9193263].
424 Howisey RL, Acheson MB, Rowbotham RK, et al. A comparison of Medicare reimbursement and results for various imaging- guided breast biopsy techniques. Am J Surg. May. 1997;173(5):395-398. PMID: 9168074. [pmid: 9168074].
425 Jackman RJ, Marzoni FA Jr. Needle-localized breast biopsy: Why do we fail?. Radiology. Sep. 1997;204(3):677-684. [pmid: 9280243].
426 Jackman RJ, Burbank F, Parker SH, et al. Atypical ductal hyperplasia diagnosed at stereotactic breast biopsy: Improved reliability with 14-gauge, directional, vacuum-assisted biopsy. Radiology. Aug. 1997;204(2):485-488. [pmid: 9240540].
427 Liberman L, Hann LE, Dershaw DD, et al. Mammographic findings after stereotactic 14-gauge vacuum biopsy. Radiology. May. 1997;203(2):343-347. PMID: 9114086. [pmid: 9114086].
428 Liberman L, Latrenta LR, Dershaw DD, et al. Impact of core biopsy on the surgical management of impalpable breast cancer. AJR Am J Roentgenol. 1997;168(2):495-499. [pmid: 9016234].
429 Lifrange E, Kridelka F, Colin C. Stereotaxic needle-core biopsy and fine-needle aspiration biopsy in the diagnosis of nonpalpable breast lesions: controversies and future prospects. Eur J Radiol. Jan. 1997;24(1):39-47. PMID: 9056148. [pmid: 9056148].
430 Meyer JE, Smith DN, DiPiro PJ, et al. Stereotactic breast biopsy of clustered microcalcifications with a directional, vacuum-assisted device. Radiology. Aug. 1997;204(2):575-576. PMID: 9240556. [pmid: 9240556].
431 Pijnappel RM, van Dalen A, Borel Rinkes IH, et al. The diagnostic accuracy of core biopsy in palpable and non-palpable breast lesions. Eur J Radiol. Feb. 1997;24(2):120-123. PMID: 9097053. [pmid: 9097053].
432 Roe SM, Mathews JA, Burns RP, et al. Stereotactic and ultrasound core needle breast biopsy performed by surgeons. Am J Surg. Dec. 1997;174(6):699-703. discussion 703–704. PMID: 9409600. [pmid: 9409600].
433 Smith DN, Christian R, Meyer JE. Large-core needle biopsy of nonpalpable breast cancers. The impact on subsequent surgical excisions. Arch Surg. Mar. 1997;132(3):256-259. discussion 260. PMID: 9125023. [pmid: 9125023].
434 Stolier AJ, Rupley DG. The impact of image-directed core biopsy on the practice of breast surgery: A new algorithm for a changing technology. Am Surg. Sep. 1997;63(9):827-830. PMID: 9290531. [pmid: 9290531].
435 Whitten TM, Wallace TW, Bird RE, et al. Image-guided core biopsy has advantages over needle localization biopsy for the diagnosis of nonpalpable breast cancer. Am Surg. Dec. 1997;63(12):1072-1077. discussion 1077–1078. PMID: 9393255. [pmid: 9393255].
436 Written TM, Wallace TW, Bird RE, et al. Image-guided core biopsy has advantages over needle localization biopsy for the diagnosis of nonpalpable breast cancer. Am Surg. 1997;63(12):1072-1078. [pmid: 9393255].
437 Ballo MS, Sneige N. Can core needle biopsy replace fine-needle aspiration cytology in the diagnosis of palpable breast carcinoma. A comparative study of 124 women. Cancer. Aug. 15. 1996;78(4):773-777. PMID: 8756371. [pmid: 8756371].
438 Burbank F, Parker SH, Fogarty TJ. Stereotactic breast biopsy: improved tissue harvesting with the Mammotome. Am Surg. Sep. 1996;62(9):738-744. PMID: 8751765. [pmid: 8751765].
439 Caines JS, Chantziantoniou K, Wright BA, et al. Nova Scotia Breast Screening Program experience: use of needle core biopsy in the diagnosis of screening-detected abnormalities. Radiology. Jan. 1996;198(1):125-130. [pmid: 8539363].
440 Chare MJB, Flowers CI, O’Brien CJ, et al. Image-guided core biopsy in patients with breast disease. Br J Surg. 1996;83(10):1415-1416. [pmid: 8944459].
441 Crotch-Harvey MA, Loughran CF. Combined stereotactic wide-core needle biopsy and fine-needle aspiration cytology in the assessment of impalpable mammographic abnormalities detected in a breast-screening programme. Breast. 1996;5(1):48-49.
442 Dershaw DD, Morris EA, Liberman L, et al. Nondiagnostic stereotaxic core breast biopsy: results of rebiopsy. Radiology. Feb. 1996;198(2):323-325. PMID: 8596825. [pmid: 8596825].
443 Di Loreto C, Puglisi F, Rimondi G, et al. Large core biopsy for diagnostic and prognostic evaluation of invasive breast carcinomas. Eur J Cancer. Sep. 1996;32A(10):1693-1700. PMID: 8983276. [pmid: 8983276].
444 Frayne J, Sterrett GF, Harvey J, et al. Stereotactic 14 gauge core-biopsy of the breast: results from 101 patients. Aust N Z J Surg. Sep. 1996;66(9):585-591. PMID: 8859155. [pmid: 8859155].
445 Handy RB, Fajardo LL, Innis CA, et al. Patient perceptions of stereotaxic large-core breast biopsy. Acad Radiol. Dec. 1996;3(12):1007-1011. PMID: 9017015. [pmid: 9017015].
446 Hillhouse RA, Norvill KA, Buchanan SW, et al. Analysis of malignancy detected by needle-localized breast biopsy. J Am Osteopath Assoc. Jul. 1996;96(7):398-400. PMID: 8758871. [pmid: 8758871].
447 Hunter TB, Roberts CC, Hunt KR, et al. Occurrence of fibroadenomas in postmenopausal women referred for breast biopsy. J Am Geriatr Soc. Jan. 1996;44(1):61-64. [pmid: 8537592].
448 Liberman L, Dershaw DD, Rosen PP, et al. Core needle biopsy of synchronous ipsilateral breast lesions: impact on treatment. AJR Am J Roentgenol. Jun. 1996;166(6):1429-1432. [pmid: 8633457].
449 Pillsbury SG Jr, Haugen JA, Roux S. Reliability of multimodal evaluation of abnormal screening mammogram results. Am J Obstet Gynecol. Jun. 1996;174(6):1683-1686. discussion 1686–1687. PMID: 8678127. [pmid: 8678127].
450 Poole GH, Willsher PC, Pinder SE, et al. Diagnosis of breast cancer with core-biopsy and fine needle aspiration cytology. Aust N Z J Surg. Sep. 1996;66(9):592-594. PMID: 8859156. [pmid: 8859156].
451 Taft R, Chao K, Dear P, et al. The role of core biopsy in the diagnosis of mammographically detected lesions. Aust N Z J Surg. Oct. 1996;66(10):664-667. PMID: 8855919. [pmid: 8855919].
452 Tocino I, Garcia BM, Carter D. Surgical biopsy findings in patients with atypical hyperplasia diagnosed by stereotaxic core needle biopsy. Ann Surg Oncol. Sep. 1996;3(5):483-488. PMID: 8876891. [pmid: 8876891].
453 Wallace JE, Sayler C, McDowell NG, et al. The role of stereotactic biopsy in assessment of nonpalpable breast lesions. Am J Surg. May. 1996;171(5):471-473. PMID: 8651387. [pmid: 8651387].
454 Yim JH, Barton P, Weber B, et al. Mammographically detected breast cancer. Benefits of stereotactic core versus wire localization biopsy. Ann Surg. Jun. 1996;223(6):688-697. discussion 697–670. PMID: 8645042. [pmid: 8645042].
455 Hann LE, Liberman L, Dershaw DD, et al. Mammography immediately after stereotaxic breast biopsy: is it necessary?. AJR Am J Roentgenol. 1995;165(1):59-62. [pmid: 7785633].
456 Israel PZ, Fine RE. Stereotactic needle biopsy for occult breast lesions: a minimally invasive alternative. Am Surg. Jan. 1995;61(1):87-91. PMID: 7832390. [pmid: 7832390].
457 Liberman L, Cohen MA, Dershaw DD, et al. Atypical ductal hyperplasia diagnosed at stereotaxic core biopsy of breast lesions: an indication for surgical biopsy. AJR Am J Roentgenol. 1995;164(5):1111-1113. [pmid: 7717215].
458 Liberman L, Dershaw DD, Rosen PP, et al. Stereotaxic core biopsy of impalpable spiculated breast masses. AJR Am J Roentgenol. 1995;165(3):551-554. [pmid: 7645467].
459 Liberman L, Dershaw D, Durfee S, et al. Recurrent carcinoma after breast conservation: diagnosis with stereotaxic core biopsy. Radiology. Dec. 1995;197(3):735-738. [pmid: 7480747].
460 McCombs MM, Bassett LW, Jahan R, et al. Imaging-guided core biopsy of the breast. Breast J. Jan-Feb. 1995;1(1):9-16.
461 Nath ME, Robinson TM, Tobon H, et al. Automated large-core needle biopsy of surgically removed breast lesions: comparison of samples obtained with 14-, 16-, and 18-gauge needles. Radiology. Dec. 1995;197(3):739-742. PMID: 7480748. [pmid: 7480748].
462 Rubin E, Dempsey PJ, Pile NS, et al. Needle-localization biopsy of the breast: impact of a selective core needle biopsy program on yield. Radiology. Jun. 1995;195(3):627-631. PMID: 7753985. [pmid: 7753985].
463 Strong JW, Worsham GF, Austin RM, et al. Stereotactic core biopsy of nonpalpable breast lesions. J S C Med Assoc. Dec. 1995;91(12):489-496. PMID: 8587312. [pmid: 8587312].
464 Vega A, Arrizabalaga R, Garijo F, et al. Nonpalpable breast lesion. Stereotaxic core needle aspiration biopsy with a single pass. Acta Radiol. Mar. 1995;36(2):117-121. PMID: 7710788. [pmid: 7710788].
465 Vega A, Garijo F, Ortega E. Core needle aspiration biopsy of palpable breast masses. Acta Oncol. 1995;34(1):31-34. PMID: 7865233. [pmid: 7865233].
466 Youngson BJ, Liberman L, Rosen PP. Displacement of carcinomatous epithelium in surgical breast specimens following stereotaxic core biopsy. Am J Clin Pathol. May. 1995;103(5):598-602. PMID: 7741106. [pmid: 7741106].
467 Caines JS, McPhee MD, Konok GP, et al. Stereotaxic needle core biopsy of breast lesions using a regular mammographic table with an adaptable stereotaxic device. AJR Am J Roentgenol. Aug. 1994;163(2):317-321. PMID: 8037022. [pmid: 8037022].
468 Jackman RJ, Nowels KW, Shepard MJ, et al. Stereotaxic large-core needle biopsy of 450 nonpalpable breast lesions with surgical correlation in lesions with cancer or atypical hyperplasia. Radiology. Oct. 1994;193(1):91-95. PMID: 8090927. [pmid: 8090927].
469 Janes RH, Bouton MS. Initial 300 consecutive stereotactic core-needle breast biopsies by a surgical group. Am J Surg. Dec. 1994;168(6):533-536. discussion 536–537. PMID: 7977991. [pmid: 7977991].
470 Kaye MD, Vicinanza-Adami CA, Sullivan ML. Mammographic findings after stereotaxic biopsy of the breast performed with large-core needles. Radiology. Jul. 1994;192(1):149-151. PMID: 8208927. [pmid: 8208927].
471 Liberman L, Dershaw DD, Rosen PP, et al. Stereotaxic 14-gauge breast biopsy: how many core biopsy specimens are needed?. Radiology. Sep. 1994;192(3):793-795. [pmid: 8058949].
472 Liberman L, Evans WP III, Dershaw DD, et al. Radiography of microcalcifications in stereotaxic mammary core biopsy specimens. Radiology. 1994;190(1):223-225. [pmid: 8259409].
473 Mikhail RA, Nathan RC, Weiss M, et al. Stereotactic core needle biopsy of mammographic breast lesions as a viable alternative to surgical biopsy. Ann Surg Oncol. Sep. 1994;1(5):363-367. PMID: 7850536. [pmid: 7850536].
474 Morrow M, Schmidt R, Cregger B, et al. Preoperative evaluation of abnormal mammographic findings to avoid unnecessary breast biopsies. Arch Surg. Oct. 1994;129(10):1091-1096. PMID: 7944941. [pmid: 7944941].
475 Sadler GP, McGee S, Dallimore NS, et al. Role of fine-needle aspiration cytology and needle-core biopsy in the diagnosis of lobular carcinoma of the breast. Br J Surg. 1994;81(9):1315-1317. [pmid: 7953397].
476 Youngson BJ, Cranor M, Rosen PP. Epithelial displacement in surgical breast specimens following needling procedures. Am J Surg Pathol. Sep. 1994;18(9):896-903. PMID: 8067510. [pmid: 8067510].
477 Rotten D, Levaillant JM, Leridon H, et al. Ultrasonographically guided fine needle aspiration cytology and core-needle biopsy in the diagnosis of breast tumors. Eur J Obstet Gynecol Reprod Biol. May. 1993;49(3):175-186. PMID: 8405632. [pmid: 8405632].
478 Dronkers DJ. Stereotaxic core biopsy of breast lesions. Radiology. Jun. 1992;183(3):631-634. PMID: 1584909. [pmid: 1584909].
479 Elliott RL, Haynes AE, Bolin JA, et al. Stereotaxic needle localization and biopsy of occult breast lesions: first year’s experience. Am Surg. Feb. 1992;58(2):126-131. PMID: 1550304. [pmid: 1550304].
480 Harter LP, Curtis JS, Ponto G, et al. Malignant seeding of the needle track during stereotaxic core needle breast biopsy. Radiology. Dec. 1992;185(3):713-714. PMID: 1343569. [pmid: 1343569].
481 Pezner RD, Lorant JA, Terz J, et al. Wound-healing complications following biopsy of the irradiated breast. Arch Surg. Mar. 1992;127(3):321-324. PMID: 1550480. [pmid: 1550480].
482 Khanna AK, Singh MR, Khanna S, et al. Fine needle aspiration cytology, imprint cytology and trucut needle biopsy in breast lumps: a comparative evaluation. J Indian Med Assoc. Jul. 1991;89(7):192-195. PMID: 1940411. [pmid: 1940411].
483 Fahrbach K, Sledge I, Cella C, et al. A comparison of the accuracy of two minimally invasive breast biopsy methods: a systematic literature review and meta-analysis. Arch Gynecol Obstet. May. 2006;274(2):63-73. PMID: 16598478. [pmid: 16598478].
484 Verkooijen HM, Peeters PH, Buskens E, et al. Diagnostic accuracy of large-core needle biopsy for nonpalpable breast disease: a meta-analysis. Br J Cancer. Mar. 2000;82(5):1017-1021. PMID: 10737383. [pmid: 10737383].
485 Jackman RJ, Marzoni FA Jr, Rosenberg J. False-negative diagnoses at stereotactic vacuum-assisted needle breast biopsy: long-term follow-up of 1,280 lesions and review of the literature. AJR Am J Roentgenol. Feb. 2009;192(2):341-351. PMID: 19155393. [pmid: 19155393].
486 Peters N, Hoorntje L, Mali W, et al. Diagnostic performance of stereotactic large core needle biopsy for nonpalpable breast lesions in routine clinical practice. Int J Cancer. Jan. 15. 2008;122(2):468-471. PMID: 17935136. [pmid: 17935136].
487 Schueller G, Jaromi S, Ponhold L, et al. US-guided 14-gauge core-needle breast biopsy: results of a validation study in 1352 cases. Radiology. Aug. 2008;248(2):406-413. PMID: 18641246. [pmid: 18641246].
488 Sim LS, Kei PL. Upright stereotactic vacuum-assisted needle biopsy of suspicious breast microcalcifications. J Med Imaging Radiat Oncol. Aug. 2008;52(4):358-364. PMID: 18811759. [pmid: 18811759].
489 Tonegutti M, Girardi V. Stereotactic vacuum-assisted breast biopsy in 268 nonpalpable lesions. Radiol Med. Feb. 2008;113(1):65-75. PMID: 18338128. [pmid: 18338128].
490 Ciatto S, Houssami N, Ambrogetti D, et al. Accuracy and underestimation of malignancy of breast core needle biopsy: the Florence experience of over 4000 consecutive biopsies. Breast Cancer Res Treat. Mar. 2007;101(3):291-297. PMID: 16823506. [pmid: 16823506].
491 de Lucena CE, Dos Santos Junior JL, de Lima Resende CA, et al. Ultrasound-guided core needle biopsy of breast masses: How many cores are necessary to diagnose cancer?. J Clin Ultrasound. Sep. 2007;35(7):363-366. PMID: 17663457. [pmid: 17663457].
492 Uematsu T, Yuen S, Kasami M, et al. Dynamic contrast-enhanced MR imaging in screening detected microcalcification lesions of the breast: is there any value?. Breast Cancer Res Treat. Jul. 2007;103(3):269-281. PMID: 17063274. [pmid: 17063274].
493 Vag T, Pfleiderer SO, Bottcher J, et al. Ultrasound-guided breast biopsy using a 10-gauge self-contained vacuum-assisted device. Eur Radiol. Dec. 2007;17(12):3100-3102. PMID: 17639409. [pmid: 17639409].
494 Chapellier C, Balu-Maestro C, Amoretti N, et al. Vacuum-assisted breast biopsies: Experience at the Antoine Lacassagne Cancer Center (Nice, France). Clin Imaging. Mar. 2006;30(2):99-107. PMID: 16500540. [pmid: 16500540].
495 Cipolla C, Fricano S, Vieni S, et al. Validity of needle core biopsy in the histological characterisation of mammary lesions. Breast. Feb. 2006;15(1):76-80. PMID: 16473738. [pmid: 16473738].
496 Dhillon MS, Bradley SA, England DW. Mammotome biopsy: Impact on preoperative diagnosis rate. Clin Radiol. Mar. 2006;61(3):276-281. PMID: 16488210. [pmid: 16488210].
497 Bolivar AV, Alonso-Bartolome P, Garcia EO, et al. Ultrasound-guided core needle biopsy of non-palpable breast lesions: a prospective analysis in 204 cases. Acta Radiol. Nov. 2005;46(7):690-695. PMID: 16372687. [pmid: 16372687].
498 Crystal P, Koretz M, Shcharynsky S, et al. Accuracy of sonographically guided 14-gauge core-needle biopsy: Results of 715 consecutive breast biopsies with at least two-year follow-up of benign lesions. J Clin Ultrasound. Feb. 2005;33(2):47-52. PMID: 15674836. [pmid: 15674836].
499 Dillon MF, Hill AD, Quinn CM, et al. The accuracy of ultrasound, stereotactic, and clinical core biopsies in the diagnosis of breast cancer, with an analysis of false-negative cases. Ann Surg. Nov. 2005;242(5):701-707. PMID: 16244544. [pmid: 16244544].
500 Koskela AK, Sudan M, Berg MH, et al. Add-on device for stereotactic core-needle breast biopsy: How many biopsy specimens are needed for a reliable diagnosis?. Radiology. Sep. 2005;236(3):801-809. PMID: 16020555. [pmid: 16020555].
501 Sauer G, Deissler H, Strunz K, et al. Ultrasound-guided large-core needle biopsies of breast lesions: Analysis of 962 cases to determine the number of samples for reliable tumour classification. Br J Cancer. Jan. 31. 2005;92(2):231-235. PMID: 15611793. [pmid: 15611793].
502 Weber WP, Zanetti R, Langer I, et al. Mammotome: Less invasive than ABBI with similar accuracy for early breast cancer detection. World J Surg. Apr. 2005;29(4):495-499. PMID: 15770379. [pmid: 15770379].
503 Wu YK, Huang YM, Chou AS, et al. Management of breast fibroadenomas by ultrasound-guided vacuum-assisted biopsy - Three years experience. Tzu Chi Med J. Dec. 2005;17(6):405-408. 52.
504 Alonso-Bartolome P, Vega-Bolivar A, Torres-Tabanera M, et al. Sonographically guided 11-G directional vacuum-assisted breast biopsy as an alternative to surgical excision: utility and cost study in probably benign lesions. Acta Radiol. Jul. 2004;45(4):390-396. PMID: 15323390. [pmid: 15323390].
505 Delle Chiaie L, Terinde R. Three-dimensional ultrasound-validated large-core needle biopsy: is it a reliable method for the histological assessment of breast lesions. Ultrasound Obstet Gynecol. Apr. 2004;23(4):393-397. PMID: 15065192. [pmid: 15065192].
506 Fajardo LL, Pisano ED, Caudry DJ, et al. Stereotactic and sonographic large-core biopsy of nonpalpable breast lesions: results of the Radiologic Diagnostic Oncology Group V study. Acad Radiol. Mar. 2004;11(3):293-308. PMID: 15035520. [pmid: 15035520].
507 Kubota K, Gomi N, Wakita T, et al. Magnetic resonance imaging of the metal clip in a breast: safety and its availability as a negative marker. Breast Cancer. 2004;11(1):55-59. PMID: 14718794. [pmid: 14718794].
508 Lomoschitz FM, Helbich TH, Rudas M, et al. Stereotactic 11-gauge vacuum-assisted breast biopsy: influence of number of specimens on diagnostic accuracy. Radiology. Sep. 2004;232(3):897-903. PMID: 15273332. [pmid: 15273332].
509 Abdsaleh S, Azavedo E, Lindgren PG. Semiautomatic core biopsy. A modified biopsy technique in breast diseases. Acta Radiol. Jan. 2003;44(1):47-51. PMID: 12630998. [pmid: 12630998].
510 Ambrogetti D, Bianchi S, Ciatto S. Accuracy of percutaneous core biopsy of isolated breast microcalcifications identified by mammography. Experience with a vacuum-assisted large-core biopsy device. Radiol Med. Oct. 2003;106(4):313-319. PMID: 14612823. [pmid: 14612823].
511 Fishman JE, Milikowski C, Ramsinghani R, et al. US-guided core-needle biopsy of the breast: How many specimens are necessary?. Radiology. Mar. 1. 2003;226(3):779-782. PMID: 12601206. [pmid: 12601206].
512 Han BK, Choe YH, Ko YH, et al. Stereotactic core-needle biopsy of non-mass calcifications: outcome and accuracy at long-term follow-up. Korean J Radiol. Oct-Dec. 2003;4(4):217-223. PMID: 14726638. [pmid: 14726638].
513 Kirshenbaum KJ, Voruganti T, Overbeeke C, et al. Stereotactic core needle biopsy of nonpalpable breast lesions using a conventional mammography unit with an add-on device. AJR Am J Roentgenol. Aug. 2003;181(2):527-531. PMID: 12876040. [pmid: 12876040].
514 March DE, Coughlin BF, Barham RB, et al. Breast masses: Removal of all US evidence during biopsy by using a handheld vacuum-assisted device—Initial experience. Radiology. May. 1. 2003;227(2):549-555. PMID: 12676972. [pmid: 12676972].
515 Pfleiderer SOR, Reichenbach JR, Azhari T, et al. A manipulator system for 14-gauge large core breast biopsies inside a high-field whole-body MR scanner. J Magn Reson Imaging. Apr. 1. 2003;17(4):493-498. [pmid: 12655591].
516 Philpotts LE, Hooley RJ, Lee CH. Comparison of automated versus vacuum-assisted biopsy methods for sonographically guided core biopsy of the breast. AJR Am J Roentgenol. Feb. 2003;180(2):347-351. PMID: 12540431. [pmid: 12540431].
517 Wong TE, Hisham AN. Core needle biopsy of palpable breast lump: the influence of needle size. Med J Malaysia. Aug. 2003;58(3):399-404. PMID: 14750380. [pmid: 14750380].
518 Apesteguia L, Mellado M, Saenz J, et al. Vacuum-assisted breast biopsy on digital stereotaxic table of nonpalpable lesions non-recognisable by ultrasonography. Eur Radiol. Mar. 2002;12(3):638-645. PMID: 11870480. [pmid: 11870480].
519 Georgian-Smith D, D’Orsi C, Morris E, et al. Stereotactic biopsy of the breast using an upright unit, a vacuum-suction needle, and a lateral arm-support system. AJR Am J Roentgenol. Apr. 2002;178(4):1017-1024. Also available: http://www.ajronline.org. PMID: 11906893.
520 Jackman RJ, Lamm RL. Stereotactic histologic biopsy in breasts with implants. Radiology. Jan. 2002;222(1):157-164. PMID: 11756720. [pmid: 11756720].
521 Johnson AT, Henry-Tillman RS, Smith LF, et al. Percutaneous excisional breast biopsy. Am J Surg. Dec. 2002;184(6):550-554. discussion 554. PMID: 12488164. [pmid: 12488164].
522 Liberman L, Kaplan JB, Morris EA, et al. To excise or to sample the mammographic target: what is the goal of stereotactic 11-gauge vacuum-assisted breast biopsy. AJR Am J Roentgenol. Sep. 2002;179(3):679-683. PMID: 12185043. [pmid: 12185043].
523 Meloni GB, Becchere MP, Soro D, et al. Percutaneous vacuum-assisted core breast biopsy with upright stereotactic equipment. Indications, limitations and results. Acta Radiol. Nov. 2002;43(6):575-578. PMID: 12485254. [pmid: 12485254].
524 Morris EA, Liberman L, Trevisan SG, et al. Histologic heterogeneity of masses at percutaneous breast biopsy. Breast J. Jul-Aug. 2002;8(4):187-191. PMID: 12100109. [pmid: 12100109].
525 Pfarl G, Helbich TH, Riedl CC, et al. Stereotactic 11-gauge vacuum-assisted breast biopsy: a validation study. AJR Am J Roentgenol. Dec. 2002;179(6):1503-1507. PMID: 12438044. [pmid: 12438044].
526 Verkooijen HM. Core Biopsy After Radiological Localisation (COBRA) Study Group. Diagnostic accuracy of stereotactic large-core needle biopsy for nonpalpable breast disease: results of a multicenter prospective study with 95% surgical confirmation. Int J Cancer. Jun. 20. 2002;99(6):853-859. PMID: 12115488. [pmid: 12115488].
527 Becker L, Taves D, McCurdy L, et al. Stereotactic core biopsy of breast microcalcifications: comparison of film versus digital mammography, both using an add-on unit. AJR Am J Roentgenol. Dec. 2001;177(6):1451-1457. PMID: 11717106. [pmid: 11717106].
528 Brenner RJ, Bassett LW, Fajardo LL, et al. Stereotactic core-needle breast biopsy: a multi-institutional prospective trial. Radiology. Mar. 2001;218(3):866-872. PMID: 11230668. [pmid: 11230668].
529 Cangiarella J, Waisman J, Symmans WF, et al. Mammotome core biopsy for mammary microcalcification: analysis of 160 biopsies from 142 women with surgical and radiologic followup. Cancer. Jan. 1. 2001;91(1):173-177. PMID: 11148574. [pmid: 11148574].
530 Dahlstrom JE, Jain S. Histological correlation of mammographically detected microcalcifications in stereotactic core biopsies. Pathology. 2001;33(4):444-448. PMID: 11827410. [pmid: 11827410].
531 Lai JT, Burrowes P, MacGregor JH. Diagnostic accuracy of a stereotaxically guided vacuum-assisted large-core breast biopsy program in Canada. Can Assoc Radiol J. Aug. 2001;52(4):223-227. PMID: 11512293. [pmid: 11512293].
532 Levin MF, Papoff WJ, Doan L, et al. Stereotaxic percutaneous core biopsy versus surgical biopsy of nonpalpable breast lesions using a standard mammographic table with an add-on device. Can Assoc Radiol J. 2001;52(1):29-32. PMID: 11247262. [pmid: 11247262].
533 Margolin FR, Leung JW, Jacobs RP, et al. Percutaneous imaging-guided core breast biopsy: 5 years’ experience in a community hospital. AJR Am J Roentgenol. Sep. 2001;177(3):559-564. PMID: 11517047. [pmid: 11517047].
534 Perez-Fuentes JA, Longobardi IR, Acosta VF, et al. Sonographically guided directional vacuum-assisted breast biopsy: preliminary experience in Venezuela. AJR Am J Roentgenol. Dec. 2001;177(6):1459-1463. PMID: 11717107. [pmid: 11717107].
535 Smith DN, Rosenfield Darling ML, Meyer JE, et al. The utility of ultrasonographically guided large-core needle biopsy: results from 500 consecutive breast biopsies. J Ultrasound Med. Jan. 2001;20(1):43-49. PMID: 11149527. [pmid: 11149527].
536 White RR, Halperin TJ, Olson JA Jr, et al. Impact of core-needle breast biopsy on the surgical management of mammographic abnormalities. Ann Surg. Jun. 2001;233(6):769-777. PMID: 11371735. [pmid: 11371735].
537 Wunderbaldinger P, Helbich TH, Partik B, et al. First experience with a new dedicated ultrasound system for computer-guided large-core breast biopsy. Eur Radiol. 2001;11(12):2460-2464. PMID: 11734940. [pmid: 11734940].
538 Yeow KM, Lo YF, Wang CS, et al. Ultrasound-guided core needle biopsy as an initial diagnostic test for palpable breast masses. J Vasc Interv Radiol. Nov. 2001;12(11):1313-1317. PMID: 11698631. [pmid: 11698631].
539 Beck RM, Gotz L, Heywang-Kobrunner SH. Stereotaxic vacuum core breast biopsy—experience of 560 patients. Swiss Surg. 2000;6(3):108-110. PMID: 10894010. [pmid: 10894010].
540 Kirwan SE, Denton ER, Nash RM, et al. Multiple 14G stereotactic core biopsies in the diagnosis of mammographically detected stellate lesions of the breast. Clin Radiol. Oct. 2000;55(10):763-766. PMID: 11052877. [pmid: 11052877].
541 Latosinsky S, Cornell D, Bear HD, et al. Evaluation of stereotactic core needle biopsy (SCNB) of the breast at a single institution. Breast Cancer Res Treat. Apr. 2000;60(3):277-283. PMID: 10930116. [pmid: 10930116].
542 Liberman L, Ernberg LA, Heerdt A, et al. Palpable breast masses: is there a role for percutaneous imaging-guided core biopsy. AJR Am J Roentgenol. Sep. 2000;175(3):779-787. PMID: 10954467. [pmid: 10954467].
543 Makoske T, Preletz R, Riley L, et al. Long-term outcomes of stereotactic breast biopsies. Am Surg. 2000;66(12):1104-1109. [pmid: 11149580].
544 Ward SE, Taves DH, McCurdy LI. Stereotaxic core needle biopsy of breast microcalcifications obtained using a standard mammography table with an add-on unit. Can Assoc Radiol J. Feb. 2000;51(1):10-15. PMID: 10711288. [pmid: 10711288].
545 Welle GJ, Clark M, Loos S, et al. Stereotactic breast biopsy: recumbent biopsy using add-on upright equipment. AJR Am J Roentgenol. Jul. 2000;175(1):59-63. PMID: 10882246. [pmid: 10882246].
546 Helbich TH, Rudas M, Bohm G, et al. Randomized in vitro and in vivo evaluation of different biopsy needles and devices for breast biopsy. Clin Radiol. 1999;54(1):56-62. PMID: 9915512. [pmid: 9915512].
547 Jackman RJ, Nowels KW, Rodriguez-Soto J, et al. Stereotactic, automated, large-core needle biopsy of nonpalpable breast lesions: false-negative and histologic underestimation rates after long-term follow-up. Radiology. Mar. 1999;210(3):799-805. PMID: 10207484. [pmid: 10207484].
548 Meyer JE, Smith DN, Lester SC, et al. Large-core needle biopsy of nonpalpable breast lesions. JAMA. May. 5. 1999;281(17):1638-1641. PMID: 10235159. [pmid: 10235159].
549 Puglisi F, Pertoldi B, Ramello M, et al. Diagnostic accuracy of perforated compression grid approach for mammographically guided core needle biopsy of breast lesions. Cancer Lett. Nov. 15. 1999;146(2):181-188. PMID: 10656624. [pmid: 10656624].
550 Soo MS, Ghate S, Delong D. Stereotactic biopsy of noncalcified breast lesions: utility of vacuum-assisted technique compared to multipass automated gun technique. Clin Imaging. Nov-Dec. 1999;23(6):347-352. PMID: 10899415. [pmid: 10899415].
551 Caruso ML, Gabrieli G, Marzullo G, et al. Core Biopsy as Alternative to Fine-Needle Aspiration Biopsy in Diagnosis of Breast Tumors. Oncologist. 1998;3(1):45-49. PMID: 10388083. [pmid: 10388083].
552 Doyle AJ, Collins JP, Forkert CD. Decubitus stereotactic core biopsy of the breast: technique and experience. AJR Am J Roentgenol. Mar. 1999;172(3):688-690. PMID: 10063861. [pmid: 10063861].
553 Fuhrman GM, Cederbom GJ, Bolton JS, et al. Image-guided core-needle breast biopsy is an accurate technique to evaluate patients with nonpalpable imaging abnormalities. Ann Surg. Jun. 1998;227(6):932-939. PMID: 9637557. [pmid: 9637557].
554 Heywang-Kobrunner SH, Schaumloffel U, Viehweg P, et al. Minimally invasive stereotaxic vacuum core breast biopsy. Eur Radiol. 1998;8(3):377-385. PMID: 9510569. [pmid: 9510569].
555 Ioffe OB, Berg WA, Silverberg SG, et al. Mammographic-histopathologic correlation of large-core needle biopsies of the breast. Mod Pathol. Aug. 1998;11(8):721-727. PMID: 9720499. [pmid: 9720499].
556 Liberman L, Feng TL, Dershaw DD, et al. US-guided core breast biopsy: use and cost-effectiveness. Radiology. Sep. 1998;208(3):717-723. PMID: 9722851. [pmid: 9722851].
557 Schulz-Wendtland R, Kramer S, Lang N, et al. Ultrasonic guided microbiopsy in mammary diagnosis: indications, technique and results. Anticancer Res. May-Jun. 1998;18(3C):2145-2146. PMID: 9703772. [pmid: 9703772].
558 Vega Bolivar A, Ortega Garcia E, Garijo Ayensa F. Stereotaxic core needle aspiration biopsy with multiple passes in nonpalpable breast lesions. Acta Radiol. Jul. 1998;39(4):389-394. PMID: 9685825. [pmid: 9685825].
559 Whitman GJ, Kopans DB, McCarthy KA, et al. Coaxial core needle biopsy under mammographic guidance: indications and applications. AJR Am J Roentgenol. 1998;171(1):67-70. PMID: 9648766. [pmid: 9648766].
560 Zannis VJ, Aliano KM. The evolving practice pattern of the breast surgeon with disappearance of open biopsy for nonpalpable lesions. Am J Surg. Dec. 1998;176(6):525-528. PMID: 9926783. [pmid: 9926783].
561 Bauer RL, Sung J, Eckhert KH Jr, et al. Comparison of histologic diagnosis between stereotactic core needle biopsy and open surgical biopsy. Ann Surg Oncol. Jun. 1997;4(4):316-320. PMID: 9181231. [pmid: 9181231].
562 Britton PD, Flower CD, Freeman AH, et al. Changing to core biopsy in an NHS breast screening unit. Clin Radiol. Oct. 1997;52(10):764-767. PMID: 9366536. [pmid: 9366536].
563 Helbich TH, Mayr W, Schick S, et al. Coaxial technique: approach to breast core biopsies. Radiology. Jun. 1997;203(3):684-690. PMID: 9169689. [pmid: 9169689].
564 Khattar SC, Torp-Pedersen S, Horn T, et al. Ultrasound-guided biopsy of palpable breast masses. Eur J Ultrasound. 1997;6(1):1-7.
565 Liberman L, Dershaw DD, Glassman JR, et al. Analysis of cancers not diagnosed at stereotactic core breast biopsy. Radiology. Apr. 1997;203(1):151-157. PMID: 9122384. [pmid: 9122384].
566 Pitre B, Baron PL, Baron LF, et al. Stereotactic core biopsy of the breast: Results of one-year follow-up of 101 patients. Am Surg. 1997;63(12):1124-1127. PMID: 9393264. [pmid: 9393264].
567 Stolier AJ. Stereotactic breast biopsy: A surgical series. J Am Coll Surg. 1997;185(3):224-228. PMID: 9291397. [pmid: 9291397].
568 Sutton S, Dahlstrom JE, Jain S. Stereotactic large-gauge core biopsy: its role in the diagnosis of non-palpable mammographic abnormalities presenting to a screening service. Australas Radiol. May. 1997;41(2):103-108. PMID: 9153803. [pmid: 9153803].
569 Walker TM. Impalpable breast lesions: Stereotactic core biopsy with an ‘add-on’ unit. Breast. Jun. 1997;6(3):126-131.
570 Frazee RC, Roberts JW, Symmonds RE, et al. Open versus stereotactic breast biopsy. Am J Surg. Nov. 1996;172(5):491-493. 494. 495. PMID: 8942551. [pmid: 8942551].
571 Fuhrman G, Cederbom G, Champagne J, et al. Stereotactic core needle breast biopsy is an accurate diagnostic technique to assess nonpalpable mammographic abnormalities. J La State Med Soc. Apr. 1996;148(4):167-170. PMID: 8935619. [pmid: 8935619].
572 Head JF, Haynes AE, Elliott MC, et al. Stereotaxic localization and core needle biopsy of nonpalpable breast lesions: two-year follow-up of a prospective study. Am Surg. Dec. 1996;62(12):1018-1023. PMID: 8955240. [pmid: 8955240].
573 Mainiero MB, Philpotts LE, Lee CH, et al. Stereotaxic core needle biopsy of breast microcalcifications: correlation of target accuracy and diagnosis with lesion size. Radiology. Mar. 1996;198(3):665-669. PMID: 8628852. [pmid: 8628852].
574 Meyer JE, Christian RL, Lester SC, et al. Evaluation of nonpalpable solid breast masses with stereotaxic large- needle core biopsy using a dedicated unit. AJR Am J Roentgenol. 1996;167(1):179-182. [pmid: 8659367].
575 Nguyen M, McCombs MM, Ghandehari S, et al. An update on core needle biopsy for radiologically detected breast lesions. Cancer. Dec. 1. 1996;78(11):2340-2345. PMID: 8941004. [pmid: 8941004].
576 Pettine S, Place R, Babu S, et al. Stereotactic breast biopsy is accurate, minimally invasive, and cost effective. Am J Surg. May. 1996;171(5):474-476. PMID: 8651388. [pmid: 8651388].
577 Rosenblatt R, Fineberg SA, Sparano JA, et al. Stereotactic core needle biopsy of multiple sites in the breast: efficacy and effect on patient care. Radiology. Oct. 1996;201(1):67-70. PMID: 8816522. [pmid: 8816522].
578 Scopa CD, Koukouras D, Spiliotis J, et al. Comparison of fine needle aspiration and Tru-Cut biopsy of palpable mammary lesions. Cancer Detect Prev. 1996;20(6):620-624. PMID: 8939348. [pmid: 8939348].
579 Cross MJ, Evans WP, Peters GN, et al. Stereotactic breast biopsy as an alternative to open excisional biopsy. Ann Surg Oncol. May. 1995;2(3):195-200. PMID: 7641014. [pmid: 7641014].
580 Doyle AJ, Murray KA, Nelson EW, et al. Selective use of image-guided large-core needle biopsy of the breast: accuracy and cost-effectiveness. AJR Am J Roentgenol. Aug. 1995;165(2):281-284. PMID: 7618540. [pmid: 7618540].
581 Hamed H, De Freitas R Jr, Rasbridge S, et al. A prospective randomized study of two gauges of biopty-cut needle in diagnosis of early breast cancer. Breast. 1995;4(2):135-136.
582 Burbank F, Kaye K, Belville J, et al. Image-guided automated core biopsies of the breast, chest, abdomen, and pelvis. Radiology. Apr. 1994;191(1):165-171. PMID: 8134564. [pmid: 8134564].
583 Gisvold JJ, Goellner JR, Grant CS, et al. Breast biopsy: a comparative study of stereotaxically guided core and excisional techniques. AJR Am J Roentgenol. Apr. 1994;162(4):815-820. PMID: 8140997. [pmid: 8140997].
584 Parker SH, Burbank F, Jackman RJ, et al. Percutaneous large-core breast biopsy: a multi-institutional study. Radiology. Nov. 1994;193(2):359-364. PMID: 7972743. [pmid: 7972743].
585 Smyth AT, Cederbom GJ. Core biopsy of breast lesions. J La State Med Soc. Nov. 1994;146(11):499-501. PMID: 7806950. [pmid: 7806950].
586 Elvecrog EL, Lechner MC, Nelson MT. Nonpalpable breast lesions: correlation of stereotaxic large-core needle biopsy and surgical biopsy results. Radiology. Aug. 1993;188(2):453-455. PMID: 8327696. [pmid: 8327696].
587 Parker SH, Jobe WE, Dennis MA, et al. US-guided automated large-core breast biopsy. Radiology. May. 1993;187(2):507-511. PMID: 8475299. [pmid: 8475299].
588 McMahon AJ, Lutfy AM, Matthew A, et al. Needle core biopsy of the breast with a spring-loaded device. Br J Surg. Oct. 1992;79(10):1042-1045. PMID: 1422715. [pmid: 1422715].
589 Barreto V, Hamed H, Griffiths AB, et al. Automatic needle biopsy in the diagnosis of early breast cancer. Eur J Surg Oncol. Jun. 1991;17(3):237-239. PMID: 2044776. [pmid: 2044776].
590 Cusick JD, Dotan J, Jaecks RD, et al. The role of Tru-Cut needle biopsy in the diagnosis of carcinoma of the breast. Surg Gynecol Obstet. May. 1990;170(5):407-410. PMID: 2183373. [pmid: 2183373].
591 Parker SH, Lovin JD, Jobe WE, et al. Stereotactic breast biopsy with a biopsy gun. Radiology. Sep. 1990;176(3):741-747. PMID: 2167501. [pmid: 2167501].
592 Friese CR, Neville BA, Edge SB, et al. Breast biopsy patterns and outcomes in Surveillance, Epidemiology, and End Results-Medicare data. Cancer. Feb. 15. 2009;115(4):716-724. PMID: 19152430. [pmid: 19152430].
593 Verkooijen HM, Borel Rinkes IH, Peeters PH, et al. Impact of stereotactic large-core needle biopsy on diagnosis and surgical treatment of non-palpable breast cancer. Eur J Surg Oncol. 2001;27(3):244-249. [pmid: 11393185].
594 Kettritz U, Rotter K, Schreer I, et al. Stereotactic vacuum-assisted breast biopsy in 2874 patients: a multicenter study. Cancer. Jan. 15. 2004;100(2):245-251. PMID: 14716757. [pmid: 14716757].
595 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3(1):25. PMID: 14606960. [pmid: 14606960].