# Data Analysis

Table F23 Accuracy data freehand biopsies

Study | Type Core Biopsy | TP | FP | FN | TN | N Atypia | N Atypia Underestimates | N DCIS | N DCIS Underestimates
Wong and Hisham 2003^517^ | Freehand automated gun 14G | 42 | 1 | 3 | 50 | NR | NR | NR | NR
Wong and Hisham 2003^517^ | Freehand automated gun 16G | 23 | 0 | 1 | 30 | NR | NR | NR | NR
Scopa et al. 1996^578^ | Freehand TruCut | 83 | 1 | 10 | 14 | 6 | 5 | NR | NR
McMahon et al. 1992^588^ | Freehand Bioptycut 14G | 21 | 0 | 3 | 27 | NR | NR | NR | NR
McMahon et al. 1992^588^ | Freehand Bioptycut 18G | 23 | 0 | 1 | 27 | NR | NR | NR | NR
McMahon et al. 1992^588^ | Freehand Trucut 14G | 17 | 0 | 8 | 24 | NR | NR | NR | NR
Barreto et al. 1991^589^ | Freehand automated gun 18G | 62 | 0 | 34 | 11 | NR | NR | NR | NR
Cusick et al. 1990^590^ | Freehand | 78 | 0 | 10 | 6 | NR | NR | NR | NR

Table F24 Accuracy data for US-guided automated gun biopsies

Study | Type of core biopsy | TP | FP | FN | TN | N atypia | N atypia underestimated | N DCIS | N DCIS underestimated
Schueller et al. 2008^487^ | US guidance automated gun 14G | 698 | 59 | 11 | 584 | 86 | 27 | 52 | 19
Youk et al. 2008^24^ | US guidance automated gun 14G | 1,281 | 68 | 31 | 1,040 | 93 | 25 | 126 | 36
de Lucena et al. 2007^491^ | US guidance automated gun 14G | 95 | 0 | 6 | 49 | 0 | 0 | 0 | 0
Bolivar et al. 2005^497^ | US guidance automated gun 14G | 118 | 2 | 4 | 79 | 2 | 0 | NR | NR
Crystal et al. 2005^498^ | US guidance automated gun 14G | 313 | 3 | 10 | 389 | 5 | 2 | 6 | 4
Sauer et al. 2005^501^ | US guidance automated gun 14G | 604 | 0 | 11 | 44 | 2 | 2 | 18 | 11
Delle and Terinde 2004^505^ | US guidance automated gun 14G | 124 | 0 | 4 | 39 | NR | NR | NR | NR
Fishman et al. 2003^511^ | US guidance automated gun 14G | 14 | 0 | 0 | 38 | NR | NR | 2 | 0
Philpotts et al. 2003^516^ | US guidance automated gun 14G | 35 | 4 | 1 | 81 | 4 | 0 | 2 | 0
Smith et al. 2001^535^ | US guidance automated gun 14G | 118 | 2 | 0 | 275 | 4 | 2 | 5 | 1
Wunderbaldinger et al. 2001^537^ | US guidance automated gun 14G | 21 | 3 | 0 | 20 | 3 | 0 | 2 | 0
Yeow et al. 2001^538^ | US guidance automated gun 14 or 16G | 66 | 2 | 0 | 30 | 2 | 0 | 2 | 0
Liberman et al. 1998^556^ | US guidance automated gun 14G | 51 | 1 | 3 | 64 | 1 | 0 | 4 | 2
Schulz-Wendtland et al. 1998^557^ | US guidance automated gun 14G | 155 | 0 | 3 | 147 | 1 | 1 | 8 | 2
Khattar et al. 1997^564^ | US guidance automated gun | 41 | 0 | 3 | 13 | NR | NR | NR | NR
Parker et al. 1993^587^ | US guidance automated gun 14G | 34 | 4 | 0 | 143 | 4 | 0 | NR | NR

Table F25 Accuracy data stereotactic guidance automated gun core-needle biopsies

Study | Type of Core Biopsy | TP | FP | FN | TN | N Atypia | N Atypia Underestimated | N DCIS | N DCIS Underestimated
Peters et al. 2008^486^ | Stereotactic guidance automated gun 14G | 483 | 16 | 0 | 312 | 22 | 6 | 196 | 55
Koskela et al. 2005^500^ | Stereotactic guidance automated gun 14G | 82 | 2 | 1 | 117 | 4 | 3 | 33 | 7
Han et al. 2003^512^ | Stereotactic guidance automated gun 14G | 44 | 8 | 11 | 33 | 8 | 0 | 39 | 4
Verkooijen et al. COBRA 2002^526^ | Stereotactic guidance automated gun 14G | 480 | 20 | 15 | 307 | 26 | 6 | 190 | 32
Becker et al. 2001^527^ | Stereotactic guidance automated gun 14G | 43 | 6 | 2 | 101 | 14 | 8 | 36 | NR
Brenner et al. 2001^528^ | Stereotactic guidance automated gun 14G | 230 | 0 | 24 | 234 | NR | NR | NR | NR
Dahlstrom and Jain 2001^530^ | Stereotactic guidance automated gun 14G | 56 | 4 | 11 | 219 | 15 | 11 | NR | NR
Levin et al. 2001^532^ | Stereotactic guidance automated gun 14G | 22 | 0 | 2 | 46 | NR | NR | NR | NR
Kirwan et al. 2000^540^ | Stereotactic guidance automated gun 14G | 23 | 6 | 0 | 34 | 11 | 5 | 3 | 0
Ward et al. 2000^544^ | Stereotactic guidance automated gun 14G | 26 | 3 | 1 | 73 | 6 | 3 | NR | NR
Jackman et al. 1999^547^ | Stereotactic guidance automated gun 14G | 159 | 13 | 2 | 305 | 29 | 16 | 56 | 8
Soo et al. 1999^550^ | Stereotactic guidance automated gun 14G | 12 | 0 | 0 | 48 | 1 | 1 | 0 | 0
Doyle et al. 1998^552^ | Stereotactic guidance automated gun 14G | 51 | 4 | 0 | 77 | 4 | 4 | 21 | NR
Vega-Bolivar et al. 1998^558^ | Stereotactic guidance Surecut 15G | 74 | 5 | 0 | 44 | 11 | 6 | 18 | 6
Whitman et al. 1998^559^ | Stereotactic guidance automated gun 16G | 6 | 2 | 0 | 3 | 2 | 0 | 4 | 3
Zannis and Alia No 1998^560^ | Stereotactic guidance automated gun 14G | 31 | 6 | 0 | 77 | 7 | 1 | 3 | 2
Bauer et al. 1997^561^ | Stereotactic guidance automated gun 14G | 85 | 12 | 1 | 697 | 20 | 8 | 32 | 8
Liberman et al. 1997^565^ | Stereotactic guidance automated gun 14G | 144 | 34 | 7 | 162 | 55 | 21 | NR | NR
Pitre et al. 1997^566^ | Stereotactic guidance automated gun | 10 | 2 | 1 | 100 | 3 | 1 | NR | NR
Sutton, et al. 1997^568^ | Stereotactic guidance automated gun 14G | 58 | 1 | 1 | 80 | 8 | 7 | NR | NR
Walker et al. 1997^569^ | Stereotactic guidance automated gun 14G | 95 | 9 | 14 | 60 | 14 | 5 | 43 | 6
Frazee et al. 1996^570^ | Stereotactic guidance automated gun | 6 | 0 | 0 | 45 | 0 | 0 | 2 | 0
Fuhrman et al. 1996^571^ | Stereotactic guidance automated gun 14G | 48 | 12 | 1 | 268 | 21 | 9 | NR | NR
Head and Haynes 1996^572^ | Stereotactic guidance automated gun 18G | 12 | 6 | 0 | 84 | 12 | 6 | NR | NR
Mainiero et al. 1996^573^ | Stereotactic guidance automated gun 14G | 23 | 10 | 3 | 79 | 14 | 4 | 13 | 6
Meyer et al. 1996^574^ | Stereotactic guidance automated gun 14G | 60 | 1 | 0 | 210 | 2 | 1 | 2 | 2
Pettine et al. 1996^576^ | Stereotactic guidance automated gun 14G | 6 | 0 | 1 | 17 | NR | NR | 1 | 0
Rosenblatt et al. 1996^577^ | Stereotactic guidance automated gun 14G | 15 | 0 | 0 | 6 | NR | NR | 2 | 2
Cross et al. 1995^579^ | Stereotactic guidance automated gun 14G | 44 | 0 | 0 | 172 | NR | NR | NR | NR
Gisvold et al. 1994^583^ | Stereotactic guidance automated gun 14G | 60 | 1 | 6 | 93 | 4 | 3 | NR | NR
Smyth and Cederbom 1994^585^ | Stereotactic guidance automated gun 14G | 14 | 0 | 0 | 44 | NR | NR | NR | NR
Elvecrog et al. 1993^586^ | Stereotactic guidance automated gun 14G | 31 | 8 | 0 | 64 | 8 | 0 | NR | NR
Parker et al. 1990^591^ | Stereotactic guidance automated gun | 15 | 0 | 1 | 80 | NR | NR | NR | NR

Table F26 Accuracy data ultrasound-guided vacuum-assisted core-needle biopsies

Study | Type of Core Biopsy | TP | FP | FN | TN | N Atypia | N Atypia Underestimated | N DCIS | N DCIS Underestimated
Vag et al. 2007^493^ | US guidance vacuum-assisted 10G | 28 | 0 | 1 | 41 | NR | NR | NR | NR
Wu et al. 2005^503^ | US guidance vacuum-assisted 11G | 0 | 0 | 1 | 112 | 0 | 0 | 0 | 0
Alonso-Bartolome et al. 2004^504^ | US guidance vacuum-assisted 11G | 1 | 1 | 0 | 100 | 1 | 0 | NR | NR
March et al. 2003^514^ | US guidance vacuum-assisted 11G | 8 | 2 | 0 | 21 | 2 | 0 | 1 | 0
Philpotts et al. 2003^516^ | US guidance vacuum-assisted 11G | 19 | 2 | 1 | 37 | 2 | 0 | 1 | 1
Johnson et al. 2002^521^ | US guidance vacuum-assisted 11 or 8G | 3 | 2 | 0 | 70 | 2 | 0 | 0 | 0
Perez-Fuentes et al. 2001^534^ | US guidance vacuum-assisted 11G | 14 | 1 | 0 | 42 | 1 | 0 | NR | NR

Table F27 Accuracy data stereotactic guidance vacuum-assisted core-needle biopsy

Study | Type of Core Biopsy | TP | FP | FN | TN | N Atypia | N Atypia Underestimated | N DCIS | N DCIS Underestimated
Jackman et al. 2009^485^ | Stereotactic guidance vacuum- assisted 11G or 14G | 503 | 97 | 5 | 604 | NR | NR | NR | NR
Sim and Kei 2008^488^ | Stereotactic guidance vacuum- assisted 11G | 16 | 7 | 0 | 69 | 7 | 0 | 15 | 0
Tonegutti and Girardi 2008^489^ | Stereotactic guidance vacuum- assisted 11G | 56 | 22 | 0 | 140 | 27 | 5 | 35 | 3
Uematsu et al. 2007^492^ | Stereotactic guidance vacuum- assisted 11G | 34 | 7 | 0 | 59 | 8 | 1 | 31 | 4
Chapellier et al. 2006^494^ | Stereotactic guidance vacuum- assisted 11G | 85 | 17 | 0 | 209 | 19 | 2 | 51 | 11
Dhillon et al. 2006^496^ | Stereotactic guidance vacuum- assisted 11G | 46 | 16 | 0 | 88 | 18 | 2 | 34 | 4
Weber et al. 2005^502^ | Stereotactic guidance vacuum- assisted 11G | 62 | 8 | 2 | 118 | 9 | 1 | 40 | 6
Kettritz et al. 2004^507^ | Stereotactic guidance vacuum- assisted 11G | 669 | 103 | 1 | 1461 | 135 | 32 | 434 | 49
Lomoschitz et al. 2004^508^ | Stereotactic guidance vacuum- assisted 11G | 45 | 2 | 2 | 22 | 4 | 2 | 12 | 2
Ambrogetti et al. 2003^510^ | Stereotactic guidance vacuum- assisted 11G | 144 | 12 | 15 | 66 | 17 | 5 | 115 | 20
Apesteguia et al. 2002^518^ | Stereotactic guidance vacuum- assisted 11G | 47 | 13 | 0 | 70 | 14 | 1 | 32 | 5
Georgian-Smith et al. 2002^519^ | Stereotactic guidance vacuum- assisted 11G | 29 | 7 | 1 | 106 | 9 | 2 | 17 | 2
Liberman et al. 2002^522^ | Stereotactic guidance vacuum- assisted 11G | 213 | 38 | 3 | 321 | 49 | 11 | 120 | 17
Meloni et al. 2002^523^ | Stereotactic guidance vacuum- assisted | 40 | 1 | 0 | 64 | 2 | 1 | 22 | 1
Morris et al. 2002^524^ | Stereotactic guidance vacuum- assisted 14G | 4 | 1 | 0 | 12 | 1 | 0 | 0 | 0
Pfarl et al. 2002^525^ | Stereotactic guidance vacuum- assisted 11G | 207 | 11 | 7 | 93 | 17 | 6 | 91 | 11
Cangiarella et al. 2001^529^ | Stereotactic guidance vacuum- assisted 11G | 15 | 8 | 0 | 92 | 10 | 2 | 12 | 1
Lai et al. 2001^531^ | Stereotactic guidance vacuum- assisted 11G | 148 | 8 | 2 | 321 | 10 | 2 | 48 | 6
Beck et al. 2000^539^ | Stereotactic guidance vacuum- assisted 11G | 105 | 13 | 0 | 477 | 13 | 0 | 74 | 0
Soo et al. 1999^550^ | Stereotactic guidance vacuum- assisted 14G | 10 | 1 | 0 | 22 | 1 | 0 | 2 | 0
Heywang-Kobrunner et al. | Stereotactic guidance vacuum- | 45 | 6 | 0 | 129 | 6 | 0 | 30 | 0
Jackman et al. 2009^485^ | Stereotactic guidance vacuum-assisted 11G or 14G | 503 | 97 | 5 | 604 | NR | NR | NR | NR
Sim and Kei 2008^488^ | Stereotactic guidance vacuum-assisted 11G | 16 | 7 | 0 | 69 | 7 | 0 | 15 | 0
1998^554^ | assisted 11 or 14G
Zannis and AliaNo 1998^560^ | Stereotactic guidance vacuum-assisted 11G | 17 | 4 | 0 | 33 | 4 | 0 | 9 | 0

Table F28 Accuracy data miscellaneous methods of biopsy

Study | Type Core Biopsy | TP | FP | FN | TN | N Atypia | N Atypia Underestimates | N DCIS | N DCIS Underestimates
Pfleiderer et al. 2003^515^ | MRI guidance automated gun 14G | 5 | 0 | 1 | 8 | 1 | 1 | NR | NR
Puglisi et al. 1999^549^ | Perforated compression grid automated gun 14G | 32 | 2 | 3 | 63 | 4 | 1 | 7 | 2

Table F29 Accuracy data mixed methods of biopsy not reported separately

Study | Type Core Biopsy | TP | FP | FN | TN | N Atypia | N Atypia Underestimated | N DCIS | N DCIS Underestimated
Ciatto et al. 2007^490^ | Multiple methods | 1,158 | 207 | 71 | 1,532 | NR | NR | NR | NR
Cipolla et al. 2006^495^ | Multiple methods | 182 | 11 | 1 | 232 | 16 | 6 | 8 | 3
Dillon et al. 2005^499^ | Multiple methods | 1,299 | 120 | 85 | 461 | 181 | 71 | NR | NR
Fajardo et al. 2004^506^ | Multiple methods | 358 | 31 | 17 | 1,025 | 54 | 23 | NR | NR
Abdsaleh et al. 2003^509^ | Multiple methods | 104 | 1 | 16 | 18 | NR | NR | 7 | 2
Kirshenbaum et al. 2003^513^ | Multiple methods | 117 | 20 | 2 | 253 | 24 | 6 | NR | NR
Jackman and Lamm 2002^520^ | Multiple methods | 11 | 3 | 0 | 17 | 3 | 0 | 5 | 0
Margolin et al. 2001^533^ | Multiple methods | 158 | 14 | 0 | 1,120 | 26 | 12 | NR | NR
White et al. 2001^536^ | Multiple methods | 231 | 31 | 7 | 464 | 39 | 10 | 65 | 18
Latosinsky et al. 2000^541^ | Multiple methods | 85 | 13 | 6 | 246 | 21 | 8 | 30 | 8
Liberman et al. 2000^542^ | Multiple methods | 62 | 4 | 1 | 36 | 4 | 2 | 4 | 2
Makoske et al. 2000^543^ | Multiple methods | 139 | 28 | 0 | 377 | 38 | 10 | 39 | 19
Welle et al. 2000^545^ | Multiple methods | 36 | 15 | 0 | 122 | 13 | 4 | 7 | 3
Meyer et al. 1999^548^ | Multiple methods | 493 | 63 | 0 | 855 | 88 | 25 | 133 | 20
Caruso et al. 1998^551^ | Multiple methods | 67 | 0 | 0 | 7 | NR | NR | 2 | 2
Fuhrman et al. 1998^553^ | Multiple methods | 295 | 31 | 3 | 852 | 67 | 36 | 84 | 30
Loffe et al. 1998^555^ | Multiple methods | 50 | 7 | 0 | 125 | 10 | 3 | NR | NR
Britton et al. 1997^562^ | Multiple methods | 94 | 2 | 7 | 95 | NR | NR | NR | NR
Helbich et al. 1997^563^ | Multiple methods | 100 | 2 | 3 | 105 | 4 | 2 | 12 | 0
Stolier et al. 1997^567^ | Multiple methods | 30 | 6 | 2 | 170 | 12 | 3 | 10 | 0
Nguyen et al. 1996^575^ | Multiple methods | 183 | 9 | 4 | 217 | NR | NR | NR | NR
Doyle et al. 1995^580^ | Multiple methods | 23 | 2 | 0 | 119 | 6 | 4 | NR | NR
Burbank et al. 1994^582^ | Multiple methods | 14 | 3 | 0 | 88 | 3 | 1 | 6 | 0
Parker et al. 1994^584^ | Multiple methods | 967 | 129 | 15 | 2,654 | 186 | 57 | 148 | 18

Table F30 Miscellaneous accuracy data

Study | Accuracy by Breast Lesion Factors | Accuracy by Patient Characteristics | Accuracy by Biopsy Methods | Accuracy by Clinician and Facility Factors
Ciatto et al. 2007^490^ | [underlined: Palpable lesions]: 400 true positives, 63 false positives, 27 false negatives, 493 true negatives [underlined: Non-palpable lesions]: 758 true positives, 144 false positives, 44 false negatives, 1038 true negative [underlined: Masses on mammography]: 540 true positives, 103 false positives, 36 false negatives, 839 true negatives [underlined: Distortions on mammography]: 17 true positives, 27 false positives, 1 false negative, 29 true negatives [underlined: Microcalcifications]: 601 true positives, 77 false positives, 34 false negatives, 663 true negatives | NR | NR | Overall sensitivity improved over the course of the study, 88% first year, 96% final year.
de Lucena et al. 2007^491^ | NR | NR | The rate of false negatives decreased from 9.9% with only one core to 5.9% with two cores. Adding additional cores beyond 2 didn’t improve the accuracy of the biopsy. | NR
Cipolla et al. 2006^495^ | Correspondence between the core-biopsy and surgical specimen was 100% in palpable lesions but only 88.6% in non-palpable lesions | NR | NR | NR
Koskela et al. 2005^500^ | [underlined: Masses on mammography]: 40 true positives, 1 false-negative, 55 true negatives [underlined: Microcalcifications]: 43 true positives, 0 false-negatives, 66 true negatives | NR | More than three samples are needed for a diagnosis of a mass lesion | NR
Fajardo et al. 2004^506^ | [underlined: Nonpalpable lesions]: Sensitivity 90.7% [underlined: Masses on mammography]: Sensitivity 97.4% [underlined: Microcalcifications]: 90.7% | NR | NR | NR
Lomoschitz et al. 2004^508^ | [underlined: Masses on mammography]: 25 true positives, 1 false-negative, 23 true negatives [underlined: Microcalcifications]: 18 true positives, 1 false-negative, 28 true negatives | NR | 12 specimens were necessary to yield correct diagnoses in 96% of patients with masses and 92% of patients with microcalcifications, and addition of further cores did not improve accuracy. | NR
Abdsaleh et al. 2003^509^ | NR | 34 of the 35 technical failures occurred in dense breasts | For one core there were 12 false-negatives out of 107 biopsies; for two cores there were 3 false-negatives out of 34 biopsies. | NR
Fishman et al. 2003^511^ | NR | NR | Cells indicating the final diagnosis were present in the first core in 51 cases, in the second core in 67 cases, in the third core in 70 cases, and in the fourth core in all 73 cases.
Pfarl et al. 2002^525^ | [underlined: Masses on mammography]: 96 true positives, 3 false negatives, 52 true negatives [underlined: Microcalcifications]: 111 true positives, 4 false negatives, 42 true negatives | NR | NR | In six of the seven false-negative cases the biopsy was performed by an operator who had previously performed 15 or fewer stereotactic vacuum-assisted biopsies.
Doyle et al. 1998^552^ | NR | NR | Of 14 biopsies performed in the seated position, there were no technical failures and no false negatives Of 137 biopsies performed in the decubuitus position, there were 2 technical failures and no false negatives | NR
Helbich et al. 1997^563^ | NR | NR | Patients were randomly assigned to supine, prone, sitting; authors comment they did not find patient position to impact the biopsy procedure. | NR
Walker et al. 1997^569^ | [underlined: Masses on mammography]: Sensitivity 93% [underlined: Distortions on mammography]: Sensitivity 89% [underlined: Microcalcifications]: Sensitivity 85% | NR | NR | NR
Barreto et al. 1991^589^ | Tumor size did not affect accuracy; however, patients with the lesion located in the right breast had a higher rate of false-negatives (right side, 45% were false negative, left side, 27% were false negative). | Age of patients did not affect accuracy | NR | Accuracy improved over time-first 25% of biopsies performed there were 50% true positives; second and third 25% of biopsies performed there were 63% true positives; last 25% of biopsies performed there were 83% true positives.
Cusick et al. 1990^590^ | 24% of lesions smaller than 2 cm had false-negative findings compared to only 7% of larger lesions having false-negative findings | NR | NR | NR

Table F31 Harms data

Study | Number of Lesions Enrolled | Type of Biopsy | Hematomas | Bleeding | Vasovagal Reactions | Infections | Other | Time to Recovery or Time to Return to Work | Use of Pain Medications | Patient Satisfaction, Quality of Life Data | Impact of Biopsy Procedure on Accuracy of Subsequent Mammography Procedures
Peters et al. 2008^486^ | 948 | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Sim and Kei 2008^488^ | 105 | Stereotactic guidance vacuum-assisted 11G | 9 had small hematomas that did not require treatment | NR | 2 | NR | NR | NR | NR | NR | NR
Tonegutti and Girardi 2008^489^ | 268 | Stereotactic guidance vacuum-assisted 11G | 3 had large hematomas that did not require treatment | 2, but did not require treatment | 1 | NR | 3 had acute localized inflammation, and one large abscess that required surgery | NR | NR | NR | NR
Youk et al. 2008^24^ | 4,359 | US guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Ciatto et al. 2007^490^ | 4,035 | Multiple methods | NR | NR | NR | NR | NR | NR | NR | NR | NR
de Lucena et al. 2007^491^ | 150 | US guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Uematsu et al. 2007^492^ | 100 | Stereotactic guidance vacuum-assisted 11G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Vag et al. 2007^493^ | 70 | US guidance vacuum-assisted 10G | NR | No severe bleeding occurred | 1 | No severe infections occurred | NR | NR | NR | NR | NR
Chapellier et al. 2006^494^ | 318 | Stereotactic guidance vacuum-assisted 11G | 123 subclinical | NR | NR | NR | No abscesses occurred | NR | NR | 269 found procedure had good tolerability and 49 reported it was acceptable or poor. Of these 49, 17 complained of intense pain, 23 of pain that didn’t respond to the local anesthetic, and 12 reported the procedure was stressful | NR
Cipolla et al. 2006^495^ | 426 | Multiple methods | NR | NR | NR | NR | NR | NR | NR | NR | NR
Dhillon et al. 2006^496^ | 150 | Stereotactic guidance vacuum-assisted 11G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Bolivar et al. 2005^497^ | 214 | US guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Crystal et al. 2005^498^ | 715 | US guidance automated gun 14G | NR | NR | NR | NR | No major complications occurred | NR | NR | NR | NR
Dillon et al. 2005^499^ | 2,427 | Multiple methods | NR | NR | NR | NR | NR | NR | NR | NR | NR
Koskela et al. 2005^500^ | 213 | Stereotactic guidance automated gun 14G | No hematomas that required treatment occurred | NR | 2 | No infections that required treatment occurred | NR | NR | NR | NR | NR
Sauer et al. 2005^501^ | 962 | US guidance automated gun 14G | NR | Some cases of minor bleeding that did not require treatment | NR | 1 that required surgery and antibiotics | NR | NR | NR | NR | NR
Weber et al. 2005^502^ | 225 | Stereotactic guidance vacuum-assisted 11G | NR | NR | NR | 2 | 1 biopsy was terminated after complaints of severe pain by the patient, 5 patients had severe bruising and 2 complained of persistent pain | NR | NR | 2 patients were not satisified with the cosmetic result | NR
Wu et al. 2005^503^ | 113 | US guidance vacuum-assisted 11G | NR | NR | NR | NR | 2 cases pneumothoraxthat resolved without treatment, 13 cases of severe ecchymosis that also resolved without treatment; All complications occurred during the first year of the study, no complications occurred during the second and third years | NR | NR | NR | NR
Alonso-Bartolome et al. 2004^504^ | 102 | US guidance vacuum-assisted 11G | 37 that did not require treatment | 3, only one required treatment | NR | NR | 1 patient complained of pain. | NR | NR | NR | NR
Delle and Terinde 2004^505^ | 169 | US guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Fajardo et al. 2004^506^ | 2,403 | Multiple methods | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kettritz et al. 2004^507^ | 2,893 | Stereotactic guidance vacuum- assisted 11G | 25 hematomas of which 3 were hospitalized overnight and 1 required surgery | 4 patients were hospitalized for persistent bleeding, of which 3 needed surgery | 5 | 5 that required antibiotics | 1 seizure | NR | NR | NR | In 196 patients a slight mammographic density was observed. In 4 patients a scar that might cause diagnostic difficulty was observed.
Lomoschitz et al. 2004^508^ | 100 | Stereotactic guidance vacuum- assisted 11G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Abdsaleh et al. 2003^509^ | 180 | Multiple methods | NR | Mild bleeding occurred in all cases | NR | NR | No significant complications occurred | NR | NR | NR | NR
Ambrogetti et al. 2003^510^ | 364 | Stereotactic guidance vacuum- assisted 11G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Fishman et al. 2003^511^ | 73 | US guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Han et al. 2003^512^ | 271 | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kirshenbaum et al. 2003^513^ | 506 | Multiple methods | NR | Three cases of minor bleeding and one case of major bleeding that required surgery | 5 vasovagal reactions; the most experienced radiologist had 3 reactions in 409 procedures while the two more inexperienced radiologists had 1 reaction out of 47 procedures and 1 reaction out of 53 procedures | NR | NR | NR | NR | NR | NR
March et al. 2003^514^ | 34 | US guidance vacuum-assisted 11G | 9 hematomas that did not require treatment | NR | NR | NR | 19 reported no pain, 13 reported mild pain, 2 reported moderate pain. 24 patients had ecchymosis 2–4 days after the procedure | 16 reported the procedure had not interferred with usual activity at all, 14 a little, 4 somewhat | 20 took acetaminophen | NR | NR
Pfleiderer et al. 2003^515^ | 14 | MRI guidance automated gun 14G | NR | NR | NR | NR | No severe side effects were observed | NR | None used | NR | NR
Philpotts et al. 2003^516^ | 281 | Multiple methods | 3 hematomas in 11G no surgery required | 3 cases of bleeding with 14G | NR | NR | NR | NR | NR | NR | NR
Wong and Hisham 2003^517^ | 150 | Freehand automated gun 14G/16G | NR | 1 patient in 14G group experienced troublesome bleeding | NR | 3 patients from 14G group developed infections | There was no difference in the amount of pain experienced between 14G and 16G as meausured on a VAS, p >0.05 | NR | NR | NR | NR
Apesteguia et al. 2002^518^ | 132 | Stereotactic guidance vacuum- assisted 11G | Some hematomas that did not require treatment | 8 cases of bleeding which caused premature termination of the procedure in 3 of the 8 cases | NR | NR | 2 cases of severe pain | NR | NR | NR | NR
Georgian-Smith et al. 2002^519^ | 185 | Stereotactic guidance vacuum- assisted 11G | 3, one case of which it became infected and required antibiotics to treat | 5, 2 of which were severe enough to require termination of the biopsy | 10, 2 of which were severe enough to require termination of the biopsy procedure | NR | 1 patient vomited | NR | NR | NR | NR
Jackman and Lamm 2002^520^ | 31 | Multiple methods | NR | 2 serious bleeding | NR | NR | NR | NR | NR | NR | NR
Johnson et al. 2002^521^ | 101 | US guidance vacuum-assisted 11 or 8G | 1 large hematoma requiring narcotics | 1 significant bleeding requiring surgery; less than 5% of cases had bleeding requiring treatment | NR | 2 infections requiring antibiotics and surgical drainage | NR | NR | 1 case required narcotics | NR | NR
Liberman et al. 2002^522^ | 800 | Stereotactic guidance vacuum- assisted 11G | 2 that required treatment | 12 | 2 | NR | 1 patient was in such severe pain that the procedure was terminated | NR | NR | NR | NR
Meloni et al. 2002^523^ | 129 | Stereotactic guidance vacuum- assisted | 2 that did not require treatment | 1 | 5 | NR | NR | NR | NR | NR | NR
Morris et al. 2002^524^ | 21 | Stereotactic guidance vacuum- assisted 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Pfarl et al. 2002^525^ | 332 | Stereotactic guidance vacuum- assisted 11G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Verkooijen et al. COBRA 2002^526^ | 984 | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Becker et al. 2001^527^ | 232 | Stereotactic guidance automated gun 14G | NR | 3 minor | 2 | NR | NR | NR | NR | NR | NR
Brenner et al. 2001^528^ | 1,003 | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Cangiarella et al. 2001^529^ | 160 | Stereotactic guidance vacuum- assisted 11G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Dahlstrom and Jain 2001^530^ | 310 | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Lai et al. 2001^531^ | 673 | Stereotactic guidance vacuum- assisted 11G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Levin et al. 2001^532^ | 70 | Stereotactic guidance automated gun 14G | NR | NR | 3 | NR | NR | NR | NR | NR | NR
Margolin et al. 2001^533^ | 1,333 | Multiple methods | NR | NR | NR | 2 that required antibiotics | NR | NR | NR | NR | NR
Perez-Fuentes et al. 2001^534^ | 88 | US guidance vacuum-assisted 11G | NR | 1 patient with implants experienced severe bleeding that required surgical treatment | NR | NR | NR | NR | NR | NR | NR
Smith et al. 2001^535^ | 500 | US guidance automated gun 14G | 0 | NR | NR | 0 | 26 had large areas of ecchymosis; one patient had a small pneumothorax that resolved without treatment | NR | NR | NR | NR
White et al. 2001^536^ | 1,042 | Multiple methods | NR | NR | NR | NR | NR | NR | NR | NR | NR
Wunderbaldinger et al. 2001^537^ | 45 | US guidance automated gun 14G | NR | NR | 4 | NR | NR | NR | NR | NR | NR
Yeow et al. 2001^538^ | 98 | US guidance automated gun 14 or 16G | 0 | NR | NR | 0 | 1 patient had a puncture site ecchymosis | NR | NR | NR | NR
Beck et al. 2000^539^ | 594 | Stereotactic guidance vacuum- assisted 11G | 1 that required surgical treatment | NR | NR | NR | 1 patient had a seizure | NR | NR | NR | In 90% of patients no scarring was seen on subsequent mammography; in 10% a faint density could be seen at the biopsy site; 1 patient had a diagnostically confusing scar that was evidentally benign on MRI
Kirwan et al. 2000^540^ | 72 | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Latosinsky et al. 2000^541^ | 692 | Multiple methods | NR | NR | NR | NR | There were no significant complications of bleeding or infection | NR | NR | NR | NR
Liberman et al. 2000^542^ | 155 | Multiple methods | NR | NR | NR | NR | NR | NR | NR | NR | NR
Makoske et al. 2000^543^ | 887 | Multiple methods | NR | NR | NR | NR | NR | NR | NR | NR | NR
Ward et al. 2000^544^ | 121 | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Welle et al. 2000^545^ | 225 | Multiple methods | 1 did not require treatment | 1 did not require treatment | 4 (in seated patients) | NR | NR | NR | NR | NR | NR
Helbich et al. 1999^546^ | 44 | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Jackman et al. 1999^547^ | 483 | Multiple methods | NR | NR | NR | NR | NR | NR | NR | NR | NR
Meyer et al. 1999^548^ | 1,836 | Perforated compression grid automated gun 14G | 0 that required treatment | NR | NR | 1 that required antibiotics | Complications were minor and infrequent. 1 pneumothorax requiring no treatment occurred | NR | NR | NR | NR
Puglisi et al. 1999^549^ | 106 | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | No complications resulted from this technique | NR | NR | NR | NR
Soo et al. 1999^550^ | 116 | Stereotactic guidance vacuum- assisted 14G | NR | NR | NR | NR | One patient was in such severe pain that the procedure was terminated | NR | NR | NR | NR
Caruso et al. 1998^551^ | 92 | Multiple methods | NR | NR | NR | NR | NR | NR | NR | NR | NR
Doyle et al. 1998^552^ | 151 | Stereotactic guidance automated gun 14G | NR | NR | 4 (in seated patients) | 1 minor | No serious complications occurred | NR | NR | Most of our patients found that decubitus position was reasonably comfortable and that discomfort was mostly related to prolonged breast compression | NR
Fuhrman et al. 1998^553^ | 1,440 | Multiple methods | NR | NR | NR | NR | Hospitalization was not required for any subjects. The only complication encountered was minor breast ecchymosis, which resolved uneventfully in all cases | NR | NR | NR | NR
Heywang- Kobrunner et al. 1998^554^ | 261 | Stereotactic guidance vacuum- assisted 11 or 14G | NR | 1 | NR | NR | No side effects occurred. No patients complained about pain. | NR | NR | NR | 117 of 129 patients had no scarring visible at 6-month mammography. Very slight scarring occurred in ten patients, and mammographically visible scarring in 2 patients, one of whom was sent for MRI to verify it was a scar and not a tumor.
Ioffe et al. 1998^555^ | 224 | US guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Liberman et al. 1998^556^ | 151 | Multiple methods | NR | NR | NR | NR | NR | NR | NR | NR | NR
Schulz-Wendtland et al. 1998^557^ | 2,307 | US guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Vega-Bolivar et al. 1998^558^ | 182 | Stereotactic guidance Surecut 15G | NR | NR | 12 | NR | NR | NR | NR | NR | NR
Whitman et al. 1998^559^ | 12 | Stereotactic guidance automated gun 16G | NR | NR | 1 | NR | NR | NR | NR | NR | NR
Zannis and AliaNo 1998^560^ | 424 | Multiple methods | NR | Bleeding requiring operative intervention was not required in any group | NR | NR | Open biopsy: 12 cases cellulitis and 4 abscesses out of 190 procedures; zero cases of cellulitis and abscesses out of 234 core- needle biopsy procedures | NR | Open biopsy: all 190 were sent home with oral narcotic analgesia; zero patients out of 157 SCNB and 77 VAB procedures required oral narcotic analgesia | NR | NR
Bauer et al. 1997^561^ | 799 | Stereotactic guidance automated gun 14G | 10 that did not require treatment | NR | NR | 0 | NR | NR | NR | NR | NR
Britton et al. 1997^562^ | 202 | Multiple methods | 0 | NR | 7 | | No complications that required treatment occurred | NR | NR | NR | NR
Helbich et al. 1997^563^ | 210 | Multiple methods | NR | NR | 4 (in seated patients) | NR | No serious complications, patients tolerated it well | NR | NR | NR | NR
Khattar et al. 1997^564^ | 106 | US guidance automated gun | NR | NR | NR | NR | NR | NR | NR | NR | NR
Liberman et al. 442 1997^565^ | | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Pitre et al. 1997^566^ | 128 | Stereotactic guidance automated gun | NR | NR | NR | NR | NR | NR | NR | NR | NR
Stolier et al. 1997^567^ | 244 | Multiple methods | NR | NR | NR | NR | NR | NR | NR | NR | NR
Sutton, et al. 1997^568^ | 206 | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | There were no cases of long-term morbidity and only 3 patients (1.5%) had a biopsy-related problem 3 days after their core-needle biopsy | NR | NR | Pain: 36% none, 27.6% un-comfortable, 12.3% slight, 7% quite, 0% very Discomfort: 50% none, 40% un-comfortable, 6% slight, 4% quite, 0% very | NR
Walker et al. 1997^569^ | 200 | Stereotactic guidance automated gun 14G | NR | 0 | 1 | 0 | A few patients complained of pain; bruising was not infrequent | NR | NR | NR | NR
Frazee et al. 1996^570^ | 103 | Stereotactic guidance automated gun | NR | NR | NR | NR | Patients rating of post-operative pain was evaluated using a Pain Analog Scale. The mean score for open biopsy was 2.5 and for stereotactic biopsy was 2.8 (P = NS) | The interval of returning to normal activies was measured. This averaged 3.8 days for open biopsy and 1.5 days for stererotactic biopsy (P = NS) | NR | Overall patient satisfaction was evaluated. No significant differences were seen in overall patient satisfaction between the two biopsy techniques | NR
Fuhrman et al. 1996^571^ | 451 | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Head and Haynes 1996^572^ | 115 | Stereotactic guidance automated gun 18G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Mainiero et al. 1996^573^ | 138 | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Meyer et al. 1996^574^ | 388 | Stereotactic guidance automated gun 14G | 3 | NR | NR | NR | Ecchymosis at the biopsy site occured in 48% of patients | NR | NR | NR | NR
Nguyen et al. 1996^575^ | 431 | Multiple methods | A few small superficial ones that required no treatment | NR | NR | NR | There were no serious complications. Several patients complained of pain related to lying on the biopsy table for a prolonged period of time | NR | NR | NR | NR
Pettine et al. 1996^576^ | 25 | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Rosenblatt et al. 1996^577^ | 58 | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Scopa et al. 1996^578^ | 120 | Freehand TruCut | NR | NR | NR | NR | NR | NR | NR | NR | NR
Cross et al. 1995^579^ | 250 | Stereotactic guidance automated gun 14G | NR | NR | NR | 0 | Pain was reported to be minimal | NR | NR | NR | NR
Doyle et al. 1995^580^ | 365 | Multiple methods | NR | NR | NR | NR | NR | NR | NR | NR | NR
Burbank et al. 1994^582^ | 105 | Multiple methods | NR | NR | NR | NR | NR | NR | NR | NR | NR
Gisvold et al. 1994^583^ | 160 | Stereotactic guidance automated gun 14G | Hemotoma formation was infrequent | NR | 0 | 1 serious systemic infection | Two patients had significant pain | NR | NR | NR | NR
Parker et al. 1994^584^ | 6,152 | Multiple methods | 3 that required surgery | NR | NR | 3 that required antibiotics | NR | NR | NR | NR | NR
Smyth and Cederbom 1994^585^ | 58 | Stereotactic guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Elvecrog et al. 1993^586^ | 100 | Stereotactic guidance automated gun 14G | 1 that required surgical treatment | NR | NR | NR | NR | NR | NR | Some patients complained of pain from biopsy, but usually with only 1 or 2 needle passes. In a few cases, deep anesthesia was administered with the biopsy needle still in the lesion. There were frequent complaints of neck, shoulder, and arm discomfort from patients lying in the same position for an extended period of time | NR
Parker et al. 1993^587^ | 181 | US guidance automated gun 14G | NR | NR | NR | NR | NR | NR | NR | NR | NR
McMahon et al. 1992^588^ | 151 | Freehand 14/1618G | NR | Troublesome bleeding occurred in 3 patients in Bioptycut 14G, 2 patients in Bioptycut 18G, and 1 in Trucut | NR | NR | There were no major complications. Minor bruising was common. No patients developed pneumothorax | NR | NR | Pain scores on a 0 to 3 scale were recorded after the procedure: Trucut 40% had a 0, 40% a 1, 15% a 2, 5% a 3. Biopty 14G 70% had a 0, 12% a 1, 15% a 2, 3% a 3. Biopty 18G 60% had a 0, 30% a 1, 10% a 2, 0% a 3. references.r18 was reported to have significantly p = 0.01 less pain thanTrucut | NR
Barreto et al. 1991^589^ | 107 | Freehand automated gun 18G | NR | NR | NR | NR | NR | NR | NR | NR | NR
Cusick et al. 1990^590^ | 96 | Freehand | NR | NR | NR | NR | NR | NR | NR | NR | NR
Parker et al. 1990^591^ | 103 | Stereotactic guidance automated gun | NR | No significant bleeding occured, even with use of the 14-gauge needle | 2 (in seated patients) | Three that required treatment with antibiotics | None of the patients suffered immediate significant complications. | NR | NR | NR | NR

NR = Not Reported

Table F32 Data for women diagnosed with cancer by biopsy

Reference | Number who were able to be treated with only one surgical procedure
Reference | Core-needle diagnosis | Open biopsy diagnosis
Friese et al. 2009^592^ | Odds ratio 2.9 (2.7 to 2.9)
Verkooijen et al. 2001^593^ | 63 out of 84 | 13 out of 80
Morrow et al. 2000^305^ | 222 out of 264 | 47 out of 142
Kaufman et al. 1998^396^ | 52 out of 66 | 10 out of 47
Lind et al. 1998^402^ | 47 out of 48 | 35 out of 69
Fenoglio et al. 1997^419^ | 20 out of 20 | 1 out of 20
Liberman et al. 1997^428^ | 76 out of 90 | 31 out of 107

META-ANALYTIC INTEGRATION OF DIAGNOSTIC TEST ACCURACY STUDIES

All biopsies

Could not fit a bivariate binomial model

[underlined: Random-effects model:]

Summary sensitivity: 96.4% (96.1% to 96.7%), I2 = 83.2%

Summary negative likelihood ratio: 0.038 (0.030 to 0.050), I2 = 86.6%

Figure F1 Summary ROC of all core-needle biopsy studies

Figure F1 depicts a summary ROC of all core-needle studies. It is a 10 cell x 10 cell grid chart with vertical sensitivity measures from 0 on the lower left to 1 on the upper left, and horizontal 1specificity measures from 0 to 1. The SROC curve roughly follows the upper left boundaries while black dots are clustered in the upper left quadrant, with the highest concentration of dots in the upper left corner.

Figure F2 Summary ROC of freehand core-needle biopsies

Figure F2 depicts a summary ROC of freehand core-needle biopsies, SROC with confidence and prediction ellipses. It is a 10 cell x 10 cell grid with vertical sensitivity measures from 0 on the lower left to 1 on the upper left, and horizontal specificity measures from 1 to 0. X's representing observed data are in the upper left, most of them located at or near 1.0 specificity. The summary operating point is located at sensitivity 0.86 and specificity 0.99. A dotted line representing a 95% confidence ellipse starts between 0.0 and 0.5 sensitivity, curves out to the right past the 0.5 specificity mark, and goes back to the sensitivity line at 1.0. Another dotted line, this one representing a 95% prediction ellipse, starts from above the 0.5 sensitivity point, goes out to the right, then returns to just below 1.0.

Figure F3 Summary ROC of ultrasound-guided automated gun core-needle biopsies

Figure F3 depicts a summary ROC of ultrasound-guided automated gun core-needle biopsies. It is a 10 cell x 10 cell grid with vertical sensitivity measures from 0 on the lower left to 1 on the upper left, and horizontal specificity measures from 0 to 1. Black dots are clustered in the upper left cell, with the greatest concentration in the upper left corner.

Figure F4 Summary ROC of stereotactic-guided automated gun core-needle biopsies

Figure F4 depicts a summary ROC of stereotactic-guided automated gun core-needle biopsies. The SROC curve is in the upper left. X's representing observed data are in the upper left quadrant, and the summary operating point is in the upper left corner at sensitivity 0.98 and specificity 0.97. A dotted line representing 95% prediction ellipses is at an angle from just above 0.5 sensitivity to 0.5 specificity in the upper left quadrant of the grid.

Figure F5 Summary ROC of ultrasound-guided vacuum-assisted core-needle biopsies

Figure F5 depicts a summary ROC of ultrasound guided vacuum-assisted core needle biopsies. It is a chart with vertical sensitivity measures from 0 on the lower left to 1 on the upper left, and horizontal specificity measures from 0 to 1 on the lower section. Dots representing observed data are in the upper left corner, with the summary operating point located at sensitivity 0.96 and specificity 0.98. A dotted line representing a 95% confidence ellipse goes from just above 0.5 sensitivity to just below 1.0 specificity, while another line representing a 95% prediction ellipse goes from just above 0.0 sensitivity to just below 1.0 specificity. The SROC line is in the upper left corner.

Figure F6 Summary ROC of stereotactic vacuum-assisted core-needle biopsies

Figure F6 depicts a summary ROC of stereotactic vacuum-assisted core-needle biopsies. Dots representing observed data are in the upper left quadrant, with the greatest concentration just below 1.0 specificity. The summary operating point is located at sensitivity 0.99 and specificity 0.92. A dotted line representing a 95% prediction ellipse starts just below 1.0 specificity in the upper left, dips slightly, then ends at about 0.6 specificity. The SROC curve runs up close to the sensitivity line, then angles over to the right slightly to end at the summary operating point just below 1.0 specificity.

Figure F7 Meta-analysis of surgeries avoided

Figure shows the odds of women to require only one surgical procedure for treatment of their cancer, after being diagnosed with cancer by either a core-needle biopsy procedure or an open biopsy procedure. I2 = 31.3%.

Figure F7 depicts a meta-analysis of surgeries avoided, showing the odds of women to require only one surgical procedure for treatment of their cancer, after being diagnosed with cancer by either a core-needle biopsy or an open biopsy procedure. The figure depicts the individual results from six different studies, and the summary odds ratio of 13.26.