# Evidence Tables

Table E3 Previously published systematic reviews: design

Study | Search Dates | Types of Biopsy Evaluated | Types of Breast Abnormalities Evaluated | Reference Standard Required | Other Inclusion Criteria | Method of Rating the Quality | Statistical Methods
Fahrbach et al. 2006^483^ | 1996 to June 2004 | Stereotactic vacuum-assisted core-needle biopsy and stereotactic core-needle biopsy | All-comer populations referred after screening mammography | Surgical biopsy or patient followup | English language; ten or more patients; conducted in North America, Europe, Australia, or New Zealand; reported absolute numbers of each lesion type on biopsy; studies of devices no longer on the market-SiteSelect, MIBB device, ABBI device were excluded | Narrative discussion, no overall rating given | Random-effects models in SAS and SPSS, multivariate regression models
Verkooijen et al. 2000^484^ | 1975 to May 1999 | Large-core needle biopsy under stereotactic or ultrasound guidance | Non-palpable lesions detected on mammography | Surgical biopsy or a minimum of 2 years of followup in at least 90% of patients | The absolute number of benign and malignant lesions had to be derivable; a minimum of five large-core biopsy specimens per lesion had to be obtained; studies of fine-needle aspiration were excluded. | Not rated | Pooled by meta-analysis using SPSS. No further details provided.

Table E4 Previously published systematic reviews: quality rating

Study | Was an ‘a priori’ design provided? | Was there duplicate study selection and data extraction? | Was a comprehensive literature search performed? | Was the status of publication (i.e., grey literature) used as an inclusion criterion? | Was a list of studies (included/excluded) provided? | Were the characteristics of the included studies provided? | Was the scientific quality of the included studies used appropriately in formulating conclusions? | Was the quality of the studies assessed and documented? | Were the methods used to combine the finding of studies appropriate? | Was the likelihood of publication bias assessed? | Was the conflict of interest stated? | Quality Rating
Fahrbach et al.2000^484^ | Can’t tell | Yes | Yes | Yes | No | Yes | No | Yes | Yes | No | No | Moderate
Verkooijen et al.2006^483^ | Can’t tell | Yes | Yes | Yes | Yes | No | No | No | Can’t tell | No | No | Moderate

Table E5 Previously published systematic reviews: results

Study | N Studies | N Patients | Accuracy | Accuracy Affected by Patient Type/Breast Abnormality Types | Accuracy Affected by Procedure-related Factors | Accuracy Affected by Personnel/Facility Factors | Harms | Conclusion
Fahrbach et al. 2006^483^ | 12 of vacuum-assisted biopsy and 25 of core-needle biopsy | 11,355 patients, 5,119 with vacuum-assisted biopsy and 6,236 patients with automated gun core-needle biopsy | Overall agreement between vacuum-assisted and reference standard was 97.3%; overall agreement between core-needle and reference standard was 93.5%. Rate of benign lesions turning out to be malignant: vacuum-assisted: 2.02% (95% CI: 0.00 to 4.35), core-needle: 2.36% (95% CI: 1.15 to 3.58). Rate of atypia lesions turning out to be malignant: vacuum-assisted: 20.38% (15.25 to 25.52), core-needle: 36.69% (26.53 to 46.84) | For atypia to malignant upgrades the type of procedure was a significant predictor, with more underestimations occurring with core-needle as compared to vacuum-assisted | Reference standard and patient position did not influence accuracy | For benign to malignant upgrades, more benign to malignant upgrades occurred in non-North American locations than in North American locations | Frequency of technical failures: 5.7% for core-needle, 1.5% for vacuum-assisted | Vacuum-assisted biopsy may provide lower miss and underestimation rates than automated gun core-needle biopsy.
Verkooijen et al. 2000^484^ | 5 | 865 biopsies performed | DCIS on needle biopsy upgraded to invasive cancer: 15% (95% CI: 8.0 to 26); ADH on needle biopsy upgraded to invasive cancer: 40% (95% CI: 26 to 56); sensitivity of core-needle for detecting malignancies: 97% (95% CI: 95 to 99) | Not performed | Not performed | Not performed | 2 complications reported: 1 hematoma 1 infection | In a setting such as the U.S. where about 20% of cases referred for biopsy are malignant, the risk of breast cancer despite a benign diagnosis on core- needle biopsy is less than 1%. However, in a setting such as Europe where about 60% of cases referred for biopsy are malignant, the risk of breast cancer despite a benign diagnosis on core- needle biopsy is 4%.

Table E6 Studies included to address Key Questions 1 and 2: design details

Study | Design of Study | Type of Study | Number of Centers | Care Setting | Country Conducted in | Funded by | Type(s) Core Biopsy | Core Biopsy Results Confirmed by | Number of Lesions Enrolled | Followup | % Attrition
Jackman et al. 2009^485^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | USA | Biopsys Medical, Inc. and Ethicon Endo-Surgery | Stereotactic guidance vacuum- assisted 11G and 14G | Combination of surgery and patient followup | 1,280 | 2 years | 10.6%
Peters et al. 2008^486^ | Single group (cohort or case series study) | Retrospective | 4 | General hospital | Netherlands | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 948 | 2 years | 5%
Schueller et al. 2008^487^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | Austria | Authors stated no financial relationship to disclose | Ultrasound guidance automated gun 14G | Combination of surgery and patient followup | 1438 | 2 years | 5.7%
Sim and Kei 2008^488^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | Singapore | NR | Stereotactic guidance vacuum- assisted 11G | Combination of surgery and patient folowup | 105 | 2 years | 12.4%
Tonegutti and Girardi 2008^489^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | Italy | NR | Stereotactic guidance vacuum- assisted 11G | Combination of surgery and patient followup | 268 | 2 years | 0%
Youk et al. 2008^24^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | South Korea | NR | US guidance automated gun 14G | Combination of surgery and patient followup | 4,359 | 2 years | 44%
Ciatto et al. 2007^490^ | Single group (cohort or case series study) | Retrospective | 1 | Dedicated breast cancer center | Italy | Funded in part by a National Helath and Medical Research Council (NHMRC) grant | Multiple methods | Combination of surgery and patient followup | 4,035 | 1 year | 26%
de Lucena et al. 2007^491^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | Brazil | NR | US guidance automated gun 14G | Open surgery or surgical biopsy only | 150 | Immediate surgery | 0%
Uematsu et al. 2007^492^ | Single group (cohort or case series study) | Prospective | 1 | General cancer center | Japan | NR | Stereotactic guidance vacuum- assisted 11G | Combination of surgery and patient followup | 100 | Mean: 26 months Range: 5 to 44 months | 0%
Vag et al. 2007^493^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | Germany | NR | US guidance vacuum-assisted 10G | Combination of surgery and patient followup | 70 | 2 years | 0%
Chapellier et al. 2006^494^ | Single group (cohort or case series study) | Prospective | 1 | General cancer center | France | NR | Stereotactic guidance vacuum- assisted 11G | Combination of surgery and patient followup | 318 | Range: 4 to 16 months | 0%
Cipolla et al. 2006^495^ | Single group (cohort or case series study) | NR | 1 | General hospital | Italy | NR | Multiple methods | Combination of surgery and patient followup | 426 | 1 year | 0%
Dhillon et al. 2006^496^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | UK | NR | Stereotactic guidance vacuum- assisted 11G | Combination of surgery and patient followup | 150 | Median: 48 months | 0%
Bolivar et al. 2005^497^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | Spain | NR | US guidance automated gun 14G | Combination of surgery and patient followup | 214 | 2 years | 5%
Crystal et al. 2005^498^ | Single group (cohort or case series study) | NR | 1 | General hospital | Israel | NR | US guidance automated gun 14G | Combination of surgery and patient followup | 715 | Median: 39 months Range: 27 to 60 months | 0%
Dillon et al. 2005^499^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | Ireland | NR | Multiple methods | Combination of surgery and patient followup | 2,427 | Median: 24 months Range: 3 to 67 months | 19%
Koskela et al. 2005^500^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | Finland | Kuopio University Hospital (the center it was conducted in) | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 213 | Mean: 24 months Range: 6 to 39 months | 4%
Sauer et al. 2005^501^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | Germany | NR | US guidance automated gun 14G | Combination of surgery and patient followup | 962 | Mean: 22.2 months Median: 21 months Range : 8 to 36 months | 13%
Weber et al. 2005^502^ | Non-randomized multiple groups study | Prospective | 1 | General hospital | Switzerland | NR | Stereotactic guidance vacuum- assisted 11G | Combination of surgery and patient followup | 225 | Median: 2.1 years Range: 0.5 to 4.4 years | 15%
Wu et al. 2005^503^ | Single group (cohort or case series study) | NR | 1 | General hospital | Taiwan | NR | US guidance vacuum-assisted 11G | Combination of surgery and patient followup | 113 | 1 year | 0%
Alonso-Bartolome et al. 2004^504^ | Single group (cohort or case series study) | Prospective | 2 | General hospital | Spain | NR | US guidance vacuum-assisted 11G | Combination of surgery and patient followup | 102 | 6 to 12 months | 0%
Delle and Terinde 2004^505^ | Single group (cohort or case series study) | NR | 1 | General hospital | Germany | NR | US guidance automated gun 14G | Combination of surgery and patient followup | 169 | 2 years | 0%
Fajardo et al. 2004^506^ | Some patients were randomized to stereotactic or US guidance but data were reported as if the study was a single-group cohort study | Prospective | 22 | Academic and community practice clinical sites | USA | National Cancer Institute | Multiple methods | Combination of surgery and patient followup | 2,403 | 2 years | 30%
Kettritz et al. 2004^507^ | Single group (cohort or case series study) | Prospective | 5 | General hospital | Germany | NR | Stereotactic guidance vacuum- assisted 11G | Combination of surgery and patient followup | 2,893 | Mean: 25 months Range: 6 to 67 months | 22%
Lomoschitz et al. 2004^508^ | Non-randomized multiple groups study | Prospective | 1 | General hospital | Austria | One author partially supported by both Ethicon Edonsurgery and Biopsys Medical | Stereotactic guidance vacuum- assisted 11G | Combination of surgery and patient followup | 100 | 2 years | 0%
Abdsaleh et al. 2003^509^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | Sweden | NR | Multiple methods | Combination of surgery and patient followup | 180 | 1 year | 21%
Ambrogetti et al. 2003^510^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | France | NR | Stereotactic guidance vacuum- assisted 11G | Combination of surgery and patient followup | 364 | Mean: 15.8 months Range: 6 to 36 months | 35%
Fishman et al. 2003^511^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | USA | NR | US guidance automated gun 14G | Combination of surgery and patient followup | 73 | Mammographic and US followup Median: 21 months Range: 4 to 30 months | 33%
Han et al. 2003^512^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | Korea | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 271 | At least 6 months | 27%
Kirshenbaum et al. 2003^513^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | USA | NR | Multiple methods | Combination of surgery and patient followup | 506 | Mean: 2.1 years Range: 3 months to 5 years | 23%
March et al. 2003^514^ | Single group (cohort or case series study) | Prospective | 2 | Dedicated breast cancer center | USA | RSNA Seed Grant and the Rays of Hope charitable fund | US guidance vacuum-assisted 11G | Combination of surgery and patient followup | 34 | 6 months | 9%
Pfleiderer et al. 2003^515^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | Germany | NR | MRI guidance automated gun 14G | Combination of surgery and patient followup | 14 | 2 years | 0%
Philpotts et al. 2003^516^ | Non-randomized multiple groups study | Retrospective | 1 | General hospital | USA | NR | Multiple methods | Combination of surgery and patient followup | 281 | Mean: 19 months Range: 3 to 53 months for 14G Mean: 13 months Range: 1 to 24 for 11G | 24%
Wong and Hisham 2003^517^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | Malaysia | NR | Freehand automated gun 14 or 16G | Combination of surgery and patient followup | 150 | Range: 6 to 13 months | 0%
Apesteguia et al. 2002^518^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | Spain | NR | Stereotactic guidance vacuum- assisted 11G | Combination of surgery and patient followup | 132 | 1 year | 0%
Georgian-Smith et al. 2002^519^ | Single group (cohort or case series study) | Retrospective | 4 | General hospital | USA | NR | Stereotactic guidance vacuum- assisted 11G | Combination of surgery and patient followup | 185 | Range: 6 to 12 months | 21%
Jackman and Lamm 2002^520^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | USA | Funded in part by Biopsys Medical | Multiple methods | Combination of surgery and patient followup | 31 | At least 6 months | 0%
Johnson et al. 2002^521^ | Single group (cohort or case series study) | NR | 1 | General hospital | USA | Fashion Footwear of NY | US guidance vacuum-assisted 11 or 8G | Combination of surgery and patient followup | 101 | Mean: 9.5 months | 24%
Liberman et al. 2002^522^ | Single group (cohort or case series study) | Retrospective | 1 | General cancer center | USA | NR | Stereotactic guidance vacuum- assisted 11G | Combination of surgery and patient followup | 800 | At least 1 year | 29%
Meloni et al. 2002^523^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | Italy | NR | Stereotactic guidance vacuum- assisted | Combination of surgery and patient followup | 129 | Mean: 18.7 months Range: 14 to 26 months | 0%
Morris et al. 2002^524^ | Single group (cohort or case series study) | Prospective | 1 | Dedicated breast cancer center | USA | NR | Stereotactic guidance vacuum- assisted 14G | Combination of surgery and patient followup | 21 | Median: 46 months Range: 40–54 months | 10%
Pfarl et al. 2002^525^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | Austria | NR | Stereotactic guidance vacuum- assisted 11G | Open surgery or surgical biopsy only | 332 | Immediate surgery | 4%
Verkooijen et al. COBRA 2002^526^ | Single group (cohort or case series study) | Prospective | 5 | General hospital | Netherlands | Dutch National Health Insurance Fund Council | Stereotactic guidance automated gun 14G | Open surgery or surgical biopsy only | 984 | Immediate surgery | 11%
Becker et al. 2001^527^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | Canada | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 232 | Range: 6 to 12 months | 27%
Brenner et al. 2001^528^ | Single group (cohort or case series study) | Prospective | 7 | Cancer centers and hospitals | USA | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 1,003 | Mean: 19.3 months Range: 0 to 36 months | 1%
Cangiarella et al. 2001^529^ | Single group (cohort or case series study) | NR | 1 | General hospital | USA | NR | Stereotactic guidance vacuum- assisted 11G | Combination of surgery and patient followup | 160 | Mean: 20.5 months Range: 6 to 35 months | 38%
Dahlstrom and Jain 2001^530^ | Single group (cohort or case series study) | NR | 1 | General hospital | Australia | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 301 | Range: 2.4 to 7.5 years | 0%
Lai et al. 2001^531^ | Single group (cohort or case series study) | NR | 1 | General hospital | Canada | NR | Stereotactic guidance vacuum- assisted 11G | Combination of surgery and patient followup | 673 | Mean: 6.7 months Range: 6 to 24 months | 29%
Levin et al. 2001^532^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | Canada | Physician’s Services Incorporated Foundation | Stereotactic guidance automated gun 14G | Open surgery or surgical biopsy only | 70 | Immediate surgery | 0%
Margolin et al. 2001^533^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | USA | NR | Multiple methods | Combination of surgery and patient followup | 1,333 | Mean: 14 months Range: 6 to 24 months; missing data were collected from SEER database; at the time of accession of SEER data followup ranged from 15 to 75 months | 3%
Perez-Fuentes et al. 2001^534^ | Single group (cohort or case series study) | NR | 1 | Dedicated breast cancer center | Venezuela | NR | US guidance vacuum-assisted 11G | Combination of surgery and patient followup | 88 | Median: 11.1 months Range: 4 to 24 months | 33%
Smith et al. 2001^535^ | Single group (cohort or case series study) | NR | 1 | General hospital | USA | NR | US guidance automated gun 14G | Combination of surgery and patient followup | 500 | Mean: 22 months Median: 14 months Range: 12 to 60 months | 21%
White et al. 2001^536^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | USA | NR | Multiple methods | Combination of surgery and patient followup | 1,042 | Median: 29 months, minimum of one year | 29%
Wunderbaldinger et al. 2001^537^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | Austria | author supported by Erwin Schroedinger Auslandsstipenium of the Austrian Science Fund | US guidance automated gun 14G | Open surgery or surgical biopsy only | 45 | Immediate surgery | 0%
Yeow et al. 2001^538^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | China | NR | US guidance automated gun 14 or 16G | Combination of surgery and patient followup | 98 | Mean: 4 years Range: 3 to 5 years | 0%
Beck et al. 2000^539^ | Single group (cohort or case series study) | NR | 1 | General hospital | Germany | NR | Stereotactic guidance vacuum- assisted 11G | Combination of surgery and patient followup | 594 | 1 year | 0%
Kirwan et al. 2000^540^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | UK | NR | Stereotactic guidance automated gun 14G | Open surgery or surgical biopsy only | 72 | Immediate surgery | 13%
Latosinsky et al. 2000^541^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | USA | NIH grant | Multiple methods | Combination of surgery and patient followup | 692 | Median: 17.2 months Range: 2.8 to 43 months | 42%
Liberman et al. 2000^542^ | Single group (cohort or case series study) | Retrospective | 1 | General cancer center | USA | NR | Multiple methods | Combination of surgery and patient followup | 155 | Median: 53 months Range: 24 to 69 months | 32%
Makoske et al. 2000^543^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | USA | NR | Multiple methods | Combination of surgery and patient followup | 817 | Mean: 1.7 years | 30%
Ward et al. 2000^544^ | Single group (cohort or case series study) | NR | 1 | General hospital | Canada | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 121 | Mean: 16 months Range: 4 to 36 months | 7%
Welle et al. 2000^545^ | Single group (cohort or case series study) | Retrospective | 3 | General hospital | USA | NR | Multiple methods | Combination of surgery and patient followup | 225 | Range: 6 to 24 months | 20%
Helbich et al. 1999^546^ | Randomized controlled trial | Prospective | 1 | General hospital | Austria | Ludwig-Boltzmann Institute for Radiologic Tumor Research; one author was supported by a grant from the Max Kade Foundation | Multiple methods | Open surgery or surgical biopsy only | 44 | Immediate surgery | 0%
Jackman et al. 1999^547^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | USA | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 483 | Median: 55 months | 1%
Meyer et al. 1999^548^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | USA | NR | Multiple methods | Combination of surgery and patient followup | 1,836 | At least 1 year | 25%
Puglisi et al. 1999^549^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | Italy | NR | Perforated compression grid automated gun 14G | Combination of surgery and patient followup | 106 | At least 6 months | 1%
Soo et al. 1999^550^ | Non-randomized multiple groups study | Retrospective | 1 | General hospital | USA | NR | Multiple methods | Combination of surgery and patient followup | 116 | Mean: 16 months Range: 5 to 31 months | 19%
Caruso et al. 1998^551^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | Italy | NR | Multiple methods | Open surgery or surgical biopsy only | 92 | Immediate surgery | 13%
Doyle et al. 1998^552^ | Single group (cohort or case series study) | Retrospective | 1 | Dedicated breast cancer center | New Zealand | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 151 | Range: 6 to 36 months | 11%
Fuhrman et al. 1998^553^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | USA | NR | Multiple methods | Combination of surgery and patient followup | 1,440 | At least 6 months | 18%
Heywang- Kobrunner et al. 1998^554^ | Single group (cohort or case series study) | NR | 1 | General hospital | Germany | NR | Stereotactic guidance vacuum- assisted 11 or 14G | Combination of surgery and patient followup | 261 | 6 months | 31%
Ioffe et al. 1998^555^ | Single group (cohort or case series study) | NR | 1 | General hospital | USA | NR | Multiple methods | Combination of surgery and patient followup | 224 | Range: 6 to 12 months | 14%
Liberman et al. 1998^556^ | Single group (cohort or case series study) | NR | 1 | General cancer center | USA | NR | US guidance automated gun 14G | Combination of surgery and patient followup | 151 | Median: 20 months Range: 6 to 48 months | 23%
Schulz-Wendtland et al. 1998^557^ | Single group (cohort or case series study) | NR | 1 | General hospital | Germany | NR | US guidance automated gun 14G | Combination of surgery and patient followup | 307 | 2 years | 0%
Vega-Bolivar et al. 1998^558^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | Spain | NR | Stereotactic guidance Surecut 15G | Combination of surgery and patient followup | 182 | Mean: 27 months Range: 6 to 47 months | 6%
Whitman et al. 1998^559^ | Single group (cohort or case series study) | Retrospective | 2 | General hospital | USA | NR | Stereotactic guidance automated gun 16G | Open surgery or surgical biopsy only | 12 | Immediate surgery | 0%
Zannis and Alia No 1998^560^ | Non-randomized multiple groups study | Retrospective | 1 | Ambulatory surgical center | USA | NR | Multiple methods | Combination of surgery and patient followup | 424 | At least 6 months | 31%
Bauer et al. 1997^561^ | Single group (cohort or case series study) | Retrospective | NR | NR | USA | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 799 | Mean: 9 months | 0%
Britton et al. 1997^562^ | Single group (cohort or case series study) | NR | 1 | General hospital | UK | NR | Multiple methods | Combination of surgery and patient followup | 202 | Mean: 20.1 months Range: 5.3 to 30.8 months | 2%
Helbich et al. 1997^563^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | Austria | NR | Multiple methods | Open surgery or surgical biopsy only | 210 | Immediate surgery | 0%
Khattar et al. 1997^564^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | Denmark | NR | US guidance automated gun | Open surgery or surgical biopsy only | 106 | Immediate surgery | 43%
Liberman et al. 1997^565^ | Single group (cohort or case series study) | Retrospective | 1 | General cancer center | USA | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 442 | Median: 18 months Range: 6 to 46 months | 34%
Pitre et al. 1997^566^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | USA | NR | Stereotactic guidance automated gun | Combination of surgery and patient followup | 128 | 1 year | 8%
Stolier et al. 1997^567^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | USA | NR | Multiple methods | Combination of surgery and patient followup | 244 | Mean: 12.8 months Range: 6 to 39 months | NR
Sutton, et al. 1997^568^ | Single group (cohort or case series study) | Retrospective | 1 | Screening clinic | Australia | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 206 | 1 year | 32%
Walker et al. 1997^569^ | Single group (cohort or case series study) | NR | 1 | General hospital | UK | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 200 | Range: 6 to 36 months | 10%
Frazee et al. 1996^570^ | Non-randomized multiple groups study | Prospective | 1 | General hospital | USA | NR | Stereotactic guidance automated gun | Combination of surgery and patient followup | 103 | At least 6 months | 0%
Fuhrman et al. 1996^571^ | Single group (cohort or case series study) | NR | 1 | General hospital | USA | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 451 | 1 year | 22%
Head and Haynes 1996^572^ | Single group (cohort or case series study) | Prospective | 1 | Dedicated breast cancer center | USA | NR | Stereotactic guidance automated gun 18G | Combination of surgery and patient followup | 115 | 2 years | 8%
Mainiero et al. 1996^573^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | USA | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 138 | At least 6 months | 14%
Meyer et al. 1996^574^ | Single group (cohort or case series study) | NR | 1 | General hospital | USA | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 388 | 1 year | 30%
Nguyen et al. 1996^575^ | Single group (cohort or case series study) | NR | 1 | General hospital | USA | American Cancer Society, UCLA Jonsson Comprehensive Cancer Center, and the Stein- Oppenheim Foundation | Multiple methods | Combination of surgery and patient followup | 431 | At least 6 months | 10%
Pettine et al. 1996^576^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | USA | NR | Stereotactic guidance automated gun 14G | Open surgery or surgical biopsy only | 25 | 6 month repeat mammography for benign | 0%
Rosenblatt et al. 1996^577^ | Single group (cohort or case series study) | Retrospective | 1 | General hospital | USA | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 25 | 1 year | 16%
Scopa et al. 1996^578^ | Non-randomized multiple groups study | NR | 1 | General hospital | Greece | NR | Freehand TruCut | Open surgery or surgical biopsy only | 120 | Immediate surgery | 0%
Cross et al. 1995^579^ | Single group (cohort or case series study) | NR | 1 | Dedicated breast cancer center | USA | NR | Stereotactic guidance automated gun 14G | Combination of surgery and patient followup | 250 | 1 year | 12%
Doyle et al. 1995^580^ | Non-randomized multiple groups study | Prospective | 1 | General Hospital | USA | NR | Multiple methods | Combination of surgery and patient followup | 150 | Range: 6 to 24 months | 3%
Hamed et al. 1995^581^ | Randomized controlled trial | Prospective | 1 | General hospital | UK | NR | Freehand Biopty-cut | Open surgery or surgical biopsy only | 122 | Immediate surgery | 0%
Burbank et al. 1994^582^ | Non-randomized multiple groups study | NR | 1 | General hospital | USA | NR | Multiple methods | Combination of surgery and patient followup | 105 | At least 6 months | 0%
Gisvold et al. 1994^583^ | Single group (cohort or case series study) | Prospective | 1 | General hospital | USA | NR | Stereotactic guidance automated gun 14G | Open surgery or surgical biopsy only | 160 | Immediate surgery | 0%
Parker et al. 1994^584^ | Non-randomized multiple groups study | Retrospective | 20 | Various hospitals, breast care centers, clinics | USA | NR | Multiple methods | Combination of surgery and patient followup | 6,152 | At least 6 months | 39%
Smyth and Cederbom 1994^585^ | Single group (cohort or case series study) | NR | 1 | General hospital | USA | NR | Stereotactic guidance automated gun 14G | Open surgery or surgical biopsy only | 58 | Immediate surgery | 0%
Elvecrog et al. 1993^586^ | Non-randomized multiple groups study | Prospective | 1 | General hospital | USA | NR | Stereotactic guidance automated gun 14G | Open surgery or surgical biopsy only | 100 | Immediate surgery | 0%
Parker et al. 1993^587^ | Single group (cohort or case series study) | NR | 1 | Specialized imaging center | USA | NR | US guidance automated gun 14G | Combination of surgery and patient followup | 181 | Range: 12 to 36 months | 0%
McMahon et al. 1992^588^ | Randomized controlled trial | Prospective | 1 | General hospital | UK | NR | Multiple methods | Combination of surgery and patient followup | 151 | Median: 11 months Range: 1 to 24 months | 0%
Barreto et al. 1991^589^ | Single group (cohort or case series study) | NR | 1 | General hospital | UK | NR | Freehand automated gun 18G | Open surgery or surgical biopsy only | 107 | Immediate surgery | 0%
Cusick et al. 1990^590^ | Single group (cohort or case series study) | NR | 1 | General hospital | USA | NR | Freehand | Open surgery or surgical biopsy only | 96 | Immediate surgery | 0%
Parker et al. 1990^591^ | Single group (cohort or case series study) | NR | 1 | General hospital | USA | NR | Stereotactic guidance automated gun | Open surgery or surgical biopsy only | 103 | Immediate surgery | 0%

NR = Not Reported

US = Ultrasound

UK = United Kingdom

USA = United States of America

Table E7 Quality assessment instrument

1. Was patient recruitment either consecutive or random?; 2. Were more than 85% of the patients approached for recruitment enrolled in the study?; 3. Were the patient inclusion/exclusion criteria consistently applied to all patients?; 4. Was the study free from obvious spectrum bias? Obvious spectrum bias was defined as more than 40% or less than 10% of the breast lesions were diagnosed as malignant; and/or the mean or median age of the enrolled population was less than 50 or greater than 70.; 5. Was the study prospective in design?; 6. Was a complete set of data reported for at least 85% of enrolled lesions?; 7. Were the patients assessed by the gold standard (open surgical procedure) regardless of the initial biopsy results?; 8. Were patients assessed by a reference standard regardless of the biopsy results?; 9. Was funding for this study provided by a source that doesn’t have an obvious financial interest in the findings of the study?; 10. Did the study account for inter-reader/scorer differences?; 11. Were the reader(s) of the biopsies blinded to the results of the reference standard?; 12. Were readers of the reference standard blinded to the results of the biopsy?; 13. Were the readers of the biopsy blinded to all other clinical information?; 14. Were readers of the reference standard blinded to all other clinical information?

Table E8 Quality of studies addressing Key Questions 1 and 2 (see Table E7 for the wording of the questions)

Study | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12 | 13 | 14 | Raw Score | Standardize
Jackman et al. 2009^485^ | Yes | Yes | Yes | NR | No | Yes | No | Yes | No | No | Yes | NR | No | NR | 1 | 5.4
Peters et al. 2008^486^ | Yes | NR | Yes | No: over 40% malignant | No | Yes | No | Yes | NR | No | Yes | No | No | No | −1 | 4.6
Schueller et al. 2008^487^ | Yes | Yes | Yes | No: over 40% malignant | No | Yes | No | Yes | Yes | NR | Yes | No | No | No | 1 | 5.4
Sim and Kei 2008^488^ | Yes | Yes | Yes | Yes | No | Yes | No | Yes | NR | NR | Yes | No | NR | No | 3 | 6.1
Tonegutti and Girardi 2008^489^ | Yes | Yes | Yes | No: 41.6% malignant | No | Yes | No | Yes | NR | NR | NR | NR | NR | NR | 3 | 6.1
Youk et al. 2008^24^ | Yes | Yes | Yes | No: mean 45.3 years of age | No | No | No | Yes | NR | NR | Yes | No | No | No | −1 | 4.6
Ciatto et al. 2007^490^ | Yes | Yes | Yes | NR | No | No | No | Yes | Yes | No | Yes | No | No | No | −1 | 4.6
de Lucena et al. 2007^491^ | NR | NR | NR | No: 67% malignant | Yes | Yes | Yes | Yes | NR | NR | Yes | NR | NR | NR | 5 | 6.8
Uematsu et al. 2007^492^ | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | NR | No | Yes | NR | NR | NR | 6 | 7.1
Vag et al. 2007^493^ | NR | NR | NR | No: 41.4% malignant | Yes | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 3 | 6.1
Chapellier et al. 2006^494^ | NR | NR | NR | Yes | Yes | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 4 | 6.4
Cipolla et al. 2006^495^ | Yes | Yes | Yes | No: 43% malignant | NR | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 5 | 6.8
Dhillon et al. 2006^496^ | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 7 | 7.5
Bolivar et al. 2005^497^ | Yes | Yes | Yes | No: 58% malignant | Yes | Yes | No | Yes | NR | No | Yes | NR | NR | NR | 5 | 6.8
Crystal et al. 2005^498^ | Yes | Yes | Yes | No: 45% malignant | NR | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 5 | 6.8
Dillon et al. 2005^499^ | Yes | Yes | Yes | No: 57% malignant | No | No | No | Yes | NR | NR | Yes | No | No | No | −1 | 4.6
Koskela et al. 2005^500^ | Yes | Yes | Yes | No: 42% malignant | Yes | Yes | No | Yes | Yes | No | Yes | No | No | No | 3 | 6.1
Sauer et al. 2005^501^ | Yes | Yes | Yes | No: 64.2% malignant | No | Yes | No | Yes | NR | No | Yes | No | No | No | 0 | 5.0
Weber et al. 2005^502^ | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | NR | Yes | Yes | NR | NR | NR | 8 | 7.9
Wu et al. 2005^503^ | Yes | Yes | Yes | No: 0% malignant | NR | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 5 | 6.8
Alonso-Bartolome et al. 2004^504^ | NR | Yes | Yes | No: 0.9% malignant, mean age 42 | Yes | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 5 | 6.8
Delle and Terinde 2004^505^ | Yes | Yes | Yes | No: 77% malignant | NR | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 5 | 6.8
Fajardo et al. 2004^506^ | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | NR | NR | NR | 9 | 8.2
Kettritz et al. 2004^507^ | NR | NR | No | NR | Yes | No | No | Yes | NR | NR | Yes | NR | No | NR | −1 | 4.6
Lomoschitz et al. 2004^508^ | Yes | Yes | Yes | No: 47% malignant | Yes | Yes | No | Yes | No | No | NR | NR | NR | NR | 3 | 6.1
Abdsaleh et al. 2003^509^ | Yes | Yes | Yes | No: 74% malignant | Yes | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 6 | 7.1
Ambrogetti et al. 2003^510^ | Yes | Yes | Yes | No: 43.4% malignant | No | No | No | Yes | NR | NR | Yes | No | No | No | −1 | 4.6
Fishman et al. 2003^511^ | Yes | Yes | No | NR | Yes | No | No | Yes | NR | No | Yes | NR | Yes | NR | 2 | 5.7
Han et al. 2003^512^ | Yes | Yes | Yes | No: mean age 47 years | No | No | No | Yes | NR | NR | NR | NR | NR | NR | 1 | 5.4
Kirshenbaum et al. 2003^513^ | Yes | Yes | Yes | Yes | No | No | No | Yes | NR | NR | Yes | No | No | No | 0 | 5.0
March et al. 2003^514^ | Yes | No: 67% | Yes | NR | Yes | Yes | No | Yes | Yes | No | Yes | No | No | No | 2 | 5.7
Pfleiderer et al. 2003^515^ | No | NR | Yes | No: 42% malignant | Yes | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 4 | 6.4
Philpotts et al. 2003^516^ | Yes | Yes | Yes | NR | No | No | No | Yes | NR | NR | Yes | No | No | No | −1 | 4.6
Wong and Hisham 2003^517^ | Yes | Yes | Yes | No: 46% malignant | Yes | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 6 | 7.1
Apesteguia et al. 2002^518^ | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | NR | NR | NR | NR | NR | NR | 6 | 7.1
Georgian-Smith et al. 2002^519^ | Yes | Yes | Yes | Yes | No | Yes | No | Yes | NR | NR | Yes | No | No | No | 2 | 5.7
Jackman and Lamm 2002^520^ | Yes | Yes | Yes | Yes | No | Yes | No | Yes | No | NR | Yes | No | No | No | 1 | 5.4
Johnson et al. 2002^521^ | Yes | Yes | Yes | No: 5% malignant | NR | No | No | Yes | Yes | NR | Yes | NR | NR | NR | 4 | 6.4
Liberman et al. 2002^522^ | Yes | Yes | Yes | No | No | No | No | Yes | NR | NR | Yes | No | No | No | −2 | 4.3
Meloni et al. 2002^523^ | Yes | Yes | Yes | NR | Yes | Yes | No | Yes | NR | NR | Yes | No | No | No | 3 | 6.1
Morris et al. 2002^524^ | NR | NR | Yes | Yes | Yes | Yes | No | Yes | NR | No | Yes | NR | NR | NR | 4 | 6.4
Pfarl et al. 2002^525^ | Yes | Yes | Yes | No: 65% malignant | No | Yes | Yes | Yes | NR | NR | Yes | No | No | No | 3 | 6.1
Verkooijen et al. COBRA 2002^526^ | Yes | NR | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | NR | NR | NR | 8 | 7.9
Becker et al. 2001^527^ | Yes | Yes | Yes | Yes | No | No | No | Yes | NR | NR | Yes | No | No | No | 0 | 5.0
Brenner et al. 2001^528^ | NR | NR | NR | NR | Yes | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 3 | 6.1
Cangiarella et al. 2001^529^ | Yes | Yes | Yes | No: 9% malignant | NR | No | No | Yes | NR | NR | Yes | NR | NR | NR | 3 | 6.1
Dahlstrom and Jain 2001^530^ | Yes | Yes | Yes | NR | NR | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 5 | 6.8
Lai et al. 2001^531^ | Yes | Yes | Yes | Yes | NR | No | No | Yes | NR | NR | Yes | NR | NR | NR | 4 | 6.4
Levin et al. 2001^532^ | NR | NR | Yes | NR | Yes | Yes | Yes | Yes | Yes | No | Yes | NR | NR | NR | 6 | 7.1
Margolin et al. 2001^533^ | Yes | Yes | Yes | No: mean age less than 50 | No | Yes | No | Yes | NR | NR | Yes | No | No | No | 1 | 5.4
Perez-Fuentes et al. 2001^534^ | No | NR | No | No: mean age 48 | NR | No | No | Yes | NR | NR | Yes | NR | NR | NR | −1 | 4.6
Smith et al. 2001^535^ | Yes | Yes | Yes | No: mean age 47 | NR | No | No | Yes | NR | NR | Yes | NR | NR | NR | 3 | 6.1
White et al. 2001^536^ | Yes | Yes | Yes | Yes | No | No | No | Yes | NR | No | Yes | No | No | No | −1 | 4.6
Wunderbaldinger et al. 2001^537^ | No | NR | Yes | No: 49% malignant | Yes | Yes | Yes | Yes | Yes | No | No | No | NR | NR | 3 | 6.1
Yeow et al. 2001^538^ | Yes | Yes | Yes | No: mean age 46 | Yes | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 6 | 7.1
Beck et al. 2000^539^ | Yes | Yes | Yes | NR | NR | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 5 | 6.8
Kirwan et al. 2000^540^ | NR | NR | NR | NR | No | Yes | Yes | Yes | NR | NR | Yes | No | No | No | 0 | 5.0
Latosinsky et al. 2000^541^ | Yes | Yes | Yes | NR | No | No | No | Yes | Yes | NR | NR | Yes | No | No | 1 | 5.4
Liberman et al. 2000^542^ | Yes | Yes | Yes | No: median age47 years | No | No | No | Yes | NR | NR | Yes | No | No | No | −1 | 4.6
Makoske et al. 2000^543^ | Yes | Yes | Yes | NR | Yes | No | No | Yes | NR | NR | Yes | No | No | No | 1 | 5.4
Ward et al. 2000^544^ | Yes | Yes | Yes | Yes | NR | Yes | No | Yes | NR | NR | Yes | No | No | No | 3 | 6.1
Welle et al. 2000^545^ | NR | NR | NR | NR | No | No | No | Yes | NR | NR | Yes | No | No | No | −4 | 3.6
Helbich et al. 1999^546^ | Yes | NR | Yes | No: 86% malignant | Yes | Yes | Yes | No | NR | No | Yes | NR | No | NR | 3 | 6.1
Jackman et al. 1999^547^ | Yes | Yes | Yes | Yes | No | Yes | No | Yes | NR | Yes | No | No | No | No | 0 | 5.0
Meyer et al. 1999^548^ | Yes | Yes | Yes | Yes | No | No | No | Yes | NR | No | Yes | No | No | No | −1 | 4.6
Puglisi et al. 1999^549^ | Yes | Yes | Yes | Yes | No | Yes | No | Yes | NR | No | Yes | No | No | No | 1 | 5.4
Soo et al. 1999^550^ | Yes | Yes | Yes | NR | No | No | No | Yes | NR | Yes | Yes | No | No | No | 0 | 5.0
Caruso et al. 1998^551^ | Yes | NR | Yes | No: 85% malignant | Yes | Yes | Yes | Yes | NR | No | Yes | NR | No | NR | 5 | 6.8
Doyle et al. 1998^552^ | Yes | Yes | Yes | NR | No | Yes | No | Yes | NR | No | Yes | No | No | No | 0 | 5.0
Fuhrman et al. 1998^553^ | Yes | Yes | Yes | Yes | No | No | No | Yes | NR | No | Yes | No | No | No | −1 | 4.6
Heywang-Kobrunner et al. 1998^554^ | Yes | Yes | Yes | NR | NR | No | No | Yes | NR | NR | Yes | NR | NR | NR | 3 | 6.1
Ioffe et al. 1998^555^ | Yes | NR | Yes | Yes | NR | NR | No | Yes | NR | NR | NR | NR | NR | NR | 3 | 6.1
Liberman et al. 1998^556^ | Yes | Yes | Yes | Yes | NR | No | No | Yes | NR | NR | Yes | NR | NR | NR | 4 | 6.4
Schulz-Wendtland et al. 1998^557^ | Yes | Yes | Yes | No: 52% malignant | NR | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 5 | 6.8
Vega-Bolivar et al. 1998^558^ | Yes | NR | Yes | No: over 40% were malignant | No | Yes | No | Yes | NR | No | Yes | No | No | No | −1 | 4.6
Whitman et al. 1998^559^ | NR | Yes | NR | No: 50% malignant | No | Yes | No | Yes | NR | NR | NR | NR | NR | NR | 1 | 5.4
Zannis and AliaNo 1998^560^ | Yes | Yes | Yes | Yes | No | Yes | No | Yes | NR | NR | Yes | No | No | No | 2 | 5.7
Bauer et al. 1997^561^ | Yes | Yes | Yes | Yes | No | Yes | No | Yes | NR | Yes | Yes | No | No | No | 2 | 5.7
Britton et al. 1997^562^ | Yes | Yes | Yes | No: 50% malignant | NR | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 5 | 6.8
Helbich et al. 1997^563^ | Yes | Yes | Yes | No: 47% malignant | Yes | Yes | Yes | Yes | NR | No | Yes | No | NR | NR | 6 | 7.1
Khattar et al. 1997^564^ | NR | NR | Yes | No: 44% malignant | Yes | No | Yes | Yes | NR | NR | Yes | NR | NR | NR | 4 | 6.4
Liberman et al. 1997^565^ | Yes | NR | Yes | NR | No | No | No | Yes | NR | NR | Yes | No | No | No | −2 | 4.3
Pitre et al. 1997^566^ | Yes | Yes | Yes | No: 8.6% malignant | No | Yes | No | Yes | NR | NR | Yes | No | No | No | 1 | 5.4
Stolier et al. 1997^567^ | Yes | Yes | Yes | NR | No | Yes | No | Yes | NR | NR | Yes | No | No | No | 1 | 5.4
Sutton, et al. 1997^568^ | NR | NR | No | Yes | No | No | No | Yes | NR | NR | Yes | No | No | No | −4 | 3.6
Walker et al. 1997^569^ | Yes | Yes | Yes | No: 54% malignant | NR | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 5 | 6.8
Frazee et al. 1996^570^ | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | NR | NR | NR | NR | NR | NR | 6 | 7.1
Fuhrman et al. 1996^571^ | NR | Yes | Yes | NR | NR | No | No | Yes | NR | NR | NR | NR | NR | NR | 1 | 5.4
Head and Haynes 1996^572^ | NR | NR | NR | Yes | Yes | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 4 | 6.4
Mainiero et al. 1996^573^ | NR | Yes | Yes | Yes | No | Yes | No | Yes | NR | NR | NR | NR | NR | NR | 3 | 6.1
Meyer et al. 1996^574^ | Yes | No: 67.7% | Yes | No: median age 49 | NR | No | No | Yes | NR | NR | NR | NR | NR | NR | 1 | 5.4
Nguyen et al. 1996^575^ | NR | NR | Yes | No: 43% malignant | NR | Yes | No | Yes | Yes | NR | Yes | NR | NR | NR | 4 | 6.4
Pettine et al. 1996^576^ | NR | Yes | Yes | NR | No | Yes | Yes | NR | NR | NR | NR | NR | NR | NR | 3 | 6.1
Rosenblatt et al. 1996^577^ | Yes | Yes | Yes | No: 52% malignant | No | No | No | Yes | NR | NR | Yes | No | No | No | −1 | 4.6
Scopa et al. 1996^578^ | NR | Yes | Yes | No: 65% malignant | NR | Yes | Yes | Yes | NR | NR | NR | NR | NR | NR | 5 | 6.8
Cross et al. 1995^579^ | NR | NR | NR | Yes | NR | Yes | No | Yes | NR | NR | Yes | No | No | No | 0 | 5.0
Doyle et al. 1995^580^ | Yes | Yes | Yes | Yes | Yes | No | No | Yes | NR | NR | NR | NR | NR | NR | 4 | 6.4
Hamed et al. 1995^581^ | Yes | Yes | Yes | No: 88% malignant | Yes | Yes | No | No | NR | NR | NR | NR | NR | NR | 3 | 6.1
Burbank et al. 1994^582^ | NR | Yes | NR | NR | NR | Yes | No | Yes | NR | NR | NR | NR | NR | NR | 2 | 5.7
Gisvold et al. 1994^583^ | Yes | No: 33.6% | No | No: 42% malignant | Yes | Yes | Yes | Yes | NR | No | Yes | NR | NR | NR | 4 | 6.4
Parker et al. 1994^584^ | NR | NR | Yes | NR | No | No | No | Yes | NR | NR | No | No | NR | NR | −3 | 3.9
Smyth and Cederbom 1994^585^ | NR | NR | NR | Yes | NR | Yes | Yes | No | NR | No | No | No | NR | NR | −1 | 4.6
Elvecrog et al. 1993^586^ | Yes | Yes | Yes | NR | Yes | Yes | Yes | Yes | Yes | NR | NR | NR | NR | NR | 8 | 7.9
Parker et al. 1993^587^ | Yes | Yes | Yes | NR | NR | Yes | No | Yes | NR | NR | Yes | NR | NR | NR | 5 | 6.8
McMahon et al. 1992^588^ | Yes | Yes | Yes | NR | Yes | Yes | No | Yes | NR | No | Yes | NR | NR | NR | 5 | 6.8
Barreto et al. 1991^589^ | NR | NR | Yes | No: 90% malignant | NR | Yes | Yes | Yes | NR | NR | Yes | NR | NR | NR | 5 | 6.8
Cusick et al. 1990^590^ | NR | Yes | Yes | No: 81.3% malignant | NR | Yes | Yes | No | NR | NR | NR | NR | NR | NR | 3 | 6.1
Parker et al. 1990^591^ | Yes | No | Yes | NR | NR | Yes | Yes | No | NR | NR | NR | NR | NR | NR | 2 | 5.7

NR = Not Reported

Table E9 Details of the core-needle biopsies performed in the studies addressing Key Questions 1 and 2

Study | Number of Different People Performing Biopsies | Training of Persons Performing Biopsies | Experience of Persons Performing Biopsies | Method of Imaging Guidance | Patient Position | Biopsy Device | Number of Cores
Jackman et al. 2009^485^ | 4 | Radiologists | 0.25 to 3.75 years of experience performing stereotactic biopsies but no experience with vacuum-assisted biopsies before the study began | Stereotactic | Prone | Mammotome 11G or 14G | 12 or more
Peters et al. 2008^486^ | NR | NR | NR | Stereotactic | Prone | Biopty automated gun 14G | Range: 5 to 8
Schueller et al. 2008^487^ | 2 | Radiologists | Performed 100 or more biopsies before the study period began | US | Supine or decubitus | Bard automated gun 14G | Mean: 5.9 Range: 5 to 10
Sim and Kei 2008^488^ | 1 | Radiologist | NR | Stereotactic | Seated | Mammotome 11G | Mean: 13.5 Range: 2 to 36
Tonegutti and Girardi 2008^489^ | 1 | Radiologists | Short training period with 30 patients | Stereotactic | Prone | Mammotome 11G | 20
Youk et al. 2008^24^ | 9 | Radiologists | 7 had fellowship training, 2 had extensive clinical experience in breast imaging and biopsy | US | Supine | Pro-Mag automated gun, 14G | Mean: 5.4 cores Range: 3 to 8
Ciatto et al. 2007^490^ | 13 | Radiologists | NR | US or stereotactic guidance | NR | Automated gun 14G or Mammotome 11G | 2 to 4
de Lucena et al. 2007^491^ | 1 | NR | NR | US | NR | Pro-Mag automated gun 14G | 6
Uematsu et al. 2007^492^ | 1 | Radiologists | 1 year of prior experience with the procedure | Stereotactic | Prone | Mammotome 11G | NR
Vag et al. 2007^493^ | NR | Radiologists | reports the device is new and they are trying it out, but the radiologist was highly experienced in breast interventions | US | NR | VACORA 10G | NR
Chapellier et al. 2006^494^ | NR | Radiologists | Device was newly acquired at start of the study | Stereotactic | NR | Mammotome | NR
Cipolla et al. 2006^495^ | NR | NR | NR | Stereotactic or US | NR | 14G needle | Mean: 3 Range: 2 to 5
Dhillon et al. 2006^496^ | NR | NR | NR | Stereotactic | Prone | Mammotome 11G | Mean: 12 Range: 6 to 18
Bolivar et al. 2005^497^ | NR | NR | NR | US | Supine | Automated gun 14G | Mean: 3.5 cores Range: 1 to 7
Crystal et al. 2005^498^ | NR | NR | NR | US | NR | Biopty automated gun 14G | Median: 4 cores Range: 1 to 8
Dillon et al. 2005^499^ | NR | NR | NR | US or stereotactic guidance or freehand | Supine or seated | Automated 14G or 16G needles | NR
Koskela et al. 2005^500^ | 5 | Radiologists | 4 to 6 years of experience | Stereotactic | Seated | Biopty automated gun 14G | Mean: 7 cores Range: 4 to 15
Sauer et al. 2005^501^ | 3 | NR | Undergone dedicated training in the biopsy method | US | NR | Biopty automated gun 14G | Mean: 2
Weber et al. 2005^502^ | NR | Surgeons | 5 month training period with the device before the study commenced | Stereotactic | Prone | Mammotome 11G | NR
Wu et al. 2005^503^ | 1 | Surgeons | Reported to be “skilled” | US | NR | Mammotome 11G | NR
Alonso-Bartolome et al. 2004^504^ | NR | NR | NR | US | Supine | NR | NR
Delle and Terinde 2004^505^ | NR | NR | NR | US | NR | Automated gun | Median: 2 Range: 1 to 4
Fajardo et al. 2004^506^ | NR | Radiologists | Radiologists at each participating site performed at least 50 procedures before enrolling patients into the trial | Stereotactic | NR | 14G needle | Minimum: 5
Kettritz et al. 2004^507^ | NR | Radiologists | NR | Stereotactic | Prone | Mammotome 11G | At least 20 or remove entire lesion
Lomoschitz et al. 2004^508^ | 4 | Radiologists | Two were highly experienced with the procedure, two were not | Stereotactic | Prone | Mammotome 11G | 20
Abdsaleh et al. 2003^509^ | 1 | Radiologists | NR | Stereotactic or US | NR | Semi-automated 14G | NR
Ambrogetti et al. 2003^510^ | 1 | NR | NR | Stereotactic | Prone | NR | Mean: 10.2 Range: 4 to 25
Fishman et al. 2003^511^ | 1 | Radiologists | Person performing procedure was a resident supervised by an attending radiologist | US | NR | Bard automated gun 14G | 5
Han et al. 2003^512^ | 2 | Radiologists | NR | Stereotactic | Prone | Biopty automated gun 14G | Mean: 7 Range: 5 to 20
Kirshenbaum et al. 2003^513^ | 3 | Radiologists | NR | Stereotactic | 72% seated | Bard automated gun 14G or Mammotome 11G | Bard gun Mean: 5.9 Range: 1 to 11 Mammotome Mean: 5.1 Range: 4 to 8
March et al. 2003^514^ | 3 | Radiologists | Reports the procedure is not their usual practice | US | NR | Mammotome 11G | Mean: 29 Range: 10 to 70
Pfleiderer et al. 2003^515^ | NR | NR | NR | MRI | Prone | Magnum automated gun 14G | Range: 3 to 6
Philpotts et al. 2003^516^ | More than 5 | Radiologists | Majority of the procedures appear to have been performed by fellows and residents under the supervision of 5 experienced breast radiologists | US | Supine | US Biopty automated gun 14G or Mammotome 11G | Biopty Mean: 4.7 Range: 1 to 17 Mammotome Mean: 5.8 Range: 1 to 12
Wong and Hisham 2003^517^ | NR | NR | NR | Freehand | NR | Bard automated gun 14 or 16G | NR
Apesteguia et al. 2002^518^ | NR | Radiologists | NR | Stereotactic | Prone | Mammotome 11G | Mean: 10.7 Range: 1 to 26
Georgian-Smith et al. 2002^519^ | NR | Radiologists | NR | Stereotactic | Most seated | Mammotome 11G | Mean: 9.5 Range: 5 to 26
Jackman and Lamm 2002^520^ | NR | Radiologists | NR | Stereotactic | Prone | Biopty automated gun 14G or Mammotome 11G or 14G | Median 14 Range: 5 to 30
Johnson et al. 2002^521^ | NR | NR | No experience at the beginning of the study | US | Supine | Mammotome 11G or 8G | Attempt to completely remove lesion
Liberman et al. 2002^522^ | NR | NR | NR | Stereotactic | Prone | Mammotome 11G | Median: 15 Range: 4 to 47
Meloni et al. 2002^523^ | NR | NR | NR | Stereotactic | Seated | Vacuum-assisted | Mean: 12 Range: 3 to 14
Morris et al. 2002^524^ | NR | NR | NR | Stereotactic | Prone | Mammotome 14G | NR
Pfarl et al. 2002^525^ | More than 7 | Radiologists | 7 had an average of 2.6 (Range: 0 to 18) procedures before the study commenced; non specified number of residents in training had no experience before the study commenced | Stereotactic | Prone | Mammotome 11G | 15 to 20
Verkooijen et al. COBRA 2002^526^ | More than 5 | Radiologists | radiologists first attended 10 biopsy procedures and subsequently they performed another 10 under the supervision of a radiologist with considerable experience | Stereotactic | Prone | Bard automated gun 14G | NR
Becker et al. 2001^527^ | 4 | Radiologists | NR | Stereotactic | Seated | 14G needle | NR
Brenner et al. 2001^528^ | NR | NR | All took a two-day course | Stereotactic | Prone | Automated gun 14G | 5 or more
Cangiarella et al. 2001^529^ | NR | Radiologists | NR | Stereotactic | Prone | Mammotome 11G | Mean: 11 Range: 7 to 15
Dahlstrom and Jain 2001^530^ | NR | NR | NR | Stereotactic | NR | Biopty automated gun 14G | 5
Lai et al. 2001^531^ | NR | NR | NR | Stereotactic | Prone | Mammotome 11G | Mean: 17.2
Levin et al. 2001^532^ | 3 | Radiologists | 2 of 3 radiologists had prior training in stereotactic core biopsy and attended a two-day course on use of the add-on unit; these two taught the third radiologist | Stereotactic | Seated | BIP automated gun 14G | 5
Margolin et al. 2001^533^ | 3 | Radiologists | NR | Stereotactic or US | Prone | Automated 14G, 16G, or 18G gun or Mammotome 11G or 14G | NR
Perez-Fuentes et al. 2001^534^ | NR | NR | NR | US | Supine | Mammotome 11G | Median: 17 Range: 8 to 40
Smith et al. 2001^535^ | NR | NR | NR | US | NR | Automated 14G gun | NR
White et al. 2001^536^ | NR | Radiologists | NR | Stereotactic or US | Prone or supine | Automated 14G gun or Mammotome 11G or 14G | NR
Wunderbaldinger et al. 2001^537^ | 1 | Radiologists | Performed 30 procedures on phantoms prior to the study | US | Seated | Magnum automated gun 14G | Mean: 6 Range: 3 to 10
Yeow et al. 2001^538^ | 1 | Radiologists | NR | US | NR | Automated gun 14G or 16G | Mean: 3.4 Range: 1 to 7
Beck et al. 2000^539^ | NR | NR | NR | Stereotactic | Prone | Mammotome 11G | NR
Kirwan et al. 2000^540^ | NR | NR | NR | Stereotactic | Prone | Automated gun 14G | NR
Latosinsky et al. 2000^541^ | NR | NR | NR | Stereotactic or US | Prone for stereotactic | Automated gun or vacuum-assisted 14G | NR
Liberman et al. 2000^542^ | NR | NR | NR | US or stereotactic | NR | Automated 14G gun | Median: 4 Range: 1 to 7
Makoske et al. 2000^543^ | More than 1 | Radiologists and surgeons | No experience in the procedure at the beginning of study; they were, however, trained and credentialed. | Stereotactic | NR | Automated gun or Mammotome | Minimum: 5
Ward et al. 2000^544^ | 2 | Radiologists | Radiologists described as “specialize in breast imaging and diagnosis” | Stereotactic | NR | Bard automated gun 14G or 16G | Mean: 11 Range: 4 to 18
Welle et al. 2000^545^ | NR | NR | NR | Stereotactic | Most decubitus | Bard automated gun 14G or Mammotome 11G | 3 to 16
Helbich et al. 1999^546^ | 1 | Radiologists | NR | Stereotactic | Seated | Patients randomized to various automated biopsy guns with different needle G | NR
Jackman et al. 1999^547^ | NR | NR | NR | Stereotactic | Prone | Biopty automated gun 14G | Mean: 8.1 Range: 2 to 20
Meyer et al. 1999^548^ | NR | NR | NR | Stereotactic | Prone | Automated gun 14G or Mammotome 11G or 14G | Mean: 5 to 8
Puglisi et al. 1999^549^ | NR | NR | NR | Perforated compression grid | NR | Automated gun 14G | Median: 5
Soo et al. 1999^550^ | 4 | Radiologists | NR | Stereotactic | Prone | Magnum automated gun 14G or Mammotome 14G | Automated gun Mean: 5.8 Mammotome Mean: 15.8
Caruso et al. 1998^551^ | 1 | Surgeons | Reports “experienced surgeon” | Freehand | NR | Trucut 18G | NR
Doyle et al. 1998^552^ | NR | NR | No experience with the procedure at the beginning of the study | Stereotactic | Decubitus | Pro-Mag automated gun 14G | NR
Fuhrman et al. 1998^553^ | 3 | Radiologists | Reports “radiologists with expertise in breast imaging” | Stereotactic or US | Stereotactic prone, US supine | Automated gun 14G | At least 5
Heywang-Kobrunner et al. 1998^554^ | NR | NR | NR | Stereotactic | Prone | Mammotome 11G or 14G | NR
Ioffe et al. 1998^555^ | NR | NR | NR | Stereotactic or US | NR | Bard automated gun 14G | At least 5
Liberman et al. 1998^556^ | NR | NR | NR | US | Supine | Pro-Mag automated gun 14G | Median: 4 Range: 2 to 7
Schulz-Wendtland et al. 1998^557^ | NR | NR | NR | US | NR | 14G needle | 1 to 3
Vega-Bolivar et al. 1998^558^ | 1 | Radiologists | NR | Stereotactic | NR | Surecut 15G | At least 2
Whitman et al. 1998^559^ | NR | NR | NR | Stereotactic | NR | Monopty 16G | NR
Zannis and AliaNo 1998^560^ | 1 | Surgeons | NR | Stereotactic | Prone | Trucut 14G or Mammotome 14G or 11G | Trucut Mean: 4.8 cores Range: 1 to 7 Mammotome at least 16
Bauer et al. 1997^561^ | NR | NR | NR | Stereotactic | Prone or seated | BIP automated gun 14G | Mean: 9 Range: 1 to 13
Britton et al. 1997^562^ | 4 | Radiologists | NR | Stereotactic or US | Supine for US | Automated gun 14, 16, or 18G | Mean: 5
Helbich et al. 1997^563^ | 1 | Radiologists | Described as an “expert” | Stereotactic or US | Prone or supine or seated | Automated gun 14G | NR
Khattar et al. 1997^564^ | NR | Surgeons | NR | US | Supine | Pro-Mag automated gun | 2 or 3
Liberman et al. 1997^565^ | NR | NR | NR | Stereotactic | Prone | Biopty-cut 14G | Mean: 6 Range: 1 to 22
Pitre et al. 1997^566^ | NR | NR | NR | Stereotactic | Prone | Pro-Mag automated gun | Mean: 5
Stolier et al. 1997^567^ | 1 | Surgeons | No experience in the procedure at the beginning of study | Stereotactic | Prone | Automated gun 14G or Mammotome | Minimum: 5
Sutton, et al. 1997^568^ | 5 | Radiologists | All involved radiologists have experience in mammography and interventional techniques in breast disease diagnosis | Stereotactic | Prone | Biopty automated gun 14G | NR
Walker et al. 1997^569^ | NR | NR | NR | Stereotactic | NR | Automated gun 14G | Minimum: 5
Frazee et al. 1996^570^ | NR | Radiologists | NR | Stereotactic | Prone | NR | Minimum: 5
Fuhrman et al. 1996^571^ | NR | NR | NR | Stereotactic | Prone | Automated gun 14G | Minimum: 5
Head and Haynes 1996^572^ | NR | NR | NR | Stereotactic | Prone | Biopty automated gun 18G | NR
Mainiero et al. 1996^573^ | NR | NR | NR | Stereotactic | Prone | Biopty automated gun 14G | NR
Meyer et al. 1996^574^ | NR | Radiologists | NR | Stereotactic | Prone | Biopty automated gun 14G | NR
Nguyen et al. 1996^575^ | NR | NR | NR | Stereotactic or US | Prone | Automated gun 14G | 5 to 10
Pettine et al. 1996^576^ | NR | NR | NR | Stereotactic | Prone | Biopty automated 14G gun | 5 to 9
Rosenblatt et al. 1996^577^ | NR | NR | NR | Stereotactic | Prone | Biopty automated gun 14G | NR
Scopa et al. 1996^578^ | NR | NR | NR | Freehand | NR | TruCut | NR
Cross et al. 1995^579^ | NR | NR | NR | Stereotactic | Prone | Bard automated gun 14G | Mean: 3.4 Range: 1 to 8
Doyle et al. 1995^580^ | NR | NR | NR | Stereotactic or US | Prone | Automated gun 14G or 15G | NR
Hamed et al. 1995^581^ | NR | NR | NR | Freehand | NR | Biopty automated gun 14G or 18G | Mean: 3
Burbank et al. 1994^582^ | NR | NR | NR | Stereotactic or US | NR | NR | NR
Gisvold et al. 1994^583^ | 7 | Radiologists | All attended a training session before performing any procedures | Stereotactic | Prone | Biopty automated gun 14G | Minimum: 5
Parker et al. 1994^584^ | NR | Radiologists | The radiologists participated in a two-day training session before the study commenced | Freehand | NR | Biopty automated gun 14G | NR
Smyth and Cederbom 1994^585^ | NR | NR | NR | Stereotactic | Prone | Automated gun | NR
Elvecrog et al. 1993^586^ | 2 | Radiologists | NR | Stereotactic | Prone | Biopty automated gun 14G | Minimum: 5
Parker et al. 1993^587^ | NR | Radiologists | NR | US | Supine | Biopty automated gun 14G | 4 to 5
McMahon et al. 1992^588^ | More than 8 | Surgeons | NR | Freehand | NR | Various 14 to 18G devices | 1
Barreto et al. 1991^589^ | NR | NR | No experience at the beginning of the study | Freehand | NR | Biopty automated gun 18G | 1
Cusick et al. 1990^590^ | NR | NR | NR | Freehand | NR | NR | NR
Parker et al. 1990^591^ | 4 | Radiologists | NR | Stereotactic | NR | Biopty automated gun 14, 16, or 18G | NR

NR = Not Reported

Table E10 Patient inclusion/exclusion criteria for studies addressing Key Questions 1 and 2

Study | Patient Inclusion Criteria | Patient Exclusion Criteria
Jackman et al. 2009^485^ | Consecutive patients referred for core-needle biopsy between March 1995 through December 2001 | Weighed more than 300 lbs; had bleeding diathesis; use of anti-coagulants that could not be discontinued (but no patients had these conditions during the study period).
Peters et al. 2008^486^ | All patients with nonpalpable lesions referred for core-needle biopsy between February 2000 and June 2002 | Coagulopathies or the use of anti-coagulants that could not be discontinued and an inability to stay in the prone position for one hour
Schueller et al. 2008^487^ | All patients referred to the center for core-needle biopsy between January 1995 and February 2004 | Patients unable to cooperate with the procedure or had a bleeding diathesis
Sim and Kei et al. 2008^488^ | All patients with microcalcifications referred for core-needle biopsy between November 2002 and August 2005 | NR
Tonegutti and Girardi 2008^489^ | Women with suspicious nonpalpable mammographic lesions (microcalcifications, mass with or without microcalcifications, architectural distortion) not recognisable by ultrasound | NR
Youk et al. 2008^24^ | All patients undergoing US-guided core-needle biopsy between February 2000 and June 2005 | NR
Ciatto et al. 2007^490^ | All consecutive core-needle biopsies performed at the study center between January 1996 and March 2005 | NR
de Lucena et al. 2007^491^ | NR | NR
Uematsu et al. 2007^492^ | Consecutive patients with mammographically-detected microcalcifications BIRADS 3, 4, or 5 whose lesions were not visible on US | Unable to provide consent or undergo MRI imaging due to pacemaker, claustrophobia, or metallic clip; blood coagulation disorder; currently being treated with anti- coagulants; unable to cooperate with the biopsy procedure
Vag et al. 2007^493^ | NR | NR
Chapellier et al. 2006^494^ | Core-needle biopsies performed between January 2001 to November 2002 | NR
Cipolla et al. 2006^495^ | Consecutive patients undergoing core-needle biopsy at the center between September 1999 to February 2004 | NR
Dhillon et al. 2006^496^ | The first 150 consecutive patients who met these criteria: all indeterminate calcifications; distortions or masses not seen on US; a non-diagnostic biopsy on US; problem cases referred from other units | NR
Bolivar et al. 2005^497^ | All patients with suspicious non-palpable breast lumps who underwent US-guided biopsy between August 1997 to April 2001 | NR
Crystal et al. 2005^498^ | Patients with US visible solid breast lesions referred for biopsy between October 1, 1998 and September 1, 2001 | Lesions that appeared to be radial scars were excluded
Dillon et al. 2005^499^ | All women who underwent biopsy at the center between January 1999 to September 2003 | NR
Koskela et al. 2005^500^ | Between June 1998 and January 2001, all patients with lesions not visible on US who were scheduled for core-needle stereotactic biopsy | Lesions located too high or too close to the chest wall such that it could not be reached by the stereotactic equipment
Sauer et al. 2005^501^ | All patients undergoing US biopsy of lesions detected on routine screening over a 28 month period | NR
Weber et al. 2005^502^ | All patients between October 1999 to August 2003 with mammographically suspicious but nonpalpable lesions | Breast too small, lesion too close to the chest wall, lesion not evident on image
Wu et al. 2005^503^ | Patients suspected of having benign lesions who underwent vacuum-assisted biopsy between July 2000 and July 2003 | NR
Alonso-Bartolome et al. 2004^504^ | Patients with “probably benign” lesions | NR
Delle and Terinde 2004^505^ | Patients referred to the clinic because of palpable or non-palpable lesions or because of suspicion of cancer on mammography between September 2000 and September 2001 | NR
Fajardo et al. 2004^506^ | NR | Lesions located in prior lumpectomy or radiation therapy site, known bleeding disorder or anticoagulant therapy, pregnancy, allergy to local anesthesia, breast implants, psychiatric or neurologic conditions limiting patient’s ability to cooperate during biopsy and/or provide informed consent
Kettritz et al. 2004^507^ | NR | NR
Lomoschitz et al. 2004^508^ | Consecutive women with solitary non-palpable lesions referred for 11G mammotome between February 1999 and July 2000, consecutive until 50 women with mammographic masses and 50 women with microcalcifications were enrolled | NR
Abdsaleh et al. 2003^509^ | Consecutive patients between August 2000 and December 2001 | NR
Ambrogetti et al. 2003^510^ | Consecutive nonpalpable isolated microcalcifications detected in routine screening considered suspicious enough to warrant investigation between February 1999 and June 2002 | NR
Fishman et al. 2003^511^ | Consecutive patients referred for an US-guided biopsy over a 7-month period | Lesion turned out to be a cyst, pathological material was lost in one case, and in two cases ad hoc exclusion because the pathologist involved in the study had come to a different diagnosis than the “routine” pathology reading
Han et al. 2003^512^ | Nonpalpable calcifications referred between April 1997- March 2002 | NR
Kirshenbaum et al. 2003^513^ | All patients undergoing stereotactic core-needle biopsy between October 1994 and February 2001 with nonpalpable lesions. | NR
March et al. 2003^514^ | Patients referred to two outpatient centers between August 2000 and October 2001 for US-guided biopsy of a single breast lesion well- visualized on US and located at least 0.5 cm from the skin and pectoralis margin and at least 2 cm from the nipple with the lesion measuring 1.2 cm or less in diameter | Lesion turned out to be a cyst
Pfleiderer et al. 2003^515^ | Women were invited after an MRI exam that found lesions with suspicious contrast enhancement, reasons why they had the MRI exam not reported | Pregnancy or lactation, coagulation abnormalities, allergies to local anesthetics or MRI contrast agents, compressed breast thickness less than 25 mm
Philpotts et al. 2003^516^ | All patients who underwent US-guided biopsy between January 1997 and August 2001 | NR
Wong and Hisham 2003^517^ | Consecutive biopsies of palpable breast lesions from May 2000 to May 2001 | Nonpalpable lesion, less than 6 months followup
Apesteguia et al. 2002^518^ | All cases detected between April and December 1999 with suspicious non-palpable lesion which could not be reliably detected by US | NR
Georgian-Smith et al. 2002^519^ | Consecutive patients between June 1999 and August 2000 | NR
Jackman and Lamm 2002^520^ | All patients who underwent core-needle biopsy between July 1991 and December 1999 who had breast implants | NR
Johnson et al. 2002^521^ | All patients with probably benign lesions scheduled for US-guided mammotome excisional attempt between April 2000 to January 2002 | NR
Liberman et al. 2002^522^ | Consecutive lesions undergoing stereotactic biopsy between October 31, 1996 to March 8, 2001. Indications for biopsy were nonpalpable lesions suspicious of malignancy, calcifications or masses 0.5 cm or less or masses that could not be viewed on US | Bleeding diathesis, patient unable to cooperate, lesion could not be targeted
Meloni et al. 2002^523^ | All cases of non-palpable mammographically detected lesions undergoing vacuum-assisted core-needle biopsy at the center between December 1999 and November 2000 | NR
Morris et al. 2002^524^ | Twenty-one nonpalpable masses seen on mammography in 19 women who gave informed consent. The masses on mammography had no associated calcifications and were classified as either BI-RADS 4 (n = 17) or 5 (n = 4) lesions. | NR
Pfarl et al. 2002^525^ | All patients undergoing 11G Mammotome biopsy from September 1997 to December 2001 | Unable to cooperate with the procedure, had a bleeding diathesis
Verkooijen et al. COBRA 2002^526^ | Nonpalpable breast lesions requiring histologic exam enrolled in 19 Dutch hospitals | Coagulotherapies or use of anticoagulants that could not be discontinued, inability to maintain prone position for one hour, inability to comprehend study protocol
Becker et al. 2001^527^ | Biopsies performed for microcalcifications at the center between November 1993 and January 1997 | NR
Brenner et al. 2001^528^ | NR | NR
Cangiarella et al. 2001^529^ | Patients with indeterminate microcalcifications that had been detected by routine screening and had no evidence of a mammographic density or mass biopsied between January 1997 and December 1997 | NR
Dahlstrom and Jain 2001^530^ | Women with suspicious calcifications detected on routine screening between July 1993 and August 1998 | NR
Lai et al. 2001^531^ | Consecutive patients who underwent biopsy between | NR
Levin et al. 2001^532^ | September 1997 and March 2000 Women with a single non-palpable lesion detected during a routine mammography and scheduled for a lumpectomy. Spiculated lesions, indeterminate nodules, indeterminate calcifications, and localized asymmetric density were eligible. | Palpable lesion, radial scar, bleeding diathesis, lesion not well visualized, in a difficult location
Margolin et al. 2001^533^ | All patients who underwent core biopsy between January 1994 and December 1998 | NR
Perez-Fuentes et al. 2001^534^ | All patients who underwent US-guided vacuum-assisted core needle biopsies at the center between August 1998 to December 2000. Criteria for deciding who got this type of core biopsy rather than another type seemed vague and inconsistently applied. Listed below: palpable or nonpalpable masses that could be seen with US and that were suspicious or highly suggestive of malignancy. Also used for occasional lesions that appeared to probably be benign. Selectively used for solid lesions that were suspicious and measured 2 cm or less. Solid lesions that were suggestive of malignancy and measured 1 cm or less. Complex lesions, intraductal lesions, subtle lesions, cysts with mural thickening, intramural nodules, or thick septations regardless of size; lesions suspected of being radial scars or papillomas; other lesions; occasional probably benign lesions 2 cm or less. | Bleeding diathesis or unable to cooperate with the procedure.
Smith et al. 2001^535^ | Betweeen August 1991 and February 1998, women referred for US-guided biopsy because of non-calcificied US visible masses | NR
White et al. 2001^536^ | All patients who had image-guided core-needle biopsy at the center between August 1992 and February 1999 | NR
Wunderbaldinger et al. 2001^537^ | Patients scheduled to undergo open biopsy for non-palpable breast lesions | NR
Yeow et al. 2001^538^ | Consecutive patients referred for needle biopsy January 1995 to October 1997 with palpable breast masses | Lesion was identified as a cyst
Beck et al. 2000^539^ | Until April 1999 patients with indeterminate lesions who were sent for biopsy | NR
Kirwan et al. 2000^540^ | Women with mammographically-detected stellate lesions with or without microcalcifications | NR
Latosinsky et al. 2000^541^ | Between November 1994 to May 1998, all patients who underwent core biopsy | NR
Liberman et al. 2000^542^ | Patients with palpable lesions who underwent core-needle biopsy betweeen August 1992 and May 1998 | NR
Makoske et al. 2000^543^ | All eligible patients from 1993 through 1998, those with nonpalpable lesions found on mammography who were sent for biopsy | NR
Ward et al. 2000^544^ | Patients with indeterminate microcalcifications sent for core biopsy between November 1993 and January 1997 | Cases with associated mass, distortion, or palpable lesion were excluded
Welle et al. 2000^545^ | Patients with stereotactic core-needle biopies performed between September 1995 trhough March 1999 | NR
Helbich et al. 1999^546^ | NR | NR
Jackman et al. 1999^547^ | Consecutive patients with nonpalpable lesions who had stereotactic core-needle biopsy between July 1991 and December 1993 | NR
Meyer et al. 1999^548^ | Patients seen between August 1991 and December 31, 1997 for suspicious nonpalpable breast abnormalities | NR
Puglisi et al. 1999^549^ | Consecutive patients seen from July 1992-December 1997 | US-guided procedures
Soo et al. 1999^550^ | Patients with noncalcified, nonpalpable, mammographically-detected lesions referred for biopsy between October 1995 and August 1997 | NR
Caruso et al. 1998^551^ | From 1990 to 1995, a consecutive series of 91 patients | NR
Doyle et al. 1998^552^ | Patients who underwent stereotactic core-needle biopsy between September 1994 and March 1998 | NR
Fuhrman et al. 1998^553^ | All nonpalpable breast lesions from July 1993-February 1997 that underwent image-guided core needle breast biopsy. | Palpable masses, lesions not clearly visualized in the stereotactic unit (usually lesions deep in the breast along the chest wall), lesions found in small breasts which compress to <2 cm in the stereotactic unit, asymmetric dense breast tissue, unable to tolerate the prone position for 30 minutes.
Heywang-Kobrunner et al. 1998^554^ | Patients referred for biopsy up to March 1997 | NR
Ioffe et al. 1998^555^ | Consecutive core-needle biopsies between July 1995 and January 1997 | NR
Liberman et al. 1998^556^ | Patients with a solitary, nonpalpable mass who underwent US-guided biopsy between May 1993 and June 1997 | The parenchyma was too thin to support the excursion of the needle, a hemorrhagic diathesis, unable to cooperate, or the lesion was less than 5 mm
Schulz-Wendtland et al. 1998^557^ | Patients who underwent US-guided biopsies between May 1992 and April 1993 | NR
Vega-Bolivar et al. 1998^558^ | Patients seen between October 1993-October 1996 for nonpalpable breast lesions | NR
Whitman et al. 1998^559^ | Mammographically-guided coaxial core-needle biopsy procedures performed with a fenestrated alphanumeric compression device between 1995-1997 | NR
Zannis and AliaNo 1998^560^ | Consecutive records of patients undergoing a stereotactic procedure and biopsy by the same surgeon for a non-palpable, mammographically-detected lesion between January 1993 and August 1997 | NR
Bauer et al. 1997^561^ | Mammographically-detected breast lesions considered worrisome enough to require biopsy, such as clustered microcalcifications, a spiculated mass, or an area of architectural distortion during the 30 months from July 1, 1993 to January 1, 1996. | NR
Britton et al. 1997^562^ | All patients after April 1994 who were recalled for core-needle biopsy after routine mammographic screening | NR
Helbich et al. 1997^563^ | Consecutive patients with solid breast lesions over 20 months | NR
Khattar et al. 1997^564^ | Between February 1993 and March 1995, patients over 18 years of age with a palpable mass scheduled for surgical excision | Lesion was revealed to be a simple cyst on US
Liberman et al. 1997^565^ | Patients who underwent stereotactic core biopsy between August 7, 1992 and December 14, 1995 | Thickness of compressed breast was inadequate to accommodate the needle; the lesion measured less than 5 mm in diameter; the lesion could not be targeted accurately; the patient had a bleeding diathesis; the patient was on anticoagulants; the patient was unable to cooperate with the procedure.
Pitre et al. 1997^566^ | Patients who had stereotactic core-needle biopsy for a nonpalpable unicentric mammographically-detected breast lesion between January 1994 and February 1995 | NR
Stolier et al. 1997^567^ | All patients who underwent core-needle biopsy at the center by the study author from August 1993 through May 1996 | NR
Sutton, et al. 1997^568^ | Women who elected to have stereotactic-guided large-gauge core biopsy between July 1993 and June 1995 after detection of suspicious non-palpable abnormalities at a mammographic screening clinic | Initially, women with abnormalities considered to be obviously malignant were excluded from the series (from July to December 1993) but after the first 70 patients, these highly suspicious lesions were offered core biopsy
Walker et al. 1997^569^ | All patients who had stereotactic core-needle for a nonpalpable lesion since 1993 | NR
Frazee et al. 1996^570^ | Patients with nonpalpable mammographic abnormality between July 1994 to June 1995 | NR
Fuhrman et al. 1996^571^ | All non-palpable suspicious masses and calcifications noted on mammography from July 1993 - January 1995 | Lesions not clearly visualized in the stereotactic unit, usually lesions deep within the breast along the chest wall, lesions found in small breasts which compress to less than 2cm in the stereotactic unit, asymmetric dense breast tissue, and patients unable to tolerate the prone position for 30 minutes
Head and Haynes 1996^572^ | Patients with nonpalpable breast lesions discovered during routine mammography | NR
Mainiero et al. 1996^573^ | Patients with microcalcifications were considered indeterminate or suspicious for malignancy | Lesions in which calcifications were within a mass or an area of architectural distortion
Meyer et al. 1996^574^ | Clinically occult suspicious mammographic abnormalities. The mass must be at least 6mm in diameter and be clearly visible on mammography | NR
Nguyen et al. 1996^575^ | All core-needle biopsies performed between December 1992 and June 1995 | NR
Pettine et al. 1996^576^ | Patients with nonpalable lesions discovered on mammogram followed immediately by wire localized biopsy | NR
Rosenblatt et al. 1996^577^ | All patients who underwent biopsy of multiple unilateral lesions between January 1994 and September 1995 | NR
Scopa et al. 1996^578^ | Patients undergoing Tru-Cut biopsies who had not been previously investigated with fine-needle aspiration | NR
Cross et al. 1995^579^ | Patients who were referred to the center for stereotactic biopsy of a nonpalpable mammographic abnormality | NR.
Doyle et al. 1995^580^ | Mammographically-detected impalpable breast lesions, completely well-circumscribed masses less than 8mm in diameter with smooth borders. Opacities containing fat or with concave margins, clusters or uniform tiny rounded calcifications, scattered calcifications, and scattered nodules. Lesions considered strongly suggestive of cancer included new spiculated masses, new clustered pleomorphic calcifications, or both. | Inability to provide informed consent and irreversible bleeding diathesis
Hamed et al. 1995^581^ | Female patients with clinically suspected breast carcinoma | Patients with locally advanced breast carcinoma
Burbank et al. 1994^582^ | NR | Patients who underwent bone biopsies
Gisvold et al. 1994^583^ | All patients referred for wire-localized open surgery between October 19, 1991 and January 15, 1993 were considered for the study. The inclusion criteria are: If it appeared the lesion and patient were suitable (patient could lie prone for an hour, no bleeding problems, and no allergy to local anesthesia; lesions thought to be visualizable and were not too superficial or close to the nipple). | Equipment or radiologist not available, lesion visualizable only on US
Parker et al. 1994^584^ | Core-needle biopsies performed at sites at which the radiologists and assisting technologists had undergone dedicated training in larger core breast biopsy and had followed a standard protocol | NR
Smyth and Cederbom 1994^585^ | Patients with mammographically suspicious non palpable lesions | NR
Elvecrog et al. 1993^586^ | Patients with single non-palpable mammographic lesion; study restricted to patients who would have undergone open biopsy if core biopsy wasn’t available | Lesions less than 5 mm in diameter
Parker et al. 1993^587^ | Consecutive patients with solid or indeterminate breast lesions visualized by US between August 1989 and July 1991 | NR
McMahon et al. 1992^588^ | Consecutive patients with palpable breast lumps between September 1989 and August 1991 | NR
Barreto et al. 1991^589^ | Symptomatic patients with palpable breast lumps suspected of having early breast cancer who were scheduled for open surgical excision | NR
Cusick et al. 1990^590^ | Patients with suggestive mammary lumps seen at the surgery clinic of San Bernardino County Medical Center | NR
Parker et al. 1990^591^ | During a 13-month period, consecutive patients who underwent stereotactic-needle core breast biopsies | NR

NR = Not Reported

Table E11 Characteristics of patients enrolled in studies addressing Key Questions 1 and 2

Study | Number of Patients Recruited for Enrollment | Number of Patients Enrolled | Number of Lesions Enrolled | Age | Age Dispersion | Ethnicity
Jackman et al. 2009^485^ | 1,152 | 1,152 | 1,280 | NR | NR | NR
Peters et al. 2008^486^ | 955 | 948 | 948 | NR | NR | NR
Schueller et al. 2008^487^ | 1390 | 1390 | 1438 | Median: 51 | Range: 15 to 93 | NR
Sim and Kei et al. 2008^488^ | 106 | 97 | 105 | Mean: 53.2 | Range: 36 to 81 | Asian: 100%
Tonegutti and Girardi 2008^489^ | 268 | 268 | 268 | Mean: 52 | Range: 22–79 | NR
Youk et al. 2008^24^ | 4,359 | 4,359 | 4,359 | Median: 45 Mean: 45.3 | Range: 12 to 88 | NR
Ciatto et al. 2007^490^ | 4,035 | 4,035 | 4,035 | NR | NR | NR
de Lucena et al. 2007^491^ | NR | 144 | 150 | Mean: 50 | Range: 15 to 89 Standard deviation: 16 | NR
Uematsu et al. 2007^492^ | NR | 96 | 100 | Mean: 49.4 | Range: 28 to 85 | NR
Vag et al. 2007^493^ | NR | 65 | 70 | Median: 57 | Range: 31 to 82 | NR
Chapellier et al. 2006^494^ | NR | 301 | 318 | Mean: 56 | Range: 35 to 78, 64% postmenopausal | NR
Cipolla et al. 2006^495^ | 426 | 426 | 426 | 64% post-menopausal | NR | NR
Dhillon et al. 2006^496^ | 150 | 150 | 150 | Median: 56 | Range: 37 to 77 | NR
Bolivar et al. 2005^497^ | 208 | 208 | 214 | Mean: 55 | Range: 32 to 87 | NR
Crystal et al. 2005^498^ | 652 | 652 | 715 | NR | NR | NR
Dillon et al. 2005^499^ | 2,427 (lesions) | NR | 2,427 | NR | NR | NR
Koskela et al. 2005^500^ | 212 | 205 | 213 | Mean: 56 | Range: 32 to 88 | NR
Sauer et al. 2005^501^ | 906 | 906 | 962 | NR | NR | NR
Weber et al. 2005^502^ | 239 | 225 | 225 | Median: 56.1 | Range: 30 to 84 | NR
Wu et al. 2005^503^ | 113 | 113 | 113 | Median: 31 | Range: 18 to 35 | NR
Alonso-Bartolome et al. 2004^504^ | 97 | 97 | 102 | Mean: 42 | Range: 18 to 77 | NR
Delle and Terinde 2004^505^ | 146 | 146 | 169 | NR | NR | NR
Fajardo et al. 2004^506^ | 2,403 | 2,403 | 2,403 | Mean: 54.6 | Range: 25 to 89 | % White European descent: 1,313 (78.1%) % Black African descent: 265 (15.8%) % Asian descent: 27 (1.6%) % Hispanic descent: 62 (3.7%) % other, please specify: 6 Native American (0.4%), 8 another race (0.5%)
Kettritz et al. 2004^507^ | 2,939 | NR | 2,893 | NR | NR | NR
Lomoschitz et al. 2004^508^ | 100 | 100 | 100 | Median: 55 | Range: 31 to 81 | NR
Abdsaleh et al. 2003^509^ | 180 | 180 | 180 | NR | Range: 35 to 93 | NR
Ambrogetti et al. 2003^510^ | 364 | 364 | 364 | Mean: 54.9 | Range: 33 to 81 | NR
Fishman et al. 2003^511^ | 75 | 70 | 73 | NR | NR | NR
Han et al. 2003^512^ | 284 (lesions) | 267 | 271 | Mean: 47 yrs | Range: 23 to 72 | NR
Kirshenbaum et al. 2003^513^ | 492 | 492 | 506 | Mean: 59.1 | Range: 27 to 78 | NR
March et al. 2003^514^ | 57 | 34 | 34 | NR | NR | NR
Pfleiderer et al. 2003^515^ | NR | 14 | 14 | Mean: 47.9 | Standard deviation: 13.1 | NR
Philpotts et al. 2003^516^ | 271 | 271 | 281 | NR | NR | NR
Wong and Hisham 2003^517^ | NR | 145 | 150 | NR | Range: 20 to 80 | % Asian descent: 80% % other, please specify: 18% Indian 2% “other”
Apesteguia et al. 2002^518^ | 126 | 126 | 132 | Mean: 50.5 | Range: 29 to 81 Standard deviation: 10.2 | NR
Georgian-Smith et al. 2002^519^ | 179 | 179 | 185 | Mean: 54.6 | Range: 35 to 85 | NR
Jackman and Lamm 2002^520^ | 25 | 25 | 31 | Median: 58 | Range: 35 to 75 | NR
Johnson et al. 2002^521^ | 81 | 81 | 101 | Mean: 46.8 | Range: 21 to 72 | NR
Liberman et al. 2002^522^ | 797 | 797 | 800 | Median: 57 | Range: 28 to 88 | NR
Meloni et al. 2002^523^ | 138 | 129 | 129 | NR | NR | NR
Morris et al. 2002^524^ | NR | 19 | 21 | Mean: 57 | Range: 36 to 75 | NR
Pfarl et al. 2002^525^ | 332 (lesions) | 325 | 332 | Median: 56 | Range: 28 to 83 | NR
Verkooijen et al. COBRA 2002^526^ | 973 | 928 | 984 | Mean: 58 | Range: 29 to 85 | NR
Becker et al. 2001^527^ | 218 | 218 | 232 | Mean: 57.3 | Range: 33 to 84 | NR
Brenner et al. 2001^528^ | NR | 1003 | 1003 | NR | NR | NR
Cangiarella et al. 2001^529^ | 142 | 142 | 160 | Mean: 53.5 | Range: 34 to 79 | NR
Dahlstrom and Jain 2001^530^ | 266 | discrepancy: study reports data for 301 core biopsies but states in methods that 266 women with 274 lesions were enrolled | 310 | NR | NR | NR
Lai et al. 2001^531^ | 650 | 650 | 673 | Mean: 54.7 | Range: 22 to 89 Standard deviation: 11.6 | NR
Levin et al. 2001^532^ | NR | 70 | 70 | NR | Range: 39 to 80 | NR
Margolin et al. 2001^533^ | 1,183 | 1,183 | 1,333 | Mean: split into three groups 55, 52, 40 | Range: 17 to 93 | NR
Perez-Fuentes et al. 2001^534^ | 88 (lesions) | 83 | 88 | Median: 48 | Range: 25 to 78 | NR
Smith et al. 2001^535^ | 446 | 446 | 500 | Median: 46 Mean: 47 | Range: 18 to 89 | NR
White et al. 2001^536^ | 939 | 939 | 1042 | Median: 60 | Range: 32 to 85 | NR
Wunderbaldinger et al. 2001^537^ | NR | 45 | 45 | Mean: 50 | Range: 20 to 77 | NR
Yeow et al. 2001^538^ | 104 | 98 | 98 | Mean: 46.5 | Range: 23 to 85 Standard deviation: 12.3 | NR
Beck et al. 2000^539^ | 560 | 560 | 594 | NR | NR | NR
Kirwan et al. 2000^540^ | NR | 72 | 72 | NR | NR | NR
Latosinsky et al. 2000^541^ | 607 | 607 | 692 | NR | NR | NR
Liberman et al. 2000^542^ | 155 (lesions) | NR | 155 | Median: 47 | Range: 19 to 88 | NR
Makoske et al. 2000^543^ | 817 | 817 | 887 | NR | NR | NR
Ward et al. 2000^544^ | 161 | NR | 121 | Mean: 58 | Range: 33 to 83 | NR
Welle et al. 2000^545^ | NR | 225 | 225 | NR | NR | NR
Helbich et al. 1999^546^ | NR | 44 | 44 | NR | Range: 20 to 77 | NR
Jackman et al. 1999^547^ | 410 | 410 | 483 | Median: 55 | Range: 29 to 89 | NR
Meyer et al. 1999^548^ | NR | 1,643 | 1,836 | Mean: 50 | Range: 20 to 85 | NR
Puglisi et al. 1999^549^ | NR | 99 | 106 | Median: 57 | Range: 33 to 84 | NR
Soo et al. 1999^550^ | 110 | 110 | 116 | NR | NR | NR
Caruso et al. 1998^551^ | NR | 91 | 92 | Median: 65 | Range: 29 to 81 | NR
Doyle et al. 1998^552^ | 151 (lesions) | NR | 151 | NR | NR | NR
Fuhrman et al. 1998^553^ | 1,440 | 1,440 | 1,440 | NR | NR | NR
Heywang-Kobrunner et al. 1998^554^ | 238 | 238 | 261 | NR | NR | NR
Ioffe et al. 1998^555^ | NR | 198 | 224 | Mean: 51 | Range: 14 to 87 | NR
Liberman et al. 1998^556^ | 179 | 151 | 151 | Median: 50 | Range: 23 to 80 | NR
Schulz-Wendtland et al. 1998^557^ | 307 | 307 | 2,307 | NR | NR | NR
Vega-Bolivar et al. 1998^558^ | 180 | 180 | 182 | Mean: 55 | Range: 30 to 79 | NR
Whitman et al. 1998^559^ | 11 | 11 | 12 | Mean: 55 | Range: 31 to 75, 8.3% older than age 65 | NR
Zannis and AliaNo 1998^560^ | 372 | 372 | 424 | Mean: 57.7 | Range: 25 to 90 | NR
Bauer et al. 1997^561^ | 799 (lesions) | NR | 799 | Mean: 61 | Range: 38 to 87 | NR
Britton et al. 1997^562^ | 202 | 202 | 202 | NR | NR | NR
Helbich et al. 1997^563^ | 205 | 205 | 210 | Mean: 52.2 | Range: 23 to 88 | NR
Khattar et al. 1997^564^ | 117 | 106 | 106 | Median: 52 | Range: 19 to 85 | NR
Liberman et al. 1997^565^ | NR | NR | 442 | NR | NR | NR
Pitre et al. 1997^566^ | 128 | 128 | 128 | Mean: 56.4 | NR | NR
Stolier et al. 1997^567^ | 242 | 242 | 244 | NR | NR | NR
Sutton, et al. 1997^568^ | 200 | 200 | 206 | Mean: 59 | Range: 41 to 85 | NR
Walker et al. 1997^569^ | 200 | 200 | 200 | NR | Range: 35 to 86 | NR
Frazee et al. 1996^570^ | 103 | 103 | 103 | Mean: 60 | NR | NR
Fuhrman et al. 1996^571^ | 451 (lesions) | NR | 451 | NR | NR | NR
Head and Haynes 1996^572^ | 115 | 115 | 115 | NR | NR | NR
Mainiero et al. 1996^573^ | 128 | 124 | 138 | Mean: 56.2 | Range: 30 to 87 | NR
Meyer et al. 1996^574^ | 545 (lesions) | 369 | 388 | Median: 49 yrs Mean: 51 yrs | Range: 24 to 81 | NR
Nguyen et al. 1996^575^ | NR | 408 | 431 | NR | NR | NR
Pettine et al. 1996^576^ | 25 | 25 | 25 | NR | NR | NR
Rosenblatt et al. 1996^577^ | 156 | 25 | 58 | NR | NR | NR
Scopa et al. 1996^578^ | 109 | 109 | 120 | Mean: 51.2 | Range: 21 to 85 | NR
Cross et al. 1995^579^ | NR | 225 | 250 | Mean: 54 | Range: 26 to 89 | NR
Doyle et al. 1995^580^ | 366 | 365 | 365 | Mean: 57 years | NR | NR
Hamed et al. 1995^581^ | 122 | 122 | 122 | NR | NR | NR
Burbank et al. 1994^582^ | 105 (lesions) | NR | 105 | NR | NR | NR
Gisvold et al. 1994^583^ | 471 | 158 | 160 | NR | NR | NR
Parker et al. 1994^584^ | 6,152 (lesions) | NR | 6,152 | NR | NR | NR
Smyth and Cederbom 1994^585^ | 52 | 52 | 58 | Mean: 57 | NR | NR
Elvecrog et al. 1993^586^ | 107 | 100 | 100 | NR | NR | NR
Parker et al. 1993^587^ | 164 | 164 | 181 | NR | NR | NR
McMahon et al. 1992^588^ | 151 | 152 | 151 | Median: 57 Trucut 50 Bipopty 14G 56 Biopty 18G | Range: 24 to 87 | NR
Barreto et al. 1991^589^ | NR | 107 | 107 | Mean: 60.5 one group, 57.9 other group | SE 1.3 one group, 2.4 other group | NR
Cusick et al. 1990^590^ | 95 | 95 | 96 | Mean: 52 years | Range: 24 to 78 | NR
Parker et al. 1990^591^ | 103 | 103 | 103 | NR | NR | NR
| Sum | | 55,936

NR = Not Reported

Table E12 Characteristics of the breast lesions in the studies addressing Key Questions 1 and 2

Study | Number of Lesions Enrolled | % Non- palpable Lesions | Number of Non- palpable Lesions | Number of Microcalcifications | Number with Mammographic Masses | Number with Mammographic Distortions | Lesion Size | BIRADS 5 | BIRADS 4 | BIRADS 3
Jackman et al. 2009^485^ | 1,280 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Peters et al. 2008^486^ | 948 | 100% | 948 | NR | NR | NR | NR | NR | NR | NR
Schueller et al. 2008^487^ | 1438 | 100% | 0 | NR | NR | NR | Median: 17 mm Range: 5 to 55 mm | 36.0% | 50.6% | 13.4%
Sim and Kei et al. 2008^488^ | 105 | NR | NR | 105 | NR | NR | NR | 0% | 89% | 1.9%
Tonegutti and Girardi 2008^489^ | 268 | 100% | 268 | 186 | 36 | 18 | 67% were 10 mm or less | 7% | 40% | 19%
Youk et al. 2008^24^ | 4,359 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Ciatto et al. 2007^490^ | 4,035 | 67% | 2,714 | 1,887 | NR | NR | NR | NR | NR | NR
de Lucena et al. 2007^491^ | 150 | NR | NR | NR | NR | NR | 44% were 2 cm or less 52% were 2 to 5 cm | NR | NR | NR
Uematsu et al. 2007^492^ | 100 | NR | NR | 100 | NR | NR | NR | 18% | 27% | 55%
Vag et al. 2007^493^ | 70 | 63% | 44 | NR | NR | NR | Median: 12 mm Range: 5 to 35 mm | 15.70% | 33% | 51.40%
Chapellier et al. 2006^494^ | 318 | NR | NR | 288 | 30 | NR | NR | 11% | 53.50% | 34.90%
Cipolla et al. 2006^495^ | 426 | 71% | 302 | NR | NR | NR | NR | 10.10% | 10.60% | 50.20%
Dhillon et al. 2006^496^ | 150 | NR | NR | 130 | 12 | 8 | NR | NR | NR | NR
Bolivar et al. 2005^497^ | 214 | 95% | 204 | 9 | 152 | 34 | 53 lesions 1 to 10 mm 119 lesions 11 to 20 mm 32 lesions larger than 20 mm | NR | NR | NR
Crystal et al. 2005^498^ | 715 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Dillon et al. 2005^499^ | 2,427 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Koskela et al. 2005^500^ | 213 | NR | NR | 108 | NR | NR | NR | 22.10% | 56.80% | 16.40%
Sauer et al. 2005^501^ | 962 | 75% | 726 | NR | NR | NR | Mean: 2.5 cm Range: 0.2 to 11 cm | NR | NR | NR
Weber et al. 2005^502^ | 225 | 100% | 225 | NR | NR | NR | NR | NR | NR | NR
Wu et al. 2005^503^ | 113 | 27% | 30 | NR | NR | NR | Median size: 1.4 cm Range: 0.5 to 2.0 cm | NR | NR | NR
Alonso-Bartolome et al. 2004^504^ | 102 | 61% | 62 | NR | NR | NR | Mean: 14.7 mm Range: 6–30 mm | NR | NR | 100%
Delle and Terinde 2004^505^ | 169 | NR | NR | NR | NR | NR | Mean 1.5 cm | NR | NR | NR
Fajardo et al. 2004^506^ | 2,403 | 70% | 1,681 | NR | NR | NR | NR | NR | NR | NR
Kettritz et al. 2004^507^ | 2,893 | NR | NR | 2,013 | NR | 61 | 1,677 were less than 10 mm, 809 were 11 to 20 mm, and 388 were larger | 5.90% | 84.30% | 9.80%
Lomoschitz et al. 2004^508^ | 100 | 100% | 100 | 50 | 50 | NR | NR | NR | NR | NR
Abdsaleh et al. 2003^509^ | 180 | NR | NR | 15 | 130 | NR | 6 to 80 mm | NR | NR | NR
Ambrogetti et al. 2003^510^ | 364 | 100% | 364 | 326 | NR | NR | NR | NR | NR | NR
Fishman et al. 2003^511^ | 73 | 78% | 57 | NR | NR | NR | Mean: 1.7 cm Range: 0.6 to 6 cm | NR | NR | NR
Han et al. 2003^512^ | 271 | 100% | 271 | 228 | NR | NR | NR | NR | NR | NR
Kirshenbaum et al. 2003^513^ | 506 | 100% | 506 | 228 | 212 | 75 | Mean: 0.8 cm Range: 0.3 to 2.3 cm | NR | NR | NR
March et al. 2003^514^ | 34 | 71% | 24 | 3 | NR | NR | Mean: 0.7 cm Range: 0.4 to 1.2 cm | NR | NR | NR
Pfleiderer et al. 2003^515^ | 14 | NR | NR | NR | NR | NR | NR | 28.60% | 64.30% | NR
Philpotts et al. 2003^516^ | 281 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Wong and Hisham 2003^517^ | 150 | 0% | 0 | NR | NR | NR | NR | NR | NR | NR
Apesteguia et al. 2002^518^ | 132 | 100% | 132 | 82 | NR | 24 | NR | NR | NR | NR
Georgian- Smith et al. 2002^519^ | 185 | NR | NR | 159 | 16 | 5 | NR | NR | NR | NR
Jackman and Lamm 2002^520^ | 31 | 97% | 30 | 21 | 10 | NR | NR | 9.70% | 90.30% | 0%
Johnson et al. 2002^521^ | 101 | 27% | 27 | NR | NR | NR | Mean: 1.15 cm | NR | NR | NR
Liberman et al. 2002^522^ | 800 | 100% | 800 | 606 | 194 | NR | Median: 0.8 cm Range: 0.2 to 10 cm | NR | NR | NR
Meloni et al. 2002^523^ | 129 | 100% | 129 | NR | NR | NR | NR | NR | NR | NR
Morris et al. 2002^524^ | 21 | 100% | 21 | NR | 21 | NR | Mean: 1.8 cm Range: 0.8 to 5.5 cm | NR | NR | NR
Pfarl et al. 2002^525^ | 332 | NR | NR | 166 | 152 | NR | NR | NR | NR | NR
Verkooijen et al. COBRA 2002^526^ | 984 | 100% | 984 | 533 | 310 | 26 | NR | NR | NR | NR
Becker et al. 2001^527^ | 232 | NR | NR | 232 | NR | NR | NR | NR | NR | NR
Brenner et al. 2001^528^ | 1,003 | 100% | 1003 | 355 | 630 | 92 | NR | 11.10% | 39.10% | 35.70%
Cangiarella et al. 2001^529^ | 160 | NR | NR | 160 | NR | NR | NR | NR | NR | NR
Dahlstrom and Jain 2001^530^ | 310 | NR | NR | 301 | NR | NR | NR | NR | NR | NR
Lai et al. 2001^531^ | 673 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Levin et al. 2001^532^ | 70 | 100% | 70 | 27 | NR | NR | NR | NR | NR | NR
Margolin et al. 2001^533^ | 1,333 | NR | NR | NR | NR | NR | NR | NR | 94% | NR
Perez-Fuentes et al. 2001^534^ | 88 | 73% | 64 | NR | NR | NR | NR | 9.10% | 81.80% | 8.00%
Smith et al. 2001^535^ | 500 | 95% | 475 | 0 | NR | NR | Mean: 15 mm Range: 4 to 60 mm | NR | NR | NR
White et al. 2001^536^ | 1,042 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Wunderbaldinger et al. 2001^537^ | 45 | 100% | 45 | 4 | 41 | NR | Mean: 18 mm Range: 8 to 41 mm | NR | NR | NR
Yeow et al. 2001^538^ | 98 | 0% | 0 | NR | NR | NR | Mean: 2.6 cm Range: 0.9 to 10 cm | NR | NR | NR
Beck et al. 2000^539^ | 594 | NR | NR | NR | NR | NR | NR | 16.50% | 83.50% | NR
Kirwan et al. 2000^540^ | 72 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Latosinsky et al. 2000^541^ | 692 | NR | NR | 313 | 426 | 4 | NR | NR | NR | NR
Liberman et al. 2000^542^ | 155 | 0% | 0 | NR | NR | NR | Median: 1.7 cm Range: 0.5 to 15 cm | NR | NR | NR
Makoske et al. 2000^543^ | 887 | 100% | 887 | NR | NR | NR | NR | NR | NR | NR
Ward et al. 2000^544^ | 121 | 100% | 121 | 121 | NR | NR | NR | NR | NR | NR
Welle et al. 2000^545^ | 225 | NR | NR | 90 | 135 | NR | NR | NR | NR | NR
Helbich et al. 1999^546^ | 44 | NR | NR | 24 | 5 | 5 | Mean 12.9 mm Range: 8 to 27 mm | NR | NR | NR
Jackman et al. 1999^547^ | 483 | 100% | 483 | 234 | 249 | NR | NR | NR | NR | NR
Meyer et al. 1999^548^ | 1,836 | 100% | 1,836 | 643 | 1,194 | NR | NR | NR | NR | NR
Puglisi et al. 1999^549^ | 106 | 75% | 79 | 66 | 59 | NR | NR | NR | NR | NR
Soo et al. 1999^550^ | 116 | 100% | 116 | 0 | NR | NR | NR | NR | NR | NR
Caruso et al. 1998^551^ | 92 | 0% | 0 | 11 | 92 | NR | NR | NR | NR | NR
Doyle et al. 1998^552^ | 151 | 100% | 151 | 88 | 71 | 5 | NR | NR | NR | NR
Fuhrman et al. 1998^553^ | 1,440 | 100% | 1,440 | 749 | 691 | NR | NR | NR | NR | NR
Heywang- Kobrunner et al. 1998^554^ | 261 | NR | NR | 134 | 127 | NR | NR | 1.90% | 10.00% | 88.10%
Ioffe et al. 1998^555^ | 224 | NR | NR | 51 | 173 | NR | NR | NR | NR | NR
Liberman et al. 1998^556^ | 151 | 100% | 151 | NR | NR | NR | NR | NR | NR | NR
Schulz- Wendtland et al. 1998^557^ | 2,307 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Vega-Bolivar et al. 1998^558^ | 182 | 100% | 182 | 75 | 33 | 24 | NR | NR | NR | NR
Whitman et al. 1998^559^ | 12 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Zannis and AliaNo 1998^560^ | 424 | 100% | 424 | NR | 424 | NR | NR | NR | NR | NR
Bauer et al. 1997^561^ | 799 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Britton et al. 1997^562^ | 202 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Helbich et al. 1997^563^ | 210 | NR | NR | NR | NR | NR | Mean: 14 mm Range: 7 to 30 mm | NR | NR | NR
Khattar et al. 1997^564^ | 106 | 0% | 0 | NR | NR | NR | NR | NR | NR | NR
Liberman et al. 1997^565^ | 442 | NR | NR | 196 | 246 | NR | NR | NR | NR | NR
Pitre et al. 1997^566^ | 128 | 100% | 128 | NR | NR | NR | NR | 3.90% | NR | NR
Stolier et al. 1997^567^ | 244 | NR | NR | 65 | 173 | 4 | NR | NR | NR | 44.70%
Sutton, et al. 1997^568^ | 206 | 100% | 206 | 81 | 125 | NR | Mean: 14 mm Range: 2 mm to 30 mm | NR | NR | NR
Walker et al. 1997^569^ | 200 | 100% | 200 | 136 | 28 | 36 | NR | NR | NR | NR
Frazee et al. 1996^570^ | 103 | 100% | 103 | NR | NR | NR | NR | NR | NR | NR
Fuhrman et al. 1996^571^ | 451 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Head and Haynes 1996^572^ | 115 | 100% | 115 | 22 | 85 | NR | NR | NR | NR | NR
Mainiero et al. 1996^573^ | 138 | NR | NR | 138 | NR | NR | NR | NR | NR | NR
Meyer et al. 1996^574^ | 388 | 100% | 388 | NR | NR | NR | NR | NR | NR | NR
Nguyen et al. 1996^575^ | 431 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Pettine et al. 1996^576^ | 25 | 100% | 25 | NR | NR | NR | NR | NR | NR | NR
Rosenblatt et al. 1996^577^ | 58 | NR | NR | 22 | 14 | NR | Median: 1.5 cm Range: 0.8 to 3.0 cm | NR | NR | NR
Scopa et al. 1996^578^ | 120 | NR | NR | NR | NR | NR | Range: 0.7 to 5 cm | NR | NR | NR
Cross et al. 1995^579^ | 250 | 100% | 250 | NR | NR | NR | NR | NR | NR | NR
Doyle et al. 1995^580^ | 365 | 62% | 225 | 59 | 225 | | Larger than 5 mm | NR | NR | NR
Hamed et al. 1995^581^ | 122 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Burbank et al. 1994^582^ | 105 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Gisvold et al. 1994^583^ | 160 | NR | NR | NR | NR | NR | Range: 3 to 70 mm | NR | NR | NR
Parker et al. 1994^584^ | 6,152 | 93% | 5,702 | 1,637 | 4,515 | | NR | NR | NR | NR
Smyth and Cederbom 1994^585^ | 58 | 100% | 58 | NR | NR | NR | NR | NR | NR | NR
Elvecrog et al. 1993^586^ | 100 | 100% | 100 | 26 | 100 | | NR | NR | NR | NR
Parker et al. 1993^587^ | 181 | 46% | 84 | NR | NR | NR | NR | NR | NR | NR
McMahon et al. 1992^588^ | 151 | 0% | 0 | NR | NR | NR | NR | NR | NR | NR
Barreto et al. 1991^589^ | 107 | 0% | 0 | NR | NR | NR | NR | NR | NR | NR
Cusick et al. 1990^590^ | 96 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Parker et al. 1990^591^ | 103 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Sum | 55,936 | | 25,760 | 13,303 | 11,186 | 421

NR = Not Reported

Table E13 Studies of the dissemination of cancerous cells during biopsy procedures

Reference | Design of Study | Number of Patients | Biopsy Methods | Conclusion
Michalopoulos et al. 2008^33^ | Prospective study. Patients underwent core-needle biopsy followed by open surgery 6–8 days later. The needle track was excised and examined by a pathologist. | 21 with DCIS and 10 with invasive ductal carcinoma | Vacuum-assisted 11G Mammotome device | No cases of dissemination of cancerous cells were observed. In two cases benign epithelial displacement was observed. The duration of the core-needle procedure was significantly longer in these two cases than for cases with no displacement observed.
Uematsu and Kasami 2007^96^ | The exterior of the core needles was washed immediately following withdrawl and the washings were examined for cells. | 207 | US-guided 18G automated Bard Magnum gun | 65% of the washings were positive for cells. Lesions diagnosed as invasive lobular carcinoma were significantly less likely to have had cells in the washings than lesions diagnosed as DCIS or invasive ductal carcinoma. Biopsies that had been performed using multiple passes were slightly but not significantly more likely to yield cells in the washings than biopsies performed with a single pass.
Fitzal et al. 2006^110^ | Retrospective case-control study of patients treated with breast-conserving surgery and radiotherapy, with or without chemotherapy/hormonal therapy. | 189 with preoperative core-needle biopsy, 530 without preoperative core-needle biopsy | 14G or 11G; stereotactic or US guidance; vacuum-assisted or not. | In patients with preoperative core-needle biopsy, the local recurrence rate was 1.1% with a median followup of 78 months (range 46 to 108 months); the mortality rate was 0%. In patients without preoperative core-needle biopsy, the local recurrence rate was 2.1% with a median followup of 71 months (range 8 to 128 months); the mortality rate was 4.7%.
Newman et al. 2006^130^ | Retrospective chart review of women who underwent sentinel lymph node biopsy | 279 with core-needle biopsy, 41 with fine-needle biopsy, and 217 with open excisional biopsy | Not described | The method of biopsy did not correlate with metastasis to the sentinel lymph node; however, patients who underwent excisional biopsy were more likely to have micrometastases to the sentinel lymph node than patients who underwent needle biopsies.
Uriburu et al. 2006^139^ | Case report | 3 | 14G under stereotactic guidance | Three women treated with skin-sparing mastectomy are reported on. All three developed recurrences of their breast tumors at the core-needle biopsy scar. Two of the three had invasive ductal carcinomas and one had a mucinous carcinoma.
Hansen et al. 2004^188^ | Retrospective chart review of women who underwent sentinel lymph node biopsy | 126 with fine-needle biopsy, 227 with core-needle biopsy and 323 with open excisional biopsy | 11 or 14G, under stereotactic or US guidance | The incidence of metastases to the sentinel lymph node was significantly higher in women who underwent needle biopsies compared to women who had excisional biopsy.
Hoorntje et al. 2004^190^ | Prospective study. Patients underwent core-needle biopsy followed by open surgery a mean of 21 days later. The needle track was excised and examined by a pathologist. | 13 | 14G automated device Bard under stereotactic guidance | Needle tracks were visible in 11 cases, and of these, 7 had displaced cells in the needle track.
Peters-Engl et al. 2004^195^ | Retrospective review of women who underwent sentinel lymph node biopsy | 1,048 with fine-needle or core-needle biopsy, 842 with open excisional biopsy | Not described | Patients who had undergone a needle biopsy had a 1.37 times increased risk of metastases to the lymph nodes, but after adjusting for known risk factors of axillary node metastases this result was overturned, 1.09 times increased risk (95% CI: 0.85% to 1.40%).
Chen et al. 2002^244^ | Retrospective review of women treated with breast-conserving surgery and radiation therapy | 86 with core-needle biopsy, 465 with open excisional biopsy | 14G Bard device or 11G vacuum-assisted device Mammotome, all under stereotactic guidance | At a mean followup of 4.9 years (range 2.0 to 8.9 years), tumor recurrence rate was 2.3% in the core-needle group and 7.7% in the open biopsy group.
Knight et al. 2002^256^ | Retrospective review of women treated with breast-conserving surgery; 78.6% had radiation therapy as well | 297 with core-needle biopsy, 101 with open excisional biopsy | 14G Bard device under stereotactic or ultrasound guidance | At a mean followup of 29.7 months (range: 2 to 90 months), 3.7% of the patients with core-needle biopsy had a tumor recurrence compared to 3.96% of patients with open biopsy who had a tumor recurrence.
Chao et al. 2001^282^ | Case report | 3 | 14G under stereotactic guidance | Two of the patients developed tumor recurrences at the site of the core-needle biopsy; the third patient had the needle track excised 1 month after biopsy and cancer cells were detected in the needle track. None of the patients received radiation therapy for the primary tumor.
King et al. 2001^295^ | Retrospective review of women diagnosed with breast cancer by either core-needle biopsy or wire-localized open excisional biopsy and then treated with breast-conserving surgery; 91% had radiation therapy as well | 132 with core-needle biopsy, 79 with open excisional biopsy | 14G under US or stereotactic guidance | At a median followup of 44.4 months, 3.0% of patients with core-needle biopsy had tumor recurrences; at a median followup of 50.1 months, 2.5% of patients with open biopsy had tumor recurrences.
Stoller et al. 2000^342^ | Prospective study. Patients underwent core-needle biopsy followed by open surgery a mean of 10.5 days later. The needle track was excised and examined by a pathologist. | 89 | 14 or 11G, stereotactic or US guidance, multiple puncture or vacuum-assisted | 2 patients had tumor cells in the needle tract. One of these patients had a local tumor recurrence 34 months after surgery at the biopsy site. Both of these patients had multiple puncture core-needle biopsies and no radiation treatment.

US = Ultrasound

Table E14 Surgical procedures avoided

Reference | Design of Study | Number of Patients | Biopsy Methods | Conclusion
Friese et al. 2009^592^ | Analysis of data from the SEER data of women diagnosed with DCIS or stage I/II breast cancer between 1991 and 1999 | 45,542 | Needle or surgical | Needle biopsy use was associated with a reduced likelihood of multiple breast surgeries (odds ratio 0.35, 95% CI: 0.34 to 0.37)
Altomare et al. 2005^145^ | Retrospective chart review of patients with nonpalpable breast lesions who underwent core-needle biopsy between January 2001-January 2004. | 591 | US- or stereotactic-guided vacuum-assisted biopsy (Mammotome) 11-gauge needle or ABBI | Core-needle biopsy spared a surgical procedure for 128 cancer patients and 134 non-cancer patients, but did not spare a procedure in 17 women
Bolivar et al. 2005^497^ | Prospective case series of patients with non-palpable suspicious breast lesions who underwent core-needle biopsy from August 1997–August 2001. | 198 | US-guided (7.5 MHz linear array transducer) using a freehand technique with patient in supine or supine oblique position. | Core-needle biopsy spared 155/198 (or 78%) women a surgical procedure.
Chapellier et al. 2005^494^ | Prospective case series of the first 318 aspiration-guided macrobiopsy procedures performed at one institution. The majority of patients had microcalcifications; approximately 50% were BIRADS 4 while 35% were BIRADS 3 but had risk factors. | 301 | Fischer stereotactic imaging table, vacuum-assisted biopsy (AND). | 128 BIRADS 4 patients and six BIRADS 5 patients were spared an additional operation by use of core-needle biopsy.
Carmon et al. 2004^176^ | Retrospective chart review of patients with nonpalpable breast lesions who were ultimately operated on for primary breast carcinoma between 1997-mid-2001. | 167 | Percutaneous image-guided core biopsy | From 1997 to 2001, the percent of patients requiring a second operation decreased from 56.2% to 11.1%, with increased availability of a preoperative diagnosis. 79.2% of subjects with a preoperative diagnosis of invasive duct carcinoma had axillary lymph node dissection vs. 37.7% of those without a preoperative CNB diagnosis.
Apesteguia et al. 2002^518^ | Prospective consecutive case series of patients with nonpalpable breast lesions non-visible or non-accessible by US. | 126 | Vacuum-assisted core biopsy on a digital stereotaxic table with an 11-gauge needle. | Second surgical procedures due to involved margins were required in 17.4% of cases and 5 additional lymphadenectomy procedures were needed based on core-needle biopsy’s inability to predict invasion.
Liberman et al. 2002^522^ | Retrospective study. Rate of spared surgical procedures was compared for those whose lesion was completely excised compared to those whose lesion was only sampled. | 800 (565 calcifications, 194 mass, 41 both) | Vacuum-assisted core biopsy (Mammotome) with 11-gauge needle | 466 lesions were totally removed by the core-needle procedure. Surgery was spared in 80.6% of lesions. There was not a significant difference between the excised versus sampled lesion groups in spared surgery rates (81.5% vs. 82%, p = 0.95).
Becker et al. 2001^527^ | Retrospective chart review of lesions with indeterminate microcalcifications | 218 | DMR regular mammography machine plus either a Stereotix 2 conventional add-on unit or a SenoVision digital add-on unit. Core-needle biopsy was performed with a 14-gauge needle in all but 5 cases (in which a 16-gauge needle was used) | Open biopsy was avoided in 78 (69.6%) of patients in the conventional treatment group and in 78 (73.6%) of the digital treatment group.
Liberman et al. 2001^298^ | Retrospective review of women with calcifications highly suggestive of malignancy who underwent a diagnostic biopsy procedure from 1993–2000. | 139 | Stereotactic vacuum-assisted biopsy with 11 or 14-gauge needle | The mean number of surgical procedures was 1.2 and 1.6 for core-needle biopsy vs. surgical biopsy. 62% of surgical biopsy patients overall and 83.8% of diagnostic surgical biopsy with cancer needed two procedures. The likelihood of requiring a single operation was greater for women who had core-needle biopsy. A surgical procedure was spared in 58.4% of this group.
Perez-Fuentes et al. 2001^534^ | Prospective case series of patients seen between August 1998-December 2000 with palpable or nonpalpable breast masses | 83 | US-guided vacuum-assisted biopsy (Mammotome) with 11-gauge needle | Of the 83 patients studied, 79 were spared a surgical procedure (95.2%).
Verkooijen et al. 2001^593^ | Prospective comparison of patients with nonpalpable breast lesions | 164 | Patient prone, 14-gauge needle | In 75% of core-needle cases, only a single surgical procedure was needed, while this was true in only 16% of open biopsy cases (p <0.001). Mean number of surgical procedures was 1.31 vs. 1.91 (p <0.001) in the core-needle and open biopsy groups, respectively.
Liberman et al. 2000^542^ | Retrospective chart review of patients with breast masses that were palpable on physical examination from 1992 to 1998. | 107 | Stereotactic- or US-guided core biopsy with a 14-gauge needle. | Core-needle biopsy spared 74% of subjects in this study an additional diagnostic tissue sampling
Morrow et al. 2000^305^ | Prospective nonrandomized comparative study of patients with nonpalpable mammographically-detected abnormalities | 1,550 | Core-needle or open biopsy | Among those with cancer, a single procedure was performed in 33% of the excisional biopsy subjects versus 84% of the core-needle group (p <0.001). The core-needle group consistently had a larger proportion of subjects treated with a single procedure, regardless of lesion type: for architectural distortions 71% vs. 46% and for highly suspicious lesions 83% vs. 45%.
Al-Sobhi et al. 1999^346^ | Retrospective review of patients found to have cancer | 67 | Vacuum-assisted with an 11 or 14-gauge needle | The number of surgical procedures performed in an operating room differed significantly for the two groups overall (CNB mean 1.1 ±0.3 and wire localization mean 1.8 ±0.4). For the subset who underwent breast-conserving treatment a significant difference between groups was also evident, mean surgical procedures were 1.2 ±0.4 and 2.1 ±0.2, respectively.
Williams et al. 1999^384^ | Prospective case series of patients with impalpable breast lesions diagnosed by stereotactic CNB on a prone table vs. a historical cohort of patients with similar lesions diagnosed prior to the use of prone stereotactic CNB. | 222 | Stereotactic prone core-needle with Mammotest and 14-gauge needle. | More patients in the prone group required only a single operation (p <0.03). The average number of operations was 1.33 (SE 0.053) vs.1.47 (SE 0.054) in the prone and control groups, respectively.
Johnson et al. 1998^395^ | Retrospective review of patients with malignant-appearing microcalcifications without an associated parenchymal abnormality on mammography. | 167 | Stereotactic biopsy was performed using Lorad Stereotactic prone biopsy table with 14-gauge needle. Digital mammography was used to localize the lesions. US biopsies were performed using a 7.5 MHz probe with real-time imaging using the same CNB device. | The mean number of procedures required until definitive treatment was 2.4 and 1.7 for the initial IGBB and initial NLOB, respectively (p = 0.0002)
Kaufman et al. 1998^396^ | Retrospective review of consecutive mammographically-detected nonpalpable breast lesions ultimately diagnosed as in situ or invasive carcinoma. | 113 | Core-needle or open biopsy | Negative margins were achieved twice as often in the core-needle group as in the open biopsy group after the first surgical procedure (77% vs. 38%, p <0.001). A one-stage surgical procedure was possible in many more of the core-needle patients than in the open biopsy group (79% vs. 21%, p <0.001). On average, 2.2 procedures (surgery and biopsy) were needed in the core-needle group vs. 1.8 among the open biopsy patients. However, the average number of surgeries was 50% higher in the open biopsy group (1.8 vs. 1.2).
Liberman et al. 1998^556^ | Retrospective review of patients with nonpalpable breast masses. | 151 | US-guided biopsy was performed in the supine or supine oblique position using high resolution (7.5 MHz linear array transducer) equipment with a 14-gauge cutting needle. | 85% of patients in this study were spared a surgical procedure by use of core-needle biopsy.
Lind et al. 1998^402^ | Retrospective review of patients with mammographically-detected breast cancer that underwent breast-conserving surgery | 117 | Biopsies were performed on a dedicated prone table with 14-gauge needle | Only 6% of patients in the core-needle group had positive margins vs. 55% of the open biopsy patients (p <0.01). One patient with positive margins in the core-needle group was re-excised vs. 34/38 of those with positive margins in the open group (p <0.01).
Fenoglio et al. 1997^419^ | Retrospective chart review of patients with mammographically-detected breast cancer | 40 | 14-gauge long throw Biopty gun plus Mammotest Stereotactic System | All 20 patients diagnosed with core-needle biopsy required one surgical procedure only whereas among the 20 initially diagnosed with open biopsy a total of 41 procedures were required to diagnose and treat their cancers
Liberman et al. 1997^428^ | Retrospective chart review of nonpalpable breast cancers | 197 | Stereotactic CNB were done with patient in prone position using StereoGuide; sonographically-guided CNB were done with patients in supine or supine oblique using a 7.5 MHz linear array transducer and high resolution sonographic equipment; all CNB used a 14-gauge needle or an ultra-core biopsy needle. | 84% of patients in the CNB group underwent a single surgical procedure vs. 29% of those diagnosed by surgical biopsy (p <0.00001). 16% of the CNB patients required two surgical procedures while 66% of the open-biopsy patients needed two surgeries and 5% underwent three surgical procedures.
Smith et al. 1997^433^ | Retrospective review. | 677 | US-guided Mammotest (67) or wire localized excisional biopsy (610) | On average, 1.25 surgical procedures were required by the core-needle group versus 2.01 in the surgical biopsy group (p <0.001).
Sutton et al. 1997^568^ | Retrospective review of patients with nonpalpable mammographic abnormalities detected at routine screening in a community-based clinic. | 200 | Biopsies were performed on a dedicated prone stereotactic table (Mammotest) with an autoguide attachment and 14-gauge 22 mm-throw Bard Biopty-cut needles held in a Bard Biopty gun. | The authors estimated that open biopsy was avoided in 82% of cases by using core-needle biopsy for diagnosis.
Whitten et al. 1997^435^ | Retrospective review | 171 | Stereotactic- or US-guided biopsy with a 14-gauge needle | Among the 86 subjects diagnosed by image-guided core-needle biopsy, 98 surgical procedures were completed (1.1 surgeries per patient) compared with 1.9 operations on average for the 85 patients undergoing a diagnostic needle localized biopsy (157 surgeries total in 85 subjects).
Yim et al. 1996^454^ | Retrospective review | 52 | Stereotactic biopsy with a 14-gauge needle was performed on a dedicated prone table | At the time of excision, surgical margins were more frequently positive in the open biopsy group (55%) vs. the CNB group (0%); the distance of the tumor from the surgical margin was greater for the CNB vs. open biopsy patients among the negative margins; and, among those having breast conservation surgery, the rate of re-excision was higher for the open biopsy group (74%) vs. no patients in the CNB treatment group.
Liberman et al. 1995^458^ | Retrospective chart review of patients with impalpable speculated masses. | 43 | Biopsies were performed with patients prone on a dedicated table using either a 14-gauge Bard Biopty needle or a 14-gauge Manan needle and either a Bard Biopty gun with 23 mm throw or Manan ProMag 2.2 gun with a 22 mm throw. | The use of core-needle biopsy in the diagnosis of breast cancer reduced the number of procedures required in 33 (77%) patients.
Strong et al. 1995^463^ | Prospective study of patients with mammographically-detected, asymptomatic, nonpalpable breast lesions | 97 | Mammotest stereotactic device using 14-gauge Manan needle. | In eight benign cases, open biopsy was performed, adding an extra procedure to the diagnostic protocol for these patients. However, 74 women (76%) were spared an open biopsy by core-needle biopsy. As the 15 women with carcinoma went directly to mastectomy without an open biopsy, core- needle biopsy did not add a diagnostic procedure in these cases.
Elliott et al. 1992^479^ | Retrospective review of 12-month period of patients with nonpalpable breast lesions. | 115 | Mammotest II with 18-gauge Bard biopsy needle using Bard Biopty gun | Core-needle biopsy spared 97 patients an open surgical biopsy.

Table E15 Patient procedure preference

Reference | Design of study | Number of patients | Biopsy methods | Conclusion
Duschesne et al. 2007^61^ | Prospective trial of new device | 113 | US-guided radiofrequency tipped vacuum-assisted with 9-gauge needle (SenoCor 360 Biopsy System). | They rated patient comfort as equivalent with other types of biopsies.
Krainick-Strobel et al. 2007^73^ | Prospective case series of patients with benign lesions undergoing biopsy for the purpose of complete extirpation. | 45 | Hand-held US-guided vacuum-assisted biopsy (Mammotome) using either an 8- or 11-gauge needle. | Ninety-five percent of respondents said they would prefer core-needle to open excisional biopsy if they needed a future procedure. A minimum of 7 days post- procedure, patients were given a questionnaire about their experience. The mean level of satisifaction with the procedure, on a scale of 0–10, was 9.2 (range 3–10).
Killebrew et al. 2006^120^ | Retrospective comparison study of patients with BIRADS 4 or 5 and mammographic lesions presenting as microcalcifications. | 1600 | Vacuum-assisted procedure (Mammotome) with 11-gauge needle vs. vacuum-assisted intact specimen biopsy with 10 or 15 mm probe. | Self-reports by patients showed that those undergoing both treatments tolerated their respective procedures equally. Patients were asked to rate the biopsy procedure for comfort and to rate comfort of lying on stereotactic table, as a comparison. In the vacuum- assisted arm, ratings of 5.8 and 2.0 (with 10 = extreme pain) were given for lying on table and actual biopsy procedure, respectively. In the other group, the ratings were 4.1 and 1.9, respectively.
Chapellier et al. 2005^494^ | Prospective case series of the first 318 aspiration-guided macrobiopsy procedures performed at one institution. The majority of patients had microcalcifications; approximately 50% were BIRADS 4 while 35% were BIRADS 3 but had risk factors. | 301 | Fischer stereotactic imaging table, vacuum-assisted | Patient tolerance of procedure was excellent, as measured by a self-administered patient questionnaire. The authors also found that the post- procedure psychological state was associated with the procedure outcome, the information given to patients and the attitudes of medical staff members.
Weber et al. 2005^502^ | Retrospective comparison study of patients with nonpalpable breast lesions | 387 | Stereotactically-guided vacuum-assisted (Mammotome) technique with 11-gauge needle or ABBI | Three patients in this series underwent both procedures but they did not indicate a preference for one over the other.
Wong et al. 2005^171^ | Prospective trial of Asian patients with nonpalpable mammographic abnormalities | 114 | Vacuum-assisted (Mammotome) on a prone biopsy table with 8- to 11-gauge needle | Bruising (one week post- procedure) occurred in 79 patients (46 minimal, 25 mild, 5 moderate and 3 severe). All patients were able to be discharged after 2–3 hours following the procedure and all reported the procedure was acceptable without undo discomfort.
Alonso-Bartolome et al. 2004^504^ | Prospective study of women with probably benign breast lesions who refused radiologic followup and, instead, insisted on removal. Complete lesion removal was the intended goal for all lesions. | 97 | US-guided vacuum-assisted biopsy (Mammotome) with 11-gauge needle | Patients estimated that the time lost to core-needle biopsy is less than 20% of the time required for a surgical biopsy.
Geller et al. 2004^183^ | Survey of women with nonpalpable breast lesions | 315 | US-guided core-needle biopsy or open excisional biopsy | Survey results 1–3 months post procedure measured convenience of the procedure (distance travelled, procedure time, and number of days of work missed post procedure). No difference was found between two groups in terms of miles travelled for procedure, but the excisional biopsy group missed more work.
March et al. 2003^514^ | Prospective study of women with breast masses who underwent biopsy in which complete removal of the lesion was attempted. | 34 | US-guided vacuum-assisted biopsy with an 11-gauge biopsy device | Radiologists examined the biopsy site 2–5 days post- procedure and found 24 subjects (71%) had ecchymosis, nine (26%) had no visible abnormality aside from the skin incision and one (3%) had slight skin convexity without ecchymosis at the biopsy site. Twenty-one subjects who did not undergo an open procedure were examined at 6 months post core-needle biopsy. All 21 said they would recommend the procedure to others.
Mariotti et al. 2003^228^ | Retrospective study of patients with suspicious non palpable mammographic lesions not confirmed by ultrasonography. | 360 | Vacuum-assisted (Mammotome) with an 11-gauge needle or ABBI | Patient acceptance of the biopsy procedure was high.
Fine et al. 2003^217^ | Women with low risk palpable masses were assessed prospectively. | 216 | Vacuum-assisted (Mammotome) with US guidance with either an 8- or 11-gauge probe | A majority of patients stated that they would recommend the procedure to others in a survey conducted 10 days post-procedure (82% and 92%, respectively). By the 6-month follow-up visit, 100% stated they would recommend the procedure to others, while 97% stated they themselves would have the procedure again, if needed.
Chun et al. 2002^245^ | Retrospective review and survey of patients who had undergone a Mammotome, ABBI or wire localized biopsy more than 2 years ago for benign disease. | 59 | Stereotactic vacuum-assisted 11-gauge (Mammotome) or stereotactic excisional biopsy with ABBI (15 or 20 mm cannula) or wire localized open biopsy | The biopsy experience was rated as satisfactory by 90%, 75% and 80% of patients in the open, ABBI, and Mammotome groups, respectively. Complaints about the procedures included uncomfortable (2 Mammotome, 4 ABBI), pain (2 each open and Mammotome), painful breast compression (3 ABBI), delay in getting results (1 each Mammotome and ABBI), rude doctors (2 Mammotome) and length of procedure (1 open).
Hui et al. 2002^252^ | Prospective case series of patients with nonpalpable breast lesions requiring a biopsy procedure. | 79 | Stereotactic-guided breast biopsy (StereoGuide with Digital Spot Mammography): Trucut with a 14-gauge needle, vacuum-assisted (Mammotome) with 11-gauge probe | 31.6% of patients were very satisfied with the procedure; 73.7% felt the level of pain associated with the biopsy was less severe than erect mammography; 34.2% felt the pain experienced was less severe than needle pricking; and 14.5% felt it was less severe than previous free- hand or ultrasound-guided breast biopsy.
Beck et al. 2000^539^ | Retrospective review of first experience using vacuum- assisted core-needle biopsy. | 560 | Digital stereotaxic biopsy table, vacuum-assisted (Mammotome) with 11-gauge needle. | A majority of patients tolerated the procedure well.
Gukas et al. 2000^326^ | Prospective study of 112 consecutive patients with palpable breast lesions | 108 | Tru-Cut and excisional biopsies. | A majority of patients, 90.7%, accepted the procedure. The authors note that patients experienced more apprehension about the procedure than actual discomfort.
Welle et al. 2000^545^ | Retrospective review of patients who underwent a stereotactic CNB in a decubitus or recumbent position from September 1995-March 1999. | 225 | Stereotactic-guided core- needle biopsy in a decubitus or recumbent position. | Two patients out of the 225 had experienced a traditional prone position CNB and both stated they preferred the decubitus position, preferring to lie on their sides. Overall, 29% of patients reported mild discomfort or numbness in the dependent arm with the decubitis or recumbent position.
Doyle et al. 1999^552^ | Retrospective study of patients with mammographically-detected lesions | 151 | Senographe 600T was used for 136 biopsies; 15 using Mammomat 3000; all in decubitus position unless the patient couldn’t tolerate that positioning and with a 14-gauge needle. | 90% of subjects were able to tolerate the decubitus position although some developed discomfort in the dependent arm and required supporting the arm away from the body on a chair or small trolley.
Helbich et al. 1998^393^ | Prospective randomized study of consecutive patients with indeterminate or suggestive lesions on mammography | 64 | Mammotest stereotactic system with 13-gauge coaxial needle. | Author reports that all patients tolerated the procedure well.
Handy et al. 1996^445^ | Prospective survey of patients. Patients completed a pre-procedure survey, one immediately after the procedure, one 24 hours post-procedure and 5 days later. | 58 | StereoGuide SM Breast Biopsy System with 14-gauge needle. The majority of patients were in a prone position. | 67% of patients reported that they understood the procedure they were about to undergo. Immediately after the procedure, 78% said they understood the procedure but the remainder still felt they did not understand it. Five of those who initially thought they understood decided they really had not after experiencing it. 38% said the clinic nurse/technologist was the best source of information about the procedure, 26% said it was the physician, 15% said there was no good source of information available to them and 21 said other (books, friends, popular media). Pre-procedure, 79% were most concerned about the results of the biopsy while 10% were most concerned about the procedure itself. 31% reported none or slight anxiety about the impending procedure, 60% said they were mild to moderately anxious and 9% were extremely anxious. Five days post procedure, 97% said they would have the procedure again in the future, if needed.
Elliott et al. 1992^479^ | Retrospective review of 12 month period | 115 | Mammotest II with 18-gauge Bard biopsy needle using Bard Biopty gun | The authors explain that patients are very accepting of the CNB procedure and found the test easy to perform in the office.

US = Ultrasound

Table E16 Cosmetic outcome

Reference | Design of Study | Number of Patients | Biopsy Methods | Conclusion
Krainick-Strobel et al. 2007^73^ | Prospective case series of patients with benign lesions undergoing vacuum-assisted biopsy for the purpose of complete lesion removal | 45 | Hand-held ultrasound-guided vacuum-assisted CNB biopsy (Mammotome) using either an 8- or 11-gauge needle. | Ninety-five percent of respondents said they would prefer CNB to open excisional biopsy if they needed a future procedure. A minimum of seven days post-procedure, patients were given a questionnaire about their experience. All patients said that the scar from the needle was cosmetically unimportant to them and, on a scale of 0–10, their mean level of satisfaction with CNB was 9.2 (range 3–10).
Weber et al. 2005^502^ | Retrospective comparison study of patients with impalpable breast lesions undergoing either Mammotome or ABBI | 387 | Stereotactically-guided vacuum-assisted CNB biopsy (Mammotome ) technique with 11-gauge needle or ABBI | Incomplete satisfaction with the cosmetic result occurred at a higher rate in the ABBI group (6.7% vs. 1.3%, p = 0.03).
Wong et al. 2005^171^ | Prospective trial of Asian patients with nonpalpable mammographic abnormalities underwent either ABBI (N = 7) or Mammotome (N = 107). | 114 | CNB was performed on a prone biopsy table with vacuum-assisted CNB (Mammotome) with 8- to 11-gauge needle or ABBI. | Bruising (one week post- procedure) occurred in 79 patients (46 minimal, 25 mild, 5 moderate and 3 severe) and at one-month followup a scar was visible in 79 patients (40 minimal, 32 mild, 7 moderate, 0 severe).
Mariotti et al. 2003^228^ | Retrospective study of patients undergoing either ABBI or Mammotome from June 1999-December 2001 for suspicious non palpable mammographic lesions not confirmed by ultrasonography | 360 | Vacuum-assisted CNB (Mammotome) with 11-gauge needle or ABBI | Both surgeons and patients were pleased with the cosmetic outcome.
March et al. 2003^514^ | Prospective study of women with breast masses who underwent CNB in which complete removal of the lesion was attempted. | 34 | Ultrasound-guided vacuum- assisted CNB with an 11-gauge biopsy device | The twenty-one subjects who did not undergo an open procedure following CNB were examined at 6 months post-CNB. Nineteen (90%) were very satisfied with appearance of biopsy area, 2 were satisfied and none were dissatisfied. Sixteen were very satisfied with how the biopsy area felt, 5 satisfied, none dissatisfied. At 6-month follow-up examination, four (19%) had no visible scar, 17 (81%) minimal scarring = 2–9 mm, none had skin retraction concavity, convexity, or other changes in breast contour.
Fine et al. 2003^217^ | Women who underwent CNB for low risk palpable masses were assessed prospectively. | 216 | Ultrasound-guided vacuum-assisted handheld biopsy device (Mammotome) with either an 8- or 11-gauge needle | A majority of patients were both satisfied with the appearance of their incisions and stated that they would recommend the procedure to others in a survey conducted 10 days post-procedure (82% and 92%, respectively). By the 6-month follow-up visit, 100% were happy with the incision’s appearance and would recommend the procedure to others, while 97% stated they themselves would have the procedure again, if needed.
Kettritz et al. 2003^594^ | Retrospective analysis of patients who underwent a CNB between January 1996- June 2000 for indeterminate lesions and microcalcifications. | 2874 | Vacuum-assisted CNB on a digital prone table (Mammotest) with an 11-gauge needle. | Scarring at the latest postbiopsy visit was graded as not relevant (86%), slight (14%) or relevant (0.3%).
Chun et al. 2002^245^ | Retrospective review and survey of patients who had undergone a Mammotome, ABBI or wire localized biopsy more than 2 years ago for benign disease, 20 patients per group. | 59 | Stereotactic vacuum-assisted CNB biopsy (Mammotome) with 11-gauge needle or stereotactic excisional biopsy with ABBI (15 or 20 mm cannula) or wire localized open biopsy | Patients were asked to rate the appearance of their scar, if they were satisfied with the biopsy procedure, and which mattered most to them, complete lesion removal or scar appearance. Ninety-five percent of the core-needle biopsy group and only 25% of the open biopsy group were very satisfied with the appearance of their breast. None of the core-needle biopsy group said the cosmetic results were unacceptable compared to 20% of the open biopsy group who found the results unacceptable. Overall, eighty percent of subjects were more concerned with complete lesion removal than scar appearance.
Perez-Fuentes et al. 2001^534^ | Prospective case series of patients seen between August 1998-December 2000 with palpable or nonpalpable breast masses diagnosed with CNB. | 83 | Ultrasound-guided vacuum-assisted CNB (Mammotome) with 11-gauge needle | No scarring was evident at followup.
Beck et al. 2000^539^ | Retrospective review of first experience using vacuum- assisted CNB | 560 | Digital stereotaxic biopsy table and vacuum-assisted CNB (Mammotome) 11-gauge needle. | In 90% no scar was visible at final followup.

CNB = Core-needle Biopsy

Table E17 Physician experience

Reference | Design of Study | Number of Patients | Biopsy Methods | Conclusion
Duschesne et al. 2007^61^ | Prospective trial of new device used on patients already scheduled for CNB between December 2002–April 2003. | 113 | US-guided radiofrequency tipped vacuum-assisted CNB with 9-gauge needle (SenoCor 360 Biopsy System). | Operators of the new device rated it in terms of ease of penetration, positioning and holding the device, acquiring a satisfactory specimen, positioning accuracy, safety, and patient comfort and compared it to existing spring and vacuum devices based on their past experiences with these. All operators of the study device were experienced in US breast biopsy techniques. Operators found the new device to be equivalent to 14-gauge biopsy devices but superior to other vacuum-assisted devices in terms of penetration of the lesion and positioning of the device at the desired location. They rated patient comfort as equivalent with other types of biopsies.
Holloway et al. 2007^67^ | Retrospective review of patients with breast abnormality seen between April 2002–December 31, 2002 who were diagnosed by CNB or fine-needle aspiration and/or surgery as the initial procedure in Ontario Canada. | 17,068 | Fine-needle aspiration or CNB or mastectomy | Differences in the availability of the CNB (specialized expertise) may account for some of the geographic variation in how often women received a needle-biopsy procedure rather than proceeding immediately to open surgery.
Liberman et al. 2007^80^ | Retrospective chart review of patients who had lesions detected with MRI and then had an MRI-guided CNB | 237 lesions | MRI-guided vacuum-assisted CNB with a 9-gauge needle | The median number of previous MRI-guided CNB performed by the radiologists was 21 (Range: 1–55).
Hoffman 2005^115^ | To compare the quality of service at a clinic only partially staffed with breast specialists in 1998 to the same clinic in 2003 after it had become fully specialized. Technologically, the only change in diagnostic equipment in that time period was more sophisticated US scanners, which were used in a majority of 2003 procedures but only a small percent of 1998 procedures. | 5,451 | CNB vs. excisional biopsy | Over time, excisional biopsy was used less, more women had breast-conserving surgery and complication rates decreased. It is the author’s conclusion that a dedicated, specialized breast care center improved the quality of care.
Lehman et al. 2004^160^ | Retrospective review of consecutive patients with nonpalpable lesions not clearly visible on mammography or targeted sonography, many of whom had recently been diagnosed with breast cancer. | 28 | MRI-guided vacuum-assisted CNB with the ETEC Breast Biopsy and Excision System. | The experience level of those performing the procedures was low, with half having no prior experience and the other half having one month of experience performing the procedure only (although they had one year of experience with MRI-guided CNB).
Popiela et al. 2002^263^ | Retrospective review of asymptomatic women without pathological resistance on physical examination but with breast pathologies below 0.5 cm confirmed by complementary examination. | 122 | Vacuum-assisted CNB (Mammotome) biopsy with either ultrasonography or digital mammography guidance | The authors contend that a lack of experience, rather than a problem with the equipment, explains problems encountered early on in precise targeting and complete removal of the lesion.
Schneider et al. 2001^312^ | Prospective case series of patients undergoing a new unilateral MR-guided breast lesion localization and core biopsy system. | 14 | MR image guidance CNB using a mechanical needle guide and trajectory planning software with 14-gauge needle. | The authors report that the new device is intuitive and easy to use as well.
Wunderbaldinger et al. 2001^537^ | Prospective nonconsecutive first-experience case series of patients with nonpalpable breast lesions diagnosed by CNB followed by surgical excision. | 45 | New dedicated US system for computer-guided CNB (Sonopsy) with a 14-gauge needle. | The authors also comment that this new device may hold promise for non-skilled physicians.
McMahon et al. 1992^588^ | Prospective randomized trial of consecutive patients with palpable breast lumps. Patients were randomized to percutaneous biopsy using Tru-Cut 14-gauge needle, Biopty-cut 14-gauge needle or a Biopty-cut 18-gauge needle. | 151 | Biopty-cut needles were used with the Biopty gun. A standard technique was used for the Tru Cut. | Tru Cut’s poor performance (sensitivity 68%) may be related to the fact that eight different surgeons performed the 49 Tru Cut biopsies included in this study whereas the Biopty gun, with an absolute diagnostic sensitivity of 92%, may be less dependent on operator experience.
Parker et al. 1990^591^ | Prospective case series of consecutive patients referred for biopsy of nonpalpable mammographically-suggestive lesions. Subjects underwent CNB followed by wire localization and excisional surgery. | 103 | 14-, 16-, or 18-gauge Biopty-cut needles were used in conjunction with a Biopty gun. The first 30 patients were treated with Senographe Mammographic System 600T coupled with Stereotix computerized stereotactic needle localization device. Logistical problems caused investigators to switch to the Mammotest Stereotactic System for remaining patients. | Increased operator experience brought about a reduction in procedure time.

CNB = Core-needle Biopsy

Table E18 Procedure duration time

Reference | Design of Study | Number of Patients | Biopsy Methods | Conclusion
Duschesne et al. 2007^61^ | Prospective trial of new device used on patients already scheduled for CNB between December 2002–April 2003. | 113 | US-guided radiofrequency tipped vacuum-assisted (SenoCor 360 Biopsy System) with 9-gauge needle | Procedure time is decreased for this device as the breast tissue offers no resistance to penetration, but the authors do not report a time estimate.
Liberman et al. 2007^80^ | Retrospective chart review of patients who had lesions detected with MRI and then had a MRI-guided CNB | 237 lesions | MRI-guided vacuum-assisted (Mammotome) with 9-gauge needle | Median procedure time was 31 minutes, with procedures ranging from 17–57 minutes in total
Michalopoulos et al. 2007^33^ | Prospective review of nonpalpable mammographic lesions diagnosed by CNB as either DCIS or IDC then surgically excised. | 31 | Vacuum-assisted CNB (Mammotome) with 11-gauge needle | Two cases of benign epithelial cell displacement occurred. The duration of the procedure was significantly longer in the two cases with displacement (52.5 ±3.5 minutes) vs. in cases without any displacement (42.0 ±4.4 min., p = 0.018).
Uematsu et al. 2007^97^ | Retrospective study of all patients who had had an 18-gauge CNB performed from July 2003–June 2004 followed by a surgical excision. | 235 lesions | US-guided 18-gauge CNB | Average procedure time was 10 minutes.
Viehweg et al. 2006^142^ | Retrospective review of consecutive patients with a family history, but no personal history, of breast cancer. | 63 | Either MR-guided preoperative wire localization or vacuum-assisted CNB. | Examination time was approximately 40 minutes per wire localization and 20–30 minutes for the vacuum-assisted CNB procedure, including pre- and post-interventional imaging.
Bolivar et al. 2005^497^ | Prospective case series of patients with non-palpable suspicious breast lesions who underwent 14-gauge US-guided CNB from August 1997–August 2001. | 198 | US-guided (7.5 MHz linear array transducer) CNB using a freehand technique with patient in supine or supine oblique position. | Examination time did not exceed 20 minutes in any cases.
Chapellier et al. 2005^494^ | Prospective case series of the first 318 aspiration-guided macrobiopsies procedures performed at one institution. | 301 | Fischer stereotactic imaging table system, AND vacuum-assisted CNB | The procedure, including manual pressure application, took less than one hour in 79% of cases, 90 minutes in 16% of cases, and two hours in about 5% of cases.
Diebold et al. 2005^152^ | Prospective consecutive case series of patients with mammographic BI-RADS IV microcalcifications who underwent stereostatic vacuum-assisted CNB. | 58 | Vacuum-assisted CNB (Mammotome) with 8-gauge needle with the ST driver (Holster) on a Mammotest plus S biopsy table. | Mean biopsy time was 28.2 minutes (Range: 10–120 minutes). Removing 5 highly complicated cases from this analysis reduced the average procedure time to 16.1 minutes.
Orel et al. 2005^131^ | Retrospective review of patients with suspicious lesions identified at MR imaging who either underwent surgery or had six month follow-up imaging. | 75 | MR-guided vacuum-assisted CNB with a 9-gauge needle | Total MRI-guided procedure time (including pre-biopsy imaging examination, biopsy and postbiopsy care) ranged from 30–60 minutes.
Perlet et al. 2005^132^ | Prospective study of MR-guided vacuum-assisted CNB visible by CE- MRI alone or localized in 3 dimensions by MRI alone | 538 | Impact, Expert or Vision MR scanner guidance, vacuum-assisted CNB (Mammotome) with an 11-gauge needle | On average, MR-guided CNB lasted 70 minutes if the patient was having one lesion biopsied and 90 minutes for patients with two lesions.
Weber et al. 2005^502^ | Retrospective comparison study of patients with impalpable breast lesions undergoing either Mammotome or ABBI. | 387 | Stereotactically-guided vacuum-assisted CNB (Mammotome) with 11-gauge needle or ABBI | Median duration of the Mammotome procedure was shorter than the ABBI procedure (p <0.0001).
Wong et al. 2005^171^ | Prospective trial of Asian patients with nonpalpable mammographic abnormalities underwent either ABBI (N = 7) or vacuum-assisted CNB (N = 107). | 114 | Vacuum-assisted CNB (Mammotome) with an 8- to 11-gauge needle prone or ABBI. | Procedures lasted from 30–128 minutes (Median: 68.5).
Alonso-Bartolome et al. 2004^504^ | Prospective study of women with probably benign breast lesions who refused radiologic followup and, instead, insisted on removal. Complete lesion removal was the intended goal for all lesions. | 97 | US-guided vacuum-assisted CNB (Mammotome) with 11-gauge needle | Mean procedure time was one hour (Range: 40–75 minutes). Based on a cost to patient estimate in terms of hours lost, investigators report that the time lost to CNB is less than 20% of the time required for a surgical biopsy.
Geller et al. 2004^183^ | Survey of women with nonpalpable breast lesions who had an US-guided CNB or excisional biopsy between 1997–1999. | 315 | US-guided CNB vs. excisional biopsy. | Survey results 1–3 months post procedure measured convenience of the procedure (distance travelled, procedure time, and number of days of work missed post procedure). No difference was found between two groups in terms of miles travelled for procedure, but the excisional biopsy group missed more work.
Lehman et al. 2004^160^ | Retrospective review of consecutive patients with nonpalpable lesions not clearly visible on mammography or targeted sonography, many of whom had recently been diagnosed with breast cancer. | 28 | MRI-guided vacuum- assisted CNB with the ETEC Breast Biopsy and Excision System. | Time to perform procedure was defined as the start of the first MRI sequence (localizing) to the last scan sequence (clip deployment). The average time for single biopsy procedures was 38 minutes (range: 23–57 minutes). Average time for multiple biopsy procedures in a single breast was 59 minutes (51–68 minutes) and for bilateral procedures 64 (46–80 minutes).
Rotenberg et al. 2004^200^ | Prospective case series of patients with palpable tumors and patients with tumors which were visible on ultrasound imaging or radiology. | 30 | Spirotome System with 8- to 10-gauge needle. No stereotactic tables were used in the study. | Biopsies took a maximum of 20 minutes to complete, with 80% of the biopsies being completed in only 10 minutes.
Chen et al. 2003^210^ | Retrospective study of patients with nonpalpable breast lesions from January 1998–2001 undergoing either a CNB or open biopsy. | 232 | Comparison of vacuum-assisted CNB (Mammotome) with 11-gauge needle vs. ultrasound-guided excisional biopsy | Procedure times were measured from initial skin incision to wound closure or needle withdrawal. Procedure times were as follows: for benign tumor cases 44.3 and 21.5 minutes (p <0.001); for malignant cases 44.0 and 27.0 (P = 0.036); for tumors <1 cm in diameter, 43.5 and 20.6 (p <0.001) and for tumors 1–2 cm, 44.2 and 23.6 minutes (p <0.001) for open and CNB, respectively. Procedure time for the older model Mammotome device (used in first year of study) vs. newer handheld variant, which was used in the second year, was 24 and 18 minutes on average, respectively (p <0.001).
Liberman et al. 2003^227^ | Prospective case series of women with one of the following: a nonpalpable mammographically-occult lesion at high risk for breast cancer or for extent of disease assessment. | 20 | MRI-guided 9-gauge vacuum-assisted breast biopsy. | Imaging time was 20 minutes, on average, including three contrast enhanced acquisitions. Median MRI-guided CNB time, from localizing image to imaging after clip deployment was 35 minutes (Mean: 35, Range: 24–48 for a single lesion and 65 minutes (Mean: 69, Range: 62–86) for patients with two lesions. Median tissue acquisition time was 38 seconds (Mean: 41, Range: 29–87).
Mariotti et al. 2003^228^ | Retrospective study of patients undergoing either ABBI or CNB from June 1999–December 2001 for suspicious non palpable mammographic lesions not confirmed by ultrasonography. | 360 | Vacuum-assisted CNB (Mammotome) with 11-gauge needle vs. ABBI | ABBI and Mammotome procedure times were 20 and 10 minutes, on average, respectively, for the operative portion of the procedure only.
Pleiderer et al. 2003^515^ | Prospective nonconsecutive case series of patients with suspicious breast lesions who had a diagnostic CNB with a new device. | 14 | Remote controlled MRI compatible prototype manipulator system (ROBITOM) using 14-gauge large core breast biopsy. | Total procedure time was between 50–70 minutes.
Apesteguia et al. 2002^518^ | Prospective consecutive case series of patients with nonpalpable breast lesions non-visible or non-accessible by US. | 126 | Vacuum-assisted CNB on a digital stereotaxic table with an 11-gauge needle. | Mean procedure time was 29.6 ±14 minutes (Range: 15–90 minutes).
Hui et al. 2002^252^ | Prospective case series of patients with nonpapable breast lesions requiring a biopsy procedure. | 79 | Stereotactic-guided breast biopsy (StereoGuide with Digital Spot Mammography): Trucut with a 14-gauge needle, Mammotome with 11-gauge probe, or FNA with a 22-gauge needle, depending on the characteristics of the lesion. | Mean duration of the biopsy procedure was 49 minutes (range: 30–90).
Mainiero et al. 2002^259^ | Prospective nonrandomized comparison study of patients with suspicious breast lesions undergoing a CNB between 1997–1999. | 193 | Either freehand high resolution sonographically- guided large core biopsy with 14-gauge needle vs. stereotactic vacuum-assisted CNB (Mammotest with 11-gauge needle). | The authors examined how much room time and physician time was expended for each type of procedure. They found stereotactic VABB took more room and physician time when all biopsies were examined together. When only room and physician time for patients with masses was examined, only room time significantly differed in the same direction by procedure type. The authors conclude that sonographically-guided breast biopsies reduce procedure time compared with stereotactic biopsy.
Becker et al. 2001^527^ | Retrospective chart review of 232 lesions with indeterminate microcalcifications in 218 women. | 218 | DMR regular mammography machine plus either a Stereotix 2 conventional add-on unit or a SenoVision digital add-on unit. CNB was performed with a 14-gauge needle in all but 5 cases (in which a 16-gauge needle was used) | Changing from a conventional to a digital add-on unit cut the procedure time by half (from 50 to 20 minutes). Most of this time savings is related to the speed of displaying digital images, 15 seconds per image, versus 3 minutes to develop radiographs.
Perez-Fuentes et al. 2001^534^ | Prospective case series of patients seen between August 1998–December 2000 with palpable or nonpalpable breast masses diagnosed with CNB. | 83 | Sonographically-guided vacuum-assisted CNB (Mammotome) with 11-gauge needle | Median procedure time (acquisition of prebiopsy sonogram to positioning of sterile bandage on skin) was 17 minutes (Range: 10–40)
Schneider et al. 2001^312^ | Prospective case series of patients undergoing a new unilateral MR-guided breast lesion localization and core biopsy system. | 14 | MR image guidance AND CNB using a mechanical needle guide and trajectory planning software with 14-gauge needle. | Mean procedure time was 15 ±5 minutes (Range: 5–24), including 3D acquisition scan, completion of the verification scan, placement of single and multiple stylettes for multiple localization wire placements, and multiple tissue sampling by CNB.
Wunderbaldinger et al. 2001^537^ | Prospective nonconsecutive first-experience case series of patients with nonpalpable breast lesions diagnosed by CNB followed by surgical excision. | 45 | New dedicated US system for computer-guided CNB (Sonopsy) with a 14-gauge needle. | Average procedure time (including patient positioning, biopsy, localization but not post procedural handling) was 30 ±2.7 minutes.
Beck et al. 2000^539^ | Retrospective review of first experience using vacuum-assisted CNB | 560 | Digital stereotaxic biopsy table and vacuum-assisted CNB (Mammotom) with 11-gauge needle. | The authors report that patient positioning took approximately 15 minutes; 30 minutes for the actual procedure; 15 minutes for compression; 10 minutes for a final mammogram; and another 30–45 for observation.
Welle et al. 2000^545^ | Retrospective review of patients who underwent a stereotactic CNB in a decubitus or recumbent position from September 1995–March 1999. | 225 | Stereotactic CNB in a decubitus or recumbent position. | Procedure time was recorded as minutes in compression (mean 25, range: 20–50). Procedures done with digital mammographic equipment and the Mammotome were approximately 10 minutes shorter
Bloomston et al. 1999^348^ | Prospective consecutive case series of women with nonpalpable breast abnormalities who had an ABBI. | 100 | Stereotactic ABBI. | Average procedure time was 20 ±8 minutes.
Doyle et al. 1999^552^ | Retrospective study of patients with mammographically-detected lesions on CNB from 1994–1998. | 151 | Senographe 600T was used for 136 biopsies; 15 using Mammomat 3000; all in decubitus position unless the patient couldn’t tolerate that positioning and with a 14-gauge needle. | Mean procedure time was 20 minutes
Bolivar et al. 1998^558^ | Patients seen between October 1993–October 1996 having a CNB for nonpalpable breast lesions. | 180 | Stereotactic CNB (Stereotix localization stereotaxic device attached to Senix 500T screen film mammographic unit) with the Menghini nonautomatic 15-gauge needle with multiple pass technique (Surecut). | THE CNB procedure averaged between 45–55 minutes.
Whitman et al. 1998^559^ | Retrospective chart review of 12 CNB in 11 women. | 11 | Mammographically- guided coaxial CNB procedure performed with a fenestrated alphanumeric compression device with a 15-gauge Tru Guide outer cannula and a 16-gauge Monopty biopsy instrument | The CNB procedure ranged in time from 30–80 minutes.
Burbank 1997^413^ | Retrospective study comparing the accuracy of directional, vacuum-assisted stereotactic CNB with stereotactic automated gun CNB | 101 | Prone position under stereotactic guidance on the Mammotest with 14-gauge needles | Directional, vacuum-assisted biopsy tissue harvest time was 18.6 ±15.8 minutes per lesion, on average, meaning 26.5 specimens can be obtained in that amount of time, at a tissue harvest rate of 1.4 specimens per minute. No information is given for automated procedure.
Florentine et al. 1997^421^ | Retrospective review of patients with palpable breast lesions who underwent a combined FNA/CNB procedure. | 12 | CNB using an 18-gauge Temno needle | The CNB procedure took approximately 20 minutes, on average.
Helbich et al. 1997^563^ | Prospective randomized trial of patients with mammographically- suspicious solid lesions. Patients were randomized to stereotactic CNB in a sitting position; stereotactic CNB in the prone position; or CNB with US guidance. CNB was followed by surgical excision. | 210 | CNB with either stereotactic or US guidance using a 14-gauge needle. | Acquisition of the CNB specimen took an average of 19±3 minutes with stereotactic guidance vs. 13±4 minutes with US guidance.
Howisey et al. 1997^424^ | Retrospective review of Medicare patients with mammographic abnormalities who went on to have ultrasound-guided CNB, stereotactic-guided CNB or wire localization with surgical excision between July 1994–December 1995. | 139 | Ultrasound or stereotactic-guided CNB | US-guided CNB had a shorter procedure time (<20 minutes per case) than stereotactic- guided CNB. No time given for stereotactic procedure.
Yim et al. 1996^454^ | Retrospective chart review of subjects with invasive breast cancer diagnosed by either CNB or needle localization surgical biopsy. | 52 | Stereotactic CNB with a 14-gauge needle was performed on a dedicated prone table (Lorad, Danbury, CT) vs. needle localized open biopsy | Average total procedure time for the CNB was 40–50 minutes, but the biopsy time itself was shorter than for open biopsy.
Janes et al. 1994^469^ | Prospective case series of initial 300 CNBs performed by a group of five surgeons. | 288 | CNB using Fischer Imaging Mammotest with Auto-Guide and the Mammoscan System, 14-gauge needle Biopty-Cut Biopsy Needle. | By the 100^th^ procedure, total procedure time, from initial image taking to completion of the acquisition, rarely exceeded 30 minutes. Acquisition times for lesions centered on the initial image were 15–20 minutes.
Elvecrog et al. 1993^586^ | Prospective study of women with a single nonpalpable breast lesion imaged by mammography who underwent CNB followed by hook-wire localization and open surgical biopsy. | 100 | Mammotest stereotaxic system and 14-gauge needle. | Average per case procedure time, including obtaining preliminary views, was 50–60 minutes. The CNB alone took between 30–40 minutes, on average. No data on average time for the open biopsy procedure was presented.
Parker et al. 1990^591^ | Prospective case series of consecutive patients referred for biopsy of nonpalpable mammographically- suggestive lesions. Subjects underwent CNB followed by wire localization and excisional surgery. | 103 | 14-, 16-, or 18-gauge Biopty-cut needles were used in conjunction with a Biopty gun. The first 30 patients were treated with Senographe Mammographic System 600T coupled with Stereotix computerized stereotactic needle localization device. Logistical problems caused investigators to switch to the Mammotest Stereotactic System for remaining patients. | Average procedure time by end of the study was 20–30 minutes without localization wire placement. No data on procedure time for early cases was provided.

CNB = Core-needle Biopsy

Table E19 Wait time for test results

Reference | Design of Study | Number of Patients | Biopsy Methods | Conclusion
Verkooijen et al. 2001^593^ | Prospective comparison of patients with nonpalpable breast lesions | 164 | Stereotactic guidance on a prone table with a 14-gauge needle. | Median wait time was 9 days for core-needle biopsies and 19 days for wire-localized open biopsies.
Gukas et al. 2000^326^ | Prospective study of patients with palpable lesions | 108 | Tru-Cut | Reduced wait time to get back a test result was, on average, 7.3 days less for Tru-Cut than excisional biopsy.

Table E20 Availability of a qualified pathologist

Reference | Design of study | Number of patients | Biopsy methods | Conclusion
Collins et al. 2004^179^ | Retrospective chart review of patients with nonpalpable lesions | 2,004 | CNB using either stereotactic mammography or ultrasound. In some cases a 14-gauge needle was used, in others a vacuum-assisted procedure was done with either a 14- or 11-gauge needle. | Local pathology diagnoses were compared to those made by a central pathologist. In 96% of CNB cases the two pathologists were in agreement. Agreement rates were as follows for the subcategories of benign lesions, invasive cancers, DCIS cases, ADH, and lobular neoplasia: 99%, 97%, 83%, 63%, and 53%, respectively. Agreement rates remained stable regardless of biopsy guidance system and biopsy device used.
Gukas et al. 2000^326^ | Prospective study of 112 consecutive patients with palpable breast lesions. | 108 | Tru-Cut and excisional biopsies. | The pathologist in this study was not highly experienced with Tru-Cut, which the authors believe explains its poor diagnosis rate in this study.

Table E21 Availability of equipment

Reference | Design of Study | Number of Patients | Biopsy Methods | Conclusion
Deurloo et al. 2001^285^ | Retrospective review of patients with nonpalpable breast lesions. | 84 | StereoGuide with 14-gauge needle | Vacuum-assisted biopsy is increasingly being used in the United States. But, in Europe, acceptance of vacuum-assisted biopsy is considerably less whereas core biopsy devices are used much more.
Verkooijen et al. 2001^593^ | Prospective comparison of patients with nonpalpable breast lesions | 164 | Stereotactic guidance, on a prone table with a 14-gauge needle. | Median wait times for access to core-needle biopsy equipment were only 4 days while access to open surgical biopsy had a median wait time of 13 days.
Williams et al. 1999^384^ | Prospective case series of patients with impalpable breast lesions diagnosed by stereotactic core- needle biopsy on a prone table vs. a historical cohort of patients with similar lesions diagnosed prior to the availability of a prone table. | 222 | Stereotactic prone CNB with Mammotest and 14-gauge needle. | There was no significant difference in lag time between screening and definitive diagnosis for the two groups. However, there was a delay in having the prone procedure due to the longer waiting list.

Table E22 Resource usage

Reference | Design of Study | Number of Patients | Biopsy Methods | Conclusion
Mainiero et al. 2002^259^ | Prospective nonrandomized comparison study of patients with suspicious breast lesions | 193 | Either freehand high resolution US-guided large core biopsy with 14-gauge needle or a stereotactic-guided vacuum- assisted biopsy (Mammotest) with 11-gauge needle | The authors examined how much room time and physician time was expended for each type of procedure. They found vacuum-assisted procedures took more room and physician time when all biopsies were examined together. When only room and physician time for patients with masses was examined, only room time significantly differed in the same direction by procedure type.
Wunderbaldinger et al. 2002^277^ | Prospective randomized study | 200 | Stereotactic-guided biopsies in either sitting or prone position with a 14-gauge needle. | In the conclusion the authors report that prone systems require four times the amount of space as a regular unit and are often underused as their only function is breast biopsy. In addition, there is a weight limit to prone machines.