# Excluded Studies

Table C2 Studies that did not meet the inclusion criteria for Key Questions 1 and 2

Study | Primary Reason for Exclusion
Bukhari et al. 2009^1^ | Patients were selected for core-needle biopsy on the basis of prior fine-needle aspiration results
Eliahou et al. 2009^2^ | Enrolled a high-risk population
Peters et al. 2009^3^ | Enrolled a high-risk population
Salem et al. 2009^4^ | Enrolled a high-risk population
Tozaki et al. 2009^5^ | Enrolled a high-risk population
Bernik et al. 2008^6^ | Retrospective case study
Brem et al. 2008^7^ | Retrospective case study
Carder et al. 2008^8^ | Retrospective case study
Cheung et al. 2008^9^ | Did not address Key Question 1
Choo et al. 2008^10^ | Did not verify core-needle diagnoses
Doren et al. 2008^11^ | Retrospective case study
Eby et al. 2008^12^ | Retrospective case study
Eun et al. 2008^13^ | Enrolled only patients with benign masses
Forgeard et al. 2008^14^ | Retrospective case study
Hahn et al. 2008^15^ | Enrolled only patients with benign masses
Hauth et al. 2008^16^ | Enrolled a high-risk population
He et al. 2008^17^ | Enrolled a high-risk population
Herti et al. 2008^18^ | Did not address Key Question 1
Hemmer et al. 2008^19^ | Did not address Key Question 1
Hukkinen et al. 2008^20^ | Enrolled only patients with malignant masses
Hwang et al. 2008^21^ | Retrospective case study
Jang et al. 2008^22^ | Retrospective case study
Ji et al. 2008^23^ | Duplicate report of Youk et al. 2008^24^
Kil et al. 2008^25^ | Retrospective case study
Kim et al. 2008^26^ | Did not verify benign diagnoses
Kim et al. 2008^27^ | Retrospective case study
Kumaroswamay et al. 2008^28^ | Did not verify benign diagnoses
Lee et al. 2008^29^ | Did not verify benign diagnoses
Londero et al. 2008^30^ | Retrospective case study
Mahoney et al. 2008^31^ | Enrolled patients with a prior diagnosis of breast cancer
Menon et al. 2008^32^ | Retrospective case study
Michalopoulos et al. 2008^33^ | Did not address Key Question 1
Perretta et al. 2008^34^ | Enrolled a high-risk population
Peter et al. 2008^35^ | Fewer than 50% of enrolled patients completed the study
Resetkova et al. 2008^36^ | Retrospective case study
Rizzo et al. 2008^37^ | Retrospective case study
Salem et al. 2008^38^ | Did not address Key Question 1
Shin et al. 2008^39^ | Retrospective case study
Sigal-Zafrani et al. 2008^40^ | Fewer than 50% of enrolled patients completed the study
Skandarajah et al. 2008^41^ | Retrospective case study
Smetherman et al. 2008^42^ | Retrospective case study
Sohn et al. 2008^43^ | Retrospective case study
Somerville et al. 2008^44^ | Did not address Key Question 1
Tagaya et al. 2008^45^ | Enrolled only patients with benign masses
Taourel et al. 2008^46^ | Did not verify benign diagnoses
Tozaki et al. 2008^47^ | Enrolled a high-risk population
Tseng et al. 2008^48^ | Retrospective case study
Zagouri et al. 2008^49^ | Did not address Key Question 1
Zografos et al. 2008^50^ | Enrolled a high-risk population
Zografos et al. 2008^51^ | Did not verify benign diagnoses
Zografos et al. 2008^52^ | Did not verify any core-needle diagnoses
Andreu et al. 2007^53^ | Fewer than 50% of enrolled patients completed the study
Arora et al. 2007^54^ | Retrospective case study
Ashkenazi et al. 2007^55^ | Retrospective case study
Bode et al. 2007^56^ | Retrospective case study
Cassano et al. 2007^57^ | Patients were selected for core-needle biopsy on the basis of prior fine-needle aspiration results
Ciatto et al. 2007^58^ | Enrolled a high-risk population
Dillon et al. 2007^59^ | Retrospective case study
Douglas-Jones et al. 2007^60^ | Retrospective case study
Duchesne et al. 2007^61^ | Fewer than 50% of enrolled patients completed the study
Duijm et al. 2007^62^ | Fewer than 50% of enrolled patients completed the study
Easley et al. 2007^63^ | Fewer than 50% of enrolled patients completed the study
Esserman et al. 2007^64^ | Retrospective case study
Foxcroft et al. 2007^65^ | Retrospective case study
Garg et al. 2007^66^ | Patients were selected for core-needle biopsy on the basis of prior fine-needle aspiration results
Hollloway et al. 2007^67^ | Did not verify benign diagnoses
Houssami et al. 2007^68^ | Retrospective case study
Karabakhtsian et al. 2007^69^ | Retrospective case study
Kikuchi et al. 2007^70^ | Did not verify benign diagnoses
Kim et al. 2007^71^ | Fewer than 50% of enrolled patients completed the study
Ko et al. 2007^72^ | Retrospective case study
Krainick-Strobel et al. 2007^73^ | Enrolled only patients with benign masses
Kumaraswamy and Carder 2007^74^ | Fewer than 50% of enrolled patients completed the study
u and Kleer 2007^75^ | Retrospective case study
Lavoue et al. 2007^76^ | Retrospective case study
Lee et al. 2007^77^ | Enrolled a high-risk population
Lee et al. 2007^78^ | Enrolled a high-risk population
Leikola et al. 2007^79^ | Retrospective case study
Liberman et al. 2007^80^ | Enrolled a high-risk population
Londero et al. 2007^81^ | Retrospective case study
Lourenco et al. 2007^82^ | Retrospective case study
Luczynska et al. 2007^83^ | Did not verify benign diagnoses
Martel et al. 2007^84^ | Retrospective case study
Mathew et al. 2007^85^ | Enrolled only patients with benign masses
Mendel et al. 2007^86^ | Fewer than 10 patients enrolled
Murta De Lucena et al. 2007^87^ | Did not verify benign diagnoses
Nakano et al. 2007^88^ | Patients were selected for core-needle biopsy on the basis of prior fine-needle aspiration results
Popiela et al. 2007^89^ | Enrolled a high-risk population
Povoski and Jimenez 2007^90^ | Did not report sufficient data to address Key Question 1
Rustein et al. 2007^91^ | Retrospective case study
Schaefer et al. 2007^92^ | Did not address any of the Key Questions
Smitt and Horst 2007^93^ | Enrolled only patients with malignant masses
Sohn et al. 2007^94^ | Retrospective case study
Sydnor et al. 2007^95^ | Retrospective case study
Uematsu and Kasami 2007^96^ | Did not address Key Question 1
Uematsu et al. 2007^97^ | Did not verify benign diagnoses
Usami et al. 2007^98^ | Enrolled only patients with malignant masses
Zagouri et al. 2007^99^ | Retrospective case study
Zografos et al. 2007^100^ | Did not verify benign diagnoses
Zuiani et al. 2007^101^ | Enrolled a high-risk population
Al-Attar et al. 2006^102^ | Did not address Key Question 1
Becker et al. 2006^103^ | Retrospective case study
Bedei et al. 2006^104^ | Retrospective case study
Chrzan et al. 2006^105^ | Retrospective case study
Cox et al. 2006^106^ | Retrospective case study
Dillon et al. 2006^107^ | Retrospective case study
Dillon et al. 2006^108^ | Retrospective case study
Fine and Staren 2006^109^ | Enrolled only patients with benign masses
Fitzal et al. 2006^110^ | Did not address Key Question 1
Gebauer et al. 2006^111^ | Less than 50% of enrolled patients completed the study
Ghate et al. 2006^112^ | Did not verify benign diagnoses
Govindarajulu et al. 2006^113^ | Enrolled only patients with malignant masses
Hanley and Kessaram 2006^114^ | Enrolled only patients with malignant masses
Hoffmann 2006^115^ | Did not address Key Question 1
Huo et al. 2006^116^ | Retrospective case study
Jackman and Rodriguez-Soto 2006^117^ | Did not address Key Question 1
Jensen et al. 2006^118^ | Fine-needle aspiration results were used in decisions about verification of results
Kamer et al. 2006^119^ | Fewer than 10 patients enrolled
Killebrew and Oneson 2006^120^ | Did not verify benign diagnoses
Koskela et al. 2006^121^ | Did not report sufficient data to address Key Question 1
Lam et al. 2006^122^ | Retrospective case study
Lannin et al. 2006^123^ | Did not address Key Question 1
Liberman et al. 2006^124^ | Retrospective case study
Lieske et al. 2006^125^ | Fine-needle aspiration results were used in decisions about verification of results
Lim et al. 2006^126^ | Retrospective case study
Lopez-Medina et al. 2006^127^ | Retrospective case study
Margenthaler et al. 2006^128^ | Enrolled a high-risk population
Mercado et al. 2006^129^ | Retrospective case study
Newman et al. 2006^130^ | Enrolled only patients with malignant masses
Orel et al. 2006^131^ | Enrolled a high-risk population
Perlet et al. 2006^132^ | Enrolled a high-risk population
Popiela et al. 2006^133^ | Less than 50% of enrolled patients completed the study
Renshaw et al. 2006^134^ | Retrospective case study
Renshaw et al. 2006^135^ | Retrospective case study
Senn et al. 2006^136^ | Did not verify benign diagnoses
Shin et al. 2006^137^ | Did not address Key Question 1
Sie et al. 2006^138^ | Retrospective case study
Uriburu et al. 2006^139^ | Did not address Key Question 1
Valdes et al. 2006^140^ | Retrospective case study
Vargas et al. 2006^141^ | Did not address Key Question 1
Viehweg et al. 2006^142^ | Enrolled a high-risk population
Wu et al. 2006^143^ | Less than 50% of enrolled patients completed the study
Yazici et al. 2006^144^ | Did not address Key Question 1
Altomare et al. 2005^145^ | Did not verify benign diagnoses
Badoual et al. 2005^146^ | Enrolled only patients with malignant masses
Bonifacino et al. 2005^147^ | Fine-needle aspiration results were used in decisions about verification of results
Brem et al. 2005^148^ | Retrospective case study
Caines et al. 2005^149^ | Did not address Key Question 1
Cho et al. 2005^150^ | Unresolvable multiple discrepancies in reported data
Costantini et al. 2005^151^ | Did not verify benign diagnoses
Diebold et al. 2005^152^ | Did not report sufficient data to address Key Question 1
Doridot et al. 2005^153^ | Used a core-needle instrument that is no longer commercially available
Doyle et al. 2005^154^ | Did not address Key Question 1
Elsheikh et al. 2005^155^ | Retrospective case study
Gambos et al. 2005^156^ | Retrospective case study
Grady et al. 2005^157^ | Retrospective case study
Hanna et al. 2005^158^ | Used a core-needle instrument that is no longer commercially available
Homesh et al. 2005^159^ | Fine-needle aspiration results were used in decisions about verification of results
Lehman et al. 2005^160^ | Did not verify benign diagnoses
Monticciolo 2005^161^ | Enrolled only patients with malignant masses
Pilgrim and Ravichandran 2005^162^ | Fine-needle aspiration results were used in decisions about verification of results
Qazi and Mohayuddin 2005^163^ | Fine-needle aspiration results were used in decisions about verification of results
Riedl et al. 2005^164^ | Did not address Key Question 1
Rulli et al. 2005^165^ | Used a core-needle instrument that is no longer commercially available
Satchithananda et al. 2005^166^ | Did not address Key Question 1
Schneider et al. 2005^167^ | Used a core-needle instrument that is no longer commercially available
Soo et al. 2005^168^ | Did not address Key Question 1
Wahner-Roedler et al. 2005^169^ | Fewer than 10 patients enrolled
Wiratkapun et al. 2005^170^ | Retrospective case study
Wong et al. 2005^171^ | Did not verify benign diagnoses
You et al. 2005^172^ | Retrospective case study
Zuiani et al. 2005^173^ | Retrospective case study
Agoff et al. 2004^174^ | Retrospective case study
Arpino et al. 2004^175^ | Retrospective case study
Carmon et al. 2004^176^ | Did not address Key Question 1
Chagpar et al. 2004^177^ | Enrolled only patients with malignant masses
Chen et al. 2004^178^ | Did not verify benign diagnoses
Collins et al. 2004^179^ | Did not address Key Question 1
Docktor et al. 2004^180^ | Did not address Key Question 1
Foster et al. 2004^181^ | Retrospective case study
Gan et al. 2004^182^ | Did not address Key Question 1
Geller et al. 2004^183^ | Did not address Key Question 1
Gendler et al. 2004^184^ | Retrospective case study
Georgina-Smith et al. 2004^185^ | Retrospective case study
Golshan et al. 2004^186^ | Enrolled only patients with malignant masses
Golub et al. 2004^187^ | Did not address Key Question 1
Hansen et al. 2004^188^ | Did not address Key Question 1
Hoorntje et al. 2004^189^ | Did not address Key Question 1
Hoorntje et al. 2004^190^ | Did not address Key Question 1
Ivan et al. 2004^191^ | Retrospective case study
Margolin et al. 2004^192^ | Did not address Key Question 1
Mendez et al. 2004^193^ | Did not confirm benign diagnoses
O’Leary et al. 2004^194^ | Did not address Key Question 1
Peters-Engl et al. 2004^195^ | Enrolled only patients with malignant masses
Piana et al. 2004^196^ | Enrolled only patients with malignant masses
Pijnappel et al. 2004^197^ | Enrolled a high-risk population
Renshaw 2004^198^ | Did not address Key Question 1
Renshaw et al. 2004^199^ | Retrospective case study
Rotenberg et al. 2004^200^ | Did not confirm benign diagnoses
Agarwal et al. 2003^201^ | Enrolled only patients with malignant masses
Baez et al. 2003^202^ | Enrolled only patients with benign masses
Bauer et al. 2003^203^ | Retrospective case study
Berg et al. 2003^204^ | Retrospective case study
Bonnett et al. 2003^205^ | Retrospective case study
Brenner et al. 2003^206^ | Retrospective case study
Carder and Liston 2003^207^ | Enrolled patients with a benign mass
Cawson et al. 2003^208^ | Retrospective case study
Charles et al. 2003^209^ | Enrolled patients with a malignant mass
Chen et al. 2003^210^ | Did not report sufficient data to address Key Question 1
Corn 2003^211^ | Used a core-needle instrument that is no longer commercially available
Crisi et al. 2003^212^ | Retrospective case study
Crowe et al. 2003^213^ | Did not verify benign diagnoses
Dennison et al. 2003^214^ | Fine-needle aspiration results were used in decisions about verification of results
Dmytrasz et al. 2003^215^ | Retrospective case study
Farshid and Rush 2003^216^ | Fine-needle aspiration results were used in decisions about verification of results
Fine et al. 2003^217^ | Enrolled only patients with benign masses
Fures et al. 2003^218^ | Did not verify benign diagnoses
Harris et al. 2003^219^ | Enrolled patients with a malignant mass
Hoorntje et al. 2003^220^ | Retrospective case study
Jackman and Marzoni 2003^221^ | Did not address Key Question 1
Kneeshaw et al. 2003^222^ | Retrospective case study
Komenaka et al. 2003^223^ | Retrospective case study
Lee et al. 2003^224^ | Enrolled only patients with malignant masses
Leifland et al. 2003^225^ | Fine-needle aspiration results were used in decisions about verification of results
Leifland et al. 2003^226^ | Fine-needle aspiration results were used in decisions about verification of results
Liberman et al. 2003^227^ | Enrolled a high-risk population
Mariotti et al. 2003^228^ | Did not verify benign diagnoses
Masood et al. 2003^229^ | Retrospective case study
Middleton et al. 2003^230^ | Retrospective case study
Miller et al. 2003^231^ | Retrospective case study
Puglisi et al. 2003^232^ | Retrospective case study
Shah et al. 2003^233^ | Retrospective case study
Sneige et al. 2003^234^ | Retrospective case study
Sperber et al. 2003^235^ | Enrolled only patients with benign masses
Tsang et al. 2003^236^ | Used a core-needle instrument that is no longer commercially available
Verkooijen et al. 2003^237^ | Did not address Key Question 1
Winchester et al. 2003^238^ | Retrospective case study
Witt et al. 2003^239^ | Did not address Key Question 1
Yeh et al. 2003^240^ | Retrospective case study
Zhao et al. 2003^241^ | Retrospective case study
Acheson et al. 2002^242^ | Retrospective case study
Bonnett et al. 2002^243^ | Retrospective case study
Chen et al. 2002^244^ | Enrolled patients with recurrent breast cancer
Chun and Velanovich et al. 2002^245^ | Did not address Key Question 1
Fine et al. 2002^246^ | Enrolled only patients with benign masses
Gal-Gombos et al. 2002^247^ | Retrospective case study
Giardina et al. 2002^248^ | Did not verify benign diagnoses
Haj et al. 2002^249^ | Used a core-needle instrument that is no longer commercially available
Harvey et al. 2002^250^ | Retrospective case study
Hoorntje et al. 2002^251^ | Did not verify benign diagnoses
Hui et al. 2002^252^ | Did not address Key Question 1
Insausti et al. 2002^253^ | Used a core-needle instrument that is no longer commercially available
Jackman et al. 2002^254^ | Retrospective case study
Jan et al. 2002^255^ | Fine-needle aspiration results were used in decisions about verification of results
Knight et al. 2002^256^ | Did not address Key Question 1
Liberman et al. 2002^257^ | Did not address Key Question 1
Lifrange et al. 2002^258^ | Used a core-needle instrument that is no longer commercially available
Mainiero et al. 2002^259^ | Did not address Key Question 1
McKee et al. 2002^260^ | Did not address Key Question 1
Perlet et al. 2002^261^ | Not published in English
Pijnappel et al. 2002^262^ | Enrolled a high-risk population
Popiela et al. 2002^263^ | Did not verify benign diagnoses
Rao et al. 2002^264^ | Retrospective case study
Renshaw 2002^265^ | Retrospective case study
Renshaw et al. 2002^266^ | Retrospective case study
Rosen et al. 2002^267^ | Retrospective case study
Schneider et al. 2002^268^ | Enrolled a high-risk population
Shin and Rosen 2002^269^ | Retrospective case study
Smyczek-Gargya et al. 2002^270^ | Did not verify benign diagnoses
Soo et al. 2002^271^ | Did not verify benign diagnoses
Tan et al. 2002^272^ | Fine-needle aspiration results were used in decisions about verification of results
Tse et al. 2002^273^ | Retrospective case study
Verkooijen and Peeters 2002^274^ | Enrolled a high-risk population
Verkooijen et al. 2002^275^ | Did not address Key Question 1
Watermann et al. 2002^276^ | Used a core-needle instrument that is no longer commercially available
Wunderbaldinger et al. 2002^277^ | Enrolled only patients with malignant masses
Bagnall et al. 2001^278^ | Enrolled only patients with malignant masses
Berg et al. 2001^279^ | Enrolled a high-risk population
Berg et al. 2001^280^ | Retrospective case study
Brem et al. 2001^281^ | Did not verify benign diagnoses
Chao et al. 2001^282^ | Not published in English
Clarke et al. 2001^283^ | Fine-needle aspiration results were used in decisions about verification of results
Daniel et al. 2001^284^ | Did not verify benign diagnoses
Deurloo et al. 2001^285^ | Did not address Key Question 1
Ely et al. 2001^286^ | Retrospective case study
Fine et al. 2001^287^ | Did not address Key Question 1
Grimes et al. 2001^288^ | Did not address Key Question 1
Hung et al. 2001^289^ | Fine-needle aspiration results were used in decisions about verification of results
Ibrahim et al. 2001^290^ | Fine-needle aspiration results were used in decisions about verification of results
Jackman et al. 2001^291^ | Retrospective case study
Jacobs et al. 2001^292^ | Core-needle biopsies were performed with a device no longer commercially available
Joshi et al. 2001^293^ | Did not verify benign diagnoses
Kaufman et al. 2001^294^ | Did not address Key Question 1
King et al. 2001^295^ | Did not address Key Question 1
Kuhl et al. 2001^296^ | Enrolled high-risk patients
Liberman et al. 2001^297^ | Did not address Key Question 1
Liberman et al. 2001^298^ | Did not address Key Question 1
Lifrange et al. 2001^299^ | Used a core-needle instrument that is no longer commercially available
Maganini et al. 2001^300^ | Retrospective case study
Marti et al. 2001^301^ | Used a core-needle instrument that is no longer commercially available
Meloni et al. 2001^302^ | Fine-needle aspiration results were used in decisions about verification of results
Mendez et al. 2001^303^ | Retrospective case study
Mercado et al. 2001^304^ | Retrospective case study
Morrow et al. 2001^305^ | Did not address Key Question 1
O’Driscoll et al. 2001^306^ | Fewer than 10 patients enrolled
Parker et al. 2001^307^ | Less than 50% of enrolled patients completed the study
Parker et al. 2001^308^ | Did not address Key Question 1
Renshaw 2001^309^ | Retrospective case study
Renshaw et al. 2001^310^ | Retrospective case study
Saarenmaa et al. 2001^311^ | Enrolled only patients with malignant masses
Schneider et al. 2001^312^ | Did not verify benign diagnoses
Schoonjans and Brem 2001^313^ | Less than 50% of enrolled patients completed the study
Shannon et al. 2001^314^ | Fine-needle aspiration results were used in decisions about verification of results
Sklair-Levy et al. 2001^315^ | Retrospective case study
Smith et al. 2001^316^ | Enrolled patients at high risk
Sun et al. 2001^317^ | Fine-needle aspiration results were used in decisions about verification of results
Verkooijen et al. 2001^318^ | Did not address Key Question 1
Westenend et al. 2001^319^ | Fine-needle aspiration results were used in decisions about verification of results
Adrales et al. 2000^320^ | Did not verify benign diagnoses
Bagnall et al. 2000^321^ | Enrolled only patients with malignant masses
Burns et al. 2000^322^ | Did not verify benign diagnoses
Darling et al. 2000^323^ | Retrospective case study
Cangiarella et al. 2000^324^ | Fine-needle aspiration results were used in decisions about verification of results
Cangiarella et al. 2000^325^ | Did not address Key Question 1
Gukas et al. 2000^326^ | Less than 50% of enrolled patients completed the study
Hatada et al. 2000^327^ | Fine-needle aspiration results were used in decisions about verification of results
Lamm et al. 2000^328^ | Did not address Key Question 1
Lee et al. 2000^329^ | Retrospective case study
Liberman et al. 2000^330^ | Retrospective case study
Melotti et al. 2000^331^ | Did not address Key Question 1
Mok and Keepin 2000^332^ | Enrolled a high-risk population
Moritz et al. 2000^333^ | Did not address any of the Key Questions
Nisbet et al. 2000^334^ | Did not verify diagnoses
O’hea and Tornos 2000^335^ | Retrospective case study
Philpotts et al. 2000^336^ | Retrospective case study
Philpotts et al. 2000^337^ | Retrospective case study
Portincasa et al. 2000^338^ | Used a core-needle instrument that is no longer commercially available
Schwatzberg et al. 2000^339^ | Used a core-needle instrument that is no longer commercially available
Simon et al. 2000^340^ | Less than 50% of enrolled patients completed the study
Sneige and Tulbah 2000^341^ | Did not address Key Question 1
Stolier et al. 2000^342^ | Did not address Key Question 1
Teh et al. 2000^343^ | Did not verify benign diagnoses
Whitlock et al. 2000^344^ | Less than 50% of enrolled patients completed the study
Yang et al. 2000^345^ | Used a core-needle instrument that is no longer commercially available
Al-Sobhi et al. 1999^346^ | Did not address Key Question 1
Baker et al. 1999^347^ | Fewer than 10 patients enrolled
Bloomston et al. 1999^348^ | Used a core-needle instrument that is no longer commercially available
Bokran et al. 1999^349^ | Retrospective case study
Brem et al. 1999^350^ | Retrospective case study
Britton and McCann 1999^351^ | Did not address Key Question 1
Damascelli et al. 1999^352^ | Used a core-needle instrument that is no longer commercially available
Deschryver et al. 1999^353^ | Retrospective case study
Diaz et al. 1999^354^ | Did not address Key Question 1
DiPiro et al. 1999^355^ | Retrospective case study
El-Tamer et al. 1999^356^ | Enrolled only patients with malignant masses
Evans et al. 1999^357^ | Did not verify benign diagnoses
Ferzli et al. 1999^358^ | Used a core-needle instrument that is no longer commercially available
Fraser et al. 1999^359^ | Fine-needle aspiration results were used in decisions about verification of results
Gajdos et al. 1999^360^ | Did not address Key Question 1
Gentry and Henry 1999^361^ | Did not address Key Question 1
Gray et al. 1999^362^ | Did not address Key Question 1
Harlow et al. 1999^363^ | Did not address Key Question 1
Harvey et al. 1999^364^ | Retrospective case study
Johnson et al. 1999^365^ | Retrospective case study
Klem et al. 1999^366^ | Did not verify benign diagnoses
LaRaja et al. 1999^367^ | Used a core-needle instrument that is no longer commercially available
Lee et al. 1999^365^ | Enrolled only patients with benign masses
Liberman et al. 1999^368^ | Retrospective case study
Liberman et al. 1999^369^ | Retrospective case study
Liberman et al. 1999^370^ | Did not address Key Question 1
Matthews and Williams 1999^371^ | Used a core-needle instrument that is no longer commercially available
Mitnick et al. 1999^372^ | Retrospective case study
Philpotts et al. 1999^373^ | Did not address Key Question 1
Rebner et al. 1999^374^ | Used a core-needle instrument that is no longer commercially available
Rich et al. 1999^375^ | Did not verify benign diagnoses
Rosen et al. 1999^376^ | Retrospective case study
Roth et al. 1999^377^ | Enrolled only patients with malignant masses
Sharifi et al. 1999^378^ | Did not address Key Question 1
Sheth et al. 1999^379^ | Used a core-needle instrument that is no longer commercially available
Shin et al. 1999^380^ | Results of fine-needle aspiration were used to decide who underwent core-needle biopsy
Staren et al. 1999^381^ | Fine-needle aspiration results were used in decisions about verification of results
Tran et al. 1999^382^ | Does not address any of the Key Questions
Velanovich et al. 1999^383^ | Did not verify benign diagnoses
Williams et al. 1999^384^ | Did not verify benign diagnoses
Won et al. 1999^385^ | Retrospective case study
Yong et al. 1999^386^ | Fine-needle aspiration results were used in decisions about verification of results
Andreu et al. 1998^387^ | Fine-needle aspiration results were used in decisions about verification of results
Antley et al. 1998^388^ | Did not report sufficient data to address Key Question 1
Bleznak et al. 1998^389^ | Did not address Key Question 1
Damascelli et al. 1998^390^ | Used a core-needle instrument that is no longer commercially available
Doyle et al. 1998^391^ | Fine-needle aspiration results were used in decisions about verification of results
Goodman et al. 1998^392^ | Did not address Key Question 1
Helbich et al. 1998^393^ | Did not address Key Question 1
Jackman et al. 1998^394^ | Enrolled only patients with benign masses
Johnson et al. 1998^395^ | Did not verify benign diagnoses
Kaufman et al. 1998^396^ | Did not address Key Question 1
Kelley et al. 1998^397^ | Used a core-needle instrument that is no longer commercially available
King et al. 1998^398^ | Retrospective case study
Liberman et al. 1998^399^ | Enrolled only patients with malignant masses
Liberman et al. 1998^400^ | Did not address Key Question 1
Lin et al. 1998^401^ | Retrospective case study
Lind et al. 1998^402^ | Enrolled only patients with benign masses
Meyer et al. 1998^403^ | Enrolled only patients with benign masses
Mitnick et al. 1998^404^ | Retrospective case study
Seoudi et al. 1998^405^ | Did not verify benign diagnoses
Slanetz et al. 1998^406^ | Did not address Key Question 1
Soo et al. 1998^407^ | Fewer than 10 patients enrolled
Woodcock et al. 1998^408^ | Did not verify benign diagnoses
Zardawi 1998^409^ | Did not verify benign diagnoses
Zonderland et al. 1998^410^ | Fine-needle aspiration results were used in decisions about verification of results
Acheson et a. 1997^411^ | Less than 50% of enrolled patients completed the study
Anania et al. 1997^412^ | Did not address Key Question 1
Burbank 1997^413^ | Retrospective case study
Burbank 1997^414^ | Did not address Key Question 1
Burbank 1997^415^ | Enrolled only patients with benign masses
Cerwenka et al. 1997^416^ | Did not verify benign diagnoses
D’Angelo et al. 1997^417^ | Used a core-needle instrument that is no longer commercially available
Devia et al. 1997^418^ | Did not address Key Question 1
Fenoglio et al. 1997^419^ | Did not address Key Question 1
Ferzli et al. 1997^420^ | Used a core-needle instrument that is no longer commercially available
Florentine et al. 1997^421^ | Fine-needle aspiration results were used in decisions about verification of results
Gadzala et al. 1997^422^ | Retrospective case study
Hirst and Davis 1997^423^ | Did not verify benign diagnoses
Howisey et al. 1997^424^ | Did not address Key Question 1
Jackman and Marzoni 1997^425^ | Did not address Key Question 1
Jackman et al. 1997^426^ | Retrospective case study
Liberman et al. 1997^427^ | Did not address Key Question 1
Liberman et al. 1997^428^ | Did not address Key Question 1
Lifrange et al. 1997^429^ | Fine-needle aspiration results were used in decisions about verification of results
Meyer et al. 1997^430^ | Did not address Key Question 1
Pijnappel et al. 1997^431^ | Fine-needle aspiration results were used in decisions about verification of results
Roe et al. 1997^432^ | Did not report sufficient data to address Key Question 1
Smith et al. 1997^433^ | Did not address Key Question 1
Stolier et al. 1997^434^ | Did not address Key Question 1
Whitten et al. 1997^435^ | Did not address Key Question 1
Written et al. 1997^436^ | Did not address Key Question 1
Ballo and Sneige 1996^437^ | Fine-needle aspiration results were used in decisions about verification of results
Burbank et al. 1996^438^ | Did not address Key Question 1
Caines et al. 1996^439^ | Did not verify benign diagnoses
Chare et al. 1996^440^ | Fine-needle aspiration results were used in decisions about verification of results
Crotch-Harvey and Loughran 1996^441^ | Fine-needle aspiration results were used in decisions about verification of results
Dershaw et al. 1996^442^ | Did not address Key Question 1
Di et al. 1996^443^ | Enrolled only patients with malignant masses
Frayne et al. 1996^444^ | Fine-needle aspiration results were used in decisions about verification of results
Handy et al. 1996^445^ | Did not address Key Question 1
Hillhouse et al. 1996^446^ | Did not address Key Question 1
Hunter et al. 1996^447^ | Did not address Key Question 1
Liberman et al. 1996^448^ | Did not address Key Question 1
Pillsbury et al. 1996^449^ | Did not verify benign diagnoses
Poole et al. 1996^450^ | Fine-needle aspiration results were used in decisions about verification of results
Taft et al. 1996^451^ | Did not verify benign diagnoses
Tocino et al. 1996^452^ | Retrospective case study
Wallace et al. 1996^453^ | Did not verify benign diagnoses
Yim et al. 1996^454^ | Did not address Key Question 1
Hann et al. 1995^455^ | Did not address Key Question 1
Israel and Fine1995^456^ | Did not verify benign diagnoses
Liberman et al. 1995^457^ | Retrospective case study
Liberman et al. 1995^458^ | Retrospective case study
Liberman et al. 1995^459^ | Enrolled patients with recurrent breast cancer
McCombs et al. 1995^460^ | Did not verify benign diagnoses
Nath et al. 1995^461^ | Fewer than 10 patients enrolled
Rubin et al. 1995^462^ | Did not address Key Question 1
Strong et al. 1995^463^ | Did not verify benign diagnoses
Vega et al. 1995^464^ | Enrolled high-risk patients
Vega et al. 1995^465^ | Did not verify benign diagnoses
Youngson et al. 1995^466^ | Did not address Key Question 1
Caines et al. 1994^467^ | Did not verify benign diagnoses
Jackman et al. 1994^468^ | Did not verify benign diagnoses
Janes and Bouton 1994^469^ | Did not verify benign diagnoses
Kaye et al. 1994^470^ | Did not address Key Question 1
Liberman et al. 1994^471^ | Did not address Key Question 1
Liberman et al. 1994^472^ | Did not address Key Question 1
Mikhail et al. 1994^473^ | Enrolled a high-risk population
Morrow et al. 1994^474^ | Did not verify benign diagnoses
Sadler et al. 1994^475^ | Fine-needle aspiration results were used in decisions about verification of results
Youngson et al. 1994^476^ | Did not address Key Question 1
Rotten et al. 1993^477^ | Fine-needle aspiration results were used in decisions about verification of results
Dronkers 1992^478^ | Did not verify benign diagnoses
Elliot et al. 1992^479^ | Did not verify benign diagnoses
Harter et al. 1992^480^ | Fewer than 10 patients enrolled
Pezner et al. 1992^481^ | Did not address any of the Key Questions
Khanna et al. 1991^482^ | Fine-needle aspiration results were used in decisions about verification of results