# Methods of Identifying the Literature

## Electronic Database Searches

The following databases have been searched for relevant information:

Name | Date Limits | Platform/Provider
CINAHL (Cumulative Index to Nursing and Allied Health Literature) | 1990 through October 30, 2008 | OVID
The Cochrane Central Register of Controlled Trials (CENTRAL) | Through 2008, Issue 2 | www.thecochranelibrary.com
The Cochrane Database of Methodology Reviews (Methodology Reviews) | Through 2008, Issue 2 | www.thecochranelibrary.com
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | Through 2008, Issue 2 | www.thecochranelibrary.com
Database of Abstracts of Reviews of Effects (DARE) | Through 2008, Issue 2 | www.thecochranelibrary.com
ECRI Institute Library Catalog | Through May 2008 | ECRI Institute
EMBASE (Excerpta Medica) | 1990 through September 11, 2009 | OVID
Health Technology Assessment Database (HTA) | Through 2008, Issue 2 | www.thecochranelibrary.com
Healthcare Standards | 1990 through May 2008 | ECRI
International Health Technology Assessment (IHTA) | Through May 2008 | ECRI
MEDLINE | 1990 through September 11, 2009 | OVID
PreMEDLINE | Searched October 30, 2008 | OVID
U.K. National Health Service Economic Evaluation Database (NHS EED) | Through 2008, Issue 2 | www.thecochranelibrary.com
U.S. National Guideline Clearinghouse™ (NGC) | Searched May 2008 | www.ngc.gov

## Hand Searches of Journal and Nonjournal Literature

Journals and supplements maintained in ECRI Institute’s collections were routinely reviewed. Nonjournal publications and conference proceedings from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature.

## Search Strategies

The search strategies employed combinations of freetext keywords as well as controlled vocabulary terms including (but not limited to) the following concepts. The strategy below is presented in OVID syntax; the search was simultaneously conducted across EMBASE, MEDLINE, and PsycINFO. A parallel strategy was used to search the databases comprising the Cochrane Library.

## Medical Subject Headings (MeSH), EMTREE, PsycINFO and Keywords

### Conventions

#### OVID

$ | truncation character (wildcard)
exp | “explodes” controlled vocabulary term(e.g., expands search to all more specific related termsin the vocabulary’s hierarchy)
.de. | limit controlled vocabulary heading
.fs. | floating subheading
.hw. | limit to heading word
.md. | type of methodology (PsycINFO)
.mp. | combined search fields (default if no fields are specified)
.pt. | publication type
.ti. | limit to title
.tw. | limit to title and abstract fields

#### PubMed

[mh] | MeSH heading
[majr] | MeSH heading designated as major topic
[pt] | Publication Type
[sb] | Subset of PubMed database (PreMEDLINE, Systematic, OldMEDLINE)
[sh] | MeSH subheading (qualifiers used in conjunction with MeSH headings)
[tiab] | keyword in title or abstract
[tw] | Text word

### Topic-Specific Search Terms

Concept | Controlled Vocabulary | Keywords
Adverse events | Ae.fs. Co.fs. Cross infection Drainage Surgical wound infection
Breast and breast diseases | Breast Breast cancer/di exp Breast disease/di exp Breast diseases/di Breast neoplasms/di | Breast$ Calcification$ Calcinosis Cancer Carcinoma$ Lesion$ Lump$ Mammar$ Papilloma Tum?or$
Breast biopsy | Biopsy Biopsy needle Breast biopsy Directional vaccum assisted biopsy Needle biopsy Percutaneous biopsy Stereotactic breast biopsy Tumor biopsy | Large core Mammatome Mammotome Needle Vacuum
Open biopsy | Breast/su Breast tumor/su Su.fs. | Excision$ Incision$ Open Surgical
Patient Satisfaction/QOL | Pain assessment Pain measurement Patient satisfaction Quality of life Visual analog scale | Preference$ QOL Satisf$
Seeding | | seeding

## CINAHL/Embase/Medline

### English Language, Human

Set N | Concept | Search statement
1 | Breast biopsy | (breast biopsy or stereotactic breast biopsy or directional vacuum assisted biopsy).de.
2 | Breast | Breast
3 | Breast diseases | Exp breast cancer/di or exp breast neoplasms/di or exp breast disease/di or exp breast diseases/di
4 | | (breast or mammar$) and (Papilloma or calcification$ or calcinosis or tum?or$ or lesion$ or cancer or carcinoma$ or lump$)
5 | Combine sets | or/2–4
6 | Biopsy | 5 and ((Biopsy or tumor biopsy).de. or biops$)
7 | Large core needle biopsy | 6 and ((needle biopsy or biopsy needle or percutaneous biopsy).de. or (large core or needle or mammotome or mammatome or vacuum))
8 | Open biopsy | 6 and (breast/su or breast tumor/su)
9 | | 6 and (su.fs. or open or excision$ or incision$ or surgical)
10 | Combine sets | 8 or 9
11 | Combine sets | or/1,7,10
12 | Limit by publication type | 11 not ((letter or editorial or news or comment or case reports or note or conference paper).de. or (letter or editorial or news or comment or case reports).pt.)
13 | Diagnostics filter | 12 and (exp prediction and forecasting/or (predictive value of tests or receiver operating characteristic or ROC curve or sensitivity and specificity or accuracy or diagnostic accuracy or precision or likelihood).de. or ((false or true) adj (positive or negative)))
14 | Clinical trials filter | 13 and ((Randomized controlled trials or random allocation or double-blind method or single-blind method or placebos or cross-over studies or crossover procedure or double blind procedure or single blind procedure or placebos or latin square design or crossover design or double-blind studies or single-blind studies or triple-blind studies or random assignment or exp controlled study/or exp clinical trial/or exp comparative study/or cohort analysis or follow-up studies.de. or intermethod comparison or parallel design or control group or prospective study or retrospective study or case control study or major clinical study).de. or Case control studies/or Cohort/or Longitudinal studies/or Evaluation studies/or Follow-up studies/or Prospective studies/or Retrospective studies/or Case control study/or Cohort analysis/or Longitudinal study/or Follow up/or Cohort analysis/or Followup studies/or random$.hw. or random$.ti. or placebo$.mp. or ((singl$ or doubl$ or tripl$ or trebl$) and (dummy or blind or sham or mask)).mp. or latin square.mp. or (time adj series) or (case adj (study or studies) or ISRCTN$.mp. or ACTRN$.mp. or (NCT$ not nctc$)))
15 | Combine sets | 13 or 14
16 | Eliminate overlap
17 | Seeding | 12 and seeding.ti,ab.
18 | Patient satisfaction/QOL | 12 and ((patient satisfaction or pain measurement or pain assessment or visual analog scale or quality of life).de. or satisf$ or QOL or preference$)
19 | Adverse events | 12 and ((ae or co).fs. or (cross infection or drainage or surgical wound infection).de.)
20 | Disfiguration | 12 and (disfigur$ or deform$)
21 | Combine sets | or/16–20