# Technical Experts and Peer Reviewers

Table A1 Technical expert panel

Name | Title | Specialty | Organization
Wendie Berg, MD, PhD | American Radiology Services Johns Hopkins at Greenspring Lutherville, Maryland | Radiology | American College of Radiology representative
R. James Brenner, MD, JD, FACR, FCLM | Professor, Clinical Radiology and Chief, Breast Imaging, UCSF | Radiology | UCSF
Patty Carney, PhD | Professor of Family Medicine, and Associate Director for Population Studies at the OHSU Cancer Institute | Family Medicine | OHSU
Joanne Elmore, MD, MPH | Section Head, Division of General Internal Medicine Professor of Medicine Adjunct Associate Professor of Epidemiology Associate Director UW Robert Wood Johnson Clinical Scholars Program | Internal Medicine/Epidemiology | University of Washington
Richard E. Fine, MD, FACS | Director Advanced Breast Care of Georgia | Surgery | Surgeon-Oncology
Carol Lee, MD | Yale University School of Medicine Chair of the American College of Radiology Breast Commission | Radiology | Yale University School of Medicine
Bev Parker, PhD | Research Analyst | Consumer | Y-ME National Breast Cancer Organiation
Elizabeth Steiner, MD | Assistant Professor of Family Medicine | Family Medicine | OHSU
Maria Wetzel, BS | Clinical Laboratory Scientist | Consumer | National Breast Cancer Coalition
Pamela Wilcox | Assistant Exec. Dir. of ACR | Radiology | American College of Radiology representative
Bonnie Yankaskas, PhD, MPH | Professor of Radiology, Adjunct Professor of Epidemiology, Principal Investigator for the Carolina Mammography Registry (CMR) | Radiology | University of North Carolina

## ECR I Institute Personnel

All ECRI Institute personnel involved in the preparation of this report may be contacted at:

- ECRI Institute
- 5200 Butler Pike
- Plymouth Meeting, PA 19462
- Telephone: (610) 825-6000
- Facsimile: (610) 834-1275

- Karen Schoelles, M.D., S.M.
- Medical Director

- Jonathon Treadwell, Ph.D.
- Associate Director, Evidence-based Practice Center

- Wendy Bruening, Ph.D.
- Senior Research Analyst

- Jason Launders MSc
- Senior Project Officer-Medical Physicist

- Joann Fontanarosa, Ph.D.
- Research Analyst

- Kelley Tipton, MPH
- Research Assistant