# Appendixes

Appendix A Technical Experts and Peer Reviewers

Appendix B Methods of Identifying the Literature

Appendix C Excluded Studies

Appendix D Data Abstraction Forms

Appendix E Evidence Tables

Appendix F Data Analysis

Appendix G Grading the Strength of Evidence